# Appendix B Evidence and Quality Assessment Tables

## Appendix B1 Quality Assessment Table

Trial | Adequate randomization | Adequate allocation concealment | Similar groups at baseline | Specified eligibility criteria | Masked outcome assessors | Masked care provider | Masked patient | Reported attrition and withdrawals | Differential/high loss to followup | People analyze in groups they were randomized | Quality
Ausems, 2002^45^ | Uncertain | NR | Yes | No | NR | NA | NA | Yes | No/No | Yes | Fair
Bauman, 2002^47^; Bauman, 2000^46^ | NR | Yes | NR | Yes | Uncertain | NA | NA | Yes | Yes/No | Yes | Fair
Colby, 2005^49^ | NR | NR | Yes | Yes | Yes | NA | NA | Yes, not per group | NR/No | Yes | Fair
Colby, 2012^50^ | Yes | Yes | No | Yes | Yes | NA | NA | Yes | No/No | Yes | Fair
Cremers, 2015^51^ | Yes | NR | Yes | Yes | NA/NR | NA/NR | NR | Yes | Yes/Yes | Yes | Fair
Curry, 2003^52^ | Uncertain | NR | Yes | Yes | NR | NA | NA | Yes | No/No | Yes | Fair
Fidler, 2001^53^ | No | No | NR | Yes | NR | NA | NA | Yes | No/Yes | Yes | Fair
Gray, 2011^54^ | NR | NR | Yes | Yes | Yes | Yes | Yes | Yes | No/Yes | Yes | Fair
Haggerty, 2007^55^ | NR | NR | Yes | Yes | NR | NA | NA | Yes | No/No | Yes | Fair
Haug, 2013^56^ | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | No/Yes | Yes | Fair
Hiemstra, 2014^57^ | Yes | Unclear | No | Yes | No | No | Yes | Yes | No/No | Yes | Fair
Hollis, 2005^58^ | Yes | Yes | Yes | Yes | Yes | NA | NA | Yes | No/No | Yes | Good
Hovell, 1996^59^ | Yes | NR | Yes | Yes | NR | NA | NA | Yes | No/No | Yes | Good
Jackson, 2006^62^ | NR | Yes | NR | Yes | Adequate | NA | NA | Yes, not per group | NR/No | Yes | Fair
Kentala, 1999^64^; Saari, 2012^73^ | No | NR | NR | Yes | NR | NA | NA | Yes | No/Yes | Yes | Fair
Killen, 2004^65^ | NR | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No/Yes | Yes | Fair
Lando, 2007^66^ | Yes | NR | NR | Yes | NR | NA | NA | Yes | No/Yes | Yes | Fair
Muramoto, 2007^67^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No/Yes | Yes | Fair
Pbert, 2008^69^ | NR | Yes | Yes | Yes | NR | Yes | Yes | Yes | No/No | Yes | Fair
Pbert, 2011^68^ | Yes | Yes | Yes | Yes | NR | NA | Unclear | Yes | No/No | Yes | Good
Prado, 2007^70^ | Yes | Un | Yes | Yes | Yes | NA | NA | Yes | No/No | Yes | Fair
Redding, 2015^71^ | Yes | Yes | NR | Yes | Yes | NR | NR | Yes | No/Yes | No | Fair
Robling, 2016^72^ | Yes | Yes | Yes | Yes | Yes | No | No | Yes | No/Yes | Yes | Fair
Scherphof, 2014^74^ | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | No/No | Yes | Good
Schuck, 2015^75^ | Yes | Unclear | Yes | Yes | Unclear/NR | No | No | Yes | No/No | Yes | Fair
Stevens, 2002^76^ | Yes | NR | Yes | Yes | NR | NA | NA | Yes | No/No | Yes | Good

Abbreviations: NA=not applicable; NR=not reported.

## Appendix B2 Behavioral Intervention Details

Focus | Trial, quality | Behavioral intervention description | Behavioral intervention duration | Primary smoking outcome
Prevention only | Ausems, 2002^45^; Fair | 3 tailored newsletters mailed at 3-week intervals addressed to the student. Included essential components of successful social influence programs. Contents of letters were individualized. The first letter contained information regarding students’ beliefs about smoking and the short-term consequences of smoking. The second letter focused on the influence of the social environment and intentions to not smoke in the future. The third letter described refusal techniques and included an exercise about cigarette refusal. | 3 newsletters mailed at 3-week intervals (Intervention ran from November 1997 to early February 1998). | % of baseline nonsmokers (not even one puff) reporting ever smoking or smoking in the past 30 days at posttest
Prevention only | Cremers, 2015^51^; Fair | Personalized log-in codes to access Fun without Smokes website. Website contained smoking and nonsmoking information, games concerning nonsmoking, web-based questionnaire, and computer-tailored feedback messages. Received 3 computer-tailored feedback messages based on info children provided in Web-based questionnaire on 3 consecutive days via email as a PDF file and also available on the website. Aim was to repeatedly expose children to nonsmoking information during the course of the year in addition to the feedback messages. | No Prompt Group: received messages on 3 consecutive days via email. They could reuse the website but were not prompted to do so; Prompt Group: received messages on 3 consecutive days via email, and 6 prompt messages via email or SMS every year to encourage them to reuse the Fun without Smokes website. | % smoking initiation
Prevention only | Curry, 2003^52^; Fair | 5 intervention components addressed important individual, interpersonal, and environmental factors known to influence the smoking onset process: the child’s attitudes, beliefs, and knowledge; dispositional factors such as high risk taking; the beliefs, attitudes, and behaviors of parents and peers; and tobacco marketing and availability. Families received a packet with materials for parents and children and a video with viewing guide. Parents received two counseling telephone calls and a mailed newsletter. Parent handbook provided information to encourage, motivate, and reinforce parent-child communication about tobacco. Children’s packet included a pen and stickers with antitobacco messages and a comic book that described the dangers of tobacco, advertising deceptiveness, and how to resist peer pressure to smoke. Could receive motivational message during any routine primary care appointments. (22% of IG and 15% of CG said their provider discussed tobacco with their child; 17% of IG and 3% of CG said the provider mentioned the Steering Clear project.) | One counseling call 3 to 6 weeks after receipt of written materials, additional call 14 months after enrollment. 28-minute video. | % of full sample^*^ reporting smoking (even a puff) in past 30 days at posttest
Prevention only | Fidler, 2001^53^; Fair | Age-related materials about the advantages of remaining a nonsmoker. Some materials addressed other smoking-related issues and only incidentally referred to the dangers and health effects of smoking. Sent certificates affirming their nonsmoking decision and status and were encouraged to contact the project team if they wished. | 4 mailings over 12 months. | % of full sample reporting “starting to smoke” at posttest (specific measure NR)
Prevention only | Haggerty, 2007^55^; Fair | Universal substance abuse and problem behavior preventive intervention for families (at least one parent and their teen together) including parenting, youth, and family components. The workbook includes the following components: roles (relating to your teen), risks (identifying and reducing them), protection (bonding with your teen to strengthen resilience), tools (working with your family to solve problems), involvement (allowing everyone to contribute), policies (setting family policies on health and safety issues), and supervision (supervising without invading). | IG1: Completed activities at home within 10 weeks. Contacted by phone once per week. IG2: Seven group and family sessions over 7 weeks, 2.5 hours for sessions 1, 4, and 7; 2 hours for sessions 2, 3, 5, and 6. Home practice encouraged. | % of baseline nonsmokers (specific measure NR) reporting initiating smoking postintervention (specific measure NR)
Prevention only | Hiemstra, 2014^57^; Fair | Based on the U.S. version of Smoke-free Kids. Concentrates on stimulating antismoking socialization within families in order to prevent children from smoking. Each module dealt with different socialization constructs and included different assignments, such as games and scripted role-plays, to gradually increase parental skills and comfort in communicating with children about smoking, addictions, and expectations regarding abstinence. Each module also included a communication sheet for mothers, providing background information about the subjects discussed in the modules and communication tips for mothers. | Families received 5 printed activity modules by mail at 4-week intervals. A booster module was delivered 12-months post-baseline. | % who initiated smoking
Prevention only | Hovell, 1996^59^; Good | Staff created a tobacco-free environment by formalizing a nonsmoking office policy, removing tobacco ads, discontinuing magazines with such ads, and displaying tobacco prevention information. Patients received antitobacco “prescriptions” with a specific antitobacco message preprinted on the form (topics: announcement of tobacco-free office, tobacco advertising, tobacco and sports, smokeless tobacco, nicotine and tobacco addiction, passive smoking, tobacco and teeth, and negative consequences of tobacco use), a space for their name to be filled in, and a place to sign the prescription. Assume there was also a brief counseling session with the orthodontist. | 0 to >7 prescriptions delivered individually over 2 years. | % of baseline nonusers (no 30-day tobacco use or having ever used tobacco more than 100 times)^†^ reporting tobacco use in the past 30 days at posttest
Prevention only | Jackson, 2006^62^; Fair | Participants received 5 core activity guides mailed to their homes at approximate 2-week intervals (1 additional booster guide was received 1 year after baseline). Delivery of newsletters, tip sheets, and incentives was timed as appropriate to complement or reinforce each program guide. | 5 activity guides mailed at 2-week intervals; 1 booster guide received 1 year after baseline. | % of full sample reporting ever smoking (even a puff) at posttest
Cessation only | Colby, 2005^49^; Fair | Motivational interviewing. Pros and cons of smoking and quitting, highlighted ambivalence and identified salient aspects of smoking. Personalized feedback sheet that summarized information from baseline assessment. Corrective normative feedback; personalized information about health effects, CO, and dependence level; and financial costs. Detailed action plan, anticipation of barriers, strategizing methods to overcome barriers. Enhanced self-efficacy. Same handouts as CG, feedback sheet, goal sheet, and information about strategies for quitting and coping with withdrawal. Telephone booster call to reinforce initial progress toward goals, emphasized personal choice for change, discussed coping skills and problem-solving, and promoted self-efficacy. | 1 baseline session (35 minutes); 1 15- to 20-minute telephone booster session at 1 week. | % of full sample reporting 7-day abstinence at posttest
Cessation only | Colby, 2012^50^; Fair | Same intervention as Colby 2005. One motivational interviewing session plus one booster phone call, as well as print materials. Additional component where parents of intervention participants were asked to participate in one session that focused on increasing parent support for the adolescent’s goals for changing smoking, increasing clear communication, and establishing home smoking rules. Parents in both conditions were mailed informational materials on helping adolescents quit smoking. | One baseline session (45 minutes), one 15- to 20-minute telephone booster session at 1 week, and one 15- to 20-minute discussion with parents. | % of full sample reporting 7-day abstinence and biochemically confirmed expired CO <9 ppm and saliva cotinine <14 ng/mL
Cessation only | Haug, 2013^56^; Fair | Online assessment of individual smoking behavior and attitudes toward smoking (assessed outcome expectancies of smoking cessation, situations or circumstances in which craving usually occurs, alternative strategies to handle craving situations, and costs per cigarette pack), a weekly SMS text message assessment of smoking-related target behaviors (based on Health Action Process Approach stage and included CBT and motivational components), 2 weekly text messages individually tailored to the data of the online and the SMS text message assessments (tailored to HAPA stage), and an integrated quit day preparation and relapse-prevention program (for those in the preparation and action stages). | Weekly SMS text message assessments. Those in either of the preparation and action stages were informed biweekly about the quit date preparation messaging option. If a quit date was entered, the program provided up to 2 daily text messages to prepare for quit date and prevent relapse after. | % 7-day abstinence rate at posttest
Cessation only | Pbert, 2011^68^; Good | Based on the 5A model and adapted to be developmentally appropriate for adolescents. Advised the student to stop smoking. Assessed motivation to quit. Assisted the adolescent to quit by addressing pros/cons of smoking, personal reasons for quitting, anticipated problems, previous quit attempts, nicotine addiction, quit methods, setting a quit date, triggers, and strategies. Assisted the adolescent to quit by addressing managing triggers, handling social situations, withdrawal symptoms and their management, managing cravings, managing stress, minimizing weight gain, gaining support, taking control of one’s environment, and rewarding oneself. Assisted in maintaining abstinence if the adolescent quit. Nurse asked open-ended questions to actively engage adolescent. | Weekly private one-on-one sessions for 4 weeks (2 30-minute). | % full sample reporting 30-day abstinence at posttest
Cessation only | Schuck, 2015^75^; Fair | Parent telephone counseling by Dutch national quit line, 3 didactic booklets entitled Smoke-free Parents. If smoked >10 cigarettes, NRT was recommended but not provided. | Up to 7 sessions in 3 month period. | % who initiated smoking (even just one puff)
Cessation only (medication) | Killen, 2004^65^; Fair | Both IG and CG received the behavioral intervention. Group-based skills training. Groups met weekly and were supervised by trained counselors. Counselors demonstrated the use of specific, concrete, self-regulatory skills for coping with risky situations without resorting to smoking and helped participants develop action plans to promote nonsmoking in self-identified, high-risk situations. (Medication: IG: 150 mg bupropion + NRT; CG: placebo + NRT). | Weekly group sessions (~8 participants/group) for 10 weeks (assumed), 45 minutes each. | % of full sample reporting 7-day abstinence (not even a puff) and biochemically confirmed saliva cotinine level <20 ng/mL at posttest
Cessation only (medication) | Muramoto, 2007^67^; Fair | Both IG and CG received the behavioral intervention. Brief individual counseling sessions standardized to address a series of topics addressing teaching skills related to changing smoking behaviors (e.g., identifying social support, identifying motivations and barriers to quitting, recognition of triggers for smoking, management of nicotine craving and withdrawal symptoms, and stress management). Telephone number for state quit line provided for additional behavioral support. (Medication: IG1: 150 mg bupropion; IG2: 300 mg bupropion; CG: placebo) | Seven individual sessions over 7 weeks, 10- to 20-minutes each. | % of baseline smokers ([underlined: ≥]6 cigarettes per day, exhaled CO level [underlined: ≥]10 ppm, [underlined: ≥]2 previous quit attempts, and were motivated to quit) reporting 7-day abstinence at posttest
Cessation only (medication) | Scherphof, 2014^74^; Good | 75 minute informational meeting to obtain background information of the participant (e.g. smoking behavior, attitudes concerning smoking, and factors related to smoking [cessation]). Participants also received (a) information about the study, (b) a short behavioral intervention aiming at quitting smoking (e.g. preparations and expectations) and (c) instructions for the use of NRT. | 1 informational meeting. | % of baseline smokers reporting 4 week abstinence at posttest
Combined prevention and cessation | Bauman, 2000^46^; Bauman, 2001^48^; Bauman, 2002^47^; Fair | Successive mailings of four booklets and health educator telephone discussions with parents 2 weeks after each mailing. Booklets focused on family motivation to participate and engage, family characteristics known to influence adolescents not specific to alcohol and tobacco use, tobacco- and alcohol-specific predictors that originate in the family, and predictors that originate outside the family. Booklets all had specific activities to reinforce content that the families completed on their own. Health educators encouraged participation of all family members, answered parents’ questions, and recorded information. Adolescent was reached through family members and was not contacted directly by health educator. | 4 booklets and related activities completed by family members over 15 weeks (total time ~4 hours and 25 minutes), ~8 phone calls with health educator over 15 weeks discussing program and completing standard protocol (total time ~57.5 minutes per family); for families that completed all four units, it required an average of nearly 6 months (173.2 days [SD, 71.3]) between booklet one and completion of the fourth unit. | % of full sample reporting ever smoking (even one puff) at posttest; Prevention: % of baseline nonsmokers (not ever smoking, even one puff) reporting ever smoking (even one puff) at posttest; Cessation: % of baseline smokers ([underlined: ≥]1 days in the past 30 days) reporting having smoked [underlined: ≥]1 days in past 30 days at posttest
Combined prevention and cessation | Hollis, 2005^58^; Good | Teen Reach (Research Approaches to Cancer in a Health Maintenance Organization). Staff provided primary care clinicians with a 30- to 60-second suggested advice message to encourage teens to stop smoking or to not start. Clinicians were asked to encourage the patient to talk briefly with a health counselor immediately after the visit. Teens had a 10- to 12-minute session on the computer with the PTC expert system, which assessed their stage of readiness to begin smoking or their stage of change to quit smoking and then delivered tailored advice and encouragement. The program included testimonial movies and graphics. Teens had 3 to 5 minutes of post-PTC motivational counseling. Handouts included a synopsis of stage-relevant advice and small quit kits. There were 2 booster sessions with the PTC and health counselor over the remaining 11 months. | 1 30- to 60-second advice message from PCP; 1 to 3, 3- to 5-minute sessions with health counselor over 12 months; one 10- to 12-minute computer session. | % of full sample reporting smoking [underlined: ≥]1 cigarettes in the past 30 days at posttest^‡^; Prevention: % of baseline nonsmokers (no smoking in past 30 days) reporting smoking [underlined: ≥]1 cigarettes in the past 30 days at posttest^‡^; Cessation: % of baseline smokers (smoking [underlined: ≥]1 cigarettes in the past 30 days) reporting smoking [underlined: ≥]1 cigarettes in the past 30 days at posttest^‡^
Combined prevention and cessation | Kentala, 1999^64^; Saari, 2012^73^; Fair | Nonsmokers were given positive feedback regarding smoking abstinence. After the dental exam, all patients were shown photos showing effects of smoking on teeth. Smokers were given a mirror to assess signs of smoking on their own teeth. Smokers and nonsmokers received the usual dental exam. | Brief part of annual dental visit (only a couple minutes). Patients had 1 to 4 visits. | % of full sample reporting ever smoking (assumed) at posttest
Combined prevention and cessation | Lando, 2007^66^; Fair | Brief advice on smoking cessation and prevention during dental exam. Videos from the CDC and Massachusetts Department of Public Health. Motivational interviewing to either encourage cessation or encourage prevention. Brief supportive telephone calls. | 60 seconds of advice from dental hygienist or dentist; one 15- to 20-minute session of motivational interviewing; 3 to 6 phone calls over 6 months (estimated 10 minutes per call). | % of full sample reporting smoking in past 30 days; Prevention: % of baseline nonsmokers (never smoked but susceptible) and baseline former smokers (ever smoked, but not in past 30 days) reporting smoking in the past 30 days at posttest; Cessation: % of baseline smokers (smoked in past 30 days) reporting smoking in past 30 days at posttest
Combined prevention and cessation | Pbert, 2008^69^; Fair | Providers asked about smoking, advised cessation or continued abstinence, and referred the patient to a peer counselor. Peer counseling combined the 5A model with motivational interviewing and behavior change counseling. | Advice from the pediatrician given during normal clinic visit (assume brief). 15-30 minute session with peer counselor at the clinic. 4 10-minute phone calls over 21 weeks. | % of smokers (smoke “occasionally or regularly”) and nonsmokers (never smoked or 1–2 puffs but not in the past year) not abstinent at posttest (specific measure NR); Prevention: % of baseline nonsmokers (never smoked or 1–2 puffs but not in the past year) abstinent at posttest (specific measure NR); Cessation: % of baseline smokers (smoke “occasionally or regularly”) abstinent at posttest (specific measure NR)
Combined prevention and cessation | Prado, 2007^70^; Fair | Providers asked about smoking, advised cessation or continued abstinence, and referred the patient to a peer counselor. Peer counseling combined the 5A model with motivational interviewing and behavior change counseling. | 15 group sessions, 8 family visits, and 2 parent-adolescent circles. Approximately 49 hours over 1 year. | % of full sample reporting smoking in the past 90 days at posttest
Combined prevention and cessation | Redding, 2015^71^; Fair | Computer-delivered personalized feedback tailored to the participant’s stage of readiness to use condoms consistently or stage of change for smoking acquisition (among nonsmokers) or smoking cessation (among smokers) followed by in-person counseling to discuss feedback. The intervention was designed to accelerate state progress among those in early stages of change or to prevent relapse among those further along. Scores for each behavior were calculated and generated immediate on-screen and print copies of reports to be discussed with their counselor at the end of the computer session. | During the 9-month intervention, participants could return to the clinic every 3 months for a total of 4 possible sessions that include both the computer-tailored feedback and in-person counseling. Each computer program took 20-30 minutes. | % who reached stage A or M (stopping smoking among those who smoke; initiating smoking among those who do not smoke)
Combined prevention and cessation | Robling, 2016^72^; Fair | Family Nurse Partnership provided by specially recruited and trained family nurses with an aim of affecting risk and protective factors within prenatal health-related behaviors, sensitive and competent caregiving, and early parental life course. | 64 structured home visits. Intervention takes place from early pregnancy until the child’s 2nd birthday. On average, the intervention group received 39.28 visits from the Family Nurse Partnership program. | % who smoked at late pregnancy
Combined prevention and cessation | Stevens, 2002^76^; Good | Dartmouth Prevention Cohort Study. Primary care clinician focused on alcohol and tobacco use. Discussed risks with the child and parent. Signed a contract that the family would talk about risks at home and develop a family policy about alcohol and tobacco. Family received signed letter by their clinician reinforcing the agreement and a refrigerator magnet to post the contract. Reminded of the importance of family communication regarding alcohol and tobacco at subsequent office visits for 36 months. Clinician’s role was to provide risk behavior information, encourage family communication, and offer help. Brochure on effective communication. 12 newsletters for each of the parents and children mailed to reinforce messages. Biannual telephone calls. | 1 baseline session with PCP; 24 newsletters over 36 months; 6 phone calls over 36 months; additional PCP encouragement if additional office visits. | % of full sample reporting ever smoked at posttest

* An estimated 1.2% of the sample had smoked in the past 30 days at baseline.

† Tobacco use includes the use of cigarettes, pipes, cigars, or smokeless tobacco.

‡ Originally reported as the percentage of participants reporting no smoking; reversed for consistency.

Abbreviations: 5A=Ask, Advise, Assess, Assist, Arrange Followup; CDC=Centers for Disease Control and Prevention; CG=control group; CO=carbon monoxide; IG=intervention group; NR=not reported; NRT=nicotine replacement therapy; PCP=primary care practitioner; PDF=portable document format; PTC=Pathways to Change; SD=standard deviation; SMS=short message service.