# Appendix A Detailed Methods

## Appendix A1 Search Strategies

Databases Searched for Overall Project

OVID MEDLINE^®^ Database Searches

Search Strategy:

------------------------------------------------------------

1. Smoking/
2. exp “Tobacco Use Cessation”/
3. “Tobacco Use Disorder”/
4. Electronic Cigarettes/
5. (smoking$ or cigarette$ or tobacco or nicotine or vape or vaping or “e-cigarette$” or “electronic cigarette$”).ti.
6. (prevent$ or prevention or use$ or usage or cessation or quit$ or stop$).ti,ab.
7. pc.fs.
8. (or/1-5) and (or/6-7)
9. (child$ or adolescen$ or teen$ or youth or “young adult”).ti,ab.
10. 8 and 9
11. 10 and (random$ or control$ or trial or study).ti,ab.
12. limit 10 to (meta analysis or systematic reviews)
13. 11 or 12
14. limit 13 to (english language and humans)
15. (201209$ or 20121$ or 2013$ or 2014$ or 2015$ or 2016$ or 2017$).ed,dp.
16. 14 and 15
17. 10 and (control$ or cohort or compare$ or comparison or comparative or observational).ti,ab.
18. 17 and (ae or co or mo).fs.
19. 17 and (harm$ or adverse).ti,ab,kw,tw.
20. 18 or 19
21. limit 20 to (english language and humans)
22. 21 and (201209$ or 20121$ or 2013$ or 2014$ or 2015$ or 2016$ or 2017$).ed,dp.
23. 16 or 22

EBM Reviews - Cochrane Central Register of Controlled Trials

Search Strategy:

------------------------------------------------------------

1. Smoking/
2. exp “Tobacco Use Cessation”/
3. “Tobacco Use Disorder”/
4. Electronic Cigarettes/
5. (smoking$ or cigarette$ or tobacco or nicotine or vape or vaping or “e-cigarette$” or “electronic cigarette$”).ti.
6. (prevent$ or prevention or use$ or usage or cessation or quit$ or stop$).ti,ab.
7. pc.fs.
8. (or/1-5) and (or/6-7)
9. (child$ or adolescen$ or teen$ or youth or “young adult”).ti,ab.
10. 8 and 9
11. limit 10 to english language
12. limit 11 to yr="2012 -Current"

EBM Reviews - Cochrane Database of Systematic Reviews

Search Strategy:

------------------------------------------------------------

1. (smoking$ or cigarette$ or tobacco or nicotine or vape or vaping or “e-cigarette$” or “electronic cigarette$”).ti.
2. (child$ or adolescen$ or teen$ or youth or “young adult”).ti.
3. 1 and 2

PsycINFO

Search Strategy:

------------------------------------------------------------

1. exp smoking cessation/
2. exp electronic cigarettes/
3. exp tobacco smoking/
4. (smoking$ or cigarette$ or tobacco or nicotine or vape or vaping or “e-cigarette$” or “electronic cigarette$”).ti.
5. exp prevention/
6. (prevent$ or prevention or use$ or usage or cessation or quit$ or stop$).ti,ab.
7. (child$ or adolescen$ or teen$ or youth or “young adult”).ti,ab.
8. (or/1-4) and (5 or 6)
9. 7 and 8
10. limit 9 to (“0300 clinical trial” or “0830 systematic review” or 1200 meta analysis)
11. 9 and (random$ or control$ or trial or cohort or comparative or comparison or compare$).ti,ab.
12. 10 or 11
13. intervention.id.
14. (intervention$ or treatment or therapy or counseling).ti,ab.
15. exp Drug Therapy/
16. 12 and (13 or 14 or 15)
17. limit 16 to yr="2012 -Current"

Elsevier Embase^®^

Search Strategy:

------------------------------------------------------------

(((‘smoking’/exp AND ‘smoking related phenomena’ OR ‘smoking cessation’/exp OR ‘vaping’/exp OR ‘electronic cigarette’/exp OR ‘electronic cigarette’) AND (‘prevention and control’/exp OR ‘prevention and control’)) AND (‘clinical trial’/de OR ‘comparative study’/de OR ‘controlled clinical trial’/de OR ‘double blind procedure’/de OR ‘meta analysis’/de OR ‘randomized controlled trial’/de OR ‘systematic review’/de) AND ([child]/lim OR [adolescent]/lim OR [young adult]/lim) AND [english]/lim) AND (2012:py OR 2013:py OR 2014:py OR 2015:py OR 2016:py OR 2017:py) AND [embase]/lim NOT [medline]/lim

Update Search: Young Adult Prevention Age Gap

OVID MEDLINE^®^ Database Searches

Search Strategy:

------------------------------------------------------------

1. (smoking$ or cigarette$ or tobacco or nicotine or vape or vaping or “e-cigarette$” or “electronic cigarette$”).ti.
2. (prevent$ or prevention or use$ or usage).ti,ab.
3. pc.fs.
4. (adolescen$ or teen$ or youth or “young adult”).ti,ab.
5. 1 and (2 or 3) and 4
6. 5 and (random$ or control$ or trial or cohort or compare$ or comparison or comparative or observational).ti,ab.
7. limit 6 to english language
8. limit 7 to yr="1902 - 2012"
9. 5 and (control$ or cohort or compare$ or comparison or comparative or observational).ti,ab.
10. 9 and (ae or co or mo).fs.
11. 9 and (harm$ or adverse).ti,ab,kw,tw.
12. 10 or 11
13. limit 12 to english language
14. limit 13 to yr="1902-2012"
15. 8 or 14

EBM Reviews - Cochrane Central Register of Controlled Trials

Search Strategy:

------------------------------------------------------------

1. Smoking/
2. “Tobacco Use Disorder”/
3. Electronic Cigarettes/
4. (smoking$ or cigarette$ or tobacco or nicotine or vape or vaping or “e-cigarette$” or “electronic cigarette$”).ti.
5. (prevent$ or prevention or use$ or usage or quit$ or stop$).ti,ab.
6. pc.fs.
7. (or/1-4) and (5 or 6)
8. (adolescen$ or teen$ or youth or “young adult”).ti,ab.
9. 7 and 8

EBM Reviews - Cochrane Database of Systematic Reviews

Search Strategy:

------------------------------------------------------------

1. (smoking$ or cigarette$ or tobacco or nicotine or vape or vaping or “e-cigarette$” or “electronic cigarette$”).ti.
2. (adolescen$ or teen$ or youth or “young adult”).ti.
3. 1 and 2

PsycINFO

Search Strategy:

------------------------------------------------------------

1. exp smoking cessation/
2. exp electronic cigarettes/
3. exp tobacco smoking/
4. (smoking$ or cigarette$ or tobacco or nicotine or vape or vaping or “e-cigarette$” or “electronic cigarette$”).ti.
5. exp prevention/
6. (prevent$ or prevention or use$ or usage).ti,ab.
7. (adolescen$ or teen$ or youth or “young adult”).ti,ab.
8. (or/1-4) and (5 or 6)
9. 7 and 8
10. limit 9 to (“0300 clinical trial” or “0830systematic review” or 1200 meta analysis)
11. 9 and (random$ or control$ or trial or cohort or comparative or comparison or compare$).ti,ab.
12. 10 or 11
13. intervention.id.
14. (intervention$ or treatment or therapy or counseling).ti,ab.
15. exp Drug Therapy/
16. 12 and (13 or 14 or 15)
17. limit 16 to yr="1861 - 2011"

## Appendix A2 Inclusion and Exclusion Criteria

| Included | Excluded
Setting | Primary care, other health care, research clinic/office, dental clinic, or school-based health clinic | - Schools (other than health clinics delivering primary care); - Inpatient settings; - Institutional/residential facilities
Populations | - Adolescents (ages 13 to 18 years) and children (age <13 years) for cessation; children and adolescents (to age 25 years) for prevention; - More than 50% of study participants must be in included age group; - Pregnant adolescents | - Adults (age >18 years for cessation >25 for prevention), unless subgroup results for adolescents are reported separately from adults; - Trials limited to children or adolescents with health issues that would limit generalizability to general primary care patients
Condition | - Use of tobacco or nicotine, including cigarettes, smokeless tobacco, cigars, pipes, and e-cigarettes | Studies that target marijuana use alone
Interventions | - Primary care–relevant behavioral counseling interventions, including individual, group, phone, or technology-based sessions; telephone quit lines; apps; and health care system–level interventions; - Adjunctive use of pharmacotherapy (nicotine replacement therapy, bupropion, or varenicline tartrate); - Interventions targeting parents or caregivers as a means to prevent or reduce tobacco or nicotine use in children and adolescents; - Complementary and alternative medicine treatments, such as acupuncture and hypnosis | - Broad public health or policy interventions; - Use of e-cigarettes as a cessation or prevention intervention; - Trials in which participants are highly likely to know one another (i.e., closed social groups, peer counseling) and participant interaction is likely
Comparisons | - Usual care; - Minimal care (no more than one single brief contact per year or brief written materials, such as pamphlets); - No intervention; - Attention control; - Wait list | Active intervention (more intensive than a single, brief contact per year or brief written materials)
Outcomes | KQ 1:; - Prevalence or severity of asthma, chronic bronchitis, or other respiratory disorders, health care utilization for respiratory disorders; - Dental/oral health outcomes; - Cardiovascular health outcomes; - Rate, incidence, or prevalence of adult tobacco or nicotine use; KQ 2:; - Tobacco or nicotine use cessation; - Frequency or quantity of alcohol use or use of other substances; KQ 3:; - Any adverse effect occurring after initiation of the intervention (e.g., paradoxical increase in tobacco or nicotine use, mental health issues) | Attitudes or knowledge about tobacco; intentions to quit
Study Design | KQs 1, 2:; - Randomized and nonrandomized, controlled trials; systematic reviews; - Trials with a minimum of 6 months (or 24 weeks) of followup postbaseline; KQ 3:; - Randomized and nonrandomized, controlled trials; comparative observational designs; systematic reviews; - No minimum followup required | KQs 1 to 3: All other study designs; KQs 1, 2: Studies with less than 6 months (or 24 weeks) of followup postbaseline
Study Quality | Fair- or good-quality studies | Poor-quality studies

Abbreviations: KQ=key question.

## Appendix A3 Literature Flow Diagram

*Other sources include reference lists of relevant articles, systematic reviews, reviewer suggestions, etc.

^†^ See Appendix 4 for the list of excluded studies and Appendix 2 for the list of exclusion criteria.

^‡^ Studies that provided data and contributed to the body of evidence were considered ‘included’.

^§^ Studies may contribute data to more than one key question.

^ǁ^ new publication73 is an update of a previously included trial.^64^

Appendix A3 is a literature flow diagram depicting the search and selection of articles for the review. The diagram shows that 5,892 citations were identified through literature database searches and other sources, which includes reference lists of relevant articles, systematic reviews, reviewer suggestions, etc. 142 articles were reviewed at the full-text level after excluding 5,486 abstracts, pulling 182 articles for background or to review references, and pulling 82 articles for the contextual question. From the 142 full-text articles reviewed, 130 were excluded for the following reasons: population not applicable (24), intervention not appropriate (9), comparison not appropriate (3), followup less than 6 months (8), wrong outcome(s) (15), wrong setting (49), wrong publication type (10), wrong study design for key question (11), or non-English language (1). See Appendix 4 for the list of excluded studies and Appendix 2 for the list of exclusion criteria. 24 articles that were included in the prior report were reviewed for the current review’s key questions. After reviewing for inclusion, 3 studies were excluded for poor quality. 33 articles were included. Studies that provided data and contributed to the body of evidence were considered ‘included.’ Studies may contribute data to more than 1 key question. For Key Question 1, there were no prior report articles and there are 2 new articles representing 2 trials; for Key Question 2, there were 23 prior report articles representing 18 trials and there are 8 new articles representing 7 trials; for Key Question 3, there were 24 prior report articles representing 19 trials and there are 9 new articles representing 7 trials. 1 new publication (reference 71) is an update of a previously included trial (reference 62) and is included for all key questions.

## Appendix A4 List of Excluded Studies

1. Allara E, Angelini P, Gorini G, . A prevention program for multiple health-compromising behaviors in adolescence: baseline results from a cluster randomized controlled trial. Prev Med. 2015 Feb;71:20–6. doi: 10.1016/j.ypmed.2014.12.002. PMID: 25500201. Exclusion reason: wrong setting.25500201
2. Al-Sheyab N, Alomari M, Shah S, . ‘Class smoke-free’ pledge impacts on nicotine dependence in male adolescents: a cluster randomized controlled trial. Trop Med Int Health. 2015;20:255–6. Exclusion reason: wrong setting.
3. Andersen A, Krolner R, Bast LS, . Effects of the X:IT smoking intervention: a school-based cluster randomized trial. Int J Epidemiol. 2015 Dec;44(6):1900–8. doi: 10.1093/ije/dyv145. PMID: 26210612. Exclusion reason: wrong setting.26210612
4. Andersen A, Krolner R, L SN, . Prevention of smoking among adolescents: first year results from the cluster randomised X:IT trial. IEA-EEF European Congress of Epidemiology 2012: Epidemiology for a Fair and Healthy Society. Eur J Epidemiol. 2012 Sep 5-8;27(1 SUPPL. 1):S29. Exclusion reason: wrong publication type.
5. Bailey SR, Hagen SA, Jeffery CJ, . A randomized clinical trial of the efficacy of extended smoking cessation treatment for adolescent smokers. Nicotine Tob Res. 2013 Oct;15(10):1655–62. doi: 10.1093/ntr/ntt017. PMID: 23460656. Exclusion reason: wrong setting.23460656
6. Barry R. It’s a bitch to quit: interview with Dr. Phoenix Matthews [Blog Interview]. 2012. http://thelstop.org/2012/11/its-a-bitch-to-quit-interview-with-dr-phoenix-matthews/. Accessed Sep 8, 2018. Exclusion reason: wrong publication type
7. Baskerville NB, Azagba S, Norman C, . Effect of a digital social media campaign on young adult smoking cessation. Nicotine Tob Res. 2016 Mar;18(3):351–60. doi: 10.1093/ntr/ntv119. PMID: 26045252. Exclusion reason: population not applicable.26045252
8. Bast LS, Due P, Bendtsen P, . High impact of implementation on school-based smoking prevention: the X:IT study-a cluster-randomized smoking prevention trial. Implementation Science. 2016 Sep 17;11(1):125. doi: 10.1186/s13012-016-0490-7. PMID: 27640187. Exclusion reason: wrong setting.27640187
9. Bast LS, Due P, Ersboll AK, . Association of school characteristics and implementation in the X:IT study-a school-randomized smoking prevention program. J Sch Health. 2017 May;87(5):329–37. doi: 10.1111/josh.12500. PMID: 28382673. Exclusion reason: wrong setting.28382673
10. Bavarian N, Duncan R, Lewis KM, . Adolescent substance use following participation in a universal drug prevention program: examining relationships with program recall and baseline use status. Subst Abus. 2015;36(3):359–67. doi: 10.1080/08897077.2014.952364. PMID: 25148566. Exclusion reason: wrong setting.25148566
11. Bernardes-Souza B, Patruz Ananias De Assis Pires F, Madeira GM, . Facial-aging mobile apps for smoking prevention in secondary schools in Brazil: appearance-focused interventional study. JMIR Public Health Surveill. 2018 Jul 17;4(3):e10234. doi: 10.2196/10234. PMID: 30021713. Exclusion reason: wrong setting.30021713
12. Bowen DJ, Henderson PN, Harvill J, . Short-term effects of a smoking prevention website in American Indian youth. J Med Internet Res. 2012 May-Jun;14(3):185–92. doi: 10.2196/jmir.1682. PMID: 22659390. Exclusion reason: followup less than 6 months.22659390
13. Bradley EG. Reducing adolescent smoking through a school-based motivational intervention: a pilot study. E-Journal of Applied Psychology. 2012;8(1):38–44. doi: 10.7790/ejap.v8i1.319. Exclusion reason: wrong outcome.
14. Brick LA, Redding CA, Paiva AL, . Intervention effects on stage transitions for adolescent smoking and alcohol use acquisition. Psychol Addict Behav. 2017 Aug;31(5):614–24. doi: 10.1037/adb0000302. PMID: 28714725. Exclusion reason: wrong outcome.28714725
15. Brinker TJ, Owczarek AD, Seeger W, . A medical student-delivered smoking prevention program, education against tobacco, for secondary schools in Germany: randomized controlled trial. J Med Internet Res. 2017 Jun 06;19(6):e199. doi: 10.2196/jmir.7906. PMID: 28588007. Exclusion reason: intervention not appropriate.28588007
16. Brinker TJ, Stamm-Balderjahn S, Seeger W, . Education Against Tobacco (EAT): a quasi-experimental prospective evaluation of a multinational medical-student-delivered smoking prevention programme for secondary schools in Germany. BMJ Open. 2015 Sep 18;5(9):e008093. doi: 10.1136/bmjopen-2015-008093. PMID: 26384722. Exclusion reason: wrong setting.26384722
17. Burford O, Jiwa M, Carter O, . Internet-based photoaging within Australian pharmacies to promote smoking cessation: randomized controlled trial. J Med Internet Res. 2013 Mar 26;15(3):e64. doi: 10.2196/jmir.2337. PMID: 23531984. Exclusion reason: population not applicable.23531984
18. Burford O, Kindarji S, Parsons R, . Using visual demonstrations in young adults to promote smoking cessation: preliminary findings from a French pilot study. Res Social Adm Pharm. 2018 04;14(4):398–400. doi: 10.1016/j.sapharm.2017.04.050. PMID: 28495124. Exclusion reason: population not applicable.28495124
19. Caldwell AL, Tingen MS, Nguyen JT, . Parental smoking cessation: impacting children’s tobacco smoke exposure in the home. Pediatrics. 2018;141:(Suppl 1):S96–S106. PMID: 29292310. Exclusion reason: wrong outcome.29292310
20. Carragher N, Krueger RF, Eaton NR, . ADHD and the externalizing spectrum: direct comparison of categorical, continuous, and hybrid models of liability in a nationally representative sample. Soc Psychiatry Psychiatr Epidemiol. 2014 Aug;49(8):1307–17. doi: 10.1007/s00127-013-0770-3. PMID: 24081325. Exclusion reason: wrong outcome.24081325
21. Castro RP, Haug S, Filler A, . Engagement within a mobile phone-based smoking cessation intervention for adolescents and its association with participant characteristics and outcomes. J Med Internet Res. 2017 Nov;19(11):e356. PMID: 29092811. Exclusion reason: wrong outcome.29092811
22. Chansatitporn N, Charoenca N, Sidhu A, . Three-month effects of Project EX: a smoking intervention pilot program with Thai adolescents. Addict Behav. 2016 Oct;61:20–4. doi: 10.1016/j.addbeh.2016.05.003. PMID: 27235988. Exclusion reason: followup less than 6 months.27235988
23. Chen YF, Yu T, Brody GH. Parenting intervention at age 11 and cotinine levels at age 20 among African American youth. Pediatrics. 2017 Jul;140(1) doi: 10.1542/peds.2016-4162. PMID: 28615354. Exclusion reason: wrong publication type.28615354
24. Clawson AH, Robinson LA, Ali JS. Physician advice to adolescents about smoking: who gets advised and who benefits most? J Adolesc Health. 2016 Feb;58(2):195–201. doi: 10.1016/j.jadohealth.2015.10.006. PMID: 26802992. Exclusion reason: wrong study design.26802992
25. Coleman T, Cooper S, Thornton JG, . A randomized trial of nicotine-replacement therapy patches in pregnancy. Obstet Gynecol Surv. 2012;67(7):387–8. doi: 10.1097/OGX.0b013e31825fd62b. Exclusion reason: population not applicable.
26. Collins BN, Lepore SJ, Winickoff JP, . An office-initiated multilevel intervention for tobacco smoke exposure: a randomized trial. [Erratum appears in PMID: 29853625]. Pediatrics. 2018 Jan;141:(Suppl 1):S75–S86. doi: 10.1542/peds.2017-1026K. PMID: 29292308. Exclusion reason: wrong outcome.29292308
27. Cooper S, Taggar J, Lewis S, . Effect of nicotine patches in pregnancy on infant and maternal outcomes at 2 years: follow-up from the randomised, double-blind, placebo-controlled SNAP trial.[Erratum appears in Lancet Respir Med. 2014 Nov;2(11):e22]. Lancet Respir Med. 2014 Sep;2(9):728–37. doi: 10.1016/S2213-2600(14)70157-2. PMID: 25127405. Exclusion reason: wrong outcome.25127405
28. Cremers HP, Mercken L, Oenema A, . A web-based computer-tailored smoking prevention programme for primary school children: intervention design and study protocol. BMC Public Health. 2012 Jun 11;12:277. doi: 10.1186/1471-2458-12-277. PMID: 22490110. Exclusion reason: wrong publication type.22490110
29. Cummins SE, Tedeschi GJ, Anderson CM, . Telephone intervention for pregnant smokers: a randomized controlled trial. Am J Prev Med. 2016;51(3):318–26. doi: 10.1016/j.amepre.2016.02.022. Exclusion reason: population not applicable.27056131
30. Daly JB, Mackenzie LJ, Freund M, . Interventions by health care professionals who provide routine child health care to reduce tobacco smoke exposure in children: a review and meta-analysis. JAMA Pediatrics. 2016 Feb;170(2):138–47. doi: 10.1001/jamapediatrics.2015.3342. PMID: 26719991. Exclusion reason: wrong study design.26719991
31. Davis JM, Mills DM, Stankevitz KA, . Pilot randomized trial on mindfulness training for smokers in young adult binge drinkers. BMC Complement Altern Med. 2013 Sep 03;13:215. doi: 10.1186/1472-6882-13-215. PMID: 24006963. Exclusion reason: population not applicable.24006963
32. Di Paco A, Boffi R, De Marco C, . A sequential school based smoke prevention program in secondary school adolescents. Monaldi Arch Chest Dis. 2013 Mar;79(1):8–11. doi: 10.4081/monaldi.2013.103. PMID: 23741940. Exclusion reason: wrong setting.23741940
33. Dotterud CK, Storro O, Simpson MR, . The impact of pre- and postnatal exposures on allergy related diseases in childhood: a controlled multicentre intervention study in primary health care. BMC Public Health. 2013 Feb 08;13:123. doi: 10.1186/1471-2458-13-123. PMID: 23394141. Exclusion reason: wrong outcome.23394141
34. Eades SJ, Sanson-Fisher RW, Wenitong M, . An intensive smoking intervention for pregnant Aboriginal and Torres Strait Islander women: a randomised controlled trial. Med J Aust. 2012 Jul 2;197(1):42–6. PMID: 22762231. Exclusion reason: population not applicable.22762231
35. Eakin MN, Rand CS, Borrelli B, . Effectiveness of motivational interviewing to reduce head start children’s secondhand smoke exposure. a randomized clinical trial. Am J Respir Crit Care Med. 2014 Jun 15;189(12):1530–7. doi: 10.1164/rccm.201404-0618OC. PMID: 24821270. Exclusion reason: wrong outcome.24821270
36. Elder JP, Woodruff SI, Eckhardt L. Participation in a telephone-based tobacco use prevention program for adolescents. Am J Health Promot. 1994;9(2):92–5. Exclusion reason: wrong setting.10150717
37. Endrighi R, McQuaid EL, Bartlett YK, . Parental depression is prospectively associated with lower smoking cessation rates and poor child asthma outcomes. Ann Behav Med. 2018 Feb 17;52(3):195–203. doi: 10.1093/abm/kax011. PMID: 29538661. Exclusion reason: wrong outcome.29538661
38. Espada JP, Gonzalvez MT, Guillen-Riquelme A, . Immediate effects of Project EX in Spain: a classroom-based smoking prevention and cessation intervention program. J Drug Educ. 2014;44(1-2):3–18. doi: 10.1177/0047237915573523. PMID: 25721322. Exclusion reason: wrong setting.25721322
39. Espada JP, Gonzalvez MT, Orgiles M, . Pilot clinic study of Project EX for smoking cessation with Spanish adolescents. Addict Behav. 2015 Jun;45:226–31. doi: 10.1016/j.addbeh.2015.02.009. PMID: 25725191. Exclusion reason: wrong setting.25725191
40. Espada JP, Gonzalvez MT, Orgiles M, . Preliminary results of Project EX in Spain: a classroom-based smoking prevention and cessation program. Drug Alcohol Depend. 2014;146(14). Exclusion reason: wrong publication type.
41. Espada JP, Gonzalvez MT, Orgiles M, . One-year effects of Project EX: a smoking intervention pilot program with Spanish adolescents. J Health Psychol. 2017 Jul;22(8):1067–74. doi: 10.1177/1359105315623628. PMID: 26826168. Exclusion reason: wrong setting.26826168
42. Fallin A, Neilands TB, Jordan JW, . Wreaking “havoc” on smoking: social branding to reach young adult “partiers” in Oklahoma. Am J Prev Med. 2015 Jan;48(1 Suppl 1):S78–85. doi: 10.1016/j.amepre.2014.09.008. PMID: 25528713. Exclusion reason: population not applicable.25528713
43. Fanshawe TR, Halliwell W, Lindson N, . Tobacco cessation interventions for young people. Cochrane Database Syst Rev. 2017 Nov 17;11:CD003289. doi: 10.1002/14651858.CD003289.pub6. PMID: 29148565. Exclusion reason: wrong study design.29148565
44. Farsalinos KE, Romagna G. Chronic idiopathic neutrophilia in a smoker, relieved after smoking cessation with the use of electronic cigarette: a case report. Clin Med Insights Case Rep. 2013;6:15–21. doi: 10.4137/CCRep.S11175. PMID: 23439796. Exclusion reason: wrong study design.23439796
45. Floden L, Taren DL, Muramoto ML, . BMI changes in adolescents treated with bupropion SR for smoking cessation. Obesity. 2016 Jan;24(1):26–9. doi: 10.1002/oby.21360. PMID: 26692579. Exclusion reason: wrong study design.26692579
46. Fosco GM, Frank JL, Stormshak EA, . Opening the “Black Box”: family check-up intervention effects on self-regulation that prevents growth in problem behavior and substance use. J Sch Psychol. 2013 Aug;51(4):455–68. doi: 10.1016/j.jsp.2013.02.001. PMID: 23870441. Exclusion reason: wrong setting.23870441
47. Fridberg DJ, Cao D, King AC. Integrating alcohol response feedback in a brief intervention for young adult heavy drinkers who smoke: a pilot study. Drug Alcohol Depend. 2015 Oct 01;155:293–7. doi: 10.1016/j.drugalcdep.2015.08.017. PMID: 26341847. Exclusion reason: intervention not appropriate.26341847
48. Fromme K, Brown SA. Empirically based prevention and treatment approaches for adolescent and young adult substance use. Cogn Behav Pract. 2000;7(1):61–4. Exclusion reason: wrong study design.
49. Gharlipour Z, Hazavehei SMM, Moeini B, . The effect of preventive educational program in cigarette smoking: Extended Parallel Process Model. J Educ Health Promot. 2015;4:4. doi: 10.4103/2277-9531.151875. PMID: 25767815. Exclusion reason: wrong setting.25767815
50. Giannotta F, Vigna-Taglianti F, Rosaria Galanti M, . Short-term mediating factors of a school-based intervention to prevent youth substance use in Europe. J Adolesc Health. 2014 May;54(5):565–73. doi: 10.1016/j.jadohealth.2013.10.009. PMID: 2013-43584-001. Exclusion reason: wrong setting.24332392
51. Gonzalvez MT, Espada JP, Orgiles M, . One-year effects of Project EX in Spain: a classroom-based smoking prevention and cessation intervention program. PLoS ONE [Electronic Resource]. 2015;10(6):e0130595. doi: 10.1371/journal.pone.0130595. PMID: 26090821. Exclusion reason: wrong setting.26090821
52. Gonzalvez MT, Espada JP, Orgiles M, . Two-year effects of a classroom-based smoking prevention and cessation intervention program. Eur Addict Res. 2017;23(3):122–8. doi: 10.1159/000475985. PMID: 28595196. Exclusion reason: wrong setting.28595196
53. Gorzkowski JA, Kaseeska KR, Wright M, . Implementation and impact of the 5As tobacco counseling intervention with adolescents in pediatric practice. J Adolesc Health. 2016 Mar 9-12;58(2016):S49. doi: 10.1016/j.jadohealth.2015.10.110. Exclusion reason: wrong publication type.
54. Gray KM, Carpenter MJ, Lewis A, . Varenicline versus bupropion XL for smoking cessation in older adolescents: a randomized, double-blind pilot trial. Nicotine Tob Res. 2012 Feb;14(2):235–9. doi: 10.1093/ntr/ntr130. PMID: 21778151. Exclusion reason: population not applicable.21778151
55. Guo J, Liao J, Chang L, . The effectiveness of an integrated multicomponent program for adolescent smoking cessation in Taiwan. Addict Behav. 2014 Oct;39(10):1491–9. doi: 10.1016/j.addbeh.2014.05.009. PMID: 2014-29596-021. Exclusion reason: wrong setting.24949950
56. Haller DM, Pfarrwaller E, Cerutti B, . Primary care interventions to reduce cardiovascular risk behaviours in adolescents: a protocol for a systematic review. BMJ Open. 2016 Oct 18;6(10):e011936. doi: 10.1136/bmjopen-2016-011936. PMID: 27798001. Exclusion reason: wrong publication type.27798001
57. Harrell MB, Arora M, Bassi S, . Reducing tobacco use among low socio-economic status youth in Delhi, India: outcomes from project ACTIVITY, a cluster randomized trial. Health Educ Res. 2016 Oct;31(5):624–38. doi: 10.1093/her/cyw039. PMID: 27540182. Exclusion reason: intervention not appropriate.27540182
58. Harutyunyan A, Movsisyan N, Petrosyan V, . Reducing children’s exposure to secondhand smoke at home: a randomized trial. Pediatrics. 2013 Dec;132(6):1071–80. doi: 10.1542/peds.2012-2351. PMID: 24190686. Exclusion reason: population not applicable.24190686
59. Haug S, Paz Castro R, Kowatsch T, . Efficacy of a technology-based, integrated smoking cessation and alcohol intervention for smoking cessation in adolescents: results of a cluster-randomised controlled trial. J Subst Abuse Treat. 2017;82(pp 55–66) PMID: CN-01412025. Exclusion reason: comparison not appropriate.29021116
60. Hawkins JD, Oesterle S, Brown EC, . Youth problem behaviors 8 years after implementing the communities that care prevention system: a community-randomized trial. JAMA Pediatrics. 2014 Feb;168(2):122–9. doi: 10.1001/jamapediatrics.2013.4009. PMID: 24322060. Exclusion reason: intervention not appropriate.24322060
61. Heffner JL, Kealey KA, Marek PM, . Proactive telephone counseling for adolescent smokers: comparing regular smokers with infrequent and occasional smokers on treatment receptivity, engagement, and outcomes. Drug Alcohol Depend. 2016 Aug;165:229–35. doi: 10.1016/j.drugalcdep.2016.06.014. PMID: 27344195. Exclusion reason: intervention not appropriate.27344195
62. Hodder RK, Freund M, Bowman J, . Effectiveness of a pragmatic school-based universal resilience intervention in reducing tobacco, alcohol and illicit substance use in a population of adolescents: cluster-randomised controlled trial. BMJ Open. 2017 Aug 18;7(8):e016060. doi: 10.1136/bmjopen-2017-016060. PMID: 28821523. Exclusion reason: wrong setting.28821523
63. Idrisov B, Sun P, Akhmadeeva L, . Immediate and six-month effects of Project EX Russia: a smoking cessation intervention pilot program. Addict Behav. 2013 Aug;38(8):2402–8. doi: 10.1016/j.addbeh.2013.03.013. PMID: 23639851. Exclusion reason: wrong setting.23639851
64. Isensee B, Hansen J, Maruska K, . Effects of a school-based prevention programme on smoking in early adolescence: a 6-month follow-up of the ‘Eigenstandig werden’ cluster randomised trial. BMJ Open. 2014 Jan 21;4(1):e004422. doi: 10.1136/bmjopen-2013-004422. PMID: 24448850. Exclusion reason: wrong setting.24448850
65. Isensee B, Morgenstern M, Stoolmiller M, . Effects of Smokefree Class Competition 1 year after the end of intervention: a cluster randomised controlled trial. J Epidemiol Community Health. 2012 Apr;66(4):334–41. doi: 10.1136/jech.2009.107490. PMID: 21071561. Exclusion reason: wrong setting.21071561
66. Jones DJ, Olson AL, Forehand R, . A family-focused randomised controlled trial to prevent adolescent alcohol and tobacco use: the moderating roles of positive parenting and adolescent gender. Behav Ther. 2005;36(4):347–55. Exclusion reason: wrong outcome.
67. Kegler MC, Bundy L, Haardorfer R, . A minimal intervention to promote smoke-free homes among 2-1-1 callers: a randomized controlled trial. Am J Public Health. 2015 Mar;105(3):530–7. doi: 10.2105/AJPH.2014.302260. PMID: 25602863. Exclusion reason: intervention not appropriate.25602863
68. Khalil GE, Wang H, Calabro KS, . From the experience of interactivity and entertainment to lower intention to smoke: a randomized controlled trial and path analysis of a web-based smoking prevention program for adolescents. J Med Internet Res. 2017 Feb 16;19(2):e44. doi: 10.2196/jmir.7174. PMID: 28209560. Exclusion reason: comparison not appropriate.28209560
69. Kong G, Larsen H, Cavallo DA, . Re-training automatic action tendencies to approach cigarettes among adolescent smokers: a pilot study. Am J Drug Alcohol Abuse. 2015;41(5):425–32. doi: 10.3109/00952990.2015.1049492. PMID: 26186485. Exclusion reason: wrong setting.26186485
70. Krist L, Lotz F, Burger C, . Long-term effectiveness of a combined student-parent and a student-only smoking prevention intervention among 7th grade school children in Berlin, Germany. Addiction. 2016 Dec;111(12):2219–29. doi: 10.1111/add.13537. PMID: 27447693. Exclusion reason: wrong setting.27447693
71. Larsen H, Kong G, Becker D, . Cognitive bias modification combined with cognitive behavioral therapy: a smoking cessation intervention for adolescents. Drug Alcohol Depend. 2015;146(14):e168. doi: 10.1016/j.drugalcdep.2014.09.374. Exclusion reason: wrong publication type.
72. Leischow SJ, Muramoto ML, Matthews E, . Adolescent smoking cessation with bupropion: the role of adherence. Nicotine Tob Res. 2016 May;18(5):1202–5. doi: 10.1093/ntr/ntv179. PMID: 26567274. Exclusion reason: followup less than 6 months.26567274
73. Levine MD, Cheng Y, Marcus MD, . Preventing postpartum smoking relapse: a randomized clinical trial. JAMA Internal Medicine. 2016 Apr;176(4):443–52. doi: 10.1001/jamainternmed.2016.0248. PMID: 26998789. Exclusion reason: population not applicable.26998789
74. Lindson-Hawley N, Thompson TP, Begh R. Motivational interviewing for smoking cessation. Cochrane Database Syst Rev. 2015 Mar 02(3):CD006936. doi: 10.1002/14651858.CD006936.pub3. PMID: 25726920. Exclusion reason: population not applicable.25726920
75. Lovato C, Watts A, Brown KS, . School and community predictors of smoking: a longitudinal study of Canadian high schools. Am J Public Health. 2013 Feb;103(2):362–8. doi: 10.2105/AJPH.2012.300922. PMID: 23237165. Exclusion reason: wrong study design.23237165
76. Luh DL, Chen HH, Yen AM, . Effect of self-reported home smoking restriction on smoking initiation among adolescents in Taiwan: a prospective cohort study. BMJ Open. 2015 Jun 26;5(6):e007025. doi: 10.1136/bmjopen-2014-007025. PMID: 26116613. Exclusion reason: wrong study design.26116613
77. Luna-Adame M, Carrasco-Gimenez TJ, Rueda-Garcia Mdel M. Evaluation of the effectiveness of a smoking prevention program based on the ‘Life Skills Training’ approach. Health Educ Res. 2013 Aug;28(4):673–82. doi: 10.1093/her/cyt061. PMID: 23784075. Exclusion reason: wrong setting.23784075
78. Ly C. The Texas Tobacco Prevention Program (T2P 2): An Update of the Minnesota Smoking Prevention Program (MSPP) [dissertation]. Houston: Texas Medical Center Dissertations (via ProQuest); 2015. Exclusion reason: wrong setting
79. Mall ASK, Bhagyalaxmi A. An informal school-based, peer-led intervention for prevention of tobacco consumption in adolescence: a cluster randomized trial in rural Gandhinagar. Indian J Community Med. 2017 Jul-Sep;42(3):143–6. doi: 10.4103/ijcm.IJCM_25_16. PMID: 28852276. Exclusion reason: wrong setting.28852276
80. Marsiglia FF, Kulis SS, Booth JM, . Long-term effects of the keepin’ it REAL model program in Mexico: substance use trajectories of Guadalajara middle school students. J Prim Prev. 2015 Apr;36(2):93–104. doi: 10.1007/s10935-014-0380-1. PMID: 25416154. Exclusion reason: wrong setting.25416154
81. Mason M, Mennis J, Way T, . Real-time readiness to quit and peer smoking within a text message intervention for adolescent smokers: modeling mechanisms of change. J Subst Abuse Treat. 2015 Dec;59:67–73. doi: 10.1016/j.jsat.2015.07.009. PMID: 26297323. Exclusion reason: wrong outcome.26297323
82. Mason M, Mennis J, Way T, . Text message delivered peer network counseling for adolescent smokers: a randomized controlled trial. J Prim Prev. 2016 Oct;37(5):403–20. doi: 10.1007/s10935-016-0439-2. PMID: 27388626. Exclusion reason: wrong outcome.27388626
83. Mason MJ, Campbell L, Way T, . Development and outcomes of a text messaging tobacco cessation intervention with urban adolescents. Subst Abus. 2015;36(4):500–6. doi: 10.1080/08897077.2014.987946. PMID: 25551337. Exclusion reason: wrong outcome.25551337
84. Masood M, Masood Y, Md Sabri BA, . Within-family discussion on harmful effects of smoking and intention to initiate smoking among European adolescents. J Addict Med. 2015 Jul-Aug;9(4):261–5. doi: 10.1097/ADM.0000000000000127. PMID: 26241085. Exclusion reason: wrong outcome.26241085
85. Mata HJ. Development and evaluation of a personalized normative feedback intervention for Hispanic youth at high risk of smoking [dissertation]. El Paso: ETD Collection for University of Texas, El Paso; 2011. Exclusion reason: followup less than 6 months
86. Matias MA, Steindl SR, Plonka KA, . Do school based anti-smoking campaigns delivered by oral health therapists work? Aust Dent J. 2013 Sep;58(3):301–5. doi: 10.1111/adj.12078. PMID: 23981210. Exclusion reason: wrong study design.23981210
87. Matthews AK, Li CC, Kuhns LM, . Results from a community-based smoking cessation treatment program for LGBT smokers. J Environ Public Health. 2013;2013:984508. doi: 10.1155/2013/984508. PMID: 23840237. Exclusion reason: population not applicable.23840237
88. Matthews AK, McConnell EA, Li CC, . Design of a comparative effectiveness evaluation of a culturally tailored versus standard community-based smoking cessation treatment program for LGBT smokers. BMC Psychol. 2014;2(1):12. doi: 10.1186/2050-7283-2-12. PMID: 25566383. Exclusion reason: population not applicable.25566383
89. McClure EA, Baker NL, Gray KM. Cigarette smoking during an N-acetylcysteine-assisted cannabis cessation trial in adolescents. Am J Drug Alcohol Abuse. 2014 Jul;40(4):285–91. doi: 10.3109/00952990.2013.878718. PMID: 24720376. Exclusion reason: intervention not appropriate.24720376
90. Mercken L, Moore L, Crone M, . The effectiveness of school-based smoking prevention interventions among low- and high-SES European teenagers. Health Educ Res. 2012 Jun;27(3):459–69. doi: 10.1093/her/cys017. PMID: 22350193. Exclusion reason: wrong setting.22350193
91. Minary L, Cambon L, Martini H, . Efficacy of a smoking cessation program in a population of adolescent smokers in vocational schools: a public health evaluative controlled study. BMC Public Health. 2013 Feb 18;13:149. doi: 10.1186/1471-2458-13-149. PMID: 23418994. Exclusion reason: wrong setting.23418994
92. Mohammed M, Eggers SM, Alotaiby FF, . Effects of a randomized controlled trial to assess the six-months effects of a school based smoking prevention program in Saudi Arabia. Prev Med. 2016 Sep;90:100–6. doi: 10.1016/j.ypmed.2016.06.032. PMID: 27386742. Exclusion reason: wrong setting.27386742
93. Patten CA, Fadahunsi O, Hanza MM, . Tobacco cessation treatment for Alaska native adolescents: group randomized pilot trial. Nicotine Tob Res. 2014 Jun;16(6):836–45. doi: 10.1093/ntr/ntu004. PMID: 24532352. Exclusion reason: wrong setting.24532352
94. Patten CA, Hughes CA, Lopez KN, . Web-based intervention for adolescent nonsmokers to help parents stop smoking: a pilot feasibility study. Addict Behav. 2012 Jan;37(1):85–91. PMID: 21955873. Exclusion reason: population not applicable.21955873
95. Pbert L, Druker S, Flint AJ, . Perspectives in implementing a pragmatic pediatric primary care-based intervention trial. Am J Prev Med. 2015 Sep;49(3 Suppl 2):S200–7. doi: 10.1016/j.amepre.2015.03.037. PMID: 26296555. Exclusion reason: wrong study design.26296555
96. Perez-Milena A, Navarrete-Guillen AB, Mesa-Gallardo MI, . Efficiency of two motivational interventions for adolescent smokers (brief and intensive) conducted in high schools. Adicciones. 2012;24(3):191–200. doi: 10.20882/adicciones.90. Exclusion reason: non-English language.22868974
97. Perry CL, Maccoby N, McAlister. Adolescent smoking prevention: a third year follow-up. World smoking & health. 1980;5:40–5. Exclusion reason: wrong study design.
98. Peterson AV, Jr., Kealey KA, Mann SL, . Group-randomized trial of a proactive, personalized telephone counseling intervention for adolescent smoking cessation. J Natl Cancer Inst. 2009 Oct 21;101(20):1378–92. doi: 10.1093/jnci/djp317. PMID: 19822836. Exclusion reason: intervention not appropriate.19822836
99. Peterson AV, Jr., Marek PM, Kealey KA, . Does effectiveness of adolescent smoking-cessation intervention endure into young adulthood? 7-year follow-up results from a group-randomized trial. PLoS ONE [Electronic Resource]. 2016;11(2):e0146459. doi: 10.1371/journal.pone.0146459. PMID: 26829013. Exclusion reason: intervention not appropriate.26829013
100. Primack BA, Douglas EL, Land SR, . Comparison of media literacy and usual education to prevent tobacco use: a cluster-randomized trial. J Sch Health. 2014 Feb;84(2):106–15. doi: 10.1111/josh.12130. PMID: 25099425. Exclusion reason: wrong setting.25099425
101. Prochaska JJ, Fromont SC, Ramo DE, . Gender differences in a randomized controlled trial treating tobacco use among adolescents and young adults with mental health concerns. Nicotine Tob Res. 2015 Apr;17(4):479–85. doi: 10.1093/ntr/ntu205. PMID: 25762759. Exclusion reason: population not applicable.25762759
102. Raja M, Saha S, Mohd S, . Cognitive behavioural therapy versus basic health education for tobacco cessation among tobacco users: a randomized clinical trial. J Clin Diagn Res. 2014;8(4):ZC47–ZC9. doi: 10.7860/JCDR/2014/8015.4279. Exclusion reason: followup less than 6 months.24959516
103. Ramo DE, Thrul J, Chavez K, . Feasibility and quit rates of the Tobacco Status Project: a Facebook smoking cessation intervention for young adults. J Med Internet Res. 2015 Dec 31;17(12):e291. doi: 10.2196/jmir.5209. PMID: 26721211. Exclusion reason: population not applicable.26721211
104. Reynolds B, Harris M, Slone SA, . A feasibility study of home-based contingency management with adolescent smokers of rural Appalachia. Exp Clin Psychopharmacol. 2015 Dec;23(6):486–93. doi: 10.1037/pha0000046. PMID: 26280592. Exclusion reason: wrong setting.26280592
105. Richmond R, Indig D, Butler T, . A randomized controlled trial of a smoking cessation intervention conducted among prisoners. Addiction. 2013 May;108(5):966–74. doi: 10.1111/add.12084. PMID: 23228222. Exclusion reason: population not applicable.23228222
106. Riesch SK, Brown RL, Anderson LS, . Strengthening families program (10-14): effects on the family environment. West J Nurs Res. 2012 Apr;34(3):340–76. doi: 10.1177/0193945911399108. PMID: 21403057. Exclusion reason: wrong setting.21403057
107. Saraf DS, Gupta SK, Pandav CS, . Effectiveness of a school based intervention for prevention of non-communicable diseases in middle school children of rural North India: a randomized controlled trial. Indian J Pediatr. 2015 Apr;82(4):354–62. doi: 10.1007/s12098-014-1562-9. PMID: 25209052. Exclusion reason: wrong setting.25209052
108. Scherphof CS, van den Eijnden RJ, Lugtig P, . Adolescents’ use of nicotine replacement therapy for smoking cessation: predictors of compliance trajectories. Psychopharmacology (Berl). 2014 Apr;231(8):1743–52. doi: 10.1007/s00213-014-3511-8. PMID: 24595505. Exclusion reason: followup less than 6 months.24595505
109. Schinke SP, Gilchrist LD, Snow WH. Skills intervention to prevent cigarette smoking among adolescents. Am J Public Health. 1985;75(6):665–7. PMID: 4003636. Exclusion reason: wrong setting.4003636
110. Schinke SP, Gilchrist LD, Snow WH, . Skills-building methods to prevent smoking by adolescents. J Adolesc Health Care. 1985;6(6):439–44. PMID: 4055463. Exclusion reason: wrong setting.4055463
111. Schuck K, Otten R, Kleinjan M, . Predictors of cessation treatment outcome and treatment moderators among smoking parents receiving quitline counselling or self-help material. Prev Med. 2014 Dec;69:126–31. doi: 10.1016/j.ypmed.2014.09.014. PMID: 25278424. Exclusion reason: population not applicable.25278424
112. Sharifirad GR, Eslami AA, Charkazi A, . The effect of individual counseling, line follow-up, and free nicotine replacement therapy on smoking cessation in the samples of Iranian smokers: examination of transtheoretical model. J Res Med Sci. 2012;17(12):1128–36. PMID: 23853630. Exclusion reason: population not applicable.23853630
113. Shi HJ, Jiang XX, Yu CY, . Use of mobile phone text messaging to deliver an individualized smoking behaviour intervention in Chinese adolescents. J Telemed Telecare. 2013 Jul;19(5):282–7. doi: 10.1177/1357633X13495489. PMID: 24163238. Exclusion reason: followup less than 6 months.24163238
114. Simon P, Connell C, Kong G, . Self-efficacy mediates treatment outcome in a smoking cessation program for adolescent smokers. Drug Alcohol Depend. 2014;146(14). Exclusion reason: comparison not appropriate.
115. Sims TH, McAfee T, Fraser DL, . Quitline cessation counseling for young adult smokers: a randomized clinical trial. Nicotine Tob Res. 2013 May;15(5):932–41. doi: 10.1093/ntr/nts227. PMID: 23080378. Exclusion reason: population not applicable.23080378
116. Skarstrand E, Sundell K, Andreasson S. Evaluation of a Swedish version of the Strengthening Families Programme. Eur J Public Health. 2014 Aug;24(4):578–84. doi: 10.1093/eurpub/ckt146. PMID: 24078373. Exclusion reason: wrong setting.24078373
117. Skov-Ettrup LS, Ringgaard LW, Dalum P, . Comparing tailored and untailored text messages for smoking cessation: a randomized controlled trial among adolescent and young adult smokers. Health Educ Res. 2014 Apr;29(2):195–205. doi: 10.1093/her/cyt112. PMID: 24399268. Exclusion reason: population not applicable.24399268
118. Stamm-Balderjahn S, Groneberg DA, Kusma B, . Smoking prevention in school students: positive effects of a hospital-based intervention. Deutsches Arzteblatt International. 2012 Nov;109(44):746–52. doi: 10.3238/arztebl.2012.0746. PMID: 23189108. Exclusion reason: wrong setting.23189108
119. Stotts AL, Green C, Northrup TF, . Feasibility and efficacy of an intervention to reduce secondhand smoke exposure among infants discharged from a neonatal intensive care unit. J Perinatol. 2013 Oct;33(10):811–6. doi: 10.1038/jp.2013.43. PMID: 23619375. Exclusion reason: population not applicable.23619375
120. Stucki S, Kuntsche E, Archimi A, . Does smoking within an individual’s peer group affect intervention effectiveness? An evaluation of the Smoke-Free Class Competition among Swiss adolescents. Prev Med. 2014 Aug;65:52–7. doi: 10.1016/j.ypmed.2014.04.018. PMID: 24786759. Exclusion reason: wrong setting.24786759
121. Sussman S, Sun P, Rohrbach LA, . One-year outcomes of a drug abuse prevention program for older teens and emerging adults: evaluating a motivational interviewing booster component. Health Psychol. 2012 Jul;31(4):476–85. doi: 10.1037/a0025756. PMID: 21988096. Exclusion reason: wrong setting.21988096
122. Tahlil T, Woodman RJ, Coveney J, . Six-months follow-up of a cluster randomized trial of school-based smoking prevention education programs in Aceh, Indonesia. BMC Public Health. 2015 Oct 24;15:1088. doi: 10.1186/s12889-015-2428-4. PMID: 26499860. Exclusion reason: wrong setting.26499860
123. Tewari A, Bassi S, Stigler MH, . Innovative intervention strategy for tobacco control in low SES communities in Delhi: Project ACTIVITY. Respir Med. 2013;107(10). Exclusion reason: wrong setting.
124. Thrul J, Buhler A, Herth FJ. Prevention of teenage smoking through negative information giving, a cluster randomized controlled trial. Drugs (Abingdon Engl). 2014 Feb;21(1):35–42. doi: 10.3109/09687637.2013.798264. Exclusion reason: followup less than 6 months.
125. Tingen MS, Andrews JO, Heath J, . Tailored Parental Cessation Delivered Concurrently with Tobacco Prevention in Children Enrolled in Urban and Rural Southern Elementary Schools. Proceedings of the Eighth AACR Conference on The Science of Health Disparities in Racial/Ethnic Minorities and the Medically Underserved; 2015 Nov 13-16; Atlanta. Philadelphia: AACR; Cancer Epidemiol Biomarkers Prev; 2016. Exclusion reason: wrong publication type
126. Tuisku A, Salmela M, Nieminen P, . Varenicline and nicotine patch therapies in young adults motivated to quit smoking: a randomized, placebo-controlled, prospective study. Basic Clin Pharmacol Toxicol. 2016 Jul;119(1):78–84. doi: 10.1111/bcpt.12548. PMID: 26709238. Exclusion reason: population not applicable.26709238
127. Vandenbergh DJ, Schlomer GL, Cleveland HH, . An Adolescent Substance Prevention Model Blocks the Effect of CHRNA5 Genotype on Smoking During High School. Nicotine Tob Res. 2016 Feb;18(2):212–20. doi: 10.1093/ntr/ntv095. PMID: 25941207. Exclusion reason: wrong setting.25941207
128. Wang Y, Storr CL, Green KM, . The effect of two elementary school-based prevention interventions on being offered tobacco and the transition to smoking. Drug Alcohol Depend. 2012 Jan;120(1-3):202–8. doi: 10.1016/j.drugalcdep.2011.07.022. PMID: 21868176. Exclusion reason: wrong setting.21868176
129. Weichold K, Tomasik MJ, Silbereisen RK, . The effectiveness of the life skills program IPSY for the prevention of adolescent tobacco use: the mediating role of yielding to peer pressure. The Journal of Early Adolescence. 2016 Oct;36(7):881–908. doi: 10.1177/0272431615589349. Exclusion reason: wrong setting.
130. Xavier LEDF, Bernardes-Souza B, Lisboa OC, . A medical student-delivered smoking prevention program, Education Against Tobacco, for secondary schools in Brazil: study protocol for a randomized trial. JMIR Research Protocols. 2017 Jan 30;6(1):e16. doi: 10.2196/resprot.7134. PMID: 28137703. Exclusion reason: wrong publication type.28137703

## Appendix A5 U.S. Preventive Services Task Force Quality Rating Criteria^43^

### Randomized Controlled Trials (RCTs) and Cohort Studies

Criteria:

- Initial assembly of comparable groups:
  - For RCTs: Adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
  - For cohort studies: Consideration of potential confounders, with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- All important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies or intention-to treat analysis for RCTs

Definition of ratings based on above criteria:

Good:: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.
Fair:: Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs.
Poor:: Studies are graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs

## Appendix A6 Expert Reviewers of the Draft Report

- Jonathan D. Klein, MD, MPH, Professor and Senior Associate Head (Chair) of the Department of Pediatrics at the University of Illinois at Chicago
- Suzanne M. Colby, PhD, Professor in Psychiatry and Human Behavior and Behavioral and Social Sciences at Brown University
- Kelvin Choi, PhD, MPH, National Institute on Minority Health and Health Disparities at the National Institutes of Health
- Alberta Becenti, MPH, Indian Health Service Health Promotion and Disease Prevention Coordinator
- Nazleen Bharmal, MD, PhD, U.S. Department of Health and Human Services - Surgeon General’s Office
- Brandy Peaker, MD, MPH, Centers for Disease Control and Prevention

Note: Reviewers provided comments on a prior version of the draft report and may or may not agree with the report findings