# References

1 Society for Vascular Surgery. Abdonimal Aortic Aneurysm. https://vascular.org/patient-resources/vascular-conditions/abdominal-aortic-aneurysm. Accessed: Jul 11, 2011.
2 Kent KC. Clinical practice. Abdominal aortic aneurysms. N Engl J Med. 2014;371(22):2101–8. PMID. 10.1056/NEJMcp1401430 25427112
3 Chaikof EL, Dalman RL, Eskandari MK, . The Society for Vascular Surgery practice guidelines on the care of patients with an abdominal aortic aneurysm. J Vasc Surg. 2018;67(1):2–77 e2. PMID: 29268916. 10.1016/j.jvs.2017.10.044 29268916
4 Moll FL, Powell JT, Fraedrich G, . Management of abdominal aortic aneurysms clinical practice guidelines of the European society for vascular surgery. Eur J Vasc Endovasc Surg. 2011;41: Suppl 1:S1–S58. PMID: 21215940. 10.1016/j.ejvs.2010.09.011 21215940
5 Wanhainen A. How to define an abdominal aortic aneurysm-influence on epidemiology and clinical practice. Scand J Surg. 2008;97(2):105–9; discussion 9. PMID: 18575024. 10.1177/145749690809700204 18575024
6 Cornuz J, Sidoti Pinto C, Tevaearai H, . Risk factors for asymptomatic abdominal aortic aneurysm: systematic review and meta-analysis of population-based screening studies. Eur J Public Health. 2004;14(4):343–9. PMID: 15542867. 10.1093/eurpub/14.4.343 15542867
7 Jamrozik K, Norman PE, Spencer CA, . Screening for abdominal aortic aneurysm: lessons from a population-based study. Med J Aust. 2000;173(7):345–50. PMID: 11062788.11062788
8 Conway AM, Malkawi AH, Hinchliffe RJ, . First-year results of a national abdominal aortic aneurysm screening programme in a single centre. Br J Surg. 2012;99(1):73–7. PMID: 21928466. 10.1002/bjs.7685 21928466
9 Schermerhorn M, Zwolak R, Velazquez O, . Ultrasound screening for abdominal aortic aneurysm in medicare beneficiaries. Ann Vasc Surg. 2008;22(1):16–24. PMID: 18055170. 10.1016/j.avsg.2007.07.026 18055170
10 Svensjo S, Bjorck M, Gurtelschmid M, . Low prevalence of abdominal aortic aneurysm among 65-year-old Swedish men indicates a change in the epidemiology of the disease. Circulation. 2011;124(10):1118–23. PMID: 21844079. 10.1161/CIRCULATIONAHA.111.030379 21844079
11 Derubertis BG, Trocciola SM, Ryer EJ, . Abdominal aortic aneurysm in women: prevalence, risk factors, and implications for screening. J Vasc Surg. 2007;46(4):630–5. PMID: 17903646. 10.1016/j.jvs.2007.06.024 17903646
12 Ashton HA, Buxton MJ, Day NE, . The Multicentre Aneurysm Screening Study (MASS) into the effect of abdominal aortic aneurysm screening on mortality in men: a randomised controlled trial. Lancet. 2002;360(9345):1531–9. PMID: 12443589.12443589
13 Scott RA, Wilson NM, Ashton HA, . Influence of screening on the incidence of ruptured abdominal aortic aneurysm: 5-year results of a randomized controlled study. Br J Surg. 1995;82(8):1066–70. PMID: 7648155.7648155
14 Lindholt JS, Juul S, Fasting H, . Screening for abdominal aortic aneurysms: single centre randomised controlled trial. BMJ. 2005;330(7494):750. PMID: 15757960. 10.1136/bmj.38369.620162.82 15757960
15 McCaul KA, Lawrence-Brown M, Dickinson JA, . Long-term Outcomes of the Western Australian Trial of Screening for Abdominal Aortic Aneurysms: Secondary Analysis of a Randomized Clinical Trial. JAMA Intern Med. 2016;176(12):1761–7. PMID: 27802493. 10.1001/jamainternmed.2016.6633 27802493
16 Benson RA, Poole R, Murray S, . Screening results from a large United Kingdom abdominal aortic aneurysm screening center in the context of optimizing United Kingdom National Abdominal Aortic Aneurysm Screening Programme protocols. J Vasc Surg. 2016;63(2):301–4. PMID: 26482996. 10.1016/j.jvs.2015.08.091 26482996
17 Choke E, Vijaynagar B, Thompson J, . Changing epidemiology of abdominal aortic aneurysms in England and Wales: older and more benign? Circulation. 2012;125(13):1617–25. PMID. 10.1161/CIRCULATIONAHA.111.077503 22361325
18 Anjum A, Powell JT. Is the incidence of abdominal aortic aneurysm declining in the 21st century? Mortality and hospital admissions for England & Wales and Scotland. Eur J Vasc Endovasc Surg. 2012;43(2):161–6. PMID. 10.1016/j.ejvs.2011.11.014 22178251
19 Sandiford P, Mosquera D, Bramley D. Trends in incidence and mortality from abdominal aortic aneurysm in New Zealand. Br J Surg. 2011;98(5):645–51. PMID: 21381003. 10.1002/bjs.7461 21381003
20 Wanhainen A, Hultgren R, Linne A, . Outcome of the Swedish Nationwide Abdominal Aortic Aneurysm Screening Program. Circulation. 2016;134(16):1141–8. PMID: 27630132. 10.1161/CIRCULATIONAHA.116.022305 27630132
21 Johansson M, Zahl PH, Siersma V, . Benefits and harms of screening men for abdominal aortic aneurysm in Sweden: a registry-based cohort study. Lancet. 2018;391(10138):2441–7. PMID: 29916384. 10.1016/S0140-6736(18)31031-6 29916384
22 Grondal N, Sogaard R, Lindholt JS. Baseline prevalence of abdominal aortic aneurysm, peripheral arterial disease and hypertension in men aged 65–74 years from a population screening study (VIVA trial). Br J Surg. 2015;102(8):902–6. PMID: 25923784. 10.1002/bjs.9825 25923784
23 Ulug P, Powell JT, Sweeting MJ, . Meta-analysis of the current prevalence of screen-detected abdominal aortic aneurysm in women. Br J Surg. 2016;103(9):1097–104. PMID: 27346306. 10.1002/bjs.10225 27346306
24 Lo RC, Schermerhorn ML. Abdominal aortic aneurysms in women. J Vasc Surg. 2016;63(3):839–44. PMID: 26747679. 10.1016/j.jvs.2015.10.087 26747679
25 Harthun NL. Current issues in the treatment of women with abdominal aortic aneurysm. Gend Med. 2008;5(1):36–43. PMID.18420164
26 Powell JT, Greenhalgh RM. Clinical practice. Small abdominal aortic aneurysms. N Engl J Med. 2003;348(19):1895–901. PMID. 10.1056/NEJMcp012641 12736283
27 Singh K, Bonaa KH, Jacobsen BK, . Prevalence of and risk factors for abdominal aortic aneurysms in a population-based study : The Tromso Study. Am J Epidemiol. 2001;154(3):236–44. PMID.11479188
28 Erbel R, Aboyans V, Boileau C, . 2014 ESC Guidelines on the diagnosis and treatment of aortic diseases: Document covering acute and chronic aortic diseases of the thoracic and abdominal aorta of the adult. The Task Force for the Diagnosis and Treatment of Aortic Diseases of the European Society of Cardiology (ESC). Eur Heart J. 2014;35(41):2873–926. PMID. 10.1093/eurheartj/ehu281 25173340
29 Kent KC, Zwolak RM, Egorova NN, . Analysis of risk factors for abdominal aortic aneurysm in a cohort of more than 3 million individuals. J Vasc Surg. 2010;52(3):539–48. PMID: 20630687. 10.1016/j.jvs.2010.05.090 20630687
30 Tang W, Yao L, Roetker NS, . Lifetime Risk and Risk Factors for Abdominal Aortic Aneurysm in a 24-Year Prospective Study: The ARIC Study (Atherosclerosis Risk in Communities). Arteriosclerosis, Thrombosis & Vascular Biology. 2016;36(12):2468–77. PMID: 27834688. 10.1161/ATVBAHA.116.308147 27834688
31 Centers for Disease Control and Prevention, National Center for Health Statistics. WONDER: Multiple Cause of Death Files, 1999–2016. http://wonder.cdc.gov/ucd-icd10.html Accessed: Oct 12, 2018.
32 Reimerink JJ, van der Laan MJ, Koelemay MJ, . Systematic review and meta-analysis of population-based mortality from ruptured abdominal aortic aneurysm. Br J Surg. 2013;100(11):1405–13. PMID: 24037558. 10.1002/bjs.9235 24037558
33 Karthikesalingam A, Holt PJ, Vidal-Diez A, . Mortality from ruptured abdominal aortic aneurysms: clinical lessons from a comparison of outcomes in England and the USA. Lancet. 2014;383(9921):963–9. PMID: 24629298. 10.1016/S0140-6736(14)60109-4 24629298
34 De Rango P, Lenti M, Cieri E, . Association between sex and perioperative mortality following endovascular repair for ruptured abdominal aortic aneurysms. J Vasc Surg. 2013;57(6):1684–92. PMID: 23719041.23719041
35 Mureebe L, Egorova N, McKinsey JF, . Gender trends in the repair of ruptured abdominal aortic aneurysms and outcomes. J Vasc Surg. 2010;51:(4 Suppl):9S–13S. PMID. 10.1016/j.jvs.2009.10.129 20080005
36 Scott RA, Bridgewater SG, Ashton HA. Randomized clinical trial of screening for abdominal aortic aneurysm in women. Br J Surg. 2002;89(3):283–5. PMID: 11872050. 10.1046/j.0007-1323.2001.02014.x 11872050
37 Abdulameer H, Al Taii H, Al-Kindi SG, . Epidemiology of fatal ruptured aortic aneurysms in the United States (1999–2016). J Vasc Surg. 2018. PMID: 29960790. 10.1016/j.jvs.2018.03.435 29960790
38 Howard DP, Banerjee A, Fairhead JF, . Age-specific incidence, risk factors and outcome of acute abdominal aortic aneurysms in a defined population. British Journal of Surgery. 2015;102(8):907–15. PMID: 25955556. 10.1002/bjs.9838 25955556
39 Centers for Disease Control and Prevention. CDC WONDER. https://wonder.cdc.gov/. Accessed: Oct, 2018.
40 Pradarelli JC, Scally CP, Nathan H, . Hospital Teaching Status and Medicare Expenditures for Complex Surgery. Ann Surg. 2017;265(3):502–13. PMID: 28169925. 10.1097/SLA.0000000000001706 28169925
41 Lederle FA, Nelson DB, Joseph AM. Smokers’ relative risk for aortic aneurysm compared with other smoking-related diseases: a systematic review. J Vasc Surg. 2003;38(2):329–34. PMID: 12891116.12891116
42 Stolle K, Berges A, Lietz M, . Cigarette smoke enhances abdominal aortic aneurysm formation in angiotensin II-treated apolipoprotein E-deficient mice. Toxicol Lett. 2010;199(3):403–9. PMID: 20937366. 10.1016/j.toxlet.2010.10.005 20937366
43 Laughlin GA, Allison MA, Jensky NE, . Abdominal aortic diameter and vascular atherosclerosis: the Multi-Ethnic Study of Atherosclerosis. Eur J Vasc Endovasc Surg. 2011;41(4):481–7. PMID: 21236707. 10.1016/j.ejvs.2010.12.015 21236707
44 Trollope AF, Golledge J. Angiopoietins, abdominal aortic aneurysm and atherosclerosis. Atherosclerosis. 2011;214(2):237–43. PMID: 20832800. 10.1016/j.atherosclerosis.2010.08.051 20832800
45 Abdul-Hussien H, Hanemaaijer R, Kleemann R, . The pathophysiology of abdominal aortic aneurysm growth: corresponding and discordant inflammatory and proteolytic processes in abdominal aortic and popliteal artery aneurysms. J Vasc Surg. 2010;51(6):1479–87. PMID: 20488324. 10.1016/j.jvs.2010.01.057 20488324
46 Kaneko H, Anzai T, Morisawa M, . Resveratrol prevents the development of abdominal aortic aneurysm through attenuation of inflammation, oxidative stress, and neovascularization. Atherosclerosis. 2011;217(2):350–7. PMID: 21530968. 10.1016/j.atherosclerosis.2011.03.042 21530968
47 Thompson AR, Drenos F, Hafez H, . Candidate gene association studies in abdominal aortic aneurysm disease: a review and meta-analysis. Eur J Vasc Endovasc Surg. 2008;35(1):19–30. PMID: 17920311. 10.1016/j.ejvs.2007.07.022 17920311
48 Nordon IM, Hinchliffe RJ, Holt PJ, . Review of current theories for abdominal aortic aneurysm pathogenesis. Vascular. 2009;17(5):253–63. PMID: 19769804. 10.2310/6670.2009.00046 19769804
49 Liu J, Jia X, Li H, . Association between MTHFR C677T polymorphism and abdominal aortic aneurysm risk: A comprehensive meta-analysis with 10,123 participants involved. Medicine (Baltimore). 2016;95(36):e4793. PMID: 27603386. 10.1097/md.0000000000004793 27603386
50 Jones GT, Tromp G, Kuivaniemi H, . Meta-Analysis of Genome-Wide Association Studies for Abdominal Aortic Aneurysm Identifies Four New Disease-Specific Risk Loci. Circ Res. 2017;120(2):341–53. PMID: 27899403. 10.1161/circresaha.116.308765 27899403
51 Kuivaniemi H, Ryer EJ, Elmore JR, . Update on abdominal aortic aneurysm research: from clinical to genetic studies. Scientifica. 2014;2014:564734. PMID: 24834361. 10.1155/2014/564734 24834361
52 Powell JT, Sweeting MJ, Brown LC, . Systematic review and meta-analysis of growth rates of small abdominal aortic aneurysms. Br J Surg. 2011;98(5):609–18. PMID: 21412998. 10.1002/bjs.7465 21412998
53 Wilmink AB, Quick CR. Epidemiology and potential for prevention of abdominal aortic aneurysm. Br J Surg. 1998;85(2):155–62. PMID: 9501808. 10.1046/j.1365-2168.1998.00714.x 9501808
54 Thompson SG, Brown LC, Sweeting MJ, . Systematic review and meta-analysis of the growth and rupture rates of small abdominal aortic aneurysms: implications for surveillance intervals and their cost-effectiveness. Health Technol Assess. 2013;17(41):1–118. PMID: 24067626. 10.3310/hta17410 24067626
55 Wilmink AB, Hubbard CS, Day NE, . The incidence of small abdominal aortic aneurysms and the change in normal infrarenal aortic diameter: implications for screening. Eur J Vasc Endovasc Surg. 2001;21(2):165–70. PMID: 11237791. 10.1053/ejvs.2000.1285 11237791
56 Vardulaki KA, Walker NM, Day NE, . Quantifying the risks of hypertension, age, sex and smoking in patients with abdominal aortic aneurysm. Br J Surg. 2000;87(2):195–200. PMID: 10671927. 10.1046/j.1365-2168.2000.01353.x 10671927
57 van Vlijmen-van Keulen CJ, Pals G, Rauwerda JA. Familial abdominal aortic aneurysm: a systematic review of a genetic background. Eur J Vasc Endovasc Surg. 2002;24(2):105–16. PMID: 12389231.12389231
58 Larsson E, Granath F, Swedenborg J, . A population-based case-control study of the familial risk of abdominal aortic aneurysm. J Vasc Surg. 2009;49(1):47–50; discussion 1. PMID: 19028058. 10.1016/j.jvs.2008.08.012 19028058
59 MacSweeney ST, O’Meara M, Alexander C, . High prevalence of unsuspected abdominal aortic aneurysm in patients with confirmed symptomatic peripheral or cerebral arterial disease. Br J Surg. 1993;80(5):582–4. PMID: 8518892.8518892
60 Lederle FA, Johnson GR, Wilson SE, . Relationship of age, gender, race, and body size to infrarenal aortic diameter. The Aneurysm Detection and Management (ADAM) Veterans Affairs Cooperative Study Investigators. J Vasc Surg. 1997;26(4):595–601. PMID: 9357459.9357459
61 Takagi H, Umemoto T. Association of peripheral artery disease with abdominal aortic aneurysm growth. J Vasc Surg. 2016;64(2):506–13. PMID: 27316409. 10.1016/j.jvs.2016.01.059 27316409
62 Li X, Zhao G, Zhang J, . Prevalence and trends of the abdominal aortic aneurysms epidemic in general population-a meta-analysis. PLoS One. 2013;8(12):e81260. PMID: 24312543. 10.1371/journal.pone.0081260 24312543
63 Takagi H, Umemoto T. Coronary artery disease and abdominal aortic aneurysm growth. Vasc Med. 2016;21(3):199–208. PMID: 26842623. 10.1177/1358863x15624026 26842623
64 Takagi H, Umemoto T. Association of Hypertension with Abdominal Aortic Aneurysm Expansion. Ann Vasc Surg. 2017;39:74–89. PMID: 27521823. 10.1016/j.avsg.2016.04.019 27521823
65 De Rango P, Farchioni L, Fiorucci B, . Diabetes and abdominal aortic aneurysms. Eur J Vasc Endovasc Surg. 2014;47(3):243–61. PMID: 24447529. 10.1016/j.ejvs.2013.12.007 24447529
66 Lederle FA, Johnson GR, Wilson SE, . The aneurysm detection and management study screening program: validation cohort and final results. Aneurysm Detection and Management Veterans Affairs Cooperative Study Investigators. Arch Intern Med. 2000;160(10):1425–30. PMID: 10826454.10826454
67 Takagi H, Umemoto T. Negative association of diabetes with rupture of abdominal aortic aneurysm. Diab Vasc Dis Res. 2016;13(5):341–7. PMID: 27334484. 10.1177/1479164116651389 27334484
68 Xiong J, Wu Z, Chen C, . Association between diabetes and prevalence and growth rate of abdominal aortic aneurysms: A meta-analysis. Int J Cardiol. 2016;221:484–95. PMID: 27414727. 10.1016/j.ijcard.2016.07.016 27414727
69 Sweeting MJ, Thompson SG, Brown LC, . Meta-analysis of individual patient data to examine factors affecting growth and rupture of small abdominal aortic aneurysms. Br J Surg. 2012;99(5):655–65. PMID: 22389113. 10.1002/bjs.8707 22389113
70 Schmitz-Rixen T, Keese M, Hakimi M, . Ruptured abdominal aortic aneurysm-epidemiology, predisposing factors, and biology. Langenbecks Arch Surg. 2016;401(3):275–88. PMID: 27001684. 10.1007/s00423-016-1401-8 27001684
71 Cronenwett JL, Murphy TF, Zelenock GB, . Actuarial analysis of variables associated with rupture of small abdominal aortic aneurysms. Surgery. 1985;98(3):472–83. PMID: 3898453.3898453
72 Lederle FA, Johnson GR, Wilson SE, . Rupture rate of large abdominal aortic aneurysms in patients refusing or unfit for elective repair. JAMA. 2002;287(22):2968–72. PMID: 12052126.12052126
73 Reed WW, Hallett JW, Jr., Damiano MA, . Learning from the last ultrasound. A population-based study of patients with abdominal aortic aneurysm. Arch Intern Med. 1997;157(18):2064–8. PMID: 9382661.9382661
74 Scott RA, Tisi PV, Ashton HA, . Abdominal aortic aneurysm rupture rates: a 7-year follow-up of the entire abdominal aortic aneurysm population detected by screening. J Vasc Surg. 1998;28(1):124–8. PMID: 9685138.9685138
75 Brown LC, Powell JT. Risk factors for aneurysm rupture in patients kept under ultrasound surveillance. UK Small Aneurysm Trial Participants. Ann Surg. 1999;230(3):289–96; discussion 96–7. PMID: 10493476.10493476
76 RESCAN Collaborators, Bown MJ, Sweeting MJ, . Surveillance intervals for small abdominal aortic aneurysms: a meta-analysis. JAMA. 2013;309(8):806–13. PMID: 23443444.23443444
77 Fillinger MF, Raghavan ML, Marra SP, . In vivo analysis of mechanical wall stress and abdominal aortic aneurysm rupture risk. J Vasc Surg. 2002;36(3):589–97. PMID: 12218986.12218986
78 Venkatasubramaniam AK, Fagan MJ, Mehta T, . A comparative study of aortic wall stress using finite element analysis for ruptured and non-ruptured abdominal aortic aneurysms. Eur J Vasc Endovasc Surg. 2004;28(2):168–76. PMID: 15234698. 10.1016/j.ejvs.2004.03.029 15234698
79 Brown PM, Zelt DT, Sobolev B. The risk of rupture in untreated aneurysms: the impact of size, gender, and expansion rate. J Vasc Surg. 2003;37(2):280–4. PMID: 12563196. 10.1067/mva.2003.119 12563196
80 Lederle FA, Walker JM, Reinke DB. Selective screening for abdominal aortic aneurysms with physical examination and ultrasound. Arch Intern Med. 1988;148(8):1753–6. PMID: 3041938.3041938
81 Lindholt JS, Vammen S, Juul S, . The validity of ultrasonographic scanning as screening method for abdominal aortic aneurysm. Eur J Vasc Endovasc Surg. 1999;17(6):472–5. PMID: 10375481. 10.1053/ejvs.1999.0835 10375481
82 Costantino TG, Bruno EC, Handly N, . Accuracy of emergency medicine ultrasound in the evaluation of abdominal aortic aneurysm. J Emerg Med. 2005;29(4):455–60. PMID: 16243207. 10.1016/j.jemermed.2005.02.016 16243207
83 Tayal VS, Graf CD, Gibbs MA. Prospective study of accuracy and outcome of emergency ultrasound for abdominal aortic aneurysm over two years. Acad Emerg Med. 2003;10(8):867–71. PMID: 12896888.12896888
84 Rubano E, Mehta N, Caputo W, . Systematic review: emergency department bedside ultrasonography for diagnosing suspected abdominal aortic aneurysm. Acad Emerg Med. 2013;20(2):128–38. PMID. 10.1111/acem.12080 23406071
85 Liisberg M, Diederichsen AC, Lindholt JS. Abdominal ultrasound-scanning versus non-contrast computed tomography as screening method for abdominal aortic aneurysm - a validation study from the randomized DANCAVAS study. BMC Medical Imaging. 2017;17(1):14. PMID: 28193267. 10.1186/s12880-017-0186-8 28193267
86 Diederichsen AC, Rasmussen LM, Sogaard R, . The Danish Cardiovascular Screening Trial (DANCAVAS): study protocol for a randomized controlled trial. Trials. 2015;16:554. PMID: 26637993. 10.1186/s13063-015-1082-6 26637993
87 Fink HA, Lederle FA, Roth CS, . The accuracy of physical examination to detect abdominal aortic aneurysm. Arch Intern Med. 2000;160(6):833–6. PMID: 10737283.10737283
88 Lederle FA, Simel DL. The rational clinical examination. Does this patient have abdominal aortic aneurysm? JAMA. 1999;281(1):77–82. PMID: 9892455.9892455
89 Beck AW, Sedrakyan A, Mao J, . Variations in Abdominal Aortic Aneurysm Care: A Report From the International Consortium of Vascular Registries. Circulation. 2016;134(24):1948–58. PMID: 27784712. 10.1161/CIRCULATIONAHA.116.024870 27784712
90 United Kingdom ETI, Greenhalgh RM, Brown LC, . Endovascular versus open repair of abdominal aortic aneurysm. N Engl J Med. 2010;362(20):1863–71. PMID: 20382983. 10.1056/NEJMoa0909305 20382983
91 Takagi H, Ando T, Umemoto T. Worse late-phase survival after elective endovascular than open surgical repair for intact abdominal aortic aneurysm. Int J Cardiol. 2017. PMID: 28096046. 10.1016/j.ijcard.2017.01.075 28096046
92 Grant SW, Sperrin M, Carlson E, . Calculating when elective abdominal aortic aneurysm repair improves survival for individual patients: development of the Aneurysm Repair Decision Aid and economic evaluation. Health Technol Assess. 2015;19(32):1–154, v–vi. PMID: 25924187. 10.3310/hta19320 25924187
93 LeFevre ML. Screening for abdominal aortic aneurysm: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2014;161(4):281–90. PMID: 24957320. 10.7326/m14-1204 24957320
94 Fleming C, Whitlock E, Beil T, . Primary Care Screening for Abdominal Aortic Aneurysm. Primary Care Screening for Abdominal Aortic Aneurysm. Rockville (MD) 2005.
95 Rooke TW, Hirsch AT, Misra S, . Management of patients with peripheral artery disease (compilation of 2005 and 2011 ACCF/AHA Guideline Recommendations): a report of the American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol. 2013;61(14):1555–70. PMID: 23473760. 10.1016/j.jacc.2013.01.004 23473760
96 Lim LS, Haq N, Mahmood S, . Atherosclerotic cardiovascular disease screening in adults: American College Of Preventive Medicine position statement on preventive practice. Am J Prev Med. 2011;40(3):381 e1–10. PMID. 10.1016/j.amepre.2010.11.021 21335273
97 American Academy of Family Physicians. Clinical Preventive Service Recommendation: Abdominal Aortic Aneurysm. https://www.aafp.org/patient-care/clinical-recommendations/all/aaa.html. Accessed: Jun, 2018.
98 American College of Cardiology F, American College of R, American Institute of Ultrasound in M, . ACCF/ACR/AIUM/ASE/ASN/ICAVL/SCAI/SCCT/SIR/SVM/SVS/SVU [corrected] 2012 appropriate use criteria for peripheral vascular ultrasound and physiological testing part I: arterial ultrasound and physiological testing: a report of the American College of Cardiology Foundation appropriate use criteria task force, American College of Radiology, American Institute of Ultrasound in Medicine, American Society of Echocardiography, American Society of Nephrology, Intersocietal Commission for the Accreditation of Vascular Laboratories, Society for Cardiovascular Angiography and Interventions, Society of Cardiovascular Computed Tomography, Society for Interventional Radiology, Society for Vascular Medicine, Society for Vascular Surgery, [corrected] and Society for Vascular Ultrasound. [corrected]. J Am Coll Cardiol. 2012;60(3):242–76. PMID: 22694840. 10.1016/j.jacc.2012.02.009 22694840
99 Duncan JL, Wolf B, Nichols DM, . Screening for abdominal aortic aneurysm in a geographically isolated area. Br J Surg. 2005;92(8):984–8. PMID: 16034847. 10.1002/bjs.5120 16034847
100 Palombo D, Lucertini G, Pane B, . District-based abdominal aortic aneurysm screening in population aged 65 years and older. J Cardiovasc Surg (Torino). 2010;51(6):777–82. PMID: 21124273.21124273
101 Chun KC, Schmidt AS, Bains S, . Surveillance outcomes of small abdominal aortic aneurysms identified from a large screening program. Journal of Vascular Surgery. 2016;63(1):55–61. PMID: 26474507. 10.1016/j.jvs.2015.08.059 26474507
102 Patel R, Sweeting MJ, Powell JT, . Endovascular versus open repair of abdominal aortic aneurysm in 15-years’ follow-up of the UK endovascular aneurysm repair trial 1 (EVAR trial 1): a randomised controlled trial. Lancet. 2016;388(10058):2366–74. PMID: 27743617. 10.1016/s0140-6736(16)31135-7 27743617
103 Mani K, Venermo M, Beiles B, . Regional Differences in Case Mix and Peri-operative Outcome After Elective Abdominal Aortic Aneurysm Repair in the Vascunet Database. Eur J Vasc Endovasc Surg. 2015;49(6):646–52. PMID: 25752419. 10.1016/j.ejvs.2015.01.021 25752419
104 Karthikesalingam A, Vidal-Diez A, Holt PJ, . Thresholds for Abdominal Aortic Aneurysm Repair in England and the United States. N Engl J Med. 2016;375(21):2051–9. PMID: 27959727. 10.1056/NEJMoa1600931 27959727
105 Guirguis-Blake JM, Beil TL, Sun X, . U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. Primary Care Screening for Abdominal Aortic Aneurysm: A Systematic Evidence Review for the U.S. Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (US); 2014.
106 Wells GA, Shea BJ, O’Connell DP, J., . The Newcastle-Ottawa Scale (NOS) for Assessing the Quality of Nonrandomised Studies in Meta-Analysis. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed: June 27, 2017.
107 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2015.
108 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177–88. PMID: 3802833.3802833
109 Morton S, Murad M, O’Connor E, . Quantitative Synthesis—An Update. Methods Guide for Comparative Effectiveness Reviews (Prepared by the Scientific Resource Center under Contract No. 290-2012-0004-C). AHRQ Publication No. 18-EHC007. Rockville, MD: AHRQ. Available from: 10.23970/AHRQEPCMETHGUIDE3.
110 Whitlock EP, Eder M, Thompson JH, . An approach to addressing subpopulation considerations in systematic reviews: the experience of reviewers supporting the U.S. Preventive Services Task Force. Syst Rev. 2017;6(1):41. PMID: 28253915. 10.1186/s13643-017-0437-3 28253915
111 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville (MD): Agency for Healthcare Research and Quality; 2014. p. 314–49.
112 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589. 10.1186/1472-6963-4-38 15615589
113 Ashton HA, Gao L, Kim LG, . Fifteen-year follow-up of a randomized clinical trial of ultrasonographic screening for abdominal aortic aneurysms. Br J Surg. 2007;94(6):696–701. PMID: 17514666. 10.1002/bjs.5780 17514666
114 Bicknell CD, Kiru G, Falaschetti E, . An evaluation of the effect of an angiotensin-converting enzyme inhibitor on the growth rate of small abdominal aortic aneurysms: a randomized placebo-controlled trial (AARDVARK). Eur Heart J. 2016;37(42):3213–21. PMID: 27371719. 10.1093/eurheartj/ehw257 27371719
115 Brown LC, Thompson SG, Greenhalgh RM, . Fit patients with small abdominal aortic aneurysms (AAAs) do not benefit from early intervention. J Vasc Surg. 2008;48(6):1375–81. PMID: 19118733. 10.1016/j.jvs.2008.07.014 19118733
116 Budtz-Lilly J, Venermo M, Debus S, . Editor’s Choice - Assessment of International Outcomes of Intact Abdominal Aortic Aneurysm Repair over 9 Years. Eur J Vasc Endovasc Surg. 2017;54(1):13–20. PMID: 28416191. 10.1016/j.ejvs.2017.03.003 28416191
117 Cao P. Comparison of surveillance vs aortic endografting for small aneurysm repair (CAESAR) trial: study design and progress. Eur J Vasc Endovasc Surg. 2005;30(3):245–51. PMID: 16130206.16130206
118 Cao P, De RP, Verzini F, . Comparison of surveillance versus aortic endografting for small aneurysm repair (CAESAR): results from a randomised trial. Eur J Vasc Endovasc Surg. 2011;41(1):13–25. PMID: 20869890. 10.1016/j.ejvs.2010.08.026 20869890
119 Crow P, Shaw E, Earnshaw JJ, . A single normal ultrasonographic scan at age 65 years rules out significant aneurysm disease for life in men. Br J Surg. 2001;88(7):941–4. PMID: 11442524. 10.1046/j.0007-1323.2001.01822.x 11442524
120 Darwood R, Earnshaw JJ, Turton G, . Twenty-year review of abdominal aortic aneurysm screening in men in the county of Gloucestershire, United Kingdom. J Vasc Surg. 2012;56(1):8–13. PMID: 22503187. 10.1016/j.jvs.2011.12.069 22503187
121 d’Audiffret A, Santilli S, Tretinyak A, . Fate of the ectatic infrarenal aorta: expansion rates and outcomes. Ann Vasc Surg. 2002;16(5):534–6. PMID.12183768
122 De Rango P, Verzini F, Parlani G, . Quality of life in patients with small abdominal aortic aneurysm: the effect of early endovascular repair versus surveillance in the CAESAR trial. Eur J Vasc Endovasc Surg. 2011;41(3):324–31. PMID: 21145269. 10.1016/j.ejvs.2010.11.005 21145269
123 Devaraj S, Dodds SR. Ultrasound surveillance of ectatic abdominal aortas. Ann R Coll Surg Engl. 2008;90(6):477–82. PMID: 18765027. 10.1308/003588408X301064 18765027
124 Eisenstein EL, Davidson-Ray L, Edwards R, . Economic analysis of endovascular repair versus surveillance for patients with small abdominal aortic aneurysms. J Vasc Surg. 2013;58(2):302–10. PMID: 23562339. 10.1016/j.jvs.2013.01.038 23562339
125 Emerton ME, Shaw E, Poskitt K, . Screening for abdominal aortic aneurysm: a single scan is enough. Br J Surg. 1994;81(8):1112–3. PMID: 7953333.7953333
126 Filardo G, Lederle FA, Ballard DJ, . Immediate open repair vs surveillance in patients with small abdominal aortic aneurysms: survival differences by aneurysm size. Mayo Clin Proc. 2013;88(9):910–9. PMID: 24001483. 10.1016/j.mayocp.2013.05.014 24001483
127 Forbes JF, Brady AR, Brown LC, . Health service costs and quality of life for early elective surgery or ultrasonographic surveillance for small abdominal aortic aneurysms. UK Small Aneurysm Trial Participants. Lancet. 1998;352(9141):1656–60. PMID: 9853437.9853437
128 Fowkes FG, Greenhalgh RM, Powell JT, . Length of hospital stay following elective abdominal aortic aneurysm repair. U.K. Small Aneurysm Trial Participants. Eur J Vasc Endovasc Surg. 1998;16(3):185–91. PMID: 9787298.9787298
129 Golledge J, Parr A, Boult M, . The outcome of endovascular repair of small abdominal aortic aneurysms. Ann Surg. 2007;245(2):326–33. PMID: 17245188. 10.1097/01.sla.0000253965.95368.52 17245188
130 Greenhalgh RM, Forbes JF, Fowkes FG, . The UK Small Aneurysm Trial: design, methods and progress. Eur J Vasc Endovasc Surg. 1995;9(1):42–8. PMID: 7664011.7664011
131 Hogh A, Vammen S, Joensen J, ., editors. Intermittent Roxithromycin Treatment for Preventing Small Abdominal Aortic Aneurysms Progression. Long Term Results from a Small Randomised Double-blinded Clinical Controlled Trial2008 2008.
132 Hogh A, Vammen S, Ostergaard L, . Intermittent roxithromycin for preventing progression of small abdominal aortic aneurysms: long-term results of a small clinical trial. Vasc Endovascular Surg. 2009;43(5):452–6. PMID: 19640922. 10.1177/1538574409335037 19640922
133 Karlsson L, Gnarpe J, Bergqvist D, . The effect of azithromycin and Chlamydophilia pneumonia infection on expansion of small abdominal aortic aneurysms-a prospective randomized double-blind trial. J Vasc Surg. 2009;50(1):23–9. PMID: 19563951. 10.1016/j.jvs.2008.12.048 19563951
134 Kim LG, Ra PS, Ashton HA, . A sustained mortality benefit from screening for abdominal aortic aneurysm. Ann Intern Med. 2007;146(10):699–706. PMID: 17502630.17502630
135 Kim LG, Scott RAP, Ashton HA, . A prolonged mortality benefit from screening for abdominal aortic aneurysm: seven-year follow-up of the MASS trial. SO: The Vascular Society of Great Britain & Ireland Yearbook 2006. 2006:77.
136 Kiru G, Bicknell C, Falaschetti E, . An evaluation of the effect of an angiotensin-converting enzyme inhibitor on the growth rate of small abdominal aortic aneurysms: a randomised placebo-controlled trial (AARDVARK). Health Technol Assess. 2016;20(59):1–180. PMID: 27488944. 10.3310/hta20590 27488944
137 Lederle FA, Johnson GR, Wilson SE, . Quality of life, impotence, and activity level in a randomized trial of immediate repair versus surveillance of small abdominal aortic aneurysm. J Vasc Surg. 2003;38(4):745–52. PMID: 14560224.14560224
138 Lederle FA, Johnson GR, Wilson SE, . Yield of repeated screening for abdominal aortic aneurysm after a 4-year interval. Aneurysm Detection and Management Veterans Affairs Cooperative Study Investigators. Arch Intern Med. 2000;160(8):1117–21. PMID: 10789604.10789604
139 Lederle FA, Wilson SE, Johnson GR, . Design of the abdominal aortic Aneurysm Detection and Management Study. ADAM VA Cooperative Study Group. J Vasc Surg. 1994;20(2):296–303. PMID: 8040955.8040955
140 Lederle FA, Wilson SE, Johnson GR, . Immediate repair compared with surveillance of small abdominal aortic aneurysms. N Engl J Med. 2002;346(19):1437–44. PMID: 12000813. 10.1056/NEJMoa012573 12000813
141 Lesjak M, Boreland F, Lyle D, . Screening for abdominal aortic aneurysm: does it affect men’s quality of life? Aust J Prim Health. 2012. PMID: 22951209. 10.1071/PY11131 22951209
142 Lindholt JS, Henneberg EW, Juul S, . Impaired results of a randomised double blinded clinical trial of propranolol versus placebo on the expansion rate of small abdominal aortic aneurysms. Int Angiol. 1999;18(1):52–7. PMID: 10392481.10392481
143 Lindholt JS, Juul S, Fasting H, . Hospital costs and benefits of screening for abdominal aortic aneurysms. Results from a randomised population screening trial. Eur J Vasc Endovasc Surg. 2002;23(1):55–60. PMID: 11748949. 10.1053/ejvs.2001.1534 11748949
144 Lindholt JS, Juul S, Fasting H, . Preliminary ten year results from a randomised single centre mass screening trial for abdominal aortic aneurysm. Eur J Vasc Endovasc Surg. 2006;32(6):608–14. PMID: 16893663. 10.1016/j.ejvs.2006.06.008 16893663
145 Lindholt JS, Juul S, Henneberg EW. High-risk and low-risk screening for abdominal aortic aneurysm both reduce aneurysm-related mortality. A stratified analysis from a single-centre randomised screening trial. Eur J Vasc Endovasc Surg. 2007;34(1):53–8. PMID: 17331750. 10.1016/j.ejvs.2006.12.031 17331750
146 Lindholt JS, Sogaard R. Population screening and intervention for vascular disease in Danish men (VIVA): a randomised controlled trial. Lancet. 2017. PMID: 28859943. 10.1016/s0140-6736(17)32250-x 28859943
147 Lindholt JS, Sorensen J, Sogaard R, . Long-term benefit and cost-effectiveness analysis of screening for abdominal aortic aneurysms from a randomized controlled trial. Br J Surg. 2010;97(6):826–34. PMID: 20473995. 10.1002/bjs.7001 20473995
148 Lindholt JS, Vammen S, Juul S, . Optimal interval screening and surveillance of abdominal aortic aneurysms. Eur J Vasc Endovasc Surg. 2000;20(4):369–73. PMID: 11035969. 10.1053/ejvs.2000.1191 11035969
149 Lo RC, Bensley RP, Hamdan AD, . Gender differences in abdominal aortic aneurysm presentation, repair, and mortality in the Vascular Study Group of New England. Journal of Vascular Surgery. 2013;57(5):1261–8, 8.e1–5. PMID: 23384493. 10.1016/j.jvs.2012.11.039 23384493
150 Lucarotti ME, Heather BP, Shaw E, . Psychological morbidity associated with abdominal aortic aneurysm screening. Eur J Vasc Endovasc Surg. 1997;14(6):499–501. PMID: 9467527.9467527
151 McCarthy RJ, Shaw E, Whyman MR, . Recommendations for screening intervals for small aortic aneurysms. Br J Surg. 2003;90(7):821–6. PMID: 12854107. 10.1002/bjs.4216 12854107
152 Meijer C, Stijnen T, Wasser M, . Doxycycline for stabilization of abdominal aortic aneurysms: A randomized trial. Ann Intern Med. 2013;159(12):815–23. PMID: 24490266. 10.7326/0003-4819-159-12-201312170-00007 24490266
153 Mosorin M, Juvonen J, Biancari F, . Use of doxycycline to decrease the growth rate of abdominal aortic aneurysms: a randomized, double-blind, placebo-controlled pilot study. J Vasc Surg. 2001;34(4):606–10. PMID: 11668312. 10.1067/mva.2001.117891 11668312
154 Norman PE, Jamrozik K, Lawrence-Brown MM, . Western Australian randomized controlled trial of screening for abdominal aortic aneurysm. Br J Surg. 2003;90(4):492.
155 Norman PE, Jamrozik K, Lawrence-Brown MM, . Population based randomised controlled trial on impact of screening on mortality from abdominal aortic aneurysm. BMJ. 2004;329(7477):1259. PMID: 15545293. 10.1136/bmj.38272.478438.55 15545293
156 Oliver-Williams C, Sweeting MJ, Turton G, . Lessons learned about prevalence and growth rates of abdominal aortic aneurysms from a 25-year ultrasound population screening programme. Br J Surg. 2018;105(1):68–74. PMID: 29265406. 10.1002/bjs.10715 29265406
157 Ouriel K. The PIVOTAL study: A randomized comparison of endovascular repair versus surveillance in patients with smaller abdominal aortic aneurysms. J Vasc Surg. 2009;49(1):266–9. PMID: 19174266. 10.1016/j.jvs.2008.11.048 19174266
158 Ouriel K, Clair DG, Kent KC, . Endovascular repair compared with surveillance for patients with small abdominal aortic aneurysms. J Vasc Surg. 2010;51(5):1081–7. PMID: 20304589. 10.1016/j.jvs.2009.10.113 20304589
159 Overbey DM, Glebova NO, Chapman BC, . Morbidity of endovascular abdominal aortic aneurysm repair is directly related to diameter. J Vasc Surg. 2017;66(4):1037–47. PMID: 28433338. 10.1016/j.jvs.2017.01.058 28433338
160 Peppelenbosch N, Buth J, Harris PL, . Diameter of abdominal aortic aneurysm and outcome of endovascular aneurysm repair: does size matter? A report from EUROSTAR. J Vasc Surg. 2004;39(2):288–97. PMID: 14743127. 10.1016/j.jvs.2003.09.047 14743127
161 Powell JT. Long-term outcomes of immediate repair compared with surveillance of small abdominal aortic aneurysms. N Engl J Med. 2002;346(19):1445–52. PMID: 12000814. 10.1056/NEJMoa013527 12000814
162 Powell JT, Brady AR, Brown LC, . Mortality results for randomised controlled trial of early elective surgery or ultrasonographic surveillance for small abdominal aortic aneurysms. The UK Small Aneurysm Trial Participants. Lancet. 1998;352(9141):1649–55. PMID: 9853436.9853436
163 Powell JT, Brown LC, Forbes JF, . Final 12-year follow-up of surgery versus surveillance in the UK Small Aneurysm Trial. Br J Surg. 2007;94(6):702–8. PMID: 17514693. 10.1002/bjs.5778 17514693
164 Propranolol Aneurysm Trial Investigators. Propranolol for small abdominal aortic aneurysms: results of a randomized trial. J Vasc Surg. 2002;35(1):72–9. PMID: 11802135.11802135
165 Scott RA, Vardulaki KA, Walker NM, . The long-term benefits of a single scan for abdominal aortic aneurysm (AAA) at age 65. Eur J Vasc Endovasc Surg. 2001;21(6):535–40. PMID: 11397028. 10.1053/ejvs.2001.1368 11397028
166 Sillesen H, Eldrup N, Hultgren R, . Randomized clinical trial of mast cell inhibition in patients with a medium-sized abdominal aortic aneurysm. Br J Surg. 2015;102(8):894–901. PMID: 25963302. 10.1002/bjs.9824 25963302
167 Soderberg P, Wanhainen A, Svensjo S. Five Year Natural History of Screening Detected Sub-Aneurysms and Abdominal Aortic Aneurysms in 70 Year Old Women and Systematic Review of Repair Rate in Women. Eur J Vasc Endovasc Surg. 2017;53(6):802–9. PMID: 28389251. 10.1016/j.ejvs.2017.02.024 28389251
168 Spencer CA, Norman PE, Jamrozik K, . Is screening for abdominal aortic aneurysm bad for your health and well-being? ANZ J Surg. 2004;74(12):1069–75. PMID: 15574151. 10.1111/j.1445-1433.2004.03270.x 15574151
169 Svensjo S, Bjorck M, Wanhainen A. Editor’s choice: five-year outcomes in men screened for abdominal aortic aneurysm at 65 years of age: a population-based cohort study. Eur J Vasc Endovasc Surg. 2014;47(1):37–44. PMID: 24262320. 10.1016/j.ejvs.2013.10.007 24262320
170 Thompson SG, Ashton HA, Gao L, . Final follow-up of the Multicentre Aneurysm Screening Study (MASS) randomized trial of abdominal aortic aneurysm screening. Br J Surg. 2012;99(12):1649–56. PMID: 23034729. 10.1002/bjs.8897 23034729
171 Thompson SG, Ashton HA, Gao L, . Screening men for abdominal aortic aneurysm: 10 year mortality and cost effectiveness results from the randomised Multicentre Aneurysm Screening Study. BMJ. 2009;338:b2307. PMID: 19553269.19553269
172 Vammen S, Lindholt JS, Ostergaard L, . Randomized double-blind controlled trial of roxithromycin for prevention of abdominal aortic aneurysm expansion. Br J Surg. 2001;88(8):1066–72. PMID: 11488791. 10.1046/j.0007-1323.2001.01845.x 11488791
173 Vardulaki KA, Walker NM, Couto E, . Late results concerning feasibility and compliance from a randomized trial of ultrasonographic screening for abdominal aortic aneurysm. Br J Surg. 2002;89(7):861–4. PMID: 12081734. 10.1046/j.1365-2168.2002.02133.x 12081734
174 Wanhainen A, Rosen C, Rutegard J, . Low quality of life prior to screening for abdominal aortic aneurysm: a possible risk factor for negative mental effects. Ann Vasc Surg. 2004;18(3):287–93. PMID: 15354629. 10.1007/s10016-004-0021-x 15354629
175 Canadian Task Force on Preventive Health Care. Recommendations on screening for abdominal aortic aneurysm in primary care. CMAJ Canadian Medical Association Journal. 2017;189(36):E1137–E45. PMID: 28893876. 10.1503/cmaj.170118 28893876
176 Takagi H, Ando T, Umemoto T. Abdominal Aortic Aneurysm Screening Reduces All-Cause Mortality. Angiology. 2017:3319717693107. PMID: 28193091. 10.1177/0003319717693107 28193091
177 Lederle FA. The Last (Randomized) Word on Screening for Abdominal Aortic Aneurysms [Comment on McCaul]. JAMA Intern Med. 2016;[Epub ahead of print]. PMID: 27802490. 10.1001/jamainternmed.2016.6663 27802490
178 Savji N, Rockman CB, Skolnick AH, . Association between advanced age and vascular disease in different arterial territories: a population database of over 3.6 million subjects. Journal of the American College of Cardiology. 2013;61(16):1736–43. PMID: 23500290.23500290
179 Greco G, Egorova NN, Gelijns AC, . Development of a novel scoring tool for the identification of large >/=5 cm abdominal aortic aneurysms. Ann Surg. 2010;252(4):675–82. PMID: 20881774 10.1097/SLA.0b013e3181f621c8 20881774
180 Han Y, Zhang S, Zhang J, . Outcomes of Endovascular Abdominal Aortic Aneurysm Repair in Octogenarians: Meta-analysis and Systematic Review. Eur J Vasc Endovasc Surg. 2017. PMID: 28822680. 10.1016/j.ejvs.2017.06.027 28822680
181 Endicott KM, Emerson D, Amdur R, . Functional status as a predictor of outcomes in open and endovascular abdominal aortic aneurysm repair. Journal of Vascular Surgery. 2017;65(1):40–5. PMID: 27460908. 10.1016/j.jvs.2016.05.079 27460908
182 Park BD, Azefor NM, Huang CC, . Elective endovascular aneurysm repair in the elderly: trends and outcomes from the Nationwide Inpatient Sample. Ann Vasc Surg. 2014;28(4):798–807. PMID: 24189191. 10.1016/j.avsg.2013.07.029 24189191
183 Mani K, Alund M, Bjorck M, . Screening for abdominal aortic aneurysm among patients referred to the vascular laboratory is cost-effective. Eur J Vasc Endovasc Surg. 2010;39(2):208–16. PMID: 19942460. 10.1016/j.ejvs.2009.11.004 19942460
184 Grant SW, Grayson AD, Mitchell DC, . Evaluation of five risk prediction models for elective abdominal aortic aneurysm repair using the UK National Vascular Database. Br J Surg. 2012;99(5):673–9. PMID. 10.1002/bjs.8731 22415901
185 Eslami MH, Rybin DV, Doros G, . External validation of Vascular Study Group of New England risk predictive model of mortality after elective abdominal aorta aneurysm repair in the Vascular Quality Initiative and comparison against established models. Journal of Vascular Surgery. 2017;11:11. PMID: 28807384. 10.1016/j.jvs.2017.05.087 28807384
186 National Institute for Health and Care Excellence. Abdominal aortic aneurysm: diagnosis and management (NICE guideline DRAFT May 2018). NICE; 2018. Available from: https://www.nice.org.uk/guidance/gid-cgwave0769/documents/short-version-of-draft-guideline.
187 Johansson M, Jorgensen KJ. Should we screen women for abdominal aortic aneurysm? Lancet. 2018;392(10146):454–6. PMID: 30057106. 10.1016/S0140-6736(18)31438-7 30057106
188 Stackelberg O, Bjorck M, Larsson SC, . Sex differences in the association between smoking and abdominal aortic aneurysm. British Journal of Surgery. 2014;101(10):1230–7. PMID: 24916023.24916023
189 Svensjo S, Bjorck M, Wanhainen A. Current prevalence of abdominal aortic aneurysm in 70-year-old women. Br J Surg. 2013;100(3):367–72. PMID: 23192439. 10.1002/bjs.8984 23192439
190 Lederle FA, Johnson GR, Wilson SE. Abdominal aortic aneurysm in women. J Vasc Surg. 2001;34(1):122–6. PMID. 10.1067/mva.2001.115275 11436084
191 Skibba AA, Evans JR, Hopkins SP, . Reconsidering gender relative to risk of rupture in the contemporary management of abdominal aortic aneurysms. Journal of Vascular Surgery. 2015;62(6):1429–36. PMID: 26409846. 10.1016/j.jvs.2015.07.079 26409846
192 Laine MT, Vanttinen T, Kantonen I, . Rupture of Abdominal Aortic Aneurysms in Patients Under Screening Age and Elective Repair Threshold. European Journal of Vascular & Endovascular Surgery. 2016;51(4):511–6. PMID: 26854209. 10.1016/j.ejvs.2015.12.011 26854209
193 Tomee SM, Lijftogt N, Vahl A, . A registry-based rationale for discrete intervention thresholds for open and endovascular elective abdominal aortic aneurysm repair in female patients. Journal of Vascular Surgery. 2017;27:27. PMID: 28964619.28964619
194 Lowry D, Singh J, Mytton J, . Sex-related Outcome Inequalities in Endovascular Aneurysm Repair. European Journal of Vascular & Endovascular Surgery. 2016;52(4):518–25. PMID: 27595522. 10.1016/j.ejvs.2016.07.083 27595522
195 Deery SE, Lancaster RT, Baril DT, . Contemporary outcomes of open complex abdominal aortic aneurysm repair. Journal of Vascular Surgery. 2016;63(5):1195–200. PMID: 27109792. 10.1016/j.jvs.2015.12.038 27109792
196 Desai M, Choke E, Sayers RD, . Sex-related trends in mortality after elective abdominal aortic aneurysm surgery between 2002 and 2013 at National Health Service hospitals in England: less benefit for women compared with men. European Heart Journal. 2016;37(46):3452–60. PMID: 27520304. 10.1093/eurheartj/ehw335 27520304
197 Heikkinen M, Salenius JP, Auvinen O. Ruptured abdominal aortic aneurysm in a well-defined geographic area. J Vasc Surg. 2002;36(2):291–6. PMID.12170209
198 Vavra AK, Kibbe MR, Bown MJ, . Debate: Whether evidence supports reducing the threshold diameter to 5 cm for elective interventions in women with abdominal aortic aneurysms. J Vasc Surg. 2014;60(6):1695–701. PMID: 25454111. 10.1016/j.jvs.2014.07.022 25454111
199 Lo RC, Lu B, Fokkema MT, . Relative importance of aneurysm diameter and body size for predicting abdominal aortic aneurysm rupture in men and women. Journal of Vascular Surgery. 2014;59(5):1209–16. PMID: 24388278. 10.1016/j.jvs.2013.10.104 24388278
200 Matyal R, Shakil O, Hess PE, . Impact of gender and body surface area on outcome after abdominal aortic aneurysm repair. Am J Surg. 2015;209(2):315–23. PMID: 25457240. 10.1016/j.amjsurg.2014.07.008 25457240
201 Pirie K, Peto R, Reeves GK, . The 21st century hazards of smoking and benefits of stopping: a prospective study of one million women in the UK. Lancet. 2013;381(9861):133–41. PMID. 10.1016/s0140-6736(12)61720-6 23107252
202 Ulug P, Sweeting MJ, von Allmen RS, . Morphological suitability for endovascular repair, non-intervention rates, and operative mortality in women and men assessed for intact abdominal aortic aneurysm repair: systematic reviews with meta-analysis. Lancet. 2017;389(10088):2482–91. PMID: 28455148. 10.1016/S0140-6736(17)30639-6 28455148
203 Mehta M, Byrne WJ, Robinson H, . Women derive less benefit from elective endovascular aneurysm repair than men. J Vasc Surg. 2012;55(4):906–13. PMID: 22322123. 10.1016/j.jvs.2011.11.047 22322123
204 Sidloff DA, Saratzis A, Sweeting MJ, . Sex differences in mortality after abdominal aortic aneurysm repair in the UK. Br J Surg. 2017. PMID: 28745403. 10.1002/bjs.10600 28745403
205 Grootenboer N, Hunink MG, Hendriks JM, . Sex differences in 30-day and 5-year outcomes after endovascular repair of abdominal aortic aneurysms in the EUROSTAR study. Journal of Vascular Surgery. 2013;58(1):42–9.e1. PMID: 23643561. 10.1016/j.jvs.2013.01.028 23643561
206 Dubois L, Novick TV, Harris JR, . Outcomes after endovascular abdominal aortic aneurysm repair are equivalent between genders despite anatomic differences in women. J Vasc Surg. 2013;57(2):382–9.e1. PMID: 23266281. 10.1016/j.jvs.2012.09.075 23266281
207 Johansson M, Harris RP. Thresholds in women with abdominal aortic aneurysm. Lancet. 2017;389(10088):2446–8. PMID: 28455147. 10.1016/S0140-6736(17)31110-8 28455147
208 Bown MJ, Powell JT. Part two: against the motion. Evidence does not support reducing the threshold diameter to 5 cm for elective interventions in women with abdominal aortic aneurysms. Eur J Vasc Endovasc Surg. 2014;48(6):614–8. PMID: 25476928. 10.1016/j.ejvs.2014.08.016 25476928
209 Preiss JE, Arya S, Duwayri Y, . Late mortality in females after endovascular aneurysm repair. J Surg Res. 2015;198(2):508–14. PMID: 25976853. 10.1016/j.jss.2015.04.003 25976853
210 Sweeting MJ, Masconi KL, Jones E, . Analysis of clinical benefit, harms, and cost-effectiveness of screening women for abdominal aortic aneurysm. Lancet. 2018;392(10146):487–95. PMID: 30057105. 10.1016/s0140-6736(18)31222-4 30057105
211 Jahangir E, Lipworth L, Edwards TL, . Smoking, sex, risk factors and abdominal aortic aneurysms: a prospective study of 18 782 persons aged above 65 years in the Southern Community Cohort Study. Journal of Epidemiology & Community Health. 2015;69(5):481–8. PMID: 25563744.25563744
212 Chun KC, Teng KY, Van Spyk EN, . Outcomes of an abdominal aortic aneurysm screening program. J Vasc Surg. 2013;57(2):376–81. PMID: 23141680. 10.1016/j.jvs.2012.08.038 23141680
213 Turan A, Mascha EJ, Roberman D, . Smoking and perioperative outcomes. Anesthesiology. 2011;114(4):837–46. PMID. 10.1097/ALN.0b013e318210f560 21372682
214 Ye Z, Bailey KR, Austin E, . Family history of atherosclerotic vascular disease is associated with the presence of abdominal aortic aneurysm. Vascular Medicine. 2016;21(1):41–6. PMID: 26566659. 10.1177/1358863X15611758 26566659
215 Joergensen TM, Christensen K, Lindholt JS, . Editor’s Choice - High Heritability of Liability to Abdominal Aortic Aneurysms: A Population Based Twin Study. European Journal of Vascular & Endovascular Surgery. 2016;52(1):41–6. PMID: 27107486.27107486
216 Wahlgren CM, Larsson E, Magnusson PK, . Genetic and environmental contributions to abdominal aortic aneurysm development in a twin population. J Vasc Surg. 2010;51(1):3–7; discussion PMID. 10.1016/j.jvs.2009.08.036 19939604
217 Joergensen TM, Houlind K, Green A, . Abdominal aortic diameter is increased in males with a family history of abdominal aortic aneurysms: results from the Danish VIVA-trial. Eur J Vasc Endovasc Surg. 2014;48(6):669–75. PMID: 25443525. 10.1016/j.ejvs.2014.09.005 25443525
218 Linne A, Lindstrom D, Hultgren R. High prevalence of abdominal aortic aneurysms in brothers and sisters of patients despite a low prevalence in the population. J Vasc Surg. 2012;56(2):305–10. PMID: 22425245. 10.1016/j.jvs.2012.01.061 22425245
219 Ogata T, MacKean GL, Cole CW, . The lifetime prevalence of abdominal aortic aneurysms among siblings of aneurysm patients is eightfold higher than among siblings of spouses: an analysis of 187 aneurysm families in Nova Scotia, Canada. J Vasc Surg. 2005;42(5):891–7. PMID: 16275443. 10.1016/j.jvs.2005.08.002 16275443
220 van de Luijtgaarden KM, Rouwet EV, Hoeks SE, . Risk of abdominal aortic aneurysm (AAA) among male and female relatives of AAA patients. Vascular Medicine. 2017;22(2):112–8. PMID: 28429660.28429660
221 Soden PA, Zettervall SL, Ultee KH, . Patient selection and perioperative outcomes are similar between targeted and nontargeted hospitals (in the National Surgical Quality Improvement Program) for abdominal aortic aneurysm repair. Journal of Vascular Surgery. 2017;65(2):362–71. PMID: 27462004. 10.1016/j.jvs.2016.04.066 27462004
222 Gonzalez AA, Sutzko DC, Osborne NH. A National Study Evaluating Hospital Volume and Inpatient Mortality after Open Abdominal Aortic Aneurysm Repair in Vulnerable Populations. Ann Vasc Surg. 2018;50:154–9. PMID: 29477676. 10.1016/j.avsg.2017.11.049 29477676
223 Public Health England. Abdominal aortic aneurysm screening: 2015 to 2016 data tables. 2016. Available from: https://www.gov.uk/government/publications/abdominal-aortic-aneurysm-screening-2015-to-2016-data.
224 Public Health England. AAA screening annual data tables 1 April 2016 to 31 March 2017. 2018. Available from: https://www.gov.uk/government/publications/abdominal-aortic-aneurysm-screening-2016-to-2017-data.
225 Mureebe L, Egorova N, Giacovelli JK, . National trends in the repair of ruptured abdominal aortic aneurysms. J Vasc Surg. 2008;48(5):1101–7. PMID. 10.1016/j.jvs.2008.06.031 18771883
226 Kung HC, Hoyert DL, Xu J, . Deaths: final data for 2005. Natl Vital Stat Rep. 2008;56(10):1–120. PMID.
227 Longo C, Upchurch GR, Jr. Abdominal aortic aneurysm screening: recommendations and controversies. Vasc Endovascular Surg. 2005;39(3):213–9. PMID. 10.1177/153857440503900301 15920649
228 Spencer CA, Jamrozik K, Norman PE, . The potential for a selective screening strategy for abdominal aortic aneurysm. J Med Screen. 2000;7(4):209–11. PMID. 10.1136/jms.7.4.209 11202589
229 Ruff AL, Teng K, Hu B, . Screening for abdominal aortic aneurysms in outpatient primary care clinics. American Journal of Medicine. 2015;128(3):283–8. PMID: 25446298.25446298
230 van Walraven C, Wong J, Morant K, . Incidence, follow-up, and outcomes of incidental abdominal aortic aneurysms. J Vasc Surg. 2010;52(2):282–9.e1-2. PMID. 10.1016/j.jvs.2010.03.006 20541348
231 Gordon JR, Wahls T, Carlos RC, . Failure to recognize newly identified aortic dilations in a health care system with an advanced electronic medical record. Ann Intern Med. 2009;151(1):21–7, w5. PMID.19581643
232 Claridge R, Arnold S, Morrison N, . Measuring abdominal aortic diameters in routine abdominal computed tomography scans and implications for abdominal aortic aneurysm screening. Journal of Vascular Surgery. 2017;65(6):1637–42. PMID: 28216357.28216357
233 Khashram M, Jones GT, Roake JA. Prevalence of abdominal aortic aneurysm (AAA) in a population undergoing computed tomography colonography in Canterbury, New Zealand. Eur J Vasc Endovasc Surg. 2015;50(2):199–205. PMID: 26072194.26072194
234 Gao G, Arora A, Scoutt L, . Imaging Redundancy in Screening for Abdominal Aortic Aneurysm. Journal of the American College of Radiology. 2017;14(5):625–8. PMID: 28223113. 10.1016/j.jacr.2017.01.002 28223113
235 van Walraven C, Wong J, Morant K, . The influence of incidental abdominal aortic aneurysm monitoring on patient outcomes. J Vasc Surg. 2011;54(5):1290–7.e2. PMID. 10.1016/j.jvs.2011.05.045 21803526
236 Ruff A, Patel K, Joyce JR, . The use of pre-existing CT imaging in screening for abdominal aortic aneurysms. Vascular Medicine. 2016;21(6):515–9. PMID: 27235992.27235992
237 Søgaard R, Laustsen J, Lindholt JS. Cost effectiveness of abdominal aortic aneurysm screening and rescreening in men in a modern context: evaluation of a hypothetical cohort using a decision analytical model. BMJ. 2012;345. PMID: 22767630.22767630
238 Johnsen SH, Forsdahl SH, Singh K, . Atherosclerosis in abdominal aortic aneurysms: a causal event or a process running in parallel? The Tromso study. Arterioscler Thromb Vasc Biol. 2010;30(6):1263–8. PMID. 10.1161/atvbaha.110.203588 20360536
239 Caradu C, Morin J, Poirier M, . Monocentric Evaluation of Chimney Versus Fenestrated Endovascular Aortic Repair for Juxtarenal Abdominal Aortic Aneurysm. Annals of Vascular Surgery. 2017;40:28–38. PMID: 28161566. 10.1016/j.avsg.2016.09.013 28161566
240 Forsdahl SH, Solberg S, Singh K, . Abdominal aortic aneurysms, or a relatively large diameter of non-aneurysmal aortas, increase total and cardiovascular mortality: the Tromso study. Int J Epidemiol. 2010;39(1):225–32. PMID. 10.1093/ije/dyp320 19897467
241 Freiberg MS, Arnold AM, Newman AB, . Abdominal aortic aneurysms, increasing infrarenal aortic diameter, and risk of total mortality and incident cardiovascular disease events: 10-year follow-up data from the Cardiovascular Health Study. Circulation. 2008;117(8):1010–7. PMID. 10.1161/circulationaha.107.720219 18268154
242 Bahia SS, Vidal-Diez A, Seshasai SR, . Cardiovascular risk prevention and all-cause mortality in primary care patients with an abdominal aortic aneurysm. Br J Surg. 2016;103(12):1626–33. PMID. 10.1002/bjs.10269 27704527
243 Stone NJ, Robinson JG, Lichtenstein AH, . Treatment of blood cholesterol to reduce atherosclerotic cardiovascular disease risk in adults: synopsis of the 2013 American College of Cardiology/American Heart Association cholesterol guideline. Ann Intern Med. 2014;160(5):339–43. PMID. 10.7326/m14-0126 24474185
244 Bibbins-Domingo K, Grossman DC, Curry SJ, . Statin Use for the Primary Prevention of Cardiovascular Disease in Adults: US Preventive Services Task Force Recommendation Statement. Jama. 2016;316(19):1997–2007. PMID. 10.1001/jama.2016.15450 27838723
245 ISRCTN Registry. The Danish Cardiovascular Screeing Trial (DANCAVAS). http://www.isrctn.com/ISRCTN12157806. Accessed: Oct, 2018.
246 Public Health England. Abdominal aortic aneurysm screening: programme overview. https://www.gov.uk/guidance/abdominal-aortic-aneurysm-screening-programme-overview. Accessed: Jun, 2018.
247 Chabok M, Nicolaides A, Aslam M, . Risk factors associated with increased prevalence of abdominal aortic aneurysm in women. Br J Surg. 2016;103(9):1132–8. PMID: 27332825. 10.1002/bjs.10179 27332825
248 Ryer EJ, Garvin RP, Zhou Y, . Outcomes of familial abdominal aortic aneurysm repair in the Vascular Quality Initiative. J Vasc Surg. 2018;[Epub ahead of print]. PMID: 30064833. 10.1016/j.jvs.2018.04.070 30064833