# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Ernest Sullivent, MD, MPH, and Iris Mabry-Hernandez, MD, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Frank Lederle, MD, former director at the Minneapolis Veterans Affairs Center for Epidemiological and Clinical Research for his longstanding support and expertise in this field; and Shannon Robalino, MS, Smyth Lai, MLS, and Katherine Essick, BS, at the Kaiser Permanente Center for Health Research for technical and editorial assistance.