# Chapter 3 Results

## Literature Search

We screened 3,946 abstracts and assessed 137 full-text articles for inclusion; 50 articles were reviewed for KQs 1–3 and 87 articles were reviewed for KQs 4 and 5 (Appendix A Figure 1). After screening the full-text articles, 33 studies (in 70 articles) were included in our systematic review.^7,^ ^12–15,^ ^22,^ ^36,^ ^75,^ ^113–174^ The full list of included studies and their ancillary articles is available in Appendix C. The list of excluded studies (with reasons for exclusion) is available in Appendix D.

## KQ1 What Are the Effects of One-Time Screening for AAA on Health Outcomes in an Asymptomatic Population Age 50 Years or Older?

### Summary of Results

Four large, population-based screening RCTs of men age 65 years or older examined the effectiveness of one-time AAA screening and found that AAA prevalence varies from 4 to 7.6 percent, with the majority of screen-detected AAAs being small in size (aortic diameter of ≤4 to 4.5 cm).^12,^ ^15,^ ^113,^ ^143,^ ^147,^ ^155,^ ^170^ One more contemporary screening trial in the same population solely contributed to outcomes of prevalence and number of operations and reports a 3.3 percent prevalence, reflecting a temporal decline in the disease.^146^ The invitation for screening among men age 65 years or older was associated with a 35 percent reduction in AAA-related mortality, a 38 percent reduction in AAA rupture rate, and a 43 percent reduction in the number of emergency surgeries. There was no statistically significant difference, however, in all-cause mortality at 12- to 15-year followup.

### Study Characteristics

Two fair- and two good-quality population-based screening RCTs from the United Kingdom, Denmark, and Australia assessed the efficacy of AAA screening in population-based settings: the Multicentre Aneurysm Screening Study (MASS) (n=67,770);^12,^ ^134,^ ^135,^ ^170,^ ^171^ the Chichester, United Kingdom, screening trial (n=15,382);^13,^ ^36,^ ^113,^ ^173^ the Viborg County, Denmark, screening trial (n=12,639);^14,^ ^143–145,^ ^147^ and the Western Australia screening trial (n=38,480) (Appendix E Tables 1 and 2).^7,^ ^15,^ ^154,^ ^155,^ ^168^ These four RCTs were included in the previous review, with new long-term data reported in the Western Australia trial^15^ included in this update. One additional population-based screening trial in Denmark (VIVA) is discussed in detail under KQ3 but is mentioned here due to its contribution to AAA prevalence in a screened population and number of operations.^146^ All trials identified potential participants age 64 or 65 years or older from population registries or regional health directories. The MASS trial identified participants from four centers in the United Kingdom; the Chichester trial included nine general practices in Chichester; the Viborg trial included the population from Viborg County; and the Western Australia trial included participants from a capital city and satellite towns. Reported mean (or median) ages ranged from 67.7 to 72.6 years, and the oldest study participants were age 83 years. One study, the Chichester trial,^14^ included women,^25^ while the other three recruited only men. Other than age and sex, no studies reported outcomes in the screened and control groups by any other demographic information.

Two trials provide some risk factor information.^15,^ ^147^ The Viborg trial, which described AAA-related comorbidity risk factor information from hospital discharge data, indicated that 26.5 percent of all participants had at least one cardiovascular risk factor or chronic obstructive pulmonary disease (COPD).^145,^ ^147^ The Western Australia trial reported cardiovascular comorbidity and risk factor information for the screened group and analyzed the association between the risk factor and AAA diagnosis, but risk factor data were not collected for the control group, nor were they linked to mortality outcomes.^15^ Three studies had no trial exclusions; only the MASS trial excluded patients who (1) were identified by their primary care clinicians as too high risk to be screened, (2) were terminally ill, or (3) had other serious health problems or prior AAA repair.

All trials randomized participants to one of two groups: the invited group received a letter invitation for one-time ultrasound screening, while the control group received usual care. All trials considered “normal” aortic diameter to be smaller than 3 cm and defined AAA as an aortic diameter of 3.0 cm or larger. Three of the RCTs (MASS, Viborg, and Chichester) further prescribed specific postscreening surveillance protocols for AAAs with an aortic diameter of 3.0 cm or larger with repeat ultrasounds,^113,^ ^147,^ ^170^ while one trial (Western Australia) sent initial ultrasound results to primary care clinicians for management.^15^ In the MASS trial, patients with aortic diameters of 3.0 to 4.4 cm were rescanned yearly, those with aortic diameters of 4.5 to 5.4 cm were rescanned at 3-month intervals, and those with aortic diameters of 5.5 cm or larger were urgently referred to a vascular surgeon.^170^ In the Viborg trial, individuals with an ectatic aortic size of 2.5 to 2.9 cm were offered a repeat scan at 5 years, those with an aortic size of 3.0 to 4.9 cm were offered annual scans, and those with an aortic size of 5.0 cm or larger were referred to vascular surgery.^147^ In the Chichester trial, patients with AAAs with an aortic diameter of 3.0 to 4.4 cm were rescanned annually, those with AAAs with an aortic diameter of 4.5 to 5.9 cm were rescanned every 3 months, and those with AAAs with an aortic diameter of 6 cm or greater were referred to vascular surgeon, as were those with increase of diameter of 1 cm or more per year (Appendix E Table 1).^113^

The primary outcome reported in trials was AAA-specific mortality (defined as all AAA-related deaths plus all deaths within 30 days of AAA surgical repair); all four trials also reported AAA rupture rate and all-cause mortality as benefit outcomes. Mortality data and causes of death were ascertained from death certificates in all studies, and three of the RCTs additionally involved an independent blinded review of autopsy reports and/or hospital records for all AAA-related deaths. Mean or median followup in these four population-based screening trials ranged from 12.8 to 15 years, with short-term results published at 3- to 5-year intervals; this report focuses solely on the longest-term followup. Local and national health departments, research councils, and heart foundations funded these studies.

The MASS trial^12,^ ^134,^ ^135,^ ^170,^ ^171^ stands out as the highest quality of the four trials; it had the greatest number of participants, the highest adherence to screening, and clear reporting of randomization, allocation, blinding of outcome assessors, and confirmation of equal followup in the invited and control groups. All trials appeared to use intention-to-treat analysis; adherence to screening varied from the lowest adherence in the Western Australia trial (62.5% of those invited attended screening) to the highest adherence in the MASS trial (80.2% adherence). Three studies reported low loss-to-followup rates in participants with AAA (MASS trial, 70% retention rate at 13-year followup in men with an AAA detected at the initial scan;^170^ Viborg trial, 75.1% retention rate in invited group and 58.0% in control group at 52-month followup;^147^ and Western Australia trial, 87.1% retention in invited group and 84.9% in the control group at 3.6-year followup).^15^

### Detailed Results (Male Only; Female Results in KQ1a)

#### AAA Prevalence in Screened Population

AAA prevalence (aortic diameter of ≥3.0 cm) on the initial screen for male attenders in the four population-based screening trials varied from as low as 3.9 percent in the Viborg trial^147^ to as high as 7.6 percent in the Chichester trial^113^ (Table 1). Notably, the Chichester and Western Australia trials reported the highest AAA prevalence rates and they recruited older participants (Chichester median age, 72 years; Western Australia mean age, 72.7 years compared to mean ages of 67.7 and 69.2 years in the Viborg and MASS trials, respectively). The VIVA trial^146^ reported a prevalence of AAAs (619/25,078 [3.3%]) similar to the older Viborg trial^147^; both trials were conducted in the same geographic area. Four of the five trials (MASS, Chichester, Western Australia, and VIVA)^12,^ ^13,^ ^15,^ ^113,^ ^143,^ ^146,^ ^155,^ ^170^ reported the prevalence of AAA by size at initial screening, with MASS, VIVA, and Western Australia trials reporting that the majority of AAAs (87% to 93%) detected were small (measuring <5.5 cm). The overall prevalence of large AAAs (≥5 cm or ≥5.5 cm) in the screened population was consistent across studies and was reported as 0.3 to 0.6 percent (Appendix E Table 3).

Table 1 AAA Prevalence, Rupture, and Surgery Data for One-Time Screening Trials (KQ1)

Author, Year; Trial Name; Quality | Mean Followup, years | Group | N Analyzed | AAA Prevalence, n (%) | AAA Rupture, n (%) | HR (95% CI) for AAA Rupture | OR (95% CI) for AAA Rupture^*^ | All AAA Procedures, n (%) | Elective Surgery, n (%) | Emergency Surgery, n (%) | HR (95% CI) for Emergency Surgery | OR (95% CI) for Emergency Surgery^*^
Ashton, 2007^113^; Chichester (men only); Fair | 15^†^ | IG | 2,995^ǂ^ | 170^§^ (7.6) | 54 (1.8) | 0.88 (0.61 to 1.26) | 0.87 (0.60 to 1.25) | 57 (1.9) | 41 (1.4) | 16 (0.5) | NR | 0.77 (0.41 to 1.48)
Ashton, 2007^113^; Chichester (men only); Fair | 15^†^ | CG | 3,045^ǂ^ | NR | 63 (2.1) | 0.88 (0.61 to 1.26) | 0.87 (0.60 to 1.25) | 40 (1.3) | 19 (0.6) | 21 (0.7) | NR | 0.77 (0.41 to 1.48)
Scott, 2002^13,^ ^36^; Chichester (women only); Fair | 10^†^ | IG | 4,682 | 40 (1.3)^║^ | 10 (0.2) | NR | 1.11 (0.45 to 2.72) | 6 (0.1) | 5 (0.1) | 1 (0.02)^║^ | NR | Not calculated
Scott, 2002^13,^ ^36^; Chichester (women only); Fair | 10^†^ | CG | 4,660 | NR | 9 (0.2) | NR | 1.11 (0.45 to 2.72) | NR | NR | 2 (0.02)^║^ | NR | Not calculated
Thompson, 2012^170^; MASS; Good | 13.1 | IG | 33,883 | 1,334 (4.9) | 273 (0.8) | 0.57 (0.49 to 0.66) | 0.58 (0.50 to 0.67) | 680 (2.0) | 600 (1.8) | 80 (0.2) | NR | 0.50 (0.39 to 0.64)
Thompson, 2012^170^; MASS; Good | 13.1 | CG | 33,887 | NR | 476 (1.4) | 0.57 (0.49 to 0.66) | 0.58 (0.50 to 0.67) | 443 (1.3) | 277 (0.8) | 166 (0.5) | NR | 0.50 (0.39 to 0.64)
Lindholt, 2010^14,^ ^147^; Viborg; Good | 13 | IG | 6,333 | 191 (3.9)^¶^ | 16 (0.3) | 0.44 (0.24 to 0.79) | 0.46 (0.27 to 0.79) | 109 (1.7) | 89 (1.4) | 20 (0.3) | 0.50 (0.15 to 1.65)^#^ | 0.47 (0.29 to 0.77)
Lindholt, 2010^14,^ ^147^; Viborg; Good | 13 | CG | 6,306 | NR | 36 (0.6) | 0.44 (0.24 to 0.79) | 0.46 (0.27 to 0.79) | 88 (1.4) | 44 (0.7) | 44 (0.7) | 0.50 (0.15 to 1.65)^#^ | 0.47 (0.29 to 0.77)
Lindholt, 2017^22,^ ^146^; VIVA; Fair | 4.4^†^ | IG | 25,078 | 619 (3.3) | NR | NA | NA | 277 (1.1) | 240 (1.0) | 37 (0.1) | 0.81 (0.53 to 1.26)^**^ | 0.82 (0.53 to 1.27)
Lindholt, 2017^22,^ ^146^; VIVA; Fair | 4.4^†^ | CG | 25,078 | NR | NR | NA | NA | 146 (0.6) | 101 (0.4) | 45 (0.2) | 0.81 (0.53 to 1.26)^**^ | 0.82 (0.53 to 1.27)
McCaul, 2016^15^; Western Australia; Fair | 12.8 | IG | 19,249 | 879 (7.2)^ǂǂ^ | 72^§§^ | NR | 0.73 (0.54 to 0.98) | 562 (2.9) | 536 (2.78)^║║^ | 26 (0.14)^¶¶^ | NR | 0.60 (0.37 to 0.95)
McCaul, 2016^15^; Western Australia; Fair | 12.8 | CG | 19,231 | NR | 99 | NR | 0.73 (0.54 to 0.98) | 458 (2.4) | 414 (2.15) | 44 (0.23)^¶¶^ | NR | 0.60 (0.37 to 0.95)

* Calculated, Peto OR.

† Median.

ǂ Due to updated computer systems and the correction of data, 391 men were excluded from the original data.

§ N analyzed for prevalence: 2,216.

║ From 5-year reported data; N analyzed for prevalence: 3,052.

¶ N analyzed for prevalence: 4,816. Prevalence reported at 4.3-year (median) followup^14^ NR in 13-year followup results.

# HR for emergency surgery without rupture; HRs reported separately for emergency surgery with rupture: 0.44 (95% CI, 0.24 to 0.79).

** Likely confounded by coscreening and resulting treatment.

ǂǂ N analyzed for prevalence: 12,203.

§§ p=0.04.

║║ p<0.001.

¶¶ Total surgery for rupture.

Abbreviations: AAA = abdominal aortic aneurysm; CG = control group; CI = confidence intervals; HR = hazard ratio; IG = intervention group; MASS = Multicenter Aneurysm Screening Study; N = population size; n = sample size; NA = not applicable; NR = not reported; OR = odds ratio.

#### Effect of Population Screening on All-Cause and AAA-Related Mortality

A meta-analysis of all-cause mortality of the four screening trials^15,^ ^113,^ ^147,^ ^170^ (N=124,929) using relative risk (RR) estimates with the DerSimonian and Laird method showed a result that when rounded, yielded a nonstatistically significant pooled result (RR, 0.99 [95% CI, 0.98 to 1.00]; I^2^=0%) (Figure 2). None of the individual screening trials reported a statistically significant reduction in all-cause mortality (Table 2) with screening except MASS (HR, 0.97 [95% CI, 0.95 to 0.99]).^170^ Individually calculated RR point estimates ranged from 0.98 to 1.00, with none reaching statistical significance.

Figure 2 Pooled Analysis of All-Cause Mortality (Male-Only) in One-Time Screening Trials

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; N = population size; n = sample size; RR = relative risk.

This figure is a forest plot of the effect of AAA screening on all-cause mortality (males only) reported in one-time screening trials.

Table 2 All-Cause and AAA-Related Mortality Data for One-Time Screening Trials (KQ1)

Author, Year; Trial Name; Quality | Mean Followup, years | Group | N Analyzed | All-Cause Mortality, n (%) | HR (95% CI) | RR (95% CI)^*^ | AAA-Related Mortality, n (%) | HR (95% CI) | OR (95% CI)^*^ | 30-Day Mortality for Elective Repairs, n (%) | RR (95% CI)^*^ | 30-Day Mortality for Emergency Repairs, n (%) | RR (95% CI)^*^
Ashton, 2007^113^; Chichester (men only); Fair | 15^†ǂ^ | IG | 2,995^§^ | 2036 (68.0) | 1.01 (0.95 to 1.07) | 1.00 (0.97 to 1.04) | 47 (1.6) | 0.89 (0.6 to 1.32) | 0.88 (0.60 to 1.31) | NR | Not calculated | NR | Not calculated
Ashton, 2007^113^; Chichester (men only); Fair | 15^†ǂ^ | CG | 3,045^§^ | 2067 (67.9) | 1.01 (0.95 to 1.07) | 1.00 (0.97 to 1.04) | 54 (1.8) | 0.89 (0.6 to 1.32) | 0.88 (0.60 to 1.31) | NR | Not calculated | NR | Not calculated
Scott, 2002^13,^ ^36^; Chichester (women only); Fair | 10^ǂ^ | IG | 4,682 | 503 (10.7)^║^ | NR | Not calculated | 3 (0.06)^║^ | NR | Not calculated | NR | Not calculated | NR | Not calculated
Scott, 2002^13,^ ^36^; Chichester (women only); Fair | 10^ǂ^ | CG | 4,660 | 476 (10.2)^║^ | NR | Not calculated | 2 (0.04)^║^ | NR | Not calculated | NR | Not calculated | NR | Not calculated
Thompson, 2012^170^; MASS; Good | 13.1 | IG | 33,883 | 13,858 (40.9) | 0.97 (0.95 to 0.99) | 0.98 (0.96 to 1.00) | 224 (0.7) | 0.58 (0.49 to 0.69) | 0.59 (0.50 to 0.70) | 23 (3.8)^¶^ | 0.76 (0.40 to 1.45) | 27 (33.8)^#^ | 0.98 (0.68 to 1.43)
Thompson, 2012^170^; MASS; Good | 13.1 | CG | 33,887 | 14,134 (41.7) | 0.97 (0.95 to 0.99) | 0.98 (0.96 to 1.00) | 381 (1.1) | 0.58 (0.49 to 0.69) | 0.59 (0.50 to 0.70) | 14 (5.1) ^¶^ | 0.76 (0.40 to 1.45) | 57 (34.3)^#^ | 0.98 (0.68 to 1.43)
Lindholt, 2010^147^; Viborg; Good | 13 | IG | 6,333 | 2,931 (46.3) | 0.98 (0.93 to 1.03) | 0.98 (0.95 to 1.02) | 19 (0.3) | 0.34 (0.20 to 0.57) | 0.37 (0.24 to 0.59) | NR | Not calculated | NR | Not calculated
Lindholt, 2010^147^; Viborg; Good | 13 | CG | 6,306 | 2,964 (47.0) | 0.98 (0.93 to 1.03) | 0.98 (0.95 to 1.02) | 55 (0.9) | 0.34 (0.20 to 0.57) | 0.37 (0.24 to 0.59) | NR | Not calculated | NR | Not calculated
McCaul, 2016^15^; Western Australia; Fair | 12.8^ǂ^ (range, 11.6 to 14.2) | IG | 19,249 | 9739 (50.6) | NR^**^ | 0.99 (0.97 to 1.01) | 90 (0.46) | 0.91 (0.68 to 1.21)^**^ | 0.92 (0.69 to 1.22) | 18 (3.4)^ǂǂ^ | 0.82 (0.43 to 1.57) | 16 (61.5)^§§^ | 1.43 (0.90 to 2.25)
McCaul, 2016^15^; Western Australia; Fair | 12.8^ǂ^ (range, 11.6 to 14.2) | CG | 19,231 | 9832 (51.1) | NR^**^ | 0.99 (0.97 to 1.01) | 98 (0.51) | 0.91 (0.68 to 1.21)^**^ | 0.92 (0.69 to 1.22) | 17 (4.1)^ǂǂ^ | 0.82 (0.43 to 1.57) | 19 (43.2)^§§^ | 1.43 (0.90 to 2.25)

* Calculated.

† Male subgroup only.

ǂ Median.

§ Due to updated computer systems and the correction of data, 391 men were excluded from the original data.

║ From 5-year reported data.

¶ N Analyzed for IG: 600, CG: 277.

# N Analyzed for IG: 80, CG: 166.

** Rate ratio (95% CI). Rate ratios reported as AAA-related and non-AAA deaths, not available for all-cause mortality.

ǂǂ N Analyzed for IG: 536, CG: 414.

§§ N Analyzed for IG: 26, CG: 44.

Abbreviations: AAA = abdominal aortic aneurysm; CG = control group; CI = confidence intervals; HR = hazard ratio; IG = intervention group; MASS = Multicenter Aneurysm Screening Study; N = population size; n = sample size; NA = not applicable; NR = not reported; OR = odds ratio; RR = relative risk.

Pooled analysis of AAA-related mortality of the four trials^15,^ ^113,^ ^147,^ ^170^ (N=124,929) showed a statistically significant 35 percent reduction associated with invitation to screening (Peto OR, 0.65 [95% CI, 0.57 to 0.74]; I^2^=80%) (Figure 3) with high heterogeneity. We estimate a number needed to screen of 305 men (95% CI, 248 to 411) to prevent one AAA death. The results lost statistical significance, however, with the restricted maximum likelihood method (data not shown). Individual trial results demonstrate that the MASS and Viborg trials found a statistically significant AAA-related mortality benefit in the invited group compared to the control group at the longest followup time points, while the Chichester study reported an HR that was less than 1 but not statistically significant (Table 2).

Figure 3 Pooled Analysis of AAA-Related Mortality and Ruptures (Male-Only) for Rupture in One-Time Screening Trials

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; N = population size; n = sample size; OR = odds ratio.

This figure is a forest plot of the effect of AAA screening on AAA-related mortality and ruptures (male only) reported in one-time screening trials.

#### Effect of Population Screening on AAA Rupture

Pooled results of the four trials^15,^ ^113,^ ^147,^ ^170^ (N=124,929) showed a statistically significant reduction in ruptures associated with the invitation to screening (Peto OR, 0.62 [95% CI, 0.55 to 0.70]; I^2^=53%) (Figure 3). We estimate a number needed to screen of 246 men (95% CI, 207 to 311) to prevent one AAA rupture. Individual study results for AAA rupture rate show mixed results, with calculated Peto ORs ranging from 0.46 to 1.11, with the beneficial effect favoring invitation to screening reaching statistical significance in three trials (MASS, Western Australia, and Viborg)^15,^ ^147,^ ^170^ (Table 1).

#### Emergency Operations

Pooled results at the longest followup of the five trials^15,^ ^113,^ ^146,^ ^147,^ ^170^ (N=175,085) showed a reduction in emergency operations in the invited group (Peto OR, 0.57 [95% CI, 0.48 to 0.68]; I^2^=27%) (Figure 4). We estimate that screening 1,000 men for AAA would reduce the number of emergency procedures by 2 (95% CI, 2 to 2). Individual trial results show that results for number of emergency surgeries were as follows: MASS, Viborg, and Western Australia trials reported significantly fewer emergency surgeries in the invited group at the longest-term followup (MASS: Peto OR, 0.50 [95% CI, 0.39 to 0.64]; Viborg: Peto OR, 0.47 [95% CI, 0.29 to 0.77]; Western Australia: Peto OR, 0.60 [95% CI, 0.37 to 0.95]), while Chichester and VIVA showed similar nonsignificant trends (Chichester: Peto OR, 0.77 [95% CI, 0.41 to 1.48]; VIVA: OR, 0.82 (95% CI, 0.53 to 1.27) (Table 1, Figure 4).

Figure 4 Pooled Analysis of Operations (Male-Only) in One-Time Screening Trials

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; N = population size; n = sample size; OR = odds ratio.

This figure is a forest plot of the effect of AAA screening on operations: all operations, elective operations, and emergency operations (male only) reported in one-time screening trials.

## KQ1a Do the Effects of One-Time Screening for AAA Vary Among Subpopulations (i.e., by Age, Sex, Smoking Status, Family History, or Race/Ethnicity)?

### Summary of Results

Available subgroup analyses are scant, and their analytical credibility is mixed. The Viborg^147^ and Western Australia^15^ trials, both of which were population-based screening trials, reported subanalyses, with substantial limitations suggesting that there is no differential screening effect based on age. While our review scope included adults age 50 years or older, none of the trials recruited patients younger than age 64 years. Only the Chichester^36,^ ^113^ trial, also a population-based screening trial, examined AAA screening in women, showing a low prevalence of AAA in women, with most screen-detected AAAs with an aortic diameter measuring 3.0 to 3.9 cm.^13,^ ^36^ There was no difference in AAA rupture rate among women at 10-year followup or in AAA-related or all-cause mortality at 5 years between the invited and control groups, but the trial was underpowered to detect such differences. While the Western Australia trial reported that smoking is associated with a higher risk of all-cause mortality (OR, 1.59 [95% CI, 1.47 to 1.72]) and AAA-related mortality (OR, 2.95 [95% CI, 1.04 to 8.43]) in the screened group,^15^ it did not compare outcomes in the unscreened control for comparison and therefore does not address modification of intervention effectiveness by smoking status.

### Study Characteristics and Results

#### Age

The oldest participants in the four major screening trials ranged from age 73 years in the Viborg trial^147^ to age 83 years in the Western Australia trial^15^ (Appendix E Table 2). The Viborg and Western Australia trials were the only two population-based screening trials reporting AAA-related mortality outcomes stratified by age, suggesting that there is no differential screening effect on mortality by age (Appendix F Table 1).^15,^ ^147^ Neither of these subgroup analyses was reported as prespecified, however. Further randomization was not stratified to ensure similar baseline characteristics and the trials were not powered to detect differences in the age subgroups. No formal interaction testing was performed. The 13-year followup of the Viborg trial performed a subgroup analysis of men ages 64 to 65 years (N=5,429) showing a similar AAA-related mortality benefit in the 64- to 65-year-old age group compared with the 66- to 73-year-old age group (N=7,210) (HR, 0.36 [95% CI, 0.14 to 0.93] in 64- to 65-year-olds; HR, 0.33 [95% CI, 0.18 to 0.62] in 66- to 73-year-olds).^93^ The Western Australia trial showed no AAA-related mortality benefit in the invited group of 65- to 74-year-olds (N=26,505) (AAA-related mortality: rate ratio, 0.92 [95% CI, 0.62 to 1.36] at 12.8-year followup).^15^ These results were similar to findings for the entire trial, which had an age range of 64 to 83 years (N=38,480) (AAA-related mortality: rate ratio, 0.91 [95% CI, 0.68 to 1.21]).^15^ A rate ratio was not provided for all-cause mortality.

#### Sex

Of the four population-based screening trials, only the Chichester study^13,^ ^36,^ ^113^ recruited female participants ages 65 to 80 years (59% of participants were women; n=9,342 women) (Appendix E Table 2). While this trial prespecified its subgroup analysis and allowed for within-study comparisons by sex, the trial was insufficiently powered to detect AAA-related mortality or all-cause mortality differences in women and no formal interaction testing was performed.

A greater proportion of women than men in the invited group refused screening; for example, in the 65-year-old cohort, 27.3 percent of invited women refused screening compared with 19.5 percent of men; in the 76- to 80-year-old cohort, 41.7 percent of invited women refused screening, while 33.8 percent of men refused. The prevalence of AAA in the screened group was 6 times lower in women than in men (1.3% vs. 7.6%) (Table 1).^13,^ ^36,^ ^113^ Prevalence by age group revealed a time delay in AAA development compared with men: no women were diagnosed with AAA at the age of 65 years, 1 percent were diagnosed at ages 66 to 70 years, 1.8 percent at ages 71 to 75 years, and 1.6 percent at ages 76 to 80 years. Seventy-five percent of AAAs were small, with an aortic diameter measuring 3.0 to ­3.9 cm; 15 percent of AAAs had an aortic diameter of 5.0 cm or larger. All-cause mortality in women at 5 years was similar in the invited and control groups (10.7% vs. 10.2%). AAA-specific mortality in women was low in both groups at 5-year followup (3 deaths [0.06%] in the invited group and 2 deaths [0.04%] in the control group; no statistical analysis) and not reported at longer followup (Table 2). The rupture rate was low (0.2%) in both the invited and control groups at 10-year followup (Table 1). Similarly, emergency repairs were rare in both the invited and control groups at 5 years (0.02%). All-cause and AAA-related mortality were not reported for women at 10-year followup. AAA-related mortality was reported in the entire unscreened population in Chichester, and while more than half of the AAA-related deaths in men occurred before age 80 years, the majority (70%) of AAA-related deaths in women occurred among those age 80 years and older.^13,^ ^36,^ ^113^

#### Smoking Status

Only the Western Australia trial^15^ reported outcomes by smoking status in the screened group (Appendix F Table 2). The analysis had low subgroup credibility; it was unclear if this analysis was prespecified, as the study was not powered to detect subpopulation differences. There was no formal test for interaction performed, and no comparisons in the unscreened group were reported. Results showed that smoking was associated with a higher risk of all-cause mortality (OR, 1.59 [95% CI, 1.47 to 1.72]) and AAA-related mortality (OR, 2.95 [95% CI, 1.04 to 8.43]) in the screened group of men ages 64 to 83 years.^15^ This trend was more pronounced among those ages 65 to 74 years; however, no formal analysis was performed to explore if there is a differential screening effect based on smoking status.

#### Race/Ethnicity and Family History

None of the population-based screening RCTs reported AAA family history or race/ethnicity descriptive data for participants to allow for the analysis of screening benefits among these subpopulations. Of note, all studies were conducted in majority-Caucasian populations (Appendix E Table 1).

## KQ2 What Are the Effects of Rescreening for AAA on Health Outcomes or AAA Incidence in a Previously Screened, Asymptomatic Population Without AAA on Initial Screening?

### Summary of Results

No trial-level evidence examined the effectiveness of one-time screening plus rescreening compared to one-time screening alone. Eight heterogeneous, prospective cohort studies recruited screen-negative participants and administered various rescreening protocols (rescreening every 1 to 5 years with 1 to 6 repeated scans) and reported the proportion of initially normal or ectatic aneurysms that reach an aortic diameter of 5.0 or 5.5 cm at the repeat scan. These studies report that AAA-related mortality over 5 to 12 years is rare (< 3%) among those with normal aortas (<3 cm) on the initial scan. Upon rescreening, few aortas grew to larger than 5 cm (0% to 2.2%) at 5 years,^121,^ ^123,^ ^138^ and 0 to 15 percent had progressed at 10 years.^120^ Four studies reported no AAA ruptures or AAA-related deaths^121,^ ^138,^ ^167,^ ^169^ at 4- to 5-year followup; one study reported 2.4 percent ruptures at median 7.9-year followup.^120^ Overall, this heterogenous body of literature was too limited to make conclusions about the effectiveness of rescreening.

### Study Characteristics

Five fair-quality prospective studies,^121,^ ^123,^ ^165,^ ^167,^ ^169^ two good-quality cohort studies,^119,^ ^120,^ ^125,^ ^138,^ ^151,^ ^156^ and one fair-quality case-control study^148^ examined the yield of rescreening participants who initially screened negative for AAA (Appendix E Table 4). Six of these studies were available in the previous review^105^ and two of the studies^167,^ ^169^ are new; one screening program has updated data.^156^ Two of these studies analyzed subsamples of the Aneurysm Detection and Management (ADAM) Veterans Affairs trial of open repair vs. surveillance strategies for small AAAs.^121,^ ^138^ Additionally, three studies were based in the United Kingdom: a subsample of the Gloucestershire screening study,^156^ a hospital screening program,^123^ and a Chichester screening program separate from the Chichester trial.^165^ Two of the cohort studies were conducted in Sweden,^167,^ ^169^ and one of these was conducted exclusively in women.^167,^ ^169^ The case-control study was a subsample of the Viborg screening trial; however, data were only considered from the cohort of participants with ectatic aortas who were offered rescreening. The size of the rescreened cohorts ranged from 33^167^ to 2,692^169^ participants; samples of those with normal or ectatic aortas were derived from larger screening programs and had mean followup ranging from 4 to 10 years. The Gloucestershire population-based screening program published their observations over the 25-year history of the program with a proportion being followed for at least 10 years^120,^ ^156^ (Appendix E Table 4).

The definition of “normal” or “ectatic” aortas differed; inclusion criteria for selection of the rescreening cohort based on aortic diameter were defined as follows: 2.5 or 2.6 to 2.9 cm,^121,^ ^123,^ ^148,^ ^156,^ ^167,^ ^169^ smaller than 2.5 cm,^169^ or 3 cm or smaller.^138,^ ^165,^ ^169^ Ultrasound measurement techniques varied, with some measurements obtained using inner-to-inner wall measurements,^119,^ ^120,^ ^125,^ ^151,^ ^156^ leading edge,^167,^ ^169^ or unspecified measurements.^121,^ ^123,^ ^138,^ ^148,^ ^165^ Repeat screening occurred at various intervals after the initial normal scan as follows: annually,^121,^ ^123,156^ once at 3 to 5 years,^138,^ ^148,^ ^167,^ ^169^ and every 2 years.^165^ Participants had a total of one,^138,^ ^148,^ ^167,^ ^169^ five,^121,^ ^165^ or six^156^ scans after initial screening over the study duration; one study^123^ did not report total number of scans.

Benefit outcomes (Tables 3 and 4) reported in these trials included all-cause mortality,^121,^ ^156,^ ^167,^ ^169^ AAA-related mortality,^121,^ ^138,^ ^156,^ ^167,^ ^169^ AAA rupture,^121,^ ^138,^ ^156,^ ^165,^ ^167,^ ^169^ and large AAA incidence.^121,^ ^123,^ ^138,^ ^148,^ ^156,^ ^165,^ ^167^ Six of these studies reported the use of procedures (Table 3).^121,^ ^138,^ ^148,^ ^156,^ ^167,^ ^169^

Table 3 AAA Prevalence, Rupture, and Surgery Data for Rescreening Studies (KQ2)

Study, Year; USPSTF Quality | Mean Followup, years | N Analyzed | Initial Aorta Size, Range | Large AAA Incidence, n (%) | AAA Rupture, n (%) | All AAA Procedures, n (%) | Elective Surgery, n (%) | Emergency Surgery, n (%)
D’Audiffret, 2002^121^; Fair | 5.9 | 223 | 2.5–2.9 cm | >5 cm: 3 (1.3) | 0 (0) | 0 (0) | 0 (0) | 0 (0)
Deveraj, 2008^123^; Fair | 5.4 | 358 | 2.6–2.9 cm | ≥5.5 cm: 8 (2.2) | NR | NR | NR | NR
Oliver-Williams, 2018^120,^ ^156^; Good | 7.8 | 1,233 | 2.6–2.9 cm | ≥5.5 cm: 181 (14.7) | 13 (2.4)^*^ | 134 (10.9) | 124 (10.1) | 10 (0.8)
Oliver-Williams, 2018^120,^ ^156^; Good | 7.9^*^ | 547 | 2.6–2.9 cm | >5.4 cm: 87 (15.9) | 13 (2.4) | 63 (11.5) | 57 (10.4) | 6 (1.1)
Lederle, 2000^138^; Good | 4 | 2,622 | ≤3.0 cm | >5 cm: 0 | 0 (0) | 0 (0) | NR | NR
Lindholt, 2000^148^; Fair | 5 | 248 | 2.5–2.9 cm | >5 cm: 0 | NR | 0 (0) | NR | NR
Scott, 2001^165^; Fair | 10 | 649 | <3.0 cm | >5 cm: 0 | NR | NR | NR | NR
Soderberg, 2017^167^; Fair | 5 | 33^†^; 25; rescreened | 2.5–2.9 cm | >5 cm: 0 | 0 (0) | 1 (4) | 1 (4)^ǂ^ | 0
Svensjo, 2014^169^; Fair | 5 | 2,652; 2,041; rescreened | <2.5 cm | NR^§^ | 0 | 0 | 0 | 0

* From median followup of 7.9 years (2.7- to 11-year range).^120^

† One woman was misclassified with a normal (2.1 cm) aorta at rescanning and was excluded from further analysis,

ǂ One participant was diagnosed with a 4.5-cm AAA at 5-year followup and was then electively repaired.

§ Did not report >5 cm AAA incidence.

║ Of those rescreened (n=38).

Abbreviations: AAA = abdominal aortic aneurysm; cm = centimeter; N = population size; n = sample size; NR = not reported.

Table 4 All-Cause and AAA-Related Mortality Data for Rescreening Studies (KQ2)

Study, Year; USPSTF Quality | Mean Followup, years | N Analyzed | All-Cause Mortality, n (%) | AAA-Related Mortality, n (%) | Operative Mortality, n (%)
D’Audiffret, 2002^121^; Fair | 5.9 | 223 | 8 (3.6) | 0 (0) | NR
Deveraj, 2008^123^; Fair | 5.4 | 358 | NR | NR | NR
Oliver-Williams, 2018^120,^ ^156^; Good | 7.8 | 1,233 | 379 (30.7) | 14 (2.4)^*^ | 7 (11.1)^*^
Lederle, 2000^138^; Good | 4 | 2,622 | NR | 0 (0) | NR
Lindholt, 2000^148^; Fair | 5 | 248 | NR | NR | NR
Scott, 2001^165^; Fair | 10 | 649 | NR | NR | NR
Soderberg, 2017^167^; Fair | 5 | 33; (2.5 to 2.9 cm AAA diameter group) | 5 (15.2) | 0 (0) | 0 (0)
Svensjo, 2014^169^; Fair | 5 | 2,652; (<2.5 AAA diameter group) | 136 (5.1) | 0 (0) | 0 (0)
Svensjo, 2014^169^; Fair | 5 | 40; (2.5 to 2.9 cm AAA diameter group) | 2 (5) | 0 (0) | 0 (0)

* AAA-related mortality from median followup of 7.9 years (2.7- to 11-year range).^120^

Abbreviations: AAA = abdominal aortic aneurysm; cm = centimeter; N = population size; n = sample size; NR = not reported.

Most studies included men age 65 years or older, with only one study including men age 50 years and older (Appendix E Table 5).^138^ The mean age of participants ranged from 65 to 70 years. One Swedish study^167^ solely recruited 70-year-old women, and one study^138^ reported the inclusion of few female participants (2.4% women). The remaining studies solely recruited men. Additionally, the two studies that followed subgroups from the ADAM trial^121,^ ^138^ and one Swedish study^167^ included risk factor information.

Overall, this group of observational studies is limited because of the following: a small number of participants with normal aortas was included; all but a single study exclusively recruited men; cohort study designs did not have matched controls, and the primary focus of most studies was growth rate because the followup time for most studies was 5 years. This time frame would be too short to expect the development of AAA-related health outcomes.

### Detailed Results

#### Large AAA Incidence

While all studies reported the percentage of participants with initially normal scans who eventually developed an AAA of 3.0 cm or larger, we were interested in the percentage of participants with normal or ectatic aortas that expanded to near or greater than the surgical threshold (≥5.0 or 5.5 cm) during the followup period. Four studies reported that none of the initially normal or ectatic aortas expanded to larger than 5 cm at a mean of 4 to 10 years of followup (Table 3).^138,^ ^148,^ ^165,^ ^167^ Three other studies report that some of the normal aortas did progress to large AAAs on rescreening. One study (N=223) reported that 1.3 percent of aortas initially measuring 2.5 to 2.9 cm expanded to larger than 5.0 cm at a mean of 5.9 years of followup,^121^ and one study (N=358) reported that 2.2 percent of aortas measuring 2.6 to 2.9 cm expanded to 5.5 cm or larger at 5.4-year mean followup.^123^ A large cohort from the Gloucestershire screening program (N=1,233) with longer followup reported that 14.7 percent of aortas measuring 2.6 to 2.9 cm expanded to 5.5 cm or larger at 7.8-year mean followup.^156^ The Gloucestershire publication provided estimates of large AAA development (≥5.5 cm) based on growth measurements after an initial measurement of 2.6 to 2.9 cm as follows: 0.5 percent at 5 years, 10.0 percent at 10 years, 28.0 percent at 15 years, and 25.6 percent at 20 years.

#### Effect of Rescreening on All-Cause and AAA-Related Mortality

Only four rescreening studies reported rates of all-cause mortality, finding variable results (Table 4). Two studies with 5-year followup and small sample sizes reported 5.0 percent (2/40) and 15.2 percent (5/33) mortality rates in persons with initial aortas of 2.5 to 2.9 cm.^167,^ ^169^ One of these studies additionally reported a 5.1 percent (136/2652) mortality rate among those with initial aortas of 2.5 cm or smaller.^169^ One study (N=1,233) of persons with an initial aortic diameter of 2.6 to 2.9 cm reported a high mortality rate (30.7%) among participants at mean 7.8-year followup.^156^ It is unclear how best to interpret these findings given the fact that most were not powered to detect differences in mortality and had followup time periods that were too short to fully evaluate health outcomes. Additionally, it is probable that mortality rates were confounded by variations in followup time and comorbidities contributing to competing causes of death unrelated to AAAs.

Five studies reported the incidence of AAA-related mortality in persons with normal or ectatic aortas.^121,^ ^138,^ ^156,^ ^167,^ ^169^ Rates were low overall and ranged from 0 to 2.4 percent (Table 4). Four of these studies with mean followup ranging from 4 to 5.9 years reported no AAA-related deaths.^121,^ ^138,^ ^167,^ ^169^ The Gloucestershire screening program (N=547) reported that 2.4 percent of participants had died of AAA-related causes by 10 years.^120,^ ^156^

#### Effect of Rescreening on AAA Rupture

Reported AAA rupture rates were low in participants with ectatic or “normal” aortas (Table 3). Four studies that included participants with an initial aortic diameter of 2.5 to 2.9 cm reported no ruptures at a mean of 4.0 to 5.9 years of followup.^121,^ ^138,^ ^167,^ ^169^ The Gloucestershire screening program (N=547) of patients with an initial aortic diameter of 2.6 to 2.9 cm and a median of 7.9-year followup reported that 2.4 percent had experienced a rupture.^120,^ ^156^ Three studies did not report rupture rates.^123,^ ^148,^ ^165^

#### AAA Procedures and Operative Mortality

AAA-related surgeries and operative mortality were rare (Tables 3 and 4). Four studies reported no AAA procedures at 4 to 5.9 years of followup;^121,^ ^138,^ ^167,^ ^169^ however, the Gloucestershire screening program reported that 11.5 percent of persons with initial aortic diameter of 2.6 cm to 2.9 cm had undergone a procedure by the median 7.9-year followup; 90 percent of these were elective surgeries.^120^ In this publication, 30-day operative mortality rate was 11.1 percent (7/63) after emergency and elective repair combined, with a 7.0 percent operative mortality after elective repair; most deaths occurred in those with ruptured aortas.^120^ Two studies reported no operative deaths^167,^ ^169^ (Table 4).

## KQ2a Do the Effects of Rescreening for AAA Vary Among Subpopulations (i.e., by Age, Sex, Smoking Status, Family History, or Race/Ethnicity)?

### Summary of Results

There were no trials available to examine the differential effectiveness of rescreening by subpopulation. Nearly all rescreening cohort studies were performed in Caucasian men and most did not perform subgroup analyses. Scant available data had low credibility. Only one good-quality rescreening study^138^ reported AAA-related health outcomes at 4 years and captured risk factor information; however, there were no AAA-related deaths or ruptures reported in this study. A single rescreening study among women (N=25)^167^ reported AAA-related health outcomes, but it was too small to make any comparisons with the other all-male studies. Two studies^138,^ ^169^ reported multivariable regression analyses suggesting that current smoking is an independent risk factor for the development of AAA at rescreening, and another study’s univariate analysis shows a similar trend for smoking status among women.^167^

### Study Details

Only four of the rescreening studies provided data on screening in subgroups.^138,^ ^165,^ ^167,^ ^169^ For all but one study,^138^ it was unclear whether the subanalyses were prespecified. Additionally, there was a lack of a proper control group in these studies and the overall study sizes were small, making the credibility of the subgroup analysis low. The conclusions about the effects of rescreening in subgroups were limited by lack of adequate reporting of health outcomes by subpopulation, as well as by the heterogeneity of study rescreening protocols and short followup times.

### Detailed Results

#### 3.0 cm AAA Incidence by Subgroup

Articles by Lederle et al^138^ (N=2,622) and Svensjo et al^169^ (n=2,059) examined numerous risk factors among participants (>10 risk factors). Both studies reported that current smoking was an independent risk factor for AAA development based on a multivariable regression analysis. Lederle et al found that current smokers were three times as likely as nonsmokers to develop AAAs (OR, 3.09 [95% CI, 1.74 to 5.50]). Other risk factors (including age, family history, race/ethnicity, and sex) were not found to be independently associated with AAA development. Similarly, in the article by Svenjo et al,^169^ current smoking was found to be independently associated with AAA development (OR, 2.78, [95% CI, 1.38 to 5.57]). In the Soderberg study (N=25), approximately half of participants who progressed from small AAAs to large AAAs at the 5-year rescreening were current smokers (7/12; p=0.01). The other ADAM subset study^121^ (N=223), however, reported that a multivariate logistic regression analysis did not identify any risk factors independently associated with the development of AAAs. The subset of the Chichester screening^165^ study showed that the screening yield among patients rescreened every 2 years diminishes with age and multiple repeat scans.

#### 5 cm or Larger AAA Incidence by Subgroup

The development of large AAAs in the rescreening trials was rarely reported by subpopulation. Lederle et al^138^ and Scott et al^165^ collected risk factor information, and both reported zero incident AAAs measuring 5 cm or larger at 4- and 10-year rescreening, respectively. Likewise, none of the aneurysms in the all-female Soderberg study^167^ progressed to 5.0 cm or larger at 5 years.

#### AAA-Related Health Outcomes by Subgroup

Of the eight rescreening studies, only the ADAM subset study^138^ collected risk factor information and reported health outcomes. Lederle et al reports AAA-related mortality by age, race/ethnicity, smoking history, and family history (along with >10 other patient characteristics), but there were zero AAA-related deaths or ruptures in the 4-year followup period among participants with initial aortas measuring smaller than 3.0 cm. Scott et al 2001^165^ reports AAA-related mortality by age but does not provide the denominator for the age groups provided. Therefore, no comparative analysis can be done. None of the studies reported within-study subgroup analyses by sex, although several studies recruited a single sex: one study included all women^167^ and five recruited all men.^123,^ ^148,^ ^156,^ ^165,^ ^169^ There was such substantial heterogeneity across these studies (e.g., rescreening intervals, followup time, and mean baseline aortic diameter) that comparisons across studies would not be appropriate.

## KQ3 What Are the Harms Associated With One-Time and Repeated Screening?

### Summary of Results

All four population-based screening RCTs (2 fair-quality, 2 good-quality) provide information on operative mortality and the number of surgeries for AAA, showing an increase in elective surgeries among the intervention group compared to the control group, but no difference in operative mortality.^12,^ ^15,^ ^113,^ ^147,^ ^168,^ ^170^ One new fair-quality population-based screening trial, VIVA,^22,^ ^146^ which looked at the impact of screening for multiple cardiovascular conditions, provides the number of elective and emergency operations among those screened. Overall, there were approximately 40 percent more surgeries in the invited group than in the control group (k=5; N=175,085; Peto OR, 1.44 [95% CI, 1.34 to 1.55]), which is largely driven by elective operations (k=5; N=175,085; Peto OR, 1.75 [95% CI, 1.61 to 1.90]). There was no statistically significant difference in 30-day mortality rates among the invited vs. control groups for either elective surgeries or emergency surgeries at 12- to 15-year followup.

Three small quality of life observational studies report mixed results.^141,^ ^150,^ ^174^ These studies, in addition to the two population-based screening RCTs that reported quality of life scores,^12,^ ^15,^ ^168,^ ^170^ generally showed no substantial differences in quality of life, anxiety, or depression scores between those who screened positive and those who were unscreened or screened negative for AAAs based on one-time screening.

### Study Characteristics

Four population-based AAA screening trials previously described for KQ1 also provide data on harms (Tables 1 and 2).^15,^ ^113,^ ^147,^ ^170^ These four RCTs were included in the previous review, with the addition of updated long-term followup data available from the Western Australia trial.^15^ One additional new multicomponent population-based Danish screening trial, VIVA, was included in this current review of harms to estimate elective surgeries.^146^ VIVA enrolled 50,156 men ages 65 to 74 years from 2008 to 2011. Participants were randomized to screening vs. no screening for hypertension, peripheral artery disease, and AAA. After screening, VIVA participants who had confirmed AAA or peripheral artery disease were counseled on the need to initiate preventive interventions including walking, smoking cessation, a low-fat diet, and cholesterol testing, with aspirin and statin therapy prescribed to those meeting a total cholesterol threshold value (Appendix E Tables 1 and 2).^146^ An interim analysis at a median of 4.4 years of followup reported number of operations, all-cause mortality, and AAA-related outcomes, including causes of death based on death certificates. The effects of AAA screening alone could not be independently assessed with respect to all-cause or AAA-mortality because there were multicomponent screening interventions administered; however, the number of surgeries were included in this review as these would almost exclusively be expected as a result of AAA screening.

One study (MASS) reported quality of life differences over time between screened and unscreened populations.^12,^ ^170^ This MASS subsample^12,^ ^170^ plus four additional studies measured various quality of life questionnaires for screened populations with and without AAA diagnoses, comparing prescreening baseline scores to repeated scores at 1 to 15 months after screening (Appendix E Tables 1 and 6).^15,^ ^141,^ ^150,^ ^168,^ ^174^ All of these quality of life studies were available in the previous review.^105^ Two studies were subsamples from the screened arms in the MASS (N=1,956; 599 AAAs, 631 normal aortas, 726 not invited for screening)^12,^ ^170^ and Western Australia (N=365; 120 AAAs, 245 normal aortas) trials;^15,^ ^168^ two additional observational comparisons were analyzed from population-based screening programs in Gloucestershire (N=161; 61 AAAs, 100 normal aortas)^150^ and Sweden (N=69; 24 AAAs, 45 normal aortas);^174^ and one small observational study analyzed screened participants in a rural Australian screening study (N=183 completed postscreening questionnaire; 35 AAAs, 89 normal aortas).^141^ The studies reported quality of life outcomes using the 36-Item Short-Form Health Survey (SF-36)^12,^ ^15,^ ^141,^ ^168,^ ^170,^ ^174^ and EuroQOL EQ-5D.^12,^ ^15,^ ^168,^ ^170^ Mood (anxiety or depression) was measured with the Hospital Anxiety and Depression scale (HADS),^15,^ ^141,^ ^168^ the General Health Questionnaire (GHQ),^150^ and an 80-point linear analogue anxiety scale.^150^ Questionnaires were administered prior to screening, after screening, or in selected subgroups of participants with screen-detected AAAs undergoing surgery or surveillance. Timing of questionnaires was up to 12 months after a specific event.

### Detailed Results

#### Operative Mortality

##### 30-Day Postoperative Mortality From Elective Surgery

Two of the four population-based screening trials report 30-day operative mortality from elective surgery, showing no difference among participants invited to screening and those in the control group (Table 2).^15,^ ^170^ The MASS^170^ and Western Australia^15^ trials reported no statistically significant difference in 30-day mortality from elective surgery between the invited and control groups at 12.8- to 13.1-year followup (n=1,827; MASS: RR, 0.76 [95% CI, 0.40 to 1.45]; Western Australia: RR, 0.82 [95% CI, 0.43 to 1.57]) (Figure 5).

Figure 5 Forest Plot of 30-Day Mortality (Male Only) Due to Elective and Emergency Surgery in One-Time Screening Trials

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; N = population size; n = sample size; RR = relative risk.

This figure is a forest plot of the effect of AAA screening on 30-day mortality due to elective and emergency surgery (male only) reported in one-time screening trials.

##### 30-Day Postoperative Mortality From Emergency Surgery

The MASS^170^ and Western Australia^15^ screening trials report 30-day operative mortality from emergency surgery and show similar results (Table 2). They showed no statistically significant difference in 30-day mortality from emergency surgery between the invited and control groups at 12.8- to 13.1-year followup (n=316; MASS: RR, 0.98 [95% CI, 0.68 to 1.43]; Western Australia: RR, 1.43 [95% CI, 0.90 to 2.25] (Figure 5).

#### Number of Operations

##### All AAA Operations

As would be expected, in all five screening trials,^15,^ ^113,^ ^146,^ ^147,^ ^170^ there were more AAA-related operations in the invited group than in the control group, with 1.1 to 2.9 percent of the screened group undergoing surgical repair (Table 1). Based on pooled data from the five trials (n=175,085), there were nearly 40 percent more surgeries in the invited group compared to the control group (Peto OR, 1.44 [95% CI, 1.34 to 1.55]; I^2^=74%) (Figure 4). We estimate that the screening program would increase the total number of operations per 1,000 men by 6 (95% CI, 5 to 8). Overall, the majority of operations in the screening group were elective, with few emergency surgeries reported. This pattern was not consistent across the studies, however, when examining the control group proportionality for elective and emergency surgery.

##### Elective Operations

Elective operations were consistently more common in the screened group than in the control group in all five trials,^15,^ ^113,^ ^146,^ ^147,^ ^170^ with surgery rates ranging from 1.0 to 2.8 percent in those screened vs. 0.4 to 2.2 percent in the control group (Table 1). The pooled analysis of these five trials (N=175,085) confirmed this finding and showed a higher elective operation rate in the screened group than in the control group (Peto OR, 1.75 [95% CI, 1.61 to 1.90]; I^2^=89%) (Figure 4). We estimate that screening 1,000 men for AAA would increase the number of elective operations by 8 procedures (95% CI, 6 to 9).

##### Emergency Operations

These outcomes are discussed under KQ1, benefits of screening.

#### Quality of Life

Results from five studies (n=2,734) were mixed but generally showed no substantial, long-term differences in quality of life, anxiety, or depression scores between participants who screened positive and negative for AAAs (Appendix E Table 6).^12,^ ^15,^ ^141,^ ^146,^ ^150,^ ^168,^ ^170,^ ^174^ Of note, the quality of life and mood scales administered in these studies have no established minimally clinically important differences in AAA populations. MASS (n=1,956) reported that SF-36 quality of life measures were similar between participants who screened positive for AAA at 6 weeks and unscreened controls.^12,^ ^170^ Compared with the screen-negative group, the group with screen-detected AAAs had statistically significantly poorer anxiety, physical health, mental health, and self-rated health and health index quality of life scores at 6 weeks, but all measures were within age-matched population norms. Further, comparisons between screen-detected participants undergoing surgery and surveillance showed initial differences at 3 months in the mental health component of the SF-36 and EQ-5D self-rating, but other measures were similar between the groups and the scores improved slightly by 12-month followup.

The Western Australia trial subsample (n=365) reported no statistically significant difference in self-perceived general health changes from baseline to 12-month followup between those with and without an AAA.^15,^ ^168^ Validated quality of life measures were only reported at 12 months for the screen-positive and screen-negative groups, with higher physical functioning in the screen-negative group but without changes from baseline comparisons between the groups provided. Similar findings were reported in a study of Swedish men and women (n=69).^174^ The study reported that even though participants who screened positive showed a statistically significant decrease from baseline in several SF-36 domains (i.e., physical functioning, social functioning, and mental health); SF-36 scores were not different at baseline or at 12 months after screening in those who screened positive compared to those who screened negative for AAAs. In the Gloucestershire Screening program (n=161),^150^ the group with screen-detected AAAs and normal aortas both had modest (up to 2 points out of an 28-point scale) reductions in anxiety levels based on GHQ scores 1 month after screening; there were no differences between the groups in prescreening scores, postscreening GHQ scores, or linear analogue anxiety scale scores. In a study conducted in rural Australia (n=183),^141^ only the screen-negative group had a statistically significant improvement in the SF-36 dimensions of general health, social function, and freedom from bodily pain, but SF-36 scores were not different 6 months after screening in participants with AAAs compared to those without AAAs. Small numbers make these results imprecise.

#### Rescreening Harms

There were no RCTs to assess the harms of rescreening vs. no rescreening in participants with normal sized aortas (<3.0 cm) on initial screening. No studies examined quality of life outcomes for rescreening.

Six fair-quality cohort studies examined procedure rates in rescreened cohorts.^121,^ ^138,^ ^148,^ ^156,^ ^167,^ ^169^ Five of these studies showed a low procedure rate (0% to 4%) up to 5-year followup; ^121,^ ^138,^ ^148,^ ^167,^ ^169^ a single study with a mean 7.8-year followup reported a higher rate of 10.9 percent (Table 3).^156^

## KQ3a Do the Harms of One-Time and Repeated Screening for AAA Vary Among Subpopulations (i.e., by Age, Sex, Smoking Status, Family History, or Race/Ethnicity)?

### Summary of Results

Overall, there is very little information on screening harms reported by subpopulation and what is reported has low credibility as it is unlikely to have been prespecified or powered to detect subpopulation differences. Available scant data from a single trial (Western Australia) suggest a trend of higher postoperative mortality after elective repair associated with screening (compared to no screening) in older age groups but no differential screening effect on number of operations by age.^15^

### Detailed Results

#### Operative Mortality

The Western Australia trial reported lower rates of 30-day postoperative mortality from elective AAA surgery attributed to screening (vs. no screening) in participants ages 65 to 74 years compared to the entire trial population age (64 to 83 years) (Appendix F Table 1).^15^ No statistical testing was performed to compare summary estimates (HRs and CIs) for age bands, nor was interaction testing performed to test differential treatment effects by age. Authors reported that 1.6 percent (6/368) died among the narrower age band (65 to 74 years), whereas 3.4 percent (18/536) of the entire study population died within 30 days of elective repair; unscreened control group 30-day mortality was 4.0 and 4.1 percent in the younger age band and entire trial population, respectively. This 30-day postoperative mortality trend was less pronounced for 30-day postoperative mortality following emergency surgery (Appendix F Table 1).

#### Number of Operations

The Western Australia trial reported no differential screening effect in the number of elective and emergency AAA surgeries attributed to screening (vs. no screening) in participants ages 65 to 74 years compared with those ages 64 to 83 years.^15^ For elective AAA surgery, authors report the similar relative rate of elective surgeries among the narrower age band compared to the entire study population for the screened and unscreened groups (screened: 2.77% vs. 2.78% in younger age band and entire study population, respectively; unscreened: 2.08% vs. 2.15% in the narrower age band and entire study population, respectively). This was similar to the findings for emergency surgery (screened: 0.11% vs. 0.14% in younger age band and entire study population, respectively; unscreened: 0.20% vs. 0.23% in narrower age band and entire study population, respectively) and overall number of operations (Appendix F Table 3).

While the Western Australia trial reported a subgroup analysis concluding that ever smokers had a higher rate of elective operations compared to never smokers (4.19% vs. 1.24%; OR, 3.47 [95% CI, 2.54 to 4.75]), this analysis did not provide comparative ORs for the unscreened group and therefore did not test the differential effect of screening by smoking status (Appendix F Table 4).^15^

#### Quality of Life

There is no information on quality of life reported for subpopulations.

## KQ4 What Are the Effects of Treatment (Pharmacotherapy or Surgery) on Intermediate and Health Outcomes in an Asymptomatic, Screen-Detected Population With Small AAAs (i.e., Aortic Diameter of 3.0 to 5.4 cm)?

### Summary of Results

Four trials evaluated the comparative effectiveness of early surgical repair vs. surveillance for small aneurysms (diameter of 4 to 5.4 cm): two evaluated the effectiveness of early open surgery^140,^ ^163^ and two evaluated early EVAR interventions.^118,^ ^158^ All four of these trials showed no difference in all-cause or AAA-related mortality between the intervention and control groups at up to 8 to 12 years for open repair^140,^ ^163^ and up to 2.6 years for EVAR.^118,^ ^158^

Seven pharmacotherapy efficacy trials examining antibiotics, antihypertensive medications, or mast cell stabilizers were identified in this updated review.^114,^ ^132,^ ^133,^ ^152,^ ^153,^ ^164,^ ^166^ In all included trials, pharmacotherapy intervention showed no overall impact on AAA growth compared to placebo. Conclusions are limited by a small number of trials evaluating each medication and trial durations, which were too short to expect the development of AAA-related events or changes in health outcomes.

### Study Characteristics

#### Early Open Surgery vs. Surveillance

Two good-quality RCTs^140,^ ^162^ evaluated the comparative effectiveness of open repair vs. surveillance for small AAAs. These two trials were available in the previous review.^105^ The ADAM trial^139,^ ^140^ (N=1,136) recruited participants from a U.S. Veteran Affairs (VA) AAA screening program from 1992 to 1997, who were ages 50 to 79 years with AAAs measuring 4.0 to 5.4 cm. The U.K. Small Aneurysm Trial (UKSAT)^75,^ ^115,^ ^128,^ ^130,^ ^161–163^ (N=1,090) recruited patients from 93 U.K.-based hospitals from 1991 to 1995, who were ages 60 to 76 years with AAAs measuring 4.0 to 5.5 cm. The mean age in these trials was 68.1 years, with nearly all men (99.2% men), and 69.3 years with mostly men (82.5% men) in ADAM and UKSAT, respectively. More than one-third of participants in both trials were current smokers. Additionally, ADAM reported that 12.9 percent of participants had a family history of AAA. There were a large proportion of participants in both trials with hypertension; however, CVD was higher in the ADAM trial (41.9% coronary disease, 12.4% cerebrovascular disease) than in UKSAT (14% probable ischemic heart disease). The mean baseline AAA diameters were similar in the trials (4.7 cm^140^ and 4.6 cm^162^), although measurement in ADAM was via CT measurement rather than ultrasound (Appendix E Tables 7 and 8).

The intervention group in both trials received open surgical repair by local surgeons using their usual clinical pre/intra/postoperative management within 6 weeks^140^ or 3 months^162^ of AAA identification. Fidelity to the assigned intervention arm was high with 520 patients (92.4%) in the UKSAT trial and 527 (92.6%) in the ADAM trial receiving procedures after a mean followup period of approximately 5 years. Control groups received surveillance every 3 to 6 months depending on AAA diameter. Participants in the surveillance arm were referred for surgical intervention if AAA reached 5.5 cm or rapidly increased by 1 cm/year, 0.7 cm in 6 months, or if symptoms developed. By the end of 5-year followup, 349 (61.6%) patients in the ADAM surveillance group and 321 (60.9%) patients in the UKSAT surveillance group had undergone open surgical repairs. By the end of 12-year followup, 401 (76.1%) patients in the UKSAT surveillance group had undergone open surgical repair.

Both studies actively managed patients for a mean of approximately 5 years (4.6 years UKSAT; 4.9 years ADAM).^140,^ ^162,^ ^163^ In addition to 5-year followup at the end of active management, the UKSAT trial reported results at 8 and 12 years.^161–163^ Followup rates were high, with more than 99 percent of patients followed up after 12 years in the UKSAT trial, and approximately 86 percent in the ADAM trial after 5 years for primary outcomes.^140,^ ^163^

#### Early EVAR vs. Surveillance

Two fair-quality RCTs (Comparison of Surveillance vs. Aortic Endografting for Small Aneurysm Repair [CAESAR],^118^ Positive Impact of endoVascular Options for Treating Aneurysm earLy [PIVOTAL] trial^158^) evaluated the impact of early EVAR compared to surveillance among patients with small aneurysms. These two trials were available in the previous review.^105^ CAESAR (N=360) recruited participants from 20 European and Western Asian hospitals from 2004 to 2008, ages 50 to 79 years with AAAs measuring 4.1 to 5.4 cm.^117,^ ^118^ PIVOTAL (N=728) recruited participants from 70 U.S. sites from 2005 to 2010, ages 40 to 90 years with AAAs measuring 4.0 to 5.0 cm. The mean age was similar in both trials (68.9 vs. 70.5 years),^157,^ ^158^ and the majority of participants were men (95.8% [CAESAR] and 86.6% [PIVOTAL]). Mean AAA diameters were 4.7 cm [CAESAR] and 4.4 cm [PIVOTAL]. Notably, there was a higher proportion of smoking patients and patients with coronary artery disease in the PIVOTAL trial compared to CAESAR (smoking: 91.0% vs. 55.3%; coronary artery disease: 55.4% vs. 39.2%, respectively) (Appendix E Tables 7 and 8).

In the intervention group, patients received EVAR as soon as possible (CAESAR)^118^ or within 30 days (PIVOTAL)^158^ of randomization. The control group received surveillance every 6 months and were offered surgery when AAAs reached 5.5 cm or enlarged at a rate of 1 cm or larger/year (CAESAR) or 0.5 cm or larger/6 months (PIVOTAL), or if aneurysms became symptomatic (CAESAR) (Appendix E Table 7). Fidelity to the assigned intervention was high with 322 patients (88.9%) allocated to the early EVAR group receiving EVAR procedures in the PIVOTAL trial, and 171 (94.0%) receiving early EVAR in CAESAR. In each trial, four patients received open surgery instead of EVAR in the early EVAR group. Of patients randomized to surveillance, 71 (39.9%) in the CAESAR trial and 108 (30.1%) in the PIVOTAL trial received EVAR by the end of followup (Table 8).

The CAESAR trial reported results at a median followup of 2.6 years,^118^ and the PIVOTAL trial reported results at 1.7-year mean followup.^158^ Both RCTs conducted interim analyses and found that detection of meaningful difference in primary outcomes between EVAR and surveillance was unlikely if patient enrollment were to continue (i.e., futility).^118,^ ^158^ Thus, both trials subsequently stopped recruiting patients early, but they completed scheduled followups in those who had already been enrolled. Likely because of early stopping of enrollment, the two studies did not adequately achieve balance between randomized arms in important prognostic factors such as family history, sex, and diabetes.

### Detailed Results

#### Open Repair vs. Surveillance

##### All-Cause Mortality

Both trials found no significant differences in all-cause mortality at any followup time between participants receiving early open repair vs. surveillance (Table 5).^140,^ ^162,^ ^163^ At 5-year followup, the ADAM trial reported slightly more deaths in the intervention group than in the control group (25.1% vs. 21.5%; RR, 1.21 [95% CI, 0.95 to 1.54]),^140^ while UKSAT reported slightly more deaths among those in the control group (30.6% vs. 46.7%, RR, 0.91 [95% CI, 0.72 to 1.16]),^162,^ ^163^ but neither finding was statistically significant. At 12-year followup, UKSAT reported a similar trend; however, the difference was not statistically significant (adjRR, 0.88 [95% CI, 0.75 to 1.02]). An individual patient data meta-analysis (n=2,226) of patients randomized to both trials showed no survival benefit at approximately 5 years in both the unadjusted (HR, 0.96, [95% CI, 0.81 to 1.14]) and adjusted analyses (HR, 0.99, [95% CI, 0.83 to 1.18]).^126^

Table 5 All-Cause and AAA-Related Mortality Data for Open vs. Surveillance Trials for Small AAA (KQ4)

Study, Year; Quality | Mean Followup, years | Treatment Group | N Analyzed | All-Cause Mortality, n (%) | HR (95% CI) | RR (95% CI)^*^ | AAA-Related Mortality, n (%) | HR (95% CI) | RR (95% CI)^*^
Lederle, 2002^140^; ADAM; Good | 4.9 | IG | 569 | 143 (25.1) | 1.21 (0.95 to 1.54)^†^ | 1.17 (0.95 to 1.44) | 17 (3.0) | 1.15 (0.58 to 2.31)^†^ | 1.13 (0.57 to 2.24)
Lederle, 2002^140^; ADAM; Good | 4.9 | CG | 567 | 122 (21.5) | 1.21 (0.95 to 1.54)^†^ | 1.17 (0.95 to 1.44) | 15 (2.6) | 1.15 (0.58 to 2.31)^†^ | 1.13 (0.57 to 2.24)
Powell, 2007^162,^ ^163^; UKSAT; Good | 4.6 | IG | 563 | 159 (30.6) | 0.91 (0.72 to 1.16) | 0.99 (0.82 to 1.20) | 32 (5.7) | NR | 0.86 (0.54 to 1.36)
Powell, 2007^162,^ ^163^; UKSAT; Good | 4.6 | CG | 527 | 150 (46.7) | 0.91 (0.72 to 1.16) | 0.99 (0.82 to 1.20) | 35 (6.6) | NR | 0.86 (0.54 to 1.36)
Powell, 2007^162,^ ^163^; UKSAT; Good | 12 | IG | 563 | 362 (64.3) | 0.88 (0.75 to 1.02)ǂ | 0.96 (0.88 to 1.05) | 36 (6.9) | NR | 0.67 (0.45 to 1.02)
Powell, 2007^162,^ ^163^; UKSAT; Good | 12 | CG | 527 | 352 (66.8) | 0.88 (0.75 to 1.02)ǂ | 0.96 (0.88 to 1.05) | 50 (9.5) | NR | 0.67 (0.45 to 1.02)

* Calculated.

† Author-reported RR.

ǂ Primary adjustment made for age, sex, initial AAA diameter, smoking status, mean of left and right ankle brachial pressure indices, and forced expiratory volume in 1 s and aspirin use (missing values for 33 patients).

Abbreviations: AAA = abdominal aortic aneurysm; ADAM = Abdominal aortic aneurysm Detection and Management study; CG = control group; CI = confidence interval; HR = hazard ratio; IG = intervention group; N = population size; n = sample size; NR = not reported; RR = relative risk; UKSAT = the UK Small Aneurysm Trial.

##### AAA-Related Mortality

Similar to the findings for all-cause mortality, both trials found no significant differences in AAA-related mortality at any followup time period (Table 5).^140,^ ^162,^ ^163^ At 5-year followup, the ADAM trial reported nearly identical rates of AAA-related mortality among participants who received open repair vs. surveillance (3.0% vs. 2.6%; HR, 1.15 [95% CI, 0.58 to 2.31]).^140^ Mortality rates in UKSAT were slightly higher at 5 years of followup and more deaths were observed in the surveillance group compared to the group receiving surgery, but the difference was not significant (5.7% [IG] vs. 6.6% [CG]; RR, 0.86 [95% CI, 0.54 to 1.36]).^162,^ ^163^ At 12 years of followup, UKSAT reports an AAA-related mortality rate of 6.9 percent in the intervention group and 9.5 percent in the surveillance group.^163^

##### Rupture

Ruptures were rare events in both trials; however, early open repair significantly reduced the rate of rupture compared to the group undergoing surveillance at each followup interval (Table 6).^140,^ ^162,^ ^163^ The ADAM trial reported a rupture rate of 0.4 percent in the early intervention group compared to 1.9 percent in the surveillance group (RR, 0.18 [95% CI, 0.04 to 0.81]).^140^ Rates were slightly higher in UKSAT at 5-year followup but remain significantly different between treatment groups (1.2% vs. 3.2%; RR, 0.33 [95% CI, 0.13 to 0.83]).^162,^ ^163^ At 12 years of followup, UKSAT reported that 2.3 percent of the early surgery group and 4.5 percent of the surveillance group experienced AAA rupture (RR, 0.51 [95% CI, 0.26 to 0.99]).^163^

Table 6 AAA Growth Rate, Rupture, and Surgery Data for Open vs. Surveillance Trials for Small AAAs (KQ4 and KQ5)

Study, Year; Quality | Mean Followup, years | Treatment Group | N Analyzed | Mean AAA Growth Rate, mm/year (IQR) | AAA Rupture, n (%) | RR (95% CI)^*^ | All AAA Procedures, n (%) | Elective Surgery, n (%) | Emergency Surgery, n (%)
Lederle, 2002^140^; ADAM; Good | 4.9 | IG | 569 | NA | 2 (0.4) | 0.18 (0.04 to 0.81) | 527 (92.6) | NR | NR
Lederle, 2002^140^; ADAM; Good | 4.9 | CG | 567 | 3.2 (1.6 to 4.2)^†^ | 11 (1.9) | 0.18 (0.04 to 0.81) | 349 (61.6) | NR | NR
Powell, 2007^162,^ ^163^; UKSAT; Good | 4.6 | IG | 563 | NA | 6 (1.2) | 0.33 (0.13 to 0.83) | 520 (92.4) | 517 (91.8) | 3 (0.5)
Powell, 2007^162,^ ^163^; UKSAT; Good | 4.6 | CG | 527 | 3.3 (2.0 to 5.3)^ǂ^ | 17 (3.2) | 0.33 (0.13 to 0.83) | 321 (60.9) | NR | NR
Powell, 2007^162,^ ^163^; UKSAT; Good | 12 | IG | 563 | NR | 13 (2.3)^§^ | 0.51 (0.26 to 0.99) | 528 (93.8) | 525 (93.3) | 3 (0.5)
Powell, 2007^162,^ ^163^; UKSAT; Good | 12 | CG | 527 | NR | 24 (4.5) | 0.51 (0.26 to 0.99) | 401 (76.1) | 395 (75.0) | 6 (1.1)

* Calculated.

† Average growth at 3 years.

ǂ Median.

§ Deaths from ruptures, plus two additional deaths whose group was not reported.

Abbreviations: AAA = abdominal aortic aneurysm; ADAM = Abdominal aortic aneurysm Detection and Management study; CI = confidence interval; HR = hazard ratio; IQR = interquartile range; mm = millimeter; N = population size; n = sample size; NA = not applicable; NR = not reported; RR = relative risk; UKSAT = the UK Small Aneurysm Trial.

##### All Operations

As expected, overall there were more surgical interventions in the early surgery groups than in the surveillance group (Table 6). The ADAM trial reported only overall procedures (IG: 92.6% vs. CG: 61.6%) and did not break them down into emergency vs. elective.^140^ In UKSAT, the majority of surgical interventions were elective at each followup timepoint.^162,^ ^163^ At 12 years of followup, there were notably fewer emergency surgeries in the early surgery group compared to the group undergoing surveillance (3 [0.5%] vs. 6 [1.1%]), but emergency surgeries overall were rare.^163^

#### Early EVAR vs. Surveillance

##### All-Cause Mortality

Both EVAR trials found no significant differences in all-cause mortality at 1.7- to 2.6-year followup between participants receiving early EVAR and those undergoing surveillance (Table 7).^118,^ ^158^ At 2.6 years, CAESAR reports similar rates of all-cause mortality between treatment groups (5.5% vs. 4.5%), with an HR (CG vs. IG) of 0.76 (95% CI, 0.30 to 1.93).^118^ Likewise, PIVOTAL found no difference in all-cause mortality between participants receiving early EVAR vs. surveillance at 1.7 years (4.1% vs. 4.1%; HR, 1.01 [95% CI, 0.49 to 2.07]).^158^

Table 7 All-Cause and AAA-Related Mortality Data for EVAR vs. Surveillance Trials for Small AAA (KQ4)

Study, Year; Quality | Mean Followup, years | Treatment Group | N Analyzed | All-Cause Mortality, n (%) | HR (95% CI) | RR (95% CI)^*^ | AAA-Related Mortality, n (%) | HR (95% CI) | RR (95% CI)^*^
Cao, 2011^118^; CAESAR; Fair | 2.6^†^ | IG | 182 | 10 (5.5) | 0.76 (0.30 to 1.93)^ǂ^ | 1.22 (0.49 to 3.03) | 1 (0.5) | NR | 0.98 (0.06 to15.52)
Cao, 2011^118^; CAESAR; Fair | 2.6^†^ | CG | 178 | 8 (4.5) | 0.76 (0.30 to 1.93)^ǂ^ | 1.22 (0.49 to 3.03) | 1 (0.6) | NR | 0.98 (0.06 to15.52)
Ouriel, 2010^158^; PIVOTAL; Fair | 1.7 | IG | 366 | 15 (4.1) | 1.01 (0.49 to 2.07) | 0.99 (0.49 to 1.99) | 2 (0.5) | NR | 1.98 (0.18 to 21.72)
Ouriel, 2010^158^; PIVOTAL; Fair | 1.7 | CG | 362 | 15 (4.1) | 1.01 (0.49 to 2.07) | 0.99 (0.49 to 1.99) | 1 (0.3) | NR | 1.98 (0.18 to 21.72)

* Calculated.

† Median.

ǂ CG vs. IG.

Abbreviations: AAA = abdominal aortic aneurysm; CAESAR = Comparison of surveillance versus Aortic Endografting for Small Aneurysm Repair; CG = control group; CI = confidence intervals; EVAR = endovascular aneurysm repair; HR = hazard ratio; IG: intervention group; N = population size: n = sample size; NA = not applicable; NR = not reported; PIVOTAL = Positive Impact of Endovascular Options for Treating Aneurysms Early; RR = relative risk.

##### AAA-Related Mortality

Similar to the findings for all-cause mortality, both trials found no significant difference in AAA-related mortality at any followup time period (Table 7).^118,^ ^158^ Events were rare and findings in both trials were nearly identical in each treatment group (1 [0.5%] vs. 1 [0.6%] in CAESAR; 2 [0.5%] vs. 1 [0.3%] in PIVOTAL). The relative risks were nonsignificant, with wide CIs. Conclusions are limited by low event rates.

##### Rupture

Ruptures were rarely reported in either trial, making comparisons challenging (Table 8). Both trials report zero ruptures among participants receiving early EVAR and few events among those undergoing surveillance (2 [1.1%] in CAESAR; 1 [0.3%] in PIVOTAL).^118,^ ^158^

Table 8 AAA Growth Rate, Rupture, and Surgery Data for EVAR vs. Surveillance Trials for Small AAAs (KQ4 and KQ5)

Study, Year; Quality | Mean Followup, years | Treatment Group | N Analyzed | AAA Growth Rate, mm/year | AAA Rupture, n (%) | All AAA Procedures, n (%) | Elective Surgery (EVAR), n (%) | Emergency Surgery, n (%)
Cao, 2011^118^; CAESAR; Fair | 2.6^¶^ | IG | 182 | NR | 0 | 175 (96.2) | 171 (94.0)^†^ | NR
Cao, 2011^118^; CAESAR; Fair | 2.6^¶^ | CG | 178 | 1.5^*^ | 2 (1.1) | 85 (47.8) | 71 (39.9)^‡^ | NR
Ouriel, 2010^158^; PIVOTAL Fair | 1.7 | IG | 366 | NR | 0 | 326 (89.1) | 322 (88.9)^§^ | NR
Ouriel, 2010^158^; PIVOTAL Fair | 1.7 | CG | 362 | NR | 1 (0.3) | 112 (30.9) | 108 (30.1)^║^ | 1 (0.3)

* Mean increase in patients who were never repaired (at time of analysis).

† 4 patients (2.3%) received repair via open surgery.

‡ 14 patients (7.9%) received repair via open surgery.

§ 5 patients (1.4%) received repair via open surgery.

║ 3 patients (0.8%) received repair via open surgery.

¶ Median.

Abbreviations: AAA = abdominal aortic aneurysm; CAESAR = Comparison of surveillance versus Aortic Endografting for Small Aneurysm Repair; CG = control group; CI = confidence intervals; EVAR = endovascular aneurysm repair; IG: intervention group; mm = millimeter; N = population size: n = sample size; NA = not applicable; NR = not reported; PIVOTAL = Positive Impact of Endovascular Options for Treating Aneurysms Early.

##### All Operations

Again, as anticipated, there were more total surgical interventions in the early surgery groups than in the surveillance groups (Table 8). In both trials, the majority of surgeries were elective. with more elective surgeries reported in the intervention groups (CAESAR: 94.0% vs 39.9%; PIVOTAL: 88.9% vs 30.1% received surgery).^118,^ ^158^ Emergency surgeries were rare events. PIVOTAL reported only a single emergency surgery in the surveillance group, and there was mention of emergency surgeries in the early EVAR group. CAESAR did not report emergency surgeries as an outcome.

### Pharmacotherapy vs. Placebo

#### Study Characteristics

Three good-quality^114,^ ^132,^ ^164^ and four fair-quality^133,^ ^152,^ ^153,^ ^166^ placebo-controlled RCTs investigated the effectiveness of antibiotics, antihypertensives, or mast cell stabilizers on small AAA growth. These trials, conducted in Finland,^153^ Denmark,^131,^ ^132,^ ^166,^ ^172^ Sweden,^133,^ ^166^ the Netherlands,^152^ the United Kingdom,^114,^ ^136,^ ^166^ and Canada,^164^ recruited participants from vascular referral centers, as well as from community/population screening programs, who had small AAAs ranging from 3 or 3.5 cm to 4.9 or 5.4 cm in diameter. Three of these trials^114,^ ^152,^ ^166^ are new since the previous review. The mean AAA diameter at baseline ranged from 3.3 to 4.4 cm (Appendix E Table 8).

The trials recruited mostly men, with women comprising 0 to 18.5 percent of the trial participants (Appendix E Table 8). The mean age ranged from 68.4 to 72.5 years and the mean percent of current smokers in the trials ranged from 25 to 60 percent. Only two trials reported the proportion of participants with a positive family history for AAA as 14 percent^133^ and 25.2 percent.^152^ The history of CVD was prevalent in the studies, ranging from approximately one-third to one-half of participants in the trials reporting this baseline characteristic. Sample sizes ranged from 32^153^ to 552.^164^

All but one included trial examined the role of either antibiotics or antihypertensives on AAA growth compared to placebo—four trials studied the effects of antibiotics on AAA growth^132,^ ^133,^ ^152,^ ^153^ and two studied antihypertensive medication effects on growth.^114,^ ^164^ Of the trials of antibiotics, two examined macrolide antibiotics (roxithromycin 300 mg daily for 28 days,^131,^ ^132,^ ^172^ azithromycin 600 mg daily for 3 days followed by 600 mg once per week for 15 weeks)^133^ and two of these trials studied doxycycline at different doses (100 mg^152^ or 150 mg^153^ daily for 3 to 18 months). There were two antihypertensive trials; one used propranolol 20 mg twice per day titrated up to a target dose of 80 to 120 mg twice per day for 2.5 years^164^ and one administered an ACE inhibitor, (perindopril 10 mg daily) or a calcium channel blocker (amlodipine 5 mg daily) for 2 years.^114,^ ^136^ The final trial examined a mast cell inhibitor (pemirolast 40 mg twice daily).^166^ The treatment duration ranged from 28 days^132^ to 2.5 years.^164^ The control group received a matching placebo in all trials (Appendix E Table 8).

The seven trials’ primary outcome was AAA growth. Two antibiotic trials of azithromycin and doxycycline^133,^ ^153^ reported the median and interquartile range of annual growth rates, while the other five trials reported the mean annual growth rate of the aneurysm (mm/year).^114,^ ^132,^ ^152,^ ^164,^ ^166^ Ultrasound measurements were performed using aortic anterior-posterior diameters in all trials, with four using the larger of the axial or transverse measurement planes.^132,^ ^133,^ ^153,^ ^166^ Only one trial (Propranolol Anuerysm Trial [PAT]) reported using outer-to-outer wall measurements, while one trial reported using the external diameter measured in the longitudinal plane^114,^ ^136^ and another reported using the anterior posterior diameter from inner to inner wall.^152^ Two trials clearly reported a standard AAA size threshold for surgical repair; PAT^164^ and Hogh et al^131,^ ^132,^ ^172^ referred all AAAs measuring 5 cm or larger to surgery. The assumption for the remainder of studies is that repair was performed according to local standard clinical practice. Only two trials measured patient adherence to medications with pill counts (Appendix E Table 7).^114,^ ^152^ Followup time in the trials was 1 to 5 years. Additionally, two of the trials reported quality of life outcomes using Screen QOL^142^ or SF-36^164^ scales (see KQ5 harms).

#### Detailed Results

##### AAA Growth Rates

All seven trials reported no significant beneficial impact of pharmacotherapy on AAA growth (Table 9).^114,^ ^131–133,^ ^136,^ ^152,^ ^153,^ ^164,^ ^166,^ ^172^ One trial of doxycycline compared with placebo reported that the intervention group had a statistically significantly greater growth in aneurysm size compared with those taking placebo (4.1 vs. 3.3 mm; difference, 0.8 mm [95% CI, 0.1 to 1.4 mm]).^152^ This trial included participants with larger AAAs who were unfit for surgery. The remaining six trials showed no statistically significant difference in growth rates between the intervention and control groups.^114,^ ^132,^ ^133,^ ^153,^ ^164,^ ^166^ Four of these trials^114,^ ^132,^ ^153,^ ^164^ showed a nonsignificant lower mean growth rate in the intervention group, with differences ranging from 0.5 mm/year^164^ to 1.5 mm/year.^153^ Conversely, one trial showed identical mean growth rates of 2.2 mm/year (median interquartile range) in the intervention and control groups,^133^ and one trial of pemirolast showed a nonsignificant greater aneurysm growth rate in the intervention group compared to those taking placebo (2.71 vs. 2.04 mm/year).^166^

Table 9 AAA Growth Rate, Rupture, and Surgery Data for Pharmacotherapy vs. Placebo Trials for Small AAAs (KQ4 and KQ5)

Study, Year; Quality | Comparison | Mean Followup, years | Treatment Group | N Analyzed | Mean AAA Growth Rate, mm/year | AAA Rupture, n (%) | All AAA Procedures, n (%) | Elective Surgery, n (%) | Emergency Surgery, n (%)
Bicknell, 2016^114^; AARDVARK; Good | Perindopril (IG1) or amlodipine (IG2) vs. placebo | 2 | IG1 | 73 | 1.77 (0.2)^**^ | 0 (0) | 10 (13.7)^††^ | NR | NR
Bicknell, 2016^114^; AARDVARK; Good | Perindopril (IG1) or amlodipine (IG2) vs. placebo | 2 | IG2 | 72 | 1.81 (0.2)^**^ | 0 (0) | 11 (15.3)^††^ | NR | NR
Bicknell, 2016^114^; AARDVARK; Good | Perindopril (IG1) or amlodipine (IG2) vs. placebo | 2 | CG | 79 | 1.68 (0.2)^**^ | 0 (0) | 11 (13.9)^††^ | NR | NR
Hogh 2009^132^; Good | Roxithromycin vs. placebo | 5 | IG | 42 | 1.16^¶^ | NR | 29 (34.5)^#^ | 29 (34.5)^#^ | NR
Hogh 2009^132^; Good | Roxithromycin vs. placebo | 5 | CG | 42 | 2.52^¶^ | NR | 29 (34.5)^#^ | 29 (34.5)^#^ | NR
Karlsson 2009^133^; Fair | Azithromycin vs. placebo | 1.5 | IG | 106 | 2.2 (0.12 to 0.36)^§^ | 1 (0.94) | 16 (15.1) | 15 (14.1)^‡^ | 1 (0.9)^‡^
Karlsson 2009^133^; Fair | Azithromycin vs. placebo | 1.5 | CG | 105 | 2.2 (0.09 to 0.34)^§^ | NR | 13 (12.4) | NR | NR
Meijer, 2013^152^; Fair | Doxycycline vs. placebo | 1.5 | IG | 144 | 4.1 (3.6 to 4.5)^‡‡^ | 0 (0) | 21 (14.6) | 21 (14.6) | 0 (0)
Meijer, 2013^152^; Fair | Doxycycline vs. placebo | 1.5 | CG | 142 | 3.3 (2.8 to 3.7)^‡‡^ | 2 (1.4) | 24 (16.9) | 22 (15.5) | 2 (1.4)
Mosorin 2001^153^; Fair | Doxycycline vs. placebo | 1.5 | IG | 17 | 1.5 (0.0 to 3.0)^†^ | 1 (5.9) | 3 (17.6) | 2 (11.8) | 1 (5.9)
Mosorin 2001^153^; Fair | Doxycycline vs. placebo | 1.5 | CG | 15 | 3.0 (0.3 to 6.0)^†^ | 0 (0) | 6 (40.0) | 6 (40.0) | 0 (0)
PAT Investigators, 2002^164^; PAT Good | Propranolol vs. placebo | 2.5 | IG | 276 | 2.1 (0.29)^*^ | 1 (0.4) | 57 (20.6) | 56 (20.3) | 1 (0.4)
PAT Investigators, 2002^164^; PAT Good | Propranolol vs. placebo | 2.5 | CG | 272 | 2.6 (0.30)^*^ | 2 (0.7) | 74 (27.2) | 72 (26.5) | 2 (0.7)
Sillensen, 2015^166^; AORTA; Fair | Pemirolast vs. placebo | 1 | IG | 84 | 2.71 (2.25 to 3.16)^§§^ | 0 (0) | 6 (7.1) | NR | NR
Sillensen, 2015^166^; AORTA; Fair | Pemirolast vs. placebo | 1 | CG | 84 | 2.04 (1.58 to 2.50)^§§^ | 0 (0) | 2 (2.4) | NR | NR

* While patients were taking the study drug assigned; values reported as mean growth rate (SD); p=0.10.

† Median (IQR); p-value was not significant.

‡ Assumed.

§ Median (IQR); p=0.85.

¶ p=0.055.

# Total referred to surgery because AAA was >5.0 cm (treatment group NR).

** Mean (SE), difference not significant (IG1, p=0.78; IG2, p=0.68).

†† Number of patients reaching 5.5 cm or being referred to/having surgery.

‡‡ Mean (95% CI), based on a linear mixed model and adjusted for incomplete data. Mean between-group difference (95% CI): 0.8 mm (0.1 to 1.4 mm); p = 0.016.

§§ Adjusted mean change (95% CI); p=0.189; doses of 10 and 25 mg are also reported; there was no significant difference in growth rate found between treatment groups.

Abbreviations: AAA = abdominal aortic aneurysm; AARDVARK = Aortic Aneurysmal Regression of Dilation: Balue of ACE-Inhibition on RisK trial; AORTA = the Anti-inflammatory Oral Treatment of AAA; CG = control group; IG = intervention group; IQR = interquartile range; N = population size; n = sample size; NR = not reported; PAT = propranolol Aneurysm Trial; SD = standard deviation; SE = standard error; vs = versus.

##### All-Cause Mortality

Few studies reported the impact of pharmacotherapy on all-cause mortality, and those that did found mixed trends without statistical significance (Table 10). Three antibiotic trials^133,^ ^152,^ ^153^ and one beta-blocker trial^164^ report rates of all-cause mortality. PAT reported a higher mortality rate among participants in the treatment group compared to those taking placebo; however, the difference was nonsignificant (12% vs. 9.6%; p=0.36).^164^ This same trend was reported in the study of doxycycline by Mosorin et al (23.5% vs. 20.0%; significance not reported).^153^ In the remaining studies, there were more deaths observed in the control group; however, these events overall were too rare to make any conclusions about effects on all-cause mortality at 1.5- to 2.5-year followup.

Table 10 All-Cause and AAA-Related Mortality Data for Pharmacotherapy vs. Placebo Trials for Small AAA (KQ4)

Study, Year; USPSTF Quality | Comparison | Mean Followup, years | Treatment Group | N Analyzed | All-Cause Mortality, n (%) | HR (95% CI) | AAA-Related Mortality, n (%) | HR (95% CI)
Hogh 2009^132^; Good | Roxithromycin vs. placebo | 5 | IG | NR | NR | NR | NR | NR
Hogh 2009^132^; Good | Roxithromycin vs. placebo | 5 | CG | NR | NR | NR | NR | NR
Karlsson 2009^133^; Fair | Azithromycin vs. placebo | 1.5 | IG | 106 | 5 (4.7) | NR | 0 | NR
Karlsson 2009^133^; Fair | Azithromycin vs. placebo | 1.5 | CG | 105 | 8 (7.6) | NR | 0 | NR
Meijer, 2013^152^; Fair | Doxycycline vs. placebo | 1.5 | IG | 144 | 2 (1.4) | NR | 0 (0) | NR
Meijer, 2013^152^; Fair | Doxycycline vs. placebo | 1.5 | CG | 142 | 5 (3.5) | NR | 1 (0.7) | NR
Mosorin 2001^153^; Fair | Doxycycline vs. placebo | 1.5 | IG | 17 | 4 (23.5)^*^ | NR | NR | NR
Mosorin 2001^153^; Fair | Doxycycline vs. placebo | 1.5 | CG | 15 | 3 (20.0)^*^ | | NR
PAT Investigators, 2002^164^; PAT; Good | Propranolol vs. placebo | 2.5 | IG | 57 | 33 (12.0) | NR | 2 (0.7) | NR
PAT Investigators, 2002^164^; PAT; Good | Propranolol vs. placebo | 2.5 | CG | 74 | 26 (9.6) | NR | 2 (0.7) | NR
Bicknell, 2016^114^; AARDVARK; Good | Perindopril (IG1) or amlodipine (IG2) vs. placebo | 2 | IG1 | 73 | NR | NR | NR | NR
Bicknell, 2016^114^; AARDVARK; Good | Perindopril (IG1) or amlodipine (IG2) vs. placebo | 2 | IG2 | 72 | NR | NR | NR | NR
Bicknell, 2016^114^; AARDVARK; Good | Perindopril (IG1) or amlodipine (IG2) vs. placebo | 2 | CG | 79 | NR | NR | NR | NR
Sillensen, 2015^166^; AORTA; Fair | Pemirolast vs. placebo | 1 | IG | 84 | NR | NR | NR | NR
Sillensen, 2015^166^; AORTA; Fair | Pemirolast vs. placebo | 1 | CG | 84 | NR | NR | NR | NR

* Defined as being “unrelated to aneurysm.”

Abbreviations: AAA = abdominal aortic aneurysm; AARDVARK = Aortic Aneurysmal Regression of Dilation: Value of ACE-Inhibition on RisK trial; AORTA = the Anti-inflammatory Oral Treatment of AAA; CG = control group; IG = intervention group; N = population size; n = sample size; NR = not reported; PAT = propranolol Aneurysm Trial; vs = versus.

##### AAA-Related Mortality

Again, few studies reported the impact of pharmacotherapy on AAA-related mortality and those that did found mixed results (Table 10). Only three trials—two antibiotic trials^133,^ ^152^ and one beta-blocker trial^164^—reported this outcome. Two of the three trials report the same number of events between treatment groups, while one trial reports a slightly higher rate among those taking placebo.^152^ Events overall were rare (0 to 2 events in each group), thereby limiting conclusions.

##### AAA Rupture

Five trials reported instances of AAA rupture between treatment groups and again found mixed results (Table 9).^114,^ ^152,^ ^153,^ ^164,^ ^166^ The event rates were very low in these trials; two trials reported no ruptures in both the intervention and control groups,^114,^ ^166^ and three trials had 0 to 2 events in each group (control group rates, 0% to 1.4%), making it difficult to make conclusions about the medication’s effect on rupture at 1- to 2.5-year followup.

##### All Operations

Total AAA-related procedures are reported in all seven pharmacotherapy trials; however, only five specify surgeries as emergency or elective procedures.^132,^ ^133,^ ^152,^ ^153,^ ^164^ Results showed a mixed pattern and statistical testing was not performed. Rates of total AAA-related procedures varied widely by study (range, 2% to 40% in control groups), with two studies^133,^ ^166^ reporting more surgeries in the intervention group, three studies^152,^ ^153,^ ^164^ reporting more surgeries in the control group, and one study^114^ reporting nearly identical rates of surgery in the intervention and control groups (Table 9). One trial did not report procedures by treatment group.^132^

Two doxycycline trials^152,^ ^153^ and one propranolol trial^164^ reported elective AAA surgeries with mixed results (Table 9). One doxycycline study^152^ reported similar rates of elective surgeries between treatment groups (IG: 14.6% vs. CG: 15.5%), while the other doxycycline trial^153^ reported more elective repairs in the control group compared to the intervention group (IG: 11.8% vs. CG: 40%; statistical information not reported). Similarly, PAT reported more elective surgeries in the control group than in the treatment group (20.3% vs. 26.5%; statistical information not reported).^164^

The same three studies reporting elective surgeries also reported emergency surgeries, finding mixed results. (Table 9).^152,^ ^153,^ ^164^ These emergency surgeries were rare, with 0 to 2 events in each group (0% to 1.4% in the control groups), again limiting conclusions about these medications’ effects on emergency surgery rates at 1.5- to 2.5-year followup.

## KQ4a Do the Effects of Treatment of Small AAAs Vary Among Subpopulations (i.e., by Age, Sex, Smoking Status, Family History, or Race/Ethnicity)?

### Summary of Results

Subpopulation information was rarely reported among treatment studies for small AAAs. For trials of early intervention via open surgery compared to surveillance, the available trials reported limited data on the subpopulations of sex, age, and smoking status. Only UKSAT, with a 12-year followup, and the individual patient data meta-analysis, which pooled 5- to 8-year followup data from ADAM and UKSAT, reported all-cause mortality by sex, finding no differential effect.^126,^ ^162,^ ^163^ Both trials reported the impact of age on all-cause mortality, utilizing slightly different age cutoffs, but did not report differential all-cause mortality treatment effect by age at 4.9 and 12-year followup. UKSAT reported no differences in all-cause mortality by smoking status but did not report outcomes in smokers for each treatment arm, so no conclusions could be made about differential treatment effect of early surgery by smoking status. Neither trial of early EVAR compared to surveillance reports data by subpopulation.

None of the pharmacotherapy trials reported health outcomes by subgroup. One small doxcycline trial and one propranolol trial performed limited subgroup analyses, which did not support treatment effect modification by age or smoking status. These available analyses would be considered exploratory at best, particularly given that the subgroup methodologies were of low quality and overall trial results do not support an AAA growth benefit.

### Detailed Results

#### Open Surgery vs. Surveillance

##### Age

Both ADAM and UKSAT reported no statistically significant treatment modification in all-cause mortality by age.^140,^ ^163^ These subgroup analyses were prespecified with adjustment for confounders and interaction testing was performed (Appendix F Table 5). In the ADAM trial, there was no statistically significant interaction with respect to mortality between treatment groups and age (age strata: 50 to 59 years, 60 to 69 years, 70 to 79 years) at a mean of 4.9-year followup; CIs were overlapping for each age group (p interaction not reported).^140^ Likewise, in UKSAT there were similar results seen by age group (age strata: 60 to 66 years, 67 to 71 years, 72 to 76 years) at 12-year followup.^163^ There was no significant interaction between treatment group and age with respect to all-cause mortality (p=0.15 for interaction). Subgroup-specific effect modification is unlikely, particularly given that the overall trial results showed no difference between the early surgery and surveillance groups.

##### Sex

Both ADAM and UKSAT conducted subgroup analysis by sex for all-cause mortality.^140,^ ^162,^ ^163^ The vast majority of participants (>90%) in ADAM and UKSAT were male and white. Only UKSAT reported outcomes by sex with a prespecified analysis, adjustment for confounders, and interaction testing. ADAM had planned a subgroup analysis by sex (only 0.8% of participants were women); however, results were not reported separately and are only available as pooled data in the individual patient data meta-analysis.^126^ In UKSAT, no sex-specific subgroup differences in all-cause mortality were found (men: n=902; adjusted HR, 0.9 [95% CI, 0.76 to 1.06]; women: n=188; adjusted HR, 0.89 [95% CI, 0.62 to 1.28]; p=0.76 for interaction).^163^ Through 12 years of followup, UKSAT found similar numbers of deaths in men and women in the early repair group (men: 63.8%; women: 66.3%) and slightly more deaths among women than men in the surveillance group (men: 65.4%; women: 73.1%) (Appendix F Table 6).^163^ Likewise, the Filardo individual patient data meta-analysis (n=2,226) pooled sex-specific all-cause mortality outcomes from UKSAT and ADAM, with up to 8-year followup, showing no differential effect by sex (men: adjusted HR, 1.01 [95% CI, 0.84 to 1.21]; women: adjusted HR, 0.96 [95% CI, 0.49 to 1.86]; p interaction not performed).^126^ No other outcomes were reported by sex subgroup.

##### Smoking Status

Only UKSAT reports all-cause mortality outcomes by smoking status (current smokers or never smokers compared to former smokers), showing no differences in all-cause mortality by smoking status at 10-year followup. No outcomes were reported in the intervention and control groups by smoking status for comparison; therefore, this subanalysis does not test whether there is a treatment modification by smoking status (Appendix F Table 7).^161–163^

Neither trial reported outcomes for early surgery compared to surveillance by family history or race/ethnicity.

#### EVAR vs. Surveillance

Neither of the two trials comparing early EVAR surgery to surveillance reported data on subpopulation effects.^117,^ ^118,^ ^157,^ ^158^

#### Pharmacotherapy vs. Surveillance

Credible subgroup analyses examining differential treatment effectiveness by subpopulation were not available among the pharmacotherapy studies. Two limited analyses are reported; one antibiotic study of doxycycline^153^ includes a subpopulation analysis of aneurysm growth by smoking status (patients with COPD and/or smoking habit), and one propranolol trial^164^ includes a subpopulation analysis of all-cause mortality by age. Neither of these trials reported whether the subanalyses were prespecified, whether they adjusted for confounders, or whether interaction testing was performed. Other subgroup analyses described in the pharmacotherapy studies were not considered because they did not actually examine any treatment effect modification by subpopulation (i.e., interaction between treatment assignment and subpopulation).

Mean growth rates in patients with a smoking habit and/or COPD in one small doxycycline trial (n=32) were reported.^153^ CIs for mean growth rates for treatment and control groups in smokers compared to the entire study population were wide and overlapping. One propranolol trial simply stated “age had no impact on the efficacy of propranolol” but provided no other details.^164^

None of the trials reported subpopulation analyses of treatment effectiveness by family history or race/ethnicity.

## KQ 5 What Are the Harms of Treatment in an Asymptomatic, Screen-Detected Population With Small AAAs (i.e., Aortic Diameter of 3.0 to 5.4 cm)?

### Summary of Results

Two trials, ADAM and UKSAT,^127,^ ^137,^ ^140,^ ^163^ reported harms of open repair vs. surveillance. These trials report rates of intervention and associated mortality, finding a 50 percent higher rate of procedures in the early intervention group compared to the control group but no difference in 30-day postoperative mortality. Readmission rates at 30 days postoperation were higher in the early intervention group in the ADAM trial than in the surveillance group; however, major surgical complications were lower in the early intervention group. Quality of life results were mixed in the early open repair vs. surveillance trials, but generally showed declines in both treatment groups over time, with no statistically significant difference observed between the groups up to 1 to 2 years postrandomization. The ADAM trial showed higher general health scores in the early repair group in the first 2 years; however, this difference did not persist over time. One trial reported higher rates of impotence in the early repair group.

Two trials of early EVAR vs. surveillance (PIVOTAL^158^ and CAESAR^118^) report an approximately 100 percent higher procedure rate in the early intervention group compared to the surveillance group but no difference in 30-day postoperative mortality (Table 11). In the CAESAR trial, the rate of complications was consistently higher among those receiving early EVAR compared to those undergoing surveillance (the number of patients with any adverse events, any morbidity at 30 days postoperation related to repair, endoleaks at 1 year, and reinterventions). Rates were similar for any major morbidity over the trial duration between treatment groups. Conversely, the PIVOTAL trial largely reported similar rates of adverse events between groups at 30 days and 1-year postoperation and reinterventions.

Table 11 Harms Data in Studies of Treatment for Small AAAs (KQ5)

Comparison | Study | Mean Followup, years | Treatment Group | N Analyzed | 30-Day Operative Mortality, n (%) | Reintervention, n (%) | Endoleak, n (%) | Readmission in 30 Days, n (%) | Complication, n (%)
Open surgery vs. surveillance | Lederle, 2002^140^; ADAM | 4.9 | IG | 526 | Elective repairs: 11 (2.1)^*^; Emergency: NR; Overall: NR | Timing NR; IG: 9 (1.7%); CG: 4 (1.2%) | NA | 108 (20.5)^†^ | Timing NR; Any complication: 275 (52.3)^ǂ^; Major complications:; MI: 5 (1.0)^ǂ^; Stroke: 3 (0.6); Pulmonary embolism: 4 (0.8); Amputation: 2 (0.4); Paraplegia: 0; Dialysis: 2 (0.6)
Open surgery vs. surveillance | Lederle, 2002^140^; ADAM | 4.9 | CG | 340 | Elective repairs: 6 (1.8)^*^; Emergency: NR; Overall: NR | Timing NR; IG: 9 (1.7%); CG: 4 (1.2%) | NA | 56 (16.5)^†^ | Timing NR; Any complication: 193 (56.8)^ǂ^; Major complications:; MI: 13 (3.8)^ǂ^; Stroke: 2 (0.6); Pulmonary embolism: 1 (0.3); Amputation: 2 (0.4); Paraplegia: 2 (0.6); Dialysis: 2 (0.6)
Open surgery vs. surveillance | Powell, 2007^163^; UKSAT | 12.0 | IG | 526 | Elective: 26 (5.0); Emergency: 3 (100); Overall (including after emergency repair): 29 (5.5)^§^ | NR | NA | 30 (6.3)^║^ | NR
Open surgery vs. surveillance | Powell, 2007^163^; UKSAT | 12.0 | CG | 389 | Elective repair: 25 (6.3); Emergency: 4 (66.7); Overall (including after emergency repair): 29 (7.2)^§^ | NR | NA | NR | NR
EVAR vs. surveillance | Cao, 2011^118^; CAESAR | 2.6^¶^ | IG | 175 | Elective: 1 (0.6); Emergency: NR; Overall: NR | 10 (5.7)^ǂ^ | Within 30-days ^#^; Type 1: 2 (1.2); Type 2: 25 (14.6); Type 3: 0 (0); Unknown: 1 (0.6); At 1 year ^#^; Type 1: 0 (0); Type 2: 19 (10.9); Type 4: 1 (0.6); Unknown: 1 (0.6) | NR | Within 30 days; Any morbidity related to repair: 31 (17.7)^ǂ^; Any major morbidity: 6 (3.4); Any device-related morbidity: 3 (1.7); At 32.4 months; Any morbidity: 34 (19.1); Any major morbidity: 6 (3.3); Cumulative probabilities of adverse events: 19.8%; (36 mo); 21.2% (54 mo)^**^
EVAR vs. surveillance | Cao, 2011^118^; CAESAR | 2.6^¶^ | CG | 85 | Elective: 0 (0); Emergency: NR; Overall: NR | 0^ǂ^ | Within 30 days ^#^; Type 1: 1 (1.4); Type 2: 4 (5.6); Type 3: 1 (1.4); Unknown: 1(1.4); At 1 year ^#^; Type 1 (0); Type 2: 2 (2.4); Type 4 0 (0); Unknown: 0 (0) | NR | Within 30 days; Any morbidity related to repair: 5 (6.0)^ǂ^; Any major morbidity: 4 (4.7); Any device-related morbidity: NR; At 32.4 months; Any morbidity: 10 (5.1); Any major morbidity: 5 (2.8); Cumulative probabilities of adverse events: 4.0% (36 mo); 14.8% (54 mo)
EVAR vs. surveillance | Ouriel, 2010^158^; PIVOTAL | 1.7 | IG | 322 | 1(0.3) | Timing NR; 12 (3.7) | Within 30 days; Overall: 36 (11.9); Type 1: 0; Type 2: 34 (11.3); Type 3: 1 (0.3); Type 4: 1 (0.3); At 1 year; Overall: 72 (26.1); Type 1: 2 (0.7); Type 2: 67 (24.4); Type 3: 1 (0.3); Type 4: 2 (0.7) | 20 (4.6; group NR) | Within 30 days; Endograph migration: 1 (0.3); Superficial wound infection: 8 (2.5); Endograph thrombosis: 4 (1.2); Deep vein thrombosis: 1 (0.3); Serious cardiac event: 17 (5.3); Serious pulmonary event: 4 (1.2); Serious renal event: 6 (1.9)
EVAR vs. surveillance | Ouriel, 2010^158^; PIVOTAL | 1.7 | CG | 109 | 1 (0.9) | Timing NR; 5 (4.6) | Within 30 days; Overall: 10 (10.3); Type 1: 1 (1.0); Type 2: 4 (9.3); Type 3: 0 (0); Type 4: 0 (0); At 1 year; Overall: 30 (35.1); Type 1: 2 (2.4); Type 2: 29 (33.4); Type 3: 0 (0); Type 4: 0 (0) | 20 (4.6; group NR) | Within 30 days; Endograph migration: 0; Superficial wound infection: 1 (0.9); Endograph thrombosis: 3 (2.8); Deep vein thrombosis: 0; Serious cardiac event: 9 (8.3); Serious pulmonary event: 1 (0.9); Serious renal event: 1 (0.9)

* Operative mortality associated with the repair of unruptured AAA.

† Timing NR.

ǂ p<0.05.

§ N analyzed for overall 30-day operative mortality, IG: 528, CG: 401.

║ From 1-year followup data; the use of bifurcated grafts (12/30 [40%]) was associated with a 2-fold increase in the risk of reoperation, p=0.03.

¶ Median.

# Denominator is those that received EVAR: IG: 171; CG: 71; at 1 year: IG: Type 2: 19 (10.9%), Type 4: 1 (0.6%), unknown: 1 (0.6%); CG: Type 2: 2 (2.4%).

** p<0.001

Abbreviations: AAA = abdominal aortic aneurysm; ADAM = Abdominal aortic aneurysm Detection and Management study; CAESAR = Comparison of surveillance versus Aortic Endografting for Small Aneurysm Repair; CG = control group; EVAR = endovascular aneurysm repair; IG = intervention group; MI = myocardial infarction; N = population size: n = sample size; NA = not applicable; NR = not reported; PIVOTAL = Positive Impact of Endovascular Options for Treating Aneurysms Early; UKSAT = the UK Small Aneurysm Trial.

In general, national and international registries report clinically important harms rates that were similar to those reported in the trials.

With the exception of the two propranolol trials reporting high rates of discontinuation due to adverse events, other medications (including other antihypertensive medications [ACE inhibitors, calcium-channel blockers] and antibiotics) appear to be well tolerated based on few trial withdrawals reported from a small number of studies per drug class.

### Study Characteristics

The two trials of early open surgery^127,^ ^137,^ ^140,^ ^163^ and the two trials of early EVAR^118,^ ^122,^ ^124,^ ^158^ discussed in detail above report data on harms (Table 11). The surgical harms considered in this review included surgical procedures, 30-day postoperative mortality, surgical complications including readmissions, and quality of life. In addition to the seven pharmacotherapy RCTs described in KQ4,^114,^ ^132,^ ^133,^ ^152,^ ^153,^ ^164,^ ^166^ one additional RCT of propranolol vs. placebo provided harms data only.^142^

Five fair-quality registry studies assessing outcomes after EVAR reported harms data for small aneurysm repair^116,^ ^129,^ ^149,^ ^159,^ ^160^ (Table 12, Appendix E Table 9). Three^116,^ ^149,^ ^159^ of the five registries are new since the last review.^105^ The five registry publications that prospectively examined EVAR complication rates with subgroup reporting for small-sized AAAs measuring smaller than 5.5 cm were the Vascunet international registry (N=12,610 small AAAs),^116^ the Australian Safety and Efficacy Register of New Interventional Procedures-Surgical (ASERNIP-S)^129^ (N=478), the U.S. Vascular Study Group New England (VSGNE) (N=1,336)^149^ and the American College of Surgeons National Surgical Quality Improvement Program (ACS NSQIP) (N=5,126),^159^ and the European Collaborators on Stent/Graft Techniques for Aortic Aneurysm Repair (EUROSTAR) (N=1,962).^160^

Table 12 Harms Data in Registry Studies (KQ5)

Study; Registry | Mean Followup, years | N Analyzed | Surgical technique(s) included | 30-day Operative Mortality, n (%) | Reintervention, n (%) | Endoleak, n (%) | Readmission in 30 days, n (%) | Complication, n (%)
Budtz-Lilly, 2017^116^; Vascunet | NR | 12,610 | EVAR, open | Open: 391 (3.1)^*^; EVAR: 88 (0.7)^*^ | NR | NR | NR | NR
Golledge, 2007^129^; ASERNIP-S^║^ | 3.2^†^ | 478 | EVAR | 5 (1.1) | Within 30 days 13 (3)^‡^ | Within 30 days; Type 1: 10 (2.1); Type 2: 35 (7.3); Type 4: 1 (0.2); 97 (20.3) patients had endoleak on followup imaging ≥30 days after procedure | NR | Within 30 days; Significant postoperative complications reported in 138 (29) patients; 52 procedural and device complications occurred in 51 (10.7) patients; 72 systemic complications were noted in 64 (13.4) patients; 41 access site and lower limb complications in 39 (8) patients
Lo, 2013^149^; Vascular Study Group of New England | 1.0 | 1,336 | EVAR, open | Men: 7 (0.7); Women: 4 (1.1) | NR | NR | NR | NR
Overbey, 2017^159^; ACS NSQIP | NR | 5,126 | EVAR, open | 56 (1.1); Open: 25 (3.5)]^§^; EVAR: 31 (0.7)^§^ | 214 (4.2); Open: 64 (9.1); EVAR: 150 (3.4) | NR | 348 (6.8); Open: 44 (6.2); EVAR: 304 (6.8) | Open:; Overall morbidity within 30 days of surgery: 69.4%; Pneumonia: 34 (4.8); Acute renal failure: 18 (2.3); Sepsis: 12 (1.7); Septic shock: 19 (2.7); Cardiac arrest: 19 (2.7); MI: 24 (3.4); Pulmonary embolism: 3 (0.4); Stroke: 5 (0.7); Bleeding complications: 460 (65.2); Ischemic colitis: 34 (4.8); Lower extremity ischemia: 15 (2.1); EVAR:; Overall morbidity within 30 days of surgery: 11.4%; Pneumonia: 24 (0.5); Acute renal failure: 15 (0.3); Sepsis: 20 (0.4); Septic shock: 6 (0.1); Cardiac arrest: 14 (0.3); MI: 46 (1.0); Pulmonary embolism: 5 (0.1); Stroke: 12 (0.3); Bleeding complications: 296 (6.6); Ischemic colitis: 16 (0.4); Lower extremity ischemia: 56 (1.3); Combined:; Pneumonia 58 (1.1); Acute renal failure: 33 (0.6); Sepsis: 32 (0.6); Septic shock: 25 (0.5); Cardiac arrest: 33 (0.6); MI: 70 (1.4); Pulmonary embolism: 8 (0.2); Stroke: 17 (0.3); Bleeding complications: 756 (14.7); Ischemic colitis 50 (0.01); Lower extremity ischemia 71 (1.4)
Peppelenbosch, 2004^160^; EUROSTAR | 1.7 | 1,962 | EVAR | 31 (1.6) | NR | Event at 4 years; Type I:; Proximal:5.3%; Distal: 11.3%; Type III: 14.4% | NR | Timing NR; Cardiac: 55 (2.8); Pulmonary: 31 (1.6); Early procedure or device-related: 57 (2.9); 30-day systemic complications combined: 235 (12.0)

* Defined as hospital death or death within 30 days of surgery.

† Median.

‡ Reinterventions ≤30 days after surgery; ≥30 days after surgery: 50 patients underwent 72 additional interventions by open repair (20 times in 16 patients [5 had an EVAR procedure]), EVAR (52 times in 39 patients), or combined approaches.

§ N analyzed for 30-day operative mortality; open repair n=705, EVAR n=4471.

║ Registry does not report whether the number includes emergency surgeries.

Abbreviations: AAA = abdominal aortic aneurysm; ACS NSQIP: American College of Surgeons National Surgical Quality Improvement Program; ASERNIP-S = Australian Safety and Efficacy Register of New Interventional Procedures-Surgical; EVAR = endovascular aneurysm repair; IG = intervention group; MI = myocardial infarction; N = population size: n = sample size; NA = not applicable; NR = not reported.

The two largest and most contemporary registries were the Vascunet^116^ and ACS NSQIP.^159^ The Vascunet international registry from 11 countries reported data on small AAA (<5.5 cm) repair with EVAR and open repair from 2010 to 2013; this registry represents the largest registry included in the review and captured greater than 90 percent of repairs done in the majority of the participating countries during the time period represented. The mean age and sex of the subgroup with small AAAs were not reported, nor was the mean followup time. The ACS NSQIP is a nationally validated, U.S.-based, risk-adjusted dataset of surgical procedures that provided complication rates for open repair and EVAR procedures of small AAAs from 2011 to 2015 with outcomes reported by size quartile, including 3.5 to 5 cm and 5.01 to 5.5 cm. The mean age was 72.3 years and the population comprised 21.9 percent females. Approximately one-third were smokers. The ASERNIP-S registry from Australia reported complication rates for small AAA (≤5.5 cm) repair by EVAR from 1999 to 2001, with mandatory reporting by vascular surgeons during the time period. The mean age was 75 years, with a population comprising 15.9 percent women and 11 percent smokers; the median followup was 3.2 years. The VSGNE registry reported complication rates for small AAAs (<5.5 cm) repaired by EVAR and open surgery from 2003 to 2011 from a voluntary collaboration among vascular surgeons, cardiologists, and radiologists from 30 community and academic hospitals in New England. The mean age was 71 years, and the population comprised 26.2 percent women and 88.5 percent smokers; the mean followup was 1 year. EUROSTAR is an international registry from 17 European countries and 110 institutions reporting complications of elective EVAR for small AAA (4.0 to 5.4 cm) repair from 1997 to 2002. The mean age of the population was 69.7 years and participants were primarily men (only 7% were female); mean followup was 1.7 years (Appendix E Table 9).

The two EVAR-only registries, ASERNIP^129^ and EUROSTAR,^160^ reported endoleaks and reinterventions, as well as 30-day operative mortality. The three registries that included both EVAR and open repair reported 30-day operative mortality,^116,^ ^149,^ ^159^ reinterventions,^159^ readmissions,^159^ and/or other complications.^159^

### Harms Associated With Early Open Surgery vs. Surveillance

#### Detailed Results for RCTs

##### Operative Mortality

Both the ADAM trial and UKSAT reported similar 30-day postoperative mortality rates in the early open repair and surveillance groups (Table 11).^140,^ ^163^ In the ADAM trial, 30-day operative mortality (defined as death within 30 days of an unruptured AAA repair) at 5 years was 2.1 percent in the early surgery group compared to 1.8 percent in the surveillance group.^140^ Conversely, at 12-year followup, the 30-day operative mortality (defined as AAA-related death within 30 days of elective repair) in the early surgery group of UKSAT was 5.0 percent compared to 6.3 percent in the surveillance group (Table 11).^163^

##### Surgical Complications

The ADAM trial reported 30-day readmissions and (nonfatal) complications associated with AAA repairs in both the early open repair and surveillance groups, finding no significant higher rates of readmission in the early surgery group, but slightly lower complication rates (Table 11).^140^ In this trial, patients in the early open surgery group had a nonstatistically significant higher rate of 30-day readmission for complications after surgery (20.5% vs. 16.5%) and a lower risk of any surgical complications (52.3% vs. 56.8%; p=0.026) compared to those who received later surgery in the surveillance group. Further, the event rate for total major complications was higher in the surveillance group than in the early treatment group (7.6% vs. 4.6%), with a significantly higher risk of surgery-related myocardial infarction reported in the surveillance group (1.0% vs. 3.8%; p=0.0051). UKSAT did not report morbidity outcomes associated with surgery and only reports a readmission rate in the early surgery group (6.3%) without a comparator.^163^

##### Quality of Life

Both UKSAT and ADAM reported quality of life, although only UKSAT reported numerical data (Appendix E Table 10).^127,^ ^137,^ ^140,^ ^163^ The UKSAT trial reported the change of quality of life, measured with the Medical Outcomes Study SF-20, 1 year after randomization.^127^ The SF-20 has several domains, including physical, role, and social functioning; mental health, health perception, and bodily pain, with a total score ranging from 0 to 100 (higher score equals better health). The physical function domain decreased in both groups 1 year after randomization, with no statistically significant difference in this change over time between the open repair and surveillance groups. The mental health domain showed no change in mean difference over time for each group or between the groups.

The ADAM trial measured quality of life using the SF-36 every 6 months through 3.5 to 8 years of followup (mean 4.9 years).^137^ There was a statistically significant decrease in all SF-36 subscales observed over time for the entire population (p<0.001); however, no difference was observed between the early repair group and the surveillance group in all SF-36 subscales. The exceptions to this was that the early repair group had a statistically higher general health score compared to the surveillance group (p<0.001), with significantly higher scores during the 6-month to 2-year time points (p<0.05); this difference did not persist beyond 2 years.

The ADAM trial additionally reported a statistically higher risk of developing impotence in patients in the early open repair group compared to the surveillance group from the 18-month time point to 4 years (p<0.03).^137^ Exact numerical data was not presented.

#### Detailed Results for Registries

##### 30-Day Operative Mortality

The two largest and most contemporary registries capturing open repairs of small aneurysms reported a 30-day operative mortality rate of 3.1 percent^116^ and 3.5 percent^159^ (Table 12). The VSGNE registry reported lower rates of operative mortality for EVAR and open repair procedures combined (0.7% in men and 1.1% in women).^149^ These operative mortality rates are in the range between the rates reported in the two early open repair trials (ADAM and UKSAT).^140,^ ^163^

##### Reintervention

Only one registry reports reintervention rates following open repair of small aneurysms. NSQIP reports a return to the operating room required in 9.1 percent of open repairs at 30 days postintervention (Table 12).^159^ This reintervention rate is higher than the data reported in the ADAM trial (IG: 1.7%, CG: 1.2%).^140^

##### Readmissions

Only one registry reported readmission rates following open repair of small aneurysms. The NSQIP reports readmission rates for small AAAs at 30-day postintervention as 6.2 percent following open repair (Table 12).^159^ This figure is similar to that reported in the trials.

##### Complications

One registry of both open and EVAR reports complication rates following open repair of small aneurysms. NSQIP reports overall 30-day morbidity for open repair as approximately 69.4 percent at 30 days postintervention, with the most common complication being bleeding (Table 12).^159^ This is slightly higher than the complication rate reported in the ADAM trial (52.3% any complication; timing not reported). ^140^

### Harms Associated With Early EVAR vs. Surveillance

#### Detailed Results for RCTs

##### Operative Mortality

Thirty-day operative mortality after EVAR in both CAESAR and PIVOTAL was rare; only one patient died in the early EVAR group in each trial (0.6% in CAESAR and 0.3% in PIVOTAL), while no patients died undergoing repair in the surveillance group in CAESAR and one patient died in PIVOTAL (Table 11).^118,^ ^158^

##### Complications

Complications were variably reported in the two trials.^118,^ ^158^ In the CAESAR trial, the percentage of patients with any adverse events was significantly higher in the early repair group compared to the surveillance group (19% vs. 5%; p<0.01) at 32.4 month followup, as was the percentage of patients with any major morbidity related to repair at 30 days (18% vs. 6%; p=0.01) (Table 11).^118^ Similar rates of any major morbidity over the trial duration, however, were observed in both treatment groups (3.3% vs. 2.8%; p=0.99). Additionally, similar rates of endoleaks were recorded within 30 days between treatment groups (16% vs. 10%; p=0.23), but the early EVAR group had significantly more endoleaks at 1 year (12 vs. 2%; p=0.028) and significantly more reinterventions than those undergoing surveillance (6% vs. 0%; p=0.03). Most of the endoleaks in the early EVAR group were type 2 endoleaks.^118^

The PIVOTAL trial largely reported adverse events within 30 days postintervention.^158^ Endoleak was the most common adverse event, occurring at similar rates in the early intervention and surveillance groups at 30 days postintervention (12% vs. 10%) and 1 year (26% vs. 35%) (Table 11). Total other complications reported within 30 days of intervention, including endograft or peripheral thromboses, wound infections, and systemic complications, occurred with 15 percent frequency in EVAR recipients, with no difference between treatment groups. Additionally, the PIVOTAL trial reported that 3.7 and 4.6 percent of patients required reintervention in the early surgery and surveillance groups, respectively.^158^

##### Quality of Life

Both trials report quality of life at baseline and at 6 to 24 months followup using the SF-36^122^ or EQ-5D^124^ scales, and show no differences in quality of life changes between the treatment groups at longer followup. The CAESAR trial^122^ reports that quality of life improved in the early EVAR group but worsened in the surveillance group over the short term. There were statistically significant and modestly greater mean differences in overall quality of life (5.4 [95% CI, 2.1 to 8.8]), physical function (3.8 [95% CI, 0.5 to 7.2]), and mental health (6.0 [95% CI, 2.7 to 9.3]) favoring the early EVAR group compared to the surveillance group from baseline to 6 months after randomization. These results were not sustained, however, and no longer statistically significant through the mean 3-year followup. PIVOTAL^124^ reported no statistically significant differences in quality of life changes between the early EVAR vs. surveillance groups in any of the EQ-5D dimensions or utility scores at 12- or 24-month followup compared to baseline (Appendix E Table 10).

#### Detailed Results for Registries

##### 30-Day Operative Mortality

The two largest and most contemporary registries capturing EVAR of small aneurysms reported a 30-day operative mortality rate for EVAR of 0.7 percent (Vascunet and NSQIP).^116,159^ The two oldest registries (ASERNIP and EUROSTAR) reported slightly higher mortality rates from EVAR at 1.1 percent (ASERNIP) and 1.6 percent (EUROSTAR) (Table 12).^129,^ ^160^ VSGNE reported 30-day operative mortality for EVAR and open repair procedures combined as 0.7 percent in men and 1.1 percent in women.^149^ The two most contemporary registries have 30-day postoperative complication rates that are comparable to the rates reported in the early EVAR trials.

##### Reintervention

Two registries of EVAR for small aneurysms report rates of reintervention following surgery. ASERNIP reports a reintervention rate within 30 days of EVAR of 3 percent^129^ (Table 12). NSQIP reports a return to the operating room required for 3.4 percent of EVAR procedures at 30 days following surgery.^159^ These reintervention rates are comparable to the trial data from CAESAR and PIVOTAL for EVAR (CAESAR IG: 5.7%, CG: 0; PIVOTAL IG: 3.7%, CG: 4.6%).^118,^ ^158^

##### Readmissions

Only one registry reported readmission rates following EVAR repair of small aneurysms. The NSQIP reports readmission rates for small AAAs at 30-day postintervention as 6.8 percent following EVAR (Table 12).^159^

##### Endoleaks Following EVAR

Endoleaks are one of the most commonly reported complications after EVAR. ASERNIP reports the occurrence of endoleaks at 9.6 percent within 30 days of surgery and 20.3 percent at followup (mean, 3.2 years);^129^ however, incomplete followup (23% lost to followup at study completion) limits this data (Table 12). EUROSTAR reports the rate of endoleaks at 31.0 percent at 4 years.^160^ Trial data from CAESAR and PIVOTAL reported similar incidence of endoleaks at 30 days as ASERNIP, ranging from 10 to 16 percent at 30 days postintervention. Endoleak incidence by type is reported in Table 11.^118,^ ^158^

##### Complications

Two EVAR registries (ASERNIP^129^ and EUROSTAR^160^) and the one registry of both open repair and EVAR (NSQIP)^159^ report complication rates following intervention. ASERNIP reports significant postoperative complications in 29 percent of individuals at 30 days after EVAR: 10.7 percent of patients experienced procedural and device complications; 13.4 percent experienced systemic complications, and 8 percent had access site and lower limb complications (Table 12). EUROSTAR reported that 12.0 percent of patients experienced systemic complications (defined as cardiac, pulmonary, renal, cerebral, or gastrointestinal complications) at 30 days after EVAR; 2.8 percent had cardiac complications, and 1.6 percent had pulmonary complications over the mean 1.7 years of followup.^160^ NSQIP reports overall morbidity for EVAR as 11.4 percent at 30 days postoperation; the most common complication was bleeding.^159^ This registry data showing 11 to 29 percent complication rates at 30 days postintervention is within the range seen in the trial data (CAESAR: IG 18% vs. CG 6%; PIVOTAL: IG and CG 15% complications, not including endoleak).^118,^ ^158^

### Harms Associated With Pharmacotherapy

Overall, the trials of antibiotic interventions show that these medications were well tolerated. Both doxycycline trials report similar withdrawals or discontinuations due to adverse events in the treatment and placebo groups at a mean of 1.5 years of followup (Table 13). The doxycycline trial by Mosorin et al^153^ (N=32) reported that the active drug was well tolerated in most patients; one patient in the doxycycline group and one in the placebo group discontinued the drug due to an allergic reaction (5.9% vs. 6.7%). The other doxycycline trial (N=286 analyzed) suggested no statistically significant difference in adverse events leading to study withdrawal (7.6% vs. 2.1%; difference, 5.5 [95% CI, −6.3 to 17.1]).^152^ In the azithromycin trial^133^ (n=211), 13 patients in the treatment group and 8 patients in the control group reported side effects due to gastrointestinal side effects, arthralgias, or allergic reactions at 1.5 years (12.3% vs. 7.6%; no statistical difference reported). In the Roxithromycin trial (N=84),^132^ there were no adverse events or drop outs reported at 2-year followup.

Table 13 Harms Data in Studies of Treatment for Small AAA (KQ5): Pharmacotherapy vs. Placebo

Study | Drug Name | Mean Followup, years | Treatment Group | N Analyzed | Readmission in 30 Days, n (%) | Trial Withdrawals Due to AEs Related to Study Medication, n (%) | Complication, n (%)
Bicknell, 2016^114^; AARDVARK | Perindopril (IG1); amlodipine (IG2) | 2.0 | IG1 | 73 | NR | 2 (2.7) | Serious AEs *; 19 (26.0)
Bicknell, 2016^114^; AARDVARK | Perindopril (IG1); amlodipine (IG2) | 2.0 | IG2 | 72 | NR | 4 (5.6) | Serious AEs *; 12 (16.7)
Bicknell, 2016^114^; AARDVARK | Perindopril (IG1); amlodipine (IG2) | 2.0 | CG | 79 | NR | 0 (0) | Serious AEs *; 16 (20.2)
Hogh, 2009^132^ | Roxithromycin | 2.0 | IG | 40 | NR | 0 (0) | No adverse events were reported
Hogh, 2009^132^ | Roxithromycin | 2.0 | CG | 44 | NR | 0 (0) | No adverse events were reported
Karlsson, 2009^133^ | Azithromycin | 1.5 | IG | 106 | NR | 3 stopped taking medication | 13 (12.3)^†^
Karlsson, 2009^133^ | Azithromycin | 1.5 | CG | 105 | NR | 2 stopped taking medication | 8 (7.6)^†^
Lindholt, 1999^142^ | Propranolol | 2.0 | IG | 30 | NR | 18^‡^ | Serious cardiac; arrhythmia: 1 (3.3)^§^; Dyspepsia: 3 (10.0)^§^; Headache: 2 (6.7)^§^; Dizziness: 3 (10.0)^§^
Lindholt, 1999^142^ | Propranolol | 2.0 | CG | 24 | NR | 7^‡^ | Serious cardiac; arrhythmia: 0 (0)^§^; Dyspepsia: 1 (4.2)^§^; Headache: 1 (4.2)^§^; Dizziness: 0 (0)^§^
Meijer, 2013^152^ | Doxycycline | 1.5 | IG | 144 | NR | 11 (7.6) | Abdominal pain, nausea, diarrhea; 5 (3.5)
Meijer, 2013^152^ | Doxycycline | 1.5 | CG | 142 | NR | 3 (2.1) | Abdominal pain, nausea, diarrhea; 11 (7.7)
Mosorin, 2001^158^ | Doxycycline | 1.5 | IG | 17 | NR | 1 (5.9)^║^ | No adverse events were reported
Mosorin, 2001^158^ | Doxycycline | 1.5 | CG | 15 | NR | 1 (6.7)^║^ | No adverse events were reported
PAT Investigators, 2002^164^; PAT | Propranolol | 2.5 | IG | 267 | NR | 104 (37.7)^¶^ | Patients who stopped their medication before surgery or the end of study: 117 (42.4); Reasons for permanently stopping study drug:^#^; Fatigue: 24 (8.7); Heart failure: 7 (2.5); Bradycardia/AVB: 11 (4); Claudication/Raynaud’s disease: 1 (0.4)
PAT Investigators, 2002^164^; PAT | Propranolol | 2.5 | CG | 272 | NR | 58 (21.3) | Patients who stopped their medication before surgery or the end of study: 73 (26.8); Reasons for permanently stopping study drug:^#^; Fatigue: 12 (4.4); Heart failure: 2 (0.7); Bradycardia/AVB: 1 (0.4); Claudication/Raynaud’s disease: 3 (1.1)
Sillensen, 2015^166^; AORTA | Pemirolast | 1.0 | IG1 | 84 | NR | 7 discontinued intervention (not specific); 1 withdrew | Any AE: 67 (79.8); Any SAE: 15 (17.9); Serious cardiac disorder: 4 (4.8)
Sillensen, 2015^166^; AORTA | Pemirolast | 1.0 | CG | 84 | NR | 14 discontinued intervention (not specific); 8 withdrew | Any AE: 68 (80.9); Any SAE: 15 (17.9); Serious cardiac disorder: 5 (5.9)

* None of the recorded SAEs were deemed to be related to the trial medications.

† All patients in CG had gastrointestinal symptoms and 2 stopped taking medications. In IG: 3 stopped taking medications (1 due to diarrhea, 1 due to arthralgia, 1 had allergic reaction [found to be to antihypertensive medication, not study medication]).

‡ Cumulated drop-outs.

§ Withdrew due to complications; subset of complications. Full list of complications listed in Figure 18.

║ Discontinued the medication due to an allergic reaction.

¶ p<0.0001.

# Complete list available in Table 2.

Abbreviations: AAA = abdominal aortic aneurysm; AARDVARK = Aortic Aneurysmal Regression of Dilation: Value of ACE-Inhibition on RisK trial; AORTA = the Anti-inflammatory Oral Treatment of AAA; AVB = atrioventricular block; CG = control group; EVAR = endovascular aneurysm repair; IG = intervention group; MI = myocardial infarction; N = population size; n = sample size; NR = not reported; PAT = Propranolol Aneurysm Trial; PVD = peripheral vascular disease; SAE = serious adverse events.

Both propranolol trials report high rates of discontinuation due to adverse events,^142, 164^ while the Aortic Aneurysmal Regression of Dilation: Value of ACE-Inhibition on Risk (AARDVARK) trial of an ACE inhibitor and a calcium-channel blocker suggests that these other antihypertensive medications are generally well tolerated (Table 13).^114^ In the PAT trial (N=539), there was a higher rate of drug discontinuation in the propranolol group compared to placebo at 2.5 years (42.4% vs. 26.8%; difference, 15.6% [95% CI, 7.6% to 23.5%]).^164^ Likewise, the propranolol group had a higher rate of trial withdrawals due to adverse events (37.7% vs. 21.3%; difference, 16.4% [95% CI, 8.7% to 24.0%]). In the small Danish propranolol trial (N=54), a substantial and statistically significantly greater proportion of patients dropped out compared to the placebo group at 2 years of followup (60% vs. 28%; RR 5.7 [95% CI, 1.5 to 22.2]).^142^ The most commonly cited reasons for these dropouts were death, serious cardiac arrhythmia, dyspepsia, headache, and dizziness in the intervention group. The AARDVARK trial (N=224) with the active ACE inhibitor and calcium-channel blocker arms had generally low withdrawals due to adverse events attributed to study medications at 2 years of followup (2.7% and 5.6% in the ACE inhibitor and calcium-channel blocker groups, respectively).^114^ Additionally, 4.1 percent (3/73) and 1.4 percent (1/72) from the ACE inhibitor and calcium-channel blocker groups, respectively, switched to another class of medication due to cough. Similarly, the only trial of a mast cell stabilizer (Anti-Inflammatory Oral Treatment of AAA [AORTA] trial) (N=168 analyzed single active drug vs. placebo arm) reported high rates of any adverse events (approximately 80%) and serious adverse events (approximately 18%) in both the intervention and placebo groups; a higher percentage of participants withdrew in the placebo group compared to the treatment arms at 1-year followup (1/84 [2.5%] vs. 8/84 [9.5%]).^166^

Two propranolol trials^142,^ ^164^ report quality of life, generally showing no difference between the intervention and control groups. One study reports a decline in SCREENQOL in both the intervention and control groups through 2 years without a significant difference between the groups,^142^ and the other study reports no significant difference in SF-36 scores between the propranolol and control groups at 1 month postrandomization.^164^

## KQ5a Do the Harms of Treatment of Small AAAs Vary Among Subpopulations (i.e., by Age, Sex, Smoking Status, Family History, or Race/Ethnicity)?

### Summary of Results

Scant data have been reported for harms among subpopulations. The only available evidence comes from surgical registries due to no trial data being available to examine harms in subpopulations. Existing evidence from three surgical registries shows higher 30-day operative mortality and secondary complications among women compared with men for both EVAR and open repair of small aneurysms.

### Detailed Results

Overall, registry data show a higher rate of postoperative mortality following elective repair of small AAAs in women compared to men, regardless of the surgical technique. One registry study^116^ reports higher rates of 30-day postoperative mortality in women compared to men for both open repair and EVAR for small AAAs; this pattern remains consistent regardless of age (≥80 and <80 years). For example, in participants younger than age 80 years, the 30-day postoperative mortality is 2.5 percent in men and 3.0 percent in women for open repair, and 0.4 percent in men and 1.1 percent in women for EVAR. In those age 80 years or older, postoperative mortality for open repair was 3.4 percent in men and 9.7 percent in women, while intervention via EVAR was associated with a postoperative mortality of 0.6 percent in men and 1.3 percent in women. One registry shows a similar pattern for AAA repair (EVAR and open repair reported combined), with a 30-day postoperative mortality of 0.7 percent in men and 1.1 percent in women.^149^ Further, one registry reports lower clinical success rates following surgery in women at 3- and 5-year followup compared to men. The difference observed was greatest at 5 years, with 93 percent (±1) of men and only 70 percent (±16%) of women having clinical success.^129^

The two early open repair vs. surveillance trials, ADAM and UKSAT,^140,^ ^163^ and the two early EVAR vs. surveillance trials, CAESAR and PIVOTAL,^118,^ ^158^ did not report harms by subpopulation. Additionally, none of the pharmacotherapy trials reported harms data by subpopulation.