# Appendix H Ongoing Studies

Trial Identifier | Study Name | Location | Participants N | Intervention | Outcome Measures | Status Aug 2018
NCT01756833 | Non-Invasive Treatment of Abdominal Aortic Aneurysm Clinical Trial (N-TA^3CT); Michael Terrin | US | Men and women age 55 years and older; N=261 | Doxycycline 100 mg po bid for 2 years vs. placebo | AAA growth | Active, expected completion 2019.; Protocol (https://www.ncbi.nlm.nih.gov/pubmed/?term=NCT01756833) published 2016
NCT01683084 | Study of the Effectiveness of Telmisartan in Slowing the Progression of Abdominal Aortic Aneurysms (TEDY); (Ronald L Dalman) | US | Adults ages 50 to 85 years; N=22 | Telmisartan 40 mg daily for 24 mo vs. placebo | Rate of AAA growth, AAA diameter, AAA biomarkers, QoL | Completed 2016. No result publication found.; Protocol (https://www.ncbi.nlm.nih.gov/pubmed/?term=26081587) published 2015
NCT02717481 | Using US to Evaluate Aortic Aneurysm Size Based on 3D Co-registration to Previous CT Scan; (Diana Gaitini) | Israel | Men and women age 18 years and older diagnosed with AAA or following invasive repair; N=120 | Ultrasound | Primary: Exact and reliable evaluation of the aneurysm size; Secondary: The size difference between systolic and diastolic aneurysm; aneurysm neck size and changes following an invasive procedure to repair it (EVAR); evaluation of the pressure on the aneurysmal wall | Not yet recruiting, expected completion 2018
NCT01205945 | The Effect of Abdominal Aortic Aneurysm Screening on Mortality in Asian Population; (Jin Hyun Joh) | South Korea | Men and women ages 50 to 85 years with CVD risk factors, family history of AAA; N=12,000 | Ultrasound | Benefits of screening older population | Ongoing, estimated completion 2017. No publications found.
NCT02345590 | Eplerenone in the Management of Abdominal Aortic Aneurysms; (Leah Isles) | Australia | Men and women ages 60 to 90 years with AAA 30 to 49 mm; N=172 | Eplerenone 25mg/day vs. placebo | AAA maximum orthogonal diameter | Ongoing, estimated completion 2019.
NCT02229006 | Sodium Fluoride Imaging of Abdominal Aortic Aneurysms (SoFIA3); (Rachael O Forsythe) | UK | Men and women age 50 years and older in MA3RS study with AAA >40 mm; N=100 | Radiation: 18F-NaF PET-CT | Primary: Change in AAA anteroposterior diameter at 6 and 12 months measured with CTA; Secondary: Co-localization of 18F-NaF with USPIO uptake on MRI scanning | Completed 2017. No publications found.
NCT02604303 | A Prospective Analysis on the Expansion Rates of Abdominal Aortic Aneurysms; (Eugene S. Lee) | US | Veteran men and women age 21 years and older screened for AAA by VA; N=200 | Observational using screening | Primary: aortic expansion rate measured with ultrasound; Secondary: RhoA levels | Ongoing, expected completion Nov 2018.
NCT02070653 | The Efficacy of Ticagrelor on Abdominal Aortic Aneurysm (AAA) Expansion (TicAAA); (Anders Wanhainen) | Sweden | Men and women ages 50 to 85 years with AAA 35 to 49 mm; N=145 | Ticagrelor 180 mg/day vs. placebo | Primary: AAA volume growth measured with MRI; Secondary: AAA diameter growth measured with ultrasound and MRI; need for surgery; rupture | Completed 2018. No publications found.
NCT02548546 | Estimation of Biomechanical Aortic Wall Properties in Healthy and Aneurysmal Aortas Using Novel Imaging Techniques; (Houssam Farres) | US | Men and women age 21 years and older with AAA ≥1.5x normal diameter; N=30 | Surveillance vs. open repair vs. EVAR | Primary: ECHO imaging; Secondary: ECG-gated MRA imaging | Ongoing (recruiting), expected completion Aug 2018.
NCT02225756 | Cyclosporine A in Patients With Small Diameter Abdominal Aortic Aneurysms (ACA4); (Eric Allaire) | France | Men with AAA 30 to 49 mm, women with AAA 25 to 44 mm, 50 to 85 years; N=360 | Cyclosporine vs. placebo | Primary: AAA diameter evolution on CT-scanner 12 months after treatment interruption; Secondary: AAA diameter evolution on duplex-scanner 12 months after treatment interruption; all-cause CV mortality/morbidity | Ongoing (recruiting), expected completion Sep 2018.
NCT02022436 | Evaluation of Predictors of Aortic Aneurysm Growth and Rupture; (Rabih Chaer) | US | Men and women age 21 years and older diagnosed with AAA; N=148 | Contrast ultrasound | Primary: time to growth and/or rupture of abdominal aortic aneurysm; Secondary: AAA biomarkers | Ongoing (recruiting), expected completion Jul 2020.
NCT02179801 | Screening Cardiovascular Patients for Aortic aNeurysms (SCAN); (Hans-Henning Eckstein, Karl-Ludwig Laugwitz) | Germany | Men any age with 1 or more risk factors for AAA and coronary artery intervention; N=1,000 | Ultrasound screening | Primary: prevalence of AAA; Secondary: prevalence of AAA in the cohort requiring treatment; correlation of risk factors for AAA with risk factors for CAD; distribution of risk factors | Ongoing (recruiting), expected completion Apr 2018. No publications found.
NCT02846883 | Safety and Efficacy of Allogeneic MSCs in Promoting T-regulatory Cells in Patients With Small Abdominal Aortic Aneurysms (VIVAAA); (Michael Patrick Murphy, Richard L. Roudebush) | US | Men and women ages 40 to 80 years diagnosed with AAA 35 to 45 mm | Intravenous infusion of 1 or 3 million allogeneic MSCs/kg vs. placebo | Primary: incidence of treatment-related adverse events at 12 months; Secondary: changes in inflammatory AAA biomarkers; change in aortic inflammation measured by 18-FDG PET/CT | Ongoing (recruiting), expected completion 2021.
ISRCTN10945166 | Abdominal Aortic Aneurysm Screening by Ultrasonography in Primary Care; (Ana Claveria) | Spain | Men ages 65 to 74 years; N=3,348 | Screening | Primary: impact of early diagnosis on overall/CV mortality with incidental AAA; Secondary: CV mortality; surgery for AAA; type of hospital discharge | Ongoing, expected completion 2021.
NCT01420991 | Brain and Abdominal Aneurysm Study (BAAS); (James Meschia) | US | Men and women age 18 years and older diagnosed with intracranial aneurysm; N=81 | Opportunistic screening | Primary: prevalence of AAA; Secondary: functional outcomes at 30 days | Ongoing, expected completion 2024.
NCT00662480 | Randomized Preventive Vascular Screening Trial of 65-74 Year Old Men in the Central Region of Denmark (VIVA) | Denmark | 40,000 | Screening for hypertension, lower limb atherosclerosis, and abdominal aortic aneurysm | All-cause mortality, cardiovascular events | Active, expected completion Dec 2023.; Median (4.4 year) results published in 2017.^146^
ISRCTN12157806 | The Danish Cardiovascular Screening Trial (DANCAVAS); (Jes Lindholt) | Denmark | 45,000 | Large population-based, randomized, clinical multicenter trial testing combination cardiovascular screening in men ages 65 to 74 years | All-cause mortality, costs, and cost-effectiveness after 3, 5, and 10 years to assess possible health and/or societal benefits of the screening; nationwide registry-based information on health care consumption | Ongoing, expected completion Jan 2026.; Protocol (https://www.ncbi.nlm.nih.gov/pubmed/26637993) published 2015.