# Appendix F Subpopulation Evidence Tables

Appendix F Table 1 Mortality Data for Age Subpopulation in One-Time Screening Trials (KQ1a)

Appendix F Table 2 Mortality Data for Age Subpopulation in One-Time Screening Trials (KQ1a)

Appendix F Table 3 AAA Prevalence, Rupture, and Surgery Data for Age Subpopulations in One-Time Screening Trials (KQ3a)

Appendix F Table 4 AAA diameter, rupture, and surgery data for smoking subpopulations in one-time screening trials (KQ3a)

Appendix F Table 5 All-Cause and AAA Mortality Data for Age Subpopulations in Open vs. Surveillance Trials (KQ4a)

Appendix F Table 6 All-Cause and AAA Mortality Data for Sex Subpopulations in Open vs. Surveillance Trials (KQ4a)

Appendix F Table 7 All-Cause Mortality Data for Smoking Subpopulations in Open vs. Surveillance Trials (KQ4a)