# Appendix E Evidence Tables

Appendix E Table 1 Methodological and Intervention Characteristics of Included One-Time Screening Studies (KQs 1 and 3)

Appendix E Table 2 Patient Characteristics of Included One-Time Screening Studies (KQs 1 and 3)

Appendix E Table 3 Percent of Screened Population With AAA of the Specified Size

Appendix E Table 4 Methodological and Intervention Characteristics of Included Rescreening Studies (KQ 2)

Appendix E Table 5 Baseline Characteristics of Included Rescreening Studies for Small AAA (KQ 2)

Appendix E Table 6 Quality of Life Results of Included One-Time Screening Studies (KQs 1 and 3)

Appendix E Table 7 Methodological and Intervention Characteristics of Included Treatment Studies (KQs 4 and 5)

Appendix E Table 8 Patient Characteristics of Included Treatment Studies (KQs 4 and 5)

Appendix E Table 9 Methodological Characteristics of Included Registry Studies (KQ5)

Appendix E Table 10 Quality of Life Results in Studies of Treatment for Small AAA (KQs 4 and 5)