# Appendix D Excluded Studies

Reason for Exclusion^*^
E1 Study Aim
E2 Setting; E2a Non-HDI country; E2b Screening and/or intervention is not conducted in, recruited from, or feasible for primary care
E3 Population; E3a Patients experience symptoms of AAA; E3b Patients with AAAs with an aortic diameter larger than 5.4 cm or smaller than 3.0 cm; E3c Patients with known or established CVD
E4 Outcome: No relevant outcomes
E5 Intervention; E5a Screening with physical examination, CT, or MRI; E5b Non-relevant treatment for small AAA
E6 Comparator: Not an included comparator (e.g., comparison of surveillance interval [KQ2], active intervention [KQ4,5])
E7 Study design: Not an included study design, which includes: KQ1,4= Case-control, cross-sectional, and cohort studies; editorials, letters, and opinions; cost studies; KQ2,3= Case-control and cross-sectional studies; editorials, letters, and opinions; cost studies
E8 Study Quality: Poor
E9 Publication type: Abstract-only, Non-English publication

* Assigned at full-text phase.

1 Anonymous. Population-Based Study of Incidence of Acute Abdominal Aortic Aneurysms With Projected Impact of Screening Strategy.[Erratum for J Am Heart Assoc. 2015 Aug;4(8):e001926; PMID: 26289347]. J Am Heart Assoc. 2015;4(10):e001992. PMID: 26486168. 10.1161/JAHA.115.001992 KQ1E9, KQ2E9, KQ3E9,26486168
2 Bath MF, Sidloff D, Saratzis A, . Impact of abdominal aortic aneurysm screening on quality of life. British Journal of Surgery. 2018;105(3):203–8. PMID: 29405273. 10.1002/bjs.10721 KQ1E1, KQ2E1, KQ3E7.29405273
3 Baxter BT, Matsumura J, Curci J, . Non-invasive Treatment of Abdominal Aortic Aneurysm Clinical Trial (N-TA(3)CT): Design of a Phase IIb, placebo-controlled, double-blind, randomized clinical trial of doxycycline for the reduction of growth of small abdominal aortic aneurysm. Contemporary clinical trials. 2016;48:91–8. PMID: 27018941. 10.1016/j.cct.2016.03.008 KQ4E4, KQ5E4.27018941
4 Bergqvist D, Lindeman JH, Lindholt JS, . Antimicrobial treatment to impair expansion of abdominal aortic aneurysm (AAA): a systematic review of the clinical evidence. Current vascular pharmacology. 2013;11(3):288–92. PMID: 22724481. KQ4E7, KQ5E7.22724481
5 Candell L, Tucker LY, Goodney P, . Early and delayed rupture after endovascular abdominal aortic aneurysm repair in a 10-year multicenter registry. Journal of vascular surgery. 2014;60(5):1146–52. PMID: 24957409. 10.1016/j.jvs.2014.05.046 KQ4E3b, KQ5E3b.24957409
6 Chung C, Tadros R, Torres M, . Evolution of gender-related differences in outcomes from two decades of endovascular aneurysm repair. Journal of vascular surgery. 2015;61(4):843–52. PMID: 25595407. 10.1016/j.jvs.2014.11.006 KQ4E3b, KQ5E3b.25595407
7 Cotter AR, Vuong K, Mustelin L, . Do psychological harms result from being labelled with an unexpected diagnosis of abdominal aortic aneurysm or prostate cancer through screening? A systematic review. BMJ open. 2017;7(12):e017565. PMID: 29237653. 10.1136/bmjopen-2017-017565 KQ1E1, KQ2E1, KQ3E7.29237653
8 Dahl M, Sogaard R, Frost L, . Effectiveness of Screening Postmenopausal Women for Cardiovascular Diseases: A Population Based, Prospective Parallel Cohort Study. European Journal of Vascular & Endovascular Surgery. 2018;55(5):721–9. PMID: 29625727. 10.1016/j.ejvs.2018.02.034 KQ1E7, KQ2E1, KQ3E1.29625727
9 Dalman RL, Xuan H, Wang W, . Angiotensin Receptor Blockers in Abdominal Aortic Aneurysm Management: Evidence Supporting the TEDY Trial. Journal of vascular surgery. 2016;64(2):539. PMID: 27763287. 10.1016/j.jvs.2016.05.009 KQ4E1, KQ5E1.
10 Davenport DL, Xenos ES. Deep venous thrombosis after repair of nonruptured abdominal aneurysm. Journal of vascular surgery. 2013;57(3):678–83.e1. PMID: 23343666. 10.1016/j.jvs.2012.09.048 KQ4E3b, KQ5E3b.23343666
11 de Blic R, Alsac JM, Julia P, . Elective treatment of abdominal aortic aneurysm is reasonable in patients >85 years of age. Annals of vascular surgery. 2014;28(1):209–16. PMID: 24084274. 10.1016/j.avsg.2013.01.022 KQ4E3b, KQ5E3b.24084274
12 Deery SE, O’Donnell TFX, Bodewes TCF, . Early reintervention after open and endovascular abdominal aortic aneurysm repair is associated with high mortality. Journal of vascular surgery. 2018;67(2):433–40.e1. PMID: 28943011. 10.1016/j.jvs.2017.06.104 KQ4E1, KQ5E3b.28943011
13 Deery SE, Schermerhorn ML. Open versus endovascular abdominal aortic aneurysm repair in Medicare beneficiaries. Surgery. 2017;162(4):721–31. PMID: 28343694. 10.1016/j.surg.2017.01.022 KQ4E3b, KQ5E3b.28343694
14 Deery SE, Soden PA, Zettervall SL, . Sex differences in mortality and morbidity following repair of intact abdominal aortic aneurysms. Journal of vascular surgery. 2017;65(4):1006–13. PMID: 27986477. 10.1016/j.jvs.2016.08.100 KQ4E3b, KQ5E3b.27986477
15 Dua A, Ali F, Traudt E, . Utilization of the National Inpatient Sample for abdominal aortic aneurysm research. Surgery. 2017;162(4):699–706. PMID: 28237647. 10.1016/j.surg.2016.12.036 KQ4E1, KQ5E1.28237647
16 Dua A, Kuy S, Lee CJ, . Epidemiology of aortic aneurysm repair in the United States from 2000 to 2010. Journal of vascular surgery. 2014;59(6):1512–7. PMID: 24560865. 10.1016/j.jvs.2014.01.007 KQ4E7, KQ5E7.24560865
17 Dubois L, Novick TV, Harris JR, . Outcomes after endovascular abdominal aortic aneurysm repair are equivalent between genders despite anatomic differences in women. Journal of vascular surgery. 2013;57(2):382–9.e1. PMID: 23266281. 10.1016/j.jvs.2012.09.075 KQ4E3b, KQ5E3b.23266281
18 Duwayri Y, Goss J, Knechtle W, . The Readmission Event after Vascular Surgery: Causes and Costs. Annals of vascular surgery. 2016;36:7–12. PMID: 27321981. 10.1016/j.avsg.2016.02.024 KQ4E3b, KQ5E3b.27321981
19 Ericsson A, Holst J, Gottsater A, . Psychosocial consequences in men taking part in a national screening program for abdominal aortic aneurysm. J Vasc Nurs. 2017;35(4):211–20. PMID: 29153229. 10.1016/j.jvn.2017.06.001 KQ1E1, KQ2E1, KQ3E7.29153229
20 Flink BJ, Long CA, Duwayri Y, . Women undergoing aortic surgery are at higher risk for unplanned readmissions compared with men especially when discharged home. Journal of vascular surgery. 2016;63(6):1496–504.e1. PMID: 27106246. 10.1016/j.jvs.2015.12.054 KQ4E3b, KQ5E3b.27106246
21 Hafez H, Druce PS, Ashton HA. Abdominal aortic aneurysm development in men following a “normal” aortic ultrasound scan. European journal of vascular and endovascular surgery : the official journal of the European Society for Vascular Surgery. 2008;36(5):553–8. PMID: 18718773. KQ1E4, KQ2E4, KQ3E4,18718773
22 Hicks CW, Obeid T, Arhuidese I, . Abdominal aortic aneurysm repair in octogenarians is associated with higher mortality compared with nonoctogenarians. Journal of vascular surgery. 2016;64(4):956–65.e1. PMID: 27364946. 10.1016/j.jvs.2016.03.440 KQ4E5b, KQ5E5b.27364946
23 Hinterseher I, Kuffner H, Berth H, . Long-term quality of life of abdominal aortic aneurysm patients under surveillance or after operative treatment. Annals of vascular surgery. 2013;27(5):553–61. PMID: 23540664. KQ4E6, KQ5E6.23540664
24 Hoel AW, Faerber AE, Moore KO, . A pilot study for long-term outcome assessment after aortic aneurysm repair using Vascular Quality Initiative data matched to Medicare claims. Journal of vascular surgery. 2017;66(3):751–9.e1. PMID: 28222989. 10.1016/j.jvs.2016.12.100 KQ4E3b, KQ5E3b.28222989
25 Hughes K, Abdulrahman H, Prendergast T, . Abdominal aortic aneurysm repair in nonagenarians. Annals of vascular surgery. 2015;29(2):183–8. PMID: 25461753. 10.1016/j.avsg.2014.07.037 KQ4E3b, KQ5E3b.25461753
26 Hultgren R. Commentary on “Five Year Natural History of Screening Detected Sub-Aneurysms and Abdominal Aortic Aneurysms in 70 Year Old Women and Systematic Review of Repair Rate in Women”. European journal of vascular and endovascular surgery : the official journal of the European Society for Vascular Surgery. 2017;53(6):810. PMID: 28420552. 10.1016/j.ejvs.2017.03.013 KQ1E7, KQ2E7, KQ3E7,28420552
27 Hye RJ, Inui TS, Anthony FF, . A multiregional registry experience using an electronic medical record to optimize data capture for longitudinal outcomes in endovascular abdominal aortic aneurysm repair. Journal of vascular surgery. 2015;61(5):1160–6. PMID: 25725597. 10.1016/j.jvs.2014.12.055 KQ4E3b, KQ5E3b.25725597
28 Jacomelli J, Summers L, Stevenson A, . Update on the prevention of death from ruptured abdominal aortic aneurysm. Journal of medical screening. 2017;24(3):166–8. PMID: 28756762. 10.1177/0969141316667409 KQ1E4, KQ2E4, KQ3E4,28756762
29 Karthikesalingam A, Bahia SS, Patterson BO, . The shortfall in long-term survival of patients with repaired thoracic or abdominal aortic aneurysms: retrospective case-control analysis of hospital episode statistics. European journal of vascular and endovascular surgery : the official journal of the European Society for Vascular Surgery. 2013;46(5):533–41. PMID: 24091096. 10.1016/j.ejvs.2013.09.008 KQ4E3b, KQ5E3b.24091096
30 Khashram M, Thomson IA, Jones GT, . Abdominal aortic aneurysm repair in New Zealand: a validation of the Australasian Vascular Audit. ANZ J Surg. 2017;87(5):394–8. PMID: 27492991. 10.1111/ans.13702 KQ4E3b, KQ5E3b.27492991
31 Lederle FA. Does Abdominal Aortic Aneurysm Screening Save Lives? JAMA Surgery. 2016;151(8):697–8. PMID: 27119312. 10.1001/jamasurg.2016.0044 KQ1E7, KQ2E7, KQ3E7,27119312
32 Lee SY, Peacock MR, Farber A, . Perioperative Infections after Open Abdominal Aortic Aneurysm Repair Lead to Increased Risk of Subsequent Complications. Annals of vascular surgery. 2017;4:203–10. PMID: 28483623. 10.1016/j.avsg.2017.04.022 KQ4E3b, KQ5E3b.28483623
33 Lijftogt N, Vahl AC, Wilschut ED, . Adjusted Hospital Outcomes of Abdominal Aortic Aneurysm Surgery Reported in the Dutch Surgical Aneurysm Audit. European journal of vascular and endovascular surgery : the official journal of the European Society for Vascular Surgery. 2017;53(4):520–32. PMID: 28256396. 10.1016/j.ejvs.2016.12.037 KQ4E3b, KQ5E3b.28256396
34 Lilja F, Mani K, Wanhainen A. Editor’s Choice - Trend-break in Abdominal Aortic Aneurysm Repair With Decreasing Surgical Workload. European journal of vascular and endovascular surgery : the official journal of the European Society for Vascular Surgery. 2017;53(6):811–9. PMID: 28392057. 10.1016/j.ejvs.2017.02.031 KQ4E3b, KQ5E3b.28392057
35 Lindholt JS, Vammen S, Fasting H, . Psychological consequences of screening for abdominal aortic aneurysm and conservative treatment of small abdominal aortic aneurysms. European journal of vascular and endovascular surgery : the official journal of the European Society for Vascular Surgery. 2000;20(1):79–83. PMID: 10906303. 10.1053/ejvs.1999.1087 KQ1E4, KQ2E4, KQ3E6,10906303
36 Locham S, Lee R, Nejim B, . Mortality after endovascular versus open repair of abdominal aortic aneurysm in the elderly. J Surg Res. 2017;215:153–9. PMID: 28688641. 10.1016/j.jss.2017.03.061 KQ4E3b, KQ5E3b.28688641
37 Loftus I, Vascular Society of Great B, Ireland. National Vascular Registry Report on surgical outcomes and implications for vascular centres (Br J Surg 2014; 101: 637–642). British Journal of Surgery. 2014;101(6):642. PMID: 24723018. KQ4E7, KQ5E7.24723018
38 Makrygiannis G, Labalue P, Erpicum M, . Extending Abdominal Aortic Aneurysm Detection to Older Age Groups: Preliminary Results from the Liege Screening Programme. Annals of vascular surgery. 2016;36:55–63. PMID: 27364735. 10.1016/j.avsg.2016.02.034 KQ1E4, KQ2E4, KQ3E4,27364735
39 Mani K, Bjorck M, Wanhainen A. Changes in the management of infrarenal abdominal aortic aneurysm disease in Sweden. British Journal of Surgery. 2013;100(5):638–44. PMID: 23334950. 10.1002/bjs.9046 KQ4E3b, KQ5E3b.23334950
40 Matyal R, Shakil O, Hess PE, . Impact of gender and body surface area on outcome after abdominal aortic aneurysm repair. Am J Surg. 2015;209(2):315–23. PMID: 25457240. 10.1016/j.amjsurg.2014.07.008 KQ4E3b, KQ5E3b.25457240
41 Mayor S. Women having surgery for abdominal aortic aneurysm are nearly twice as likely to die as men. BMJ. 2017;357:j2054. PMID: 28446431. 10.1136/bmj.j2054 KQ4E9, KQ5E9.
42 Morris DR, Cunningham MA, Ahimastos AA, . TElmisartan in the management of abDominal aortic aneurYsm (TEDY): The study protocol for a randomized controlled trial. Trials. 2015;16:274. PMID: 26081587. 10.1186/s13063-015-0793-z KQ4E4, KQ5E4.26081587
43 Morris DR, Cunningham MA, Ahimastos AA, . Erratum to: ‘TElmisartan in the management of abDominal aortic aneurYsm (TEDY): The study protocol for a randomized controlled trial’.[Erratum for Trials. 2015;16:274; PMID: 26081587]. Trials [Electronic Resource]. 2016;17:43. PMID: 26791257. 10.1186/s13063-016-1183-x KQ4E4, KQ5E4.26791257
44 Murohara T, Kureishi BY, Nishigami K, . Effects of angiotensin-II receptor blocker or calcium channel blocker on abdominal aortic aneurysm growth at presurgical stage. European heart journal. 2015;36:880–1. PMID: None. 10.1093/eurheartj/ehv401 KQ4E9, KQ5E9.
45 Myers J, McElrath M, Jaffe A, . A randomized trial of exercise training in abdominal aortic aneurysm disease. Med Sci Sports Exerc. 2014;46(1):2–9. PMID: 23793234. 10.1249/MSS.0b013e3182a088b8 KQ4E5b, KQ5E5b.23793234
46 Nevidomskyte D, Shalhub S, Niten S, ., editors. Influence of gender on abdominal aortic aneurysm repair in the community. Annals of vascular surgery. Conference: 25th annual winter meeting vascular and endovascular surgery society. United states; 2015; United States. KQ Search 20170914 - CENTRAL. KQ4E9, KQ5E9.
47 Nevidomskyte D, Shalhub S, Singh N, . Influence of Gender on Abdominal Aortic Aneurysm Repair in the Community. Annals of vascular surgery. 2017;39:128–36. PMID: 27575306. 10.1016/j.avsg.2016.06.012 KQ4E3b, KQ5E3b.27575306
48 Park BD, Azefor NM, Huang CC, . Elective endovascular aneurysm repair in the elderly: trends and outcomes from the Nationwide Inpatient Sample. Annals of vascular surgery. 2014;28(4):798–807. PMID: 24189191. 10.1016/j.avsg.2013.07.029 KQ4E3b, KQ5E3b.24189191
49 Powell JT. Prophylactic Abdominal Aortic Aneurysm Repair? Open Repair Brings Early Pain but Later Gain. European journal of vascular and endovascular surgery : the official journal of the European Society for Vascular Surgery. 2016;52(6):719–20. PMID: 27914533. 10.1016/j.ejvs.2016.07.008 KQ4E7, KQ5E7.27914533
50 Qadura M, Pervaiz F, Harlock J, . Mortality and reintervention following elective abdominal aortic aneurysm repair. Journal of vascular surgery. 2013;57(6):1676–83. PMID: 23719040. KQ4E3b, KQ5E3b.23719040
51 Quinn AA, Mehta M, Teymouri MJ, . The incidence and fate of endoleaks vary between ruptured and elective endovascular abdominal aortic aneurysm repair. Journal of vascular surgery. 2017;65(6):1617–24. PMID: 28268109. 10.1016/j.jvs.2016.10.092 KQ4E3b, KQ5E3b.28268109
52 RESCAN Collaborators, Bown MJ, Sweeting MJ, . Surveillance intervals for small abdominal aortic aneurysms: a meta-analysis. JAMA. 2013;309(8):806–13. PMID: 23443444. KQ1E4, KQ2E4, KQ3E4,23443444
53 Roddy SP. Abdominal aortic aneurysm screening. Journal of vascular surgery. 2017;65(5):1537. PMID: 28434598. 10.1016/j.jvs.2017.02.021 KQ1E7, KQ2E7, KQ3E7,28434598
54 Schmitz-Rixen T, Steffen M, Grundmann R. Treatment of abdominal aortic aneurysms (AAA) 2015: registry report from the German Institute of Vascular Healthcare Research (DIGG) of the German Society for Vascular Surgery and Vascular Medicine (DGG).Gerasschirurgie. 2017:1–9. PMID: None. 10.1007/s00772-017-0253-z KQ4E9, KQ5E9.
55 Sillesen H, Eldrup N, Hultgren R, . Randomized clinical trial of mast cell inhibition in patients with a medium-sized abdominal aortic aneurysm.[Erratum for Br J Surg. 2015 Jul;102(8):894–901; PMID: 25963302]. British Journal of Surgery. 2015;102(10):1295. PMID: 26267607. 10.1002/bjs.9917 KQ4E9, KQ5E9.26267607
56 Sillesen H, Eldrup N, Hultgren R, . Randomized clinical trial of mast cell inhibition in patients with a medium-sized abdominal aortic aneurysm.[Erratum appears in Br J Surg. 2015 Sep;102(10):1295; PMID: 26267607], [Erratum appears in Br J Surg. 2016 Feb;103(3):308; PMID: 26785648]. British Journal of Surgery. 2015;102(8):894–901. PMID: 25963302. 10.1002/bjs.9824 KQ4E9, KQ5E9.25963302
57 Stather P, Sidloff D, Dattani N, . Systematic review and meta-analysis of the early and late outcomes of open and endovascular repair of abdominal aortic aneurysm (Provisional abstract). British Journal of Surgery. 2013;100(7):863–72. PMID: None. KQ4E7, KQ5E7.23475697
58 Takagi H, Umemoto T, Group A. A meta-analysis pooling survival curves in randomized controlled trials and propensity-score matched studies of endovascular versus open abdominal aortic aneurysm repair. International journal of cardiology. 2014;174(3):785–8. PMID: 24798785. KQ4E3b, KQ5E3b.24798785
59 Tan TW, Eslami M, Rybin D, . Outcomes of endovascular and open surgical repair of ruptured abdominal aortic aneurysms in elderly patients. Journal of vascular surgery. 2017;66(1):64–70. PMID: 28216354. 10.1016/j.jvs.2016.10.119 KQ4E3a, KQ5E3a.28216354
60 Tomee SM, Lijftogt N, Vahl A, . A registry-based rationale for discrete intervention thresholds for open and endovascular elective abdominal aortic aneurysm repair in female patients. Journal of vascular surgery. 2017;27:27. PMID: 28964619. KQ4E3b, KQ5E3b.28964619
61 Trenner M, Haller B, Storck M, . Trends in Patient Safety of Intact Abdominal Aortic Aneurysm Repair: German Registry Data on 36,594 Procedures. European journal of vascular and endovascular surgery : the official journal of the European Society for Vascular Surgery. 2017;53(5):641–7. PMID: 28110907. 10.1016/j.ejvs.2016.12.024 KQ4E3b, KQ5E3b.28110907
62 Ulug P, Sweeting MJ, von Allmen RS, . Morphological suitability for endovascular repair, non-intervention rates, and operative mortality in women and men assessed for intact abdominal aortic aneurysm repair: systematic reviews with meta-analysis. Lancet. 2017;389(10088):2482–91. PMID: 28455148. 10.1016/S0140-6736(17)30639-6 KQ4E3b, KQ5E3b.28455148
63 van de Luijtgaarden KM, Bastos Goncalves F, Hoeks SE, . Higher 30 Day Mortality in Patients with Familial Abdominal Aortic Aneurysm after EVAR. European journal of vascular and endovascular surgery : the official journal of the European Society for Vascular Surgery. 2017;54(2):142–9. PMID: 28579278. 10.1016/j.ejvs.2017.04.018 KQ4E3b, KQ5E3b.28579278
64 Wang GJ. Commentary on “Should Abdominal Aortic Aneurysms in Women Be Repaired at a Lower Diameter Threshold?”. Vascular & Endovascular Surgery. 2017:1538574417723483. PMID: 28782416. 10.1177/1538574417723483 KQ1E7, KQ2E7, KQ3E7,28782416
65 Wendt K, Kristiansen R, Krohg-Sorensen K, . Trends in Abdominal Aortic and Iliac Aneurysm Repairs in Norway from 2001 to 2013. European journal of vascular and endovascular surgery : the official journal of the European Society for Vascular Surgery. 2016;51(2):194–201. PMID: 26482508. 10.1016/j.ejvs.2015.08.015 KQ4E4, KQ5E4.26482508
66 Yin K, Locham SS, Schermerhorn ML, . Trends of 30-day mortality and morbidities in endovascular repair of intact abdominal aortic aneurysm during the last decade. Journal of vascular surgery. 2018. PMID: 29914839. 10.1016/j.jvs.2018.04.032 KQ4E1, KQ5E3b.29914839
67 Zettervall SL, Buck DB, Soden PA, . Regional variation exists in patient selection and treatment of abdominal aortic aneurysms. Journal of vascular surgery. 2016;64(4):921–7.e1. PMID: 27066949. 10.1016/j.jvs.2016.02.036 KQ4E3b, KQ5E3b.27066949