# Appendix C Included Studies

Below is a list of included studies and their ancillary publications (indented below main results publication):

## Key Questions 1 & 3

### Chichester

- Ashton HA, Gao L, Kim LG, . Fifteen-year follow-up of a randomized clinical trial of ultrasonographic screening for abdominal aortic aneurysms. The British journal of surgery. 2007;94(6):696–701. PMID: 17514666. 10.1002/bjs.5780.17514666
  - Scott RA, Wilson NM, Ashton HA, . Influence of screening on the incidence of ruptured abdominal aortic aneurysm: 5-year results of a randomized controlled study. The British journal of surgery. 1995;82(8):1066–70. PMID: 7648155.7648155
  - Scott RA, Bridgewater SG, Ashton HA. Randomized clinical trial of screening for abdominal aortic aneurysm in women. The British journal of surgery. 2002;89(3):283–5. PMID: 11872050. 10.1046/j.0007-1323.2001.02014.x.11872050
  - Vardulaki KA, Walker NM, Couto E, . Late results concerning feasibility and compliance from a randomized trial of ultrasonographic screening for abdominal aortic aneurysm. The British journal of surgery. 2002;89(7):861–4. PMID: 12081734. 10.1046/j.1365-2168.2002.02133.x.12081734

### Multicentre Aneurysm Screening Study (MASS)

- Thompson SG, Ashton HA, Gao L, . Final follow-up of the Multicentre Aneurysm Screening Study (MASS) randomized trial of abdominal aortic aneurysm screening. The British journal of surgery. 2012;99(12):1649–56. PMID: 23034729. 10.1002/bjs.8897.23034729
  - Ashton HA, Buxton MJ, Day NE, . The Multicentre Aneurysm Screening Study (MASS) into the effect of abdominal aortic aneurysm screening on mortality in men: a randomised controlled trial. Lancet. 2002;360(9345):1531–9. PMID: 12443589.12443589
  - Kim LG, Ra PS, Ashton HA, . A sustained mortality benefit from screening for abdominal aortic aneurysm. Annals of internal medicine. 2007;146(10):699–706. PMID: 17502630.17502630
  - Kim LG, Scott RAP, Ashton HA, . A prolonged mortality benefit from screening for abdominal aortic aneurysm: seven-year follow-up of the MASS trial. SO: The Vascular Society of Great Britain & Ireland Yearbook 2006. 2006:77.
  - Thompson SG, Ashton HA, Gao L, . Screening men for abdominal aortic aneurysm: 10 year mortality and cost effectiveness results from the randomised Multicentre Aneurysm Screening Study. BMJ. 2009;338:b2307. PMID: 19553269.19553269

### Viborg

- Lindholt JS, Sorensen J, Sogaard R, . Long-term benefit and cost-effectiveness analysis of screening for abdominal aortic aneurysms from a randomized controlled trial. The British journal of surgery. 2010;97(6):826–34. PMID: 20473995. 10.1002/bjs.7001.20473995
  - Lindholt JS, Juul S, Fasting H, . Hospital costs and benefits of screening for abdominal aortic aneurysms. Results from a randomised population screening trial. Eur J Vasc Endovasc Surg. 2002;23(1):55–60. PMID: 11748949. 10.1053/ejvs.2001.1534.11748949
  - Lindholt JS, Juul S, Fasting H, . Screening for abdominal aortic aneurysms: single centre randomised controlled trial. BMJ. 2005;330(7494):750. PMID: 15757960. 10.1136/bmj.38369.620162.82 15757960
  - Lindholt JS, Juul S, Henneberg EW. High-risk and low-risk screening for abdominal aortic aneurysm both reduce aneurysm-related mortality. A stratified analysis from a single-centre randomised screening trial. Eur J Vasc Endovasc Surg. 2007;34(1):53–8. PMID: 17331750. 10.1016/j.ejvs.2006.12.031.17331750
  - Lindholt JS, Juul S, Fasting H, . Preliminary ten year results from a randomised single centre mass screening trial for abdominal aortic aneurysm. Eur J Vasc Endovasc Surg. 2006;32(6):608–14. PMID: 16893663. 10.1016/j.ejvs.2006.06.008.16893663

### Western Australia

- McCaul KA, Lawrence-Brown M, Dickinson JA, . Long-term Outcomes of the Western Australian Trial of Screening for Abdominal Aortic Aneurysms: Secondary Analysis of a Randomized Clinical Trial. JAMA Intern Med. 2016;176(12):1761–7. PMID: 27802493. 10.1001/jamainternmed.2016.6633.27802493
  - Jamrozik K, Norman PE, Spencer CA, . Screening for abdominal aortic aneurysm: lessons from a population-based study. Med J Aust. 2000;173(7):345–50. PMID: 11062788.11062788
  - Norman PE, Jamrozik K, Lawrence-Brown MM, . Western Australian randomized controlled trial of screening for abdominal aortic aneurysm. The British journal of surgery. 2003;90(4):492.
  - Norman PE, Jamrozik K, Lawrence-Brown MM, . Population based randomised controlled trial on impact of screening on mortality from abdominal aortic aneurysm. BMJ. 2004;329(7477):1259. PMID: 15545293. 10.1136/bmj.38272.478438.55.15545293
  - Spencer CA, Norman PE, Jamrozik K, . Is screening for abdominal aortic aneurysm bad for your health and well-being? ANZ J Surg. 2004;74(12):1069–75. PMID: 15574151. 10.1111/j.1445-1433.2004.03270.x.15574151

## Key Question 2

- d’Audiffret A, Santilli S, Tretinyak A, . Fate of the ectatic infrarenal aorta: expansion rates and outcomes. Annals of vascular surgery. 2002;16(5):534–6.12183768
- Devaraj S, Dodds SR. Ultrasound surveillance of ectatic abdominal aortas. Ann R Coll Surg Engl. 2008;90(6):477–82. PMID: 18765027. 10.1308/003588408X301064.18765027
- Lederle FA, Johnson GR, Wilson SE, . Yield of repeated screening for abdominal aortic aneurysm after a 4-year interval. Aneurysm Detection and Management Veterans Affairs Cooperative Study Investigators. Arch Intern Med. 2000;160(8):1117–21. PMID: 10789604.10789604
- Oliver-Williams C, Sweeting MJ, Turton G, . Lessons learned about prevalence and growth rates of abdominal aortic aneurysms from a 25-year ultrasound population screening programme. Br J Surg. 2018;105(1):68–74. PMID: 29265406. 10.1002/bjs.10715.29265406
  - Crow P, Shaw E, Earnshaw JJ, . A single normal ultrasonographic scan at age 65 years rules out significant aneurysm disease for life in men. The British journal of surgery. 2001;88(7):941–4. PMID: 11442524. 10.1046/j.0007-1323.2001.01822.x.11442524
  - Darwood R, Earnshaw JJ, Turton G, . Twenty-year review of abdominal aortic aneurysm screening in men in the county of Gloucestershire, United Kingdom. Journal of vascular surgery. 2012;56(1):8–13. PMID: 22503187. 10.1016/j.jvs.2011.12.069.22503187
  - Emerton ME, Shaw E, Poskitt K, . Screening for abdominal aortic aneurysm: a single scan is enough. The British journal of surgery. 1994;81(8):1112–3. PMID: 7953333.7953333
  - McCarthy RJ, Shaw E, Whyman MR, . Recommendations for screening intervals for small aortic aneurysms. The British journal of surgery. 2003;90(7):821–6. PMID: 12854107. 10.1002/bjs.4216.12854107

### Chichester

- Scott RA, Vardulaki KA, Walker NM, . The long-term benefits of a single scan for abdominal aortic aneurysm (AAA) at age 65. Eur J Vasc Endovasc Surg. 2001;21(6):535–40. PMID: 11397028. 10.1053/ejvs.2001.1368.11397028
- Soderberg P, Wanhainen A, Svensjo S. Five Year Natural History of Screening Detected Sub-Aneurysms and Abdominal Aortic Aneurysms in 70 Year Old Women and Systematic Review of Repair Rate in Women. Eur J Vasc Endovasc Surg. 2017;53(6):802–9. PMID: 28389251. 10.1016/j.ejvs.2017.02.024.28389251
- Svensjo S, Bjorck M, Wanhainen A. Editor’s choice: five-year outcomes in men screened for abdominal aortic aneurysm at 65 years of age: a population-based cohort study. European journal of vascular and endovascular surgery : the official journal of the European Society for Vascular Surgery. 2014;47(1):37–44. PMID: 24262320. 10.1016/j.ejvs.2013.10.007.24262320

## Additional studies for Key Question 3 (only included for screening harms)

- Lesjak M, Boreland F, Lyle D, . Screening for abdominal aortic aneurysm: does it affect men’s quality of life? Aust J Prim Health. 2012. PMID: 22951209. 10.1071/PY11131.22951209

### Viborg Vascular (VIVA)

- Lindholt JS, Sogaard R. Population screening and intervention for vascular disease in Danish men (VIVA): a randomised controlled trial. Lancet. 2017. PMID: 28859943. 10.1016/s0140-6736(17)32250-x.28859943
  - Grondal N, Sogaard R, Lindholt JS. Baseline prevalence of abdominal aortic aneurysm, peripheral arterial disease and hypertension in men aged 65–74 years from a population screening study (VIVA trial). Br J Surg. 2015;102(8):902–6. PMID: 25923784. 10.1002/bjs.9825.25923784
- Lucarotti ME, Heather BP, Shaw E, . Psychological morbidity associated with abdominal aortic aneurysm screening. Eur J Vasc Endovasc Surg. 1997;14(6):499–501. PMID: 9467527.9467527
- Wanhainen A, Rosen C, Rutegard J, . Low quality of life prior to screening for abdominal aortic aneurysm: a possible risk factor for negative mental effects. Annals of vascular surgery. 2004;18(3):287–93. PMID: 15354629. 10.1007/s10016-004-0021-x.15354629

## Key Questions 4 & 5

### Open vs. Surveillance

#### ADAM

- Lederle FA, Wilson SE, Johnson GR, . Immediate repair compared with surveillance of small abdominal aortic aneurysms. N Engl J Med. 2002;346(19):1437–44. PMID: 12000813. 10.1056/NEJMoa012573.12000813
  - Lederle FA, Wilson SE, Johnson GR, . Design of the abdominal aortic Aneurysm Detection and Management Study. ADAM VA Cooperative Study Group. Journal of vascular surgery. 1994;20(2):296–303. PMID: 8040955.8040955
  - Filardo G, Lederle FA, Ballard DJ, . Immediate open repair vs surveillance in patients with small abdominal aortic aneurysms: survival differences by aneurysm size. Mayo Clin Proc. 2013;88(9):910–9. PMID: 24001483. 10.1016/j.mayocp.2013.05.014.24001483

#### UKSAT

- Powell JT, Brown LC, Forbes JF, . Final 12-year follow-up of surgery versus surveillance in the UK Small Aneurysm Trial. Br J Surg. 2007;94(6):702–8. PMID: 17514693. 10.1002/bjs.5778.17514693
  - Brown LC, Powell JT. Risk factors for aneurysm rupture in patients kept under ultrasound surveillance. UK Small Aneurysm Trial Participants. Ann Surg. 1999;230(3):289–96; discussion 96–7. PMID: 10493476.10493476
  - Brown LC, Thompson SG, Greenhalgh RM, . Fit patients with small abdominal aortic aneurysms (AAAs) do not benefit from early intervention. J Vasc Surg. 2008;48(6):1375–81. PMID: 19118733. 10.1016/j.jvs.2008.07.014 19118733
  - Fowkes FG, Greenhalgh RM, Powell JT, . Length of hospital stay following elective abdominal aortic aneurysm repair. U.K. Small Aneurysm Trial Participants. Eur J Vasc Endovasc Surg. 1998;16(3):185–91. PMID: 9787298.9787298
  - Greenhalgh RM, Forbes JF, Fowkes FG, . The UK Small Aneurysm Trial: design, methods and progress. Eur J Vasc Endovasc Surg. 1995;9(1):42–8. PMID: 7664011.7664011
  - Powell JT. Long-term outcomes of immediate repair compared with surveillance of small abdominal aortic aneurysms. N Engl J Med. 2002;346(19):1445–52. PMID: 12000814. 10.1056/NEJMoa013527.12000814
  - Powell JT, Brady AR, Brown LC, . Mortality results for randomised controlled trial of early elective surgery or ultrasonographic surveillance for small abdominal aortic aneurysms. The UK Small Aneurysm Trial Participants. Lancet. 1998;352(9141):1649–55. PMID: 9853436.9853436
  - Filardo G, Lederle FA, Ballard DJ, . Immediate open repair vs surveillance in patients with small abdominal aortic aneurysms: survival differences by aneurysm size. Mayo Clin Proc. 2013;88(9):910–9. PMID: 24001483. 10.1016/j.mayocp.2013.05.014.24001483

### EVAR vs. Surveillance

#### CAESAR

- Cao P, De RP, Verzini F, . Comparison of surveillance versus aortic endografting for small aneurysm repair (CAESAR): results from a randomised trial. European journal of vascular and endovascular surgery : the official journal of the European Society for Vascular Surgery. 2011;41(1):13–25. PMID: 20869890. 10.1016/j.ejvs.2010.08.026 20869890
  - Cao P. Comparison of surveillance vs aortic endografting for small aneurysm repair (CAESAR) trial: study design and progress. Eur J Vasc Endovasc Surg. 2005;30(3):245–51. PMID: 16130206.16130206

#### PIVOTAL

- Ouriel K, Clair DG, Kent KC, . Endovascular repair compared with surveillance for patients with small abdominal aortic aneurysms. Journal of vascular surgery. 2010;51(5):1081–7. PMID: 20304589. 10.1016/j.jvs.2009.10.113 20304589
  - Ouriel K. The PIVOTAL study: A randomized comparison of endovascular repair versus surveillance in patients with smaller abdominal aortic aneurysms. Journal of vascular surgery. 2009;49(1):266–9. PMID: 19174266. 10.1016/j.jvs.2008.11.048.19174266

#### Pharmacotherapy vs. Placebo

- Bicknell CD, Kiru G, Falaschetti E, . An evaluation of the effect of an angiotensin-converting enzyme inhibitor on the growth rate of small abdominal aortic aneurysms: a randomized placebo-controlled trial (AARDVARK). European heart journal. 2016;37(42):3213–21. PMID: 27371719. 10.1093/eurheartj/ehw257 27371719
  - Kiru G, Bicknell C, Falaschetti E, . An evaluation of the effect of an angiotensin-converting enzyme inhibitor on the growth rate of small abdominal aortic aneurysms: a randomised placebo-controlled trial (AARDVARK). Health technology assessment (Winchester, England). 2016;20(59):1–180. PMID: 27488944. 10.3310/hta20590.27488944
- Karlsson L, Gnarpe J, Bergqvist D, . The effect of azithromycin and Chlamydophilia pneumonia infection on expansion of small abdominal aortic aneurysms-a prospective randomized double-blind trial. Journal of vascular surgery. 2009;50(1):23–9. PMID: 19563951. 10.1016/j.jvs.2008.12.048.19563951
- Hogh A, Vammen S, Ostergaard L, . Intermittent roxithromycin for preventing progression of small abdominal aortic aneurysms: long-term results of a small clinical trial. Vasc Endovascular Surg. 2009;43(5):452–6. PMID: 19640922. 10.1177/1538574409335037.19640922
  - Vammen S, Lindholt JS, Ostergaard L, . Randomized double-blind controlled trial of roxithromycin for prevention of abdominal aortic aneurysm expansion. The British journal of surgery. 2001;88(8):1066–72. PMID: 11488791. 10.1046/j.0007-1323.2001.01845.x.11488791
  - Hogh A, Vammen S, Joensen J, ., editors. Intermittent Roxithromycin Treatment for Preventing Small Abdominal Aortic Aneurysms Progression. Long Term Results from a Small Randomised Double-blinded Clinical Controlled Trial 2008 2008. PMID: None.
- Meijer C, Stijnen T, Wasser M, . Doxycycline for stabilization of abdominal aortic aneurysms: A randomized trial. Annals of internal medicine. 2013;159(12):815–23. PMID: 24490266. 10.7326/0003-4819-159-12-201312170-00007.24490266
- Mosorin M, Juvonen J, Biancari F, . Use of doxycycline to decrease the growth rate of abdominal aortic aneurysms: a randomized, double-blind, placebo-controlled pilot study. Journal of vascular surgery. 2001;34(4):606–10. PMID: 11668312. 10.1067/mva.2001.117891.11668312
- Propranolol Aneurysm Trial Investigators. Propranolol for small abdominal aortic aneurysms: results of a randomized trial. Journal of vascular surgery. 2002;35(1):72–9. PMID: 11802135.11802135
- Sillesen H, Eldrup N, Hultgren R, . Randomized clinical trial of mast cell inhibition in patients with a medium-sized abdominal aortic aneurysm. The British journal of surgery. 2015;102(8):894–901. PMID: 25963302. 10.1002/bjs.9824 25963302

## Additional studies for Key Question 5 (only included for treatment harms)

### Open vs. Surveillance

#### ADAM

- Lederle FA, Johnson GR, Wilson SE, . Quality of life, impotence, and activity level in a randomized trial of immediate repair versus surveillance of small abdominal aortic aneurysm. Journal of vascular surgery. 2003;38(4):745–52. PMID: 14560224.14560224

#### UKSAT

- Forbes JF, Brady AR, Brown LC, . Health service costs and quality of life for early elective surgery or ultrasonographic surveillance for small abdominal aortic aneurysms. UK Small Aneurysm Trial Participants. Lancet. 1998;352(9141):1656–60. PMID: 9853437.9853437

### EVAR vs. Surveillance

#### CAESAR

- De Rango P, Verzini F, Parlani G, . Quality of life in patients with small abdominal aortic aneurysm: the effect of early endovascular repair versus surveillance in the CAESAR trial. Eur J Vasc Endovasc Surg. 2011;41(3):324–31. PMID: 21145269. 10.1016/j.ejvs.2010.11.005.21145269

#### PIVOTAL

- Eisenstein EL, Davidson-Ray L, Edwards R, . Economic analysis of endovascular repair versus surveillance for patients with small abdominal aortic aneurysms. Journal of vascular surgery. 2013;58(2):302–10. PMID: 23562339. 10.1016/j.jvs.2013.01.038.23562339

### Pharmacotherapy vs. Placebo

- Lindholt JS, Henneberg EW, Juul S, . Impaired results of a randomised double blinded clinical trial of propranolol versus placebo on the expansion rate of small abdominal aortic aneurysms. International angiology : a journal of the International Union of Angiology. 1999;18(1):52–7. PMID: 10392481.10392481

### Surgical Registries

#### VASCUNET

- Budtz-Lilly J, Venermo M, Debus S, . Editor’s Choice - Assessment of International Outcomes of Intact Abdominal Aortic Aneurysm Repair over 9 Years. Eur J Vasc Endovasc Surg. 2017;54(1):13–20. PMID: 28416191. 10.1016/j.ejvs.2017.03.003 28416191

#### ASERNIP-S

- Golledge J, Parr A, Boult M, . The outcome of endovascular repair of small abdominal aortic aneurysms. Ann Surg. 2007;245(2):326–33. PMID: 17245188. 10.1097/01.sla.0000253965.95368.52.17245188

#### VSGNE

- Lo RC, Bensley RP, Hamdan AD, . Gender differences in abdominal aortic aneurysm presentation, repair, and mortality in the Vascular Study Group of New England. Journal of vascular surgery. 2013;57(5):1261–8, 8.e1–5. PMID: 23384493. 10.1016/j.jvs.2012.11.039 23384493

#### ACS NSQIP

- Overbey DM, Glebova NO, Chapman BC, . Morbidity of endovascular abdominal aortic aneurysm repair is directly related to diameter. Journal of vascular surgery. 2017;66(4):1037–47. PMID: 28433338. 10.1016/j.jvs.2017.01.058 28433338

#### EUROSTAR

- Peppelenbosch N, Buth J, Harris PL, . Diameter of abdominal aortic aneurysm and outcome of endovascular aneurysm repair: does size matter? A report from EUROSTAR. Journal of vascular surgery. 2004;39(2):288–97. PMID: 14743127. 10.1016/j.jvs.2003.09.047.14743127