# Appendix B AAA Screening With Ultrasonography Recommendations

Appendix B Table 1 Expert Groups’ Recommendation of AAA Screening With Ultrasonography

Organization (Year) | Population | Surveillance interval
American College of Cardiology and American Heart Association (2013)^95^ | Men age ≥60 years with a family history; Men ages 65–75 years who have ever smoked; Men & women age >50 years should be asked if they have AAA family history | <4.0 cm: every 2–3 years; 4.0–5.4 cm: every 6–12 months
American Academy of Family Physicians (NR)^97^ | Refers to USPSTF recommendation; Men ages 65–75 years who have ever smoked; Selectively screen men ages 65–75 years who have never smoked; Recommends against routine screening for women who have never smoked | Not stated
American College of Preventive Medicine (2011)^96^ | Men ages 65–75 years who have ever smoked; Recommends against routine screening in women | Not stated
Society for Vascular Surgery (2018)^3^ | All men and women ages 65–75 years with history of tobacco use; Men age ≥55 years with family history; Women age ≥65 years if family history/smoker | 2.5–3.0 cm: after 10 years; 3.0–3.9 cm: every 3 years; 4.0–4.9 cm: every 12 months; 5.0–5.4 cm: every 6 months
Canadian Task Force on Preventive Health Care (2017)^175^ | Men ages 65–80 years; Recommends not screening men age >80 or women at any age. | Not stated
Public Health England (2015)^246^ | Men ages 65–74 years | 3.0–4.4 cm: every 12 months; 4.5–5.4 cm: every 3 months
National Institute for Health and Care Excellence (NICE) DRAFT Guideline (2018)^186^ | All men age ≥66 years eligible to self-refer to screening; Encourage men age ≥66 years with risk factors to be screened; Consider screening women age ≥70 years with risk factors; Risk factors: COPD, family history, history of tobacco use, hyperlipdemia, hypertension, European origin | 3.0–4.4 cm: every 2 years; 4.5–5.4 cm: every 3 months

Abbreviations: AAA = abdominal aortic aneurysm; COPD = chronic obstructive pulmonary disease.