# References

1 U.S. Preventive Services Task Force. Screening for asymptomatic bacteriuria in adults: U.S. Preventive Services Task Force reaffirmation recommendation statement. Annals of Internal Medicine. 2008;149(1):43–7. PMID: 18591636.18591636
2 Foxman B. Urinary tract infection syndromes: occurrence, recurrence, bacteriology, risk factors, and disease burden. Infect Dis Clin North Am. 2014;28(1):1–13. PMID: 24484571. 10.1016/j.idc.2013.09.003 24484571
3 Nicolle LE, Gupta K, Bradley SF, . Clinical Practice Guideline for the Management of Asymptomatic Bacteriuria: 2019 Update by the Infectious Diseases Society of America. 2019. 10.1093/cid/ciy1121
4 Schnarr J, Smaill F. Asymptomatic bacteriuria and symptomatic urinary tract infections in pregnancy. European Journal of Clinical Investigation. 2008;38: Suppl 2:50–7. PMID: 18826482. 10.1111/j.1365-2362.2008.02009.x 18826482
5 Duff P. Pyelonephritis in pregnancy. Clin Obstet Gynecol. 1984;27(1):17–31. PMID: 6368078.6368078
6 Hill JB, Sheffield JS, McIntire DD, . Acute pyelonephritis in pregnancy. Obstetrics & Gynecology. 2005;105(1):18–23. PMID: 15625136. 10.1097/01.AOG.0000149154.96285.a0 15625136
7 Wing DA, Fassett MJ, Getahun D. Acute pyelonephritis in pregnancy: an 18-year retrospective analysis. American Journal of Obstetrics & Gynecology. 2014;210(3):219.e1–6. PMID: 24100227. 10.1016/j.ajog.2013.10.006 24100227
8 Hooton TM, Scholes D, Stapleton AE, . A prospective study of asymptomatic bacteriuria in sexually active young women. New England Journal of Medicine. 2000;343(14):992–7. PMID: 11018165. 10.1056/NEJM200010053431402 11018165
9 Ferroni MaT, A.K. Asymptomatic bacteriuria in noncatheterized adults. Urologic Clinics of North America. 2015;42(4):537–45. PMID: 26475950.26475950
10 Renko M, Tapanainen P, Tossavainen P, . Meta-analysis of the significance of asymptomatic bacteriuria in diabetes. Diabetes Care. 2011;34(1):230–5. PMID: 20937688. 10.2337/dc10-0421 20937688
11 Glaser AP, Schaeffer AJ. Urinary Tract Infection and Bacteriuria in Pregnancy. Urologic Clinics of North America. 2015;42(4):547–60. PMID: 26475951. 10.1016/j.ucl.2015.05.004 26475951
12 Antunes-Lopes T, Vale L, Coelho AM, . The Role of Urinary Microbiota in Lower Urinary Tract Dysfunction: A Systematic Review. European urology focus. 2018. PMID: 30270128. 10.1016/j.euf.2018.09.011 30270128
13 Kass EH. Bacteriuria and pyelonephritis of pregnancy. AMA Archives of Internal Medicine. 1960;105(2):194–8. PMID: 14404662.14404662
14 Zinner SH, Kass EH. Long-term (10 to 14 years) follow-up of bacteriuria of pregnancy. New England Journal of Medicine. 1971;285(15):820–4. PMID: 4936826. 10.1056/NEJM197110072851502 4936826
15 Kass E. Pyelonephritis and bacteriuria. A major problem in preventive medicine. Annals of internal medicine. 1962;56:46–53. PMID: CN-00232611.14454174
16 Sheiner E, Mazor-Drey E, Levy A. Asymptomatic bacteriuria during pregnancy. Journal of Maternal-Fetal & Neonatal Medicine. 2009;22(5):423–7. PMID: 19530000. 10.1080/14767050802360783 19530000
17 Smaill FM, Vazquez JC. Antibiotics for asymptomatic bacteriuria in pregnancy. Cochrane Database Syst Rev. 2015(8):CD000490. PMID: 26252501. 10.1002/14651858.CD000490.pub3 26252501
18 Farkash E, Weintraub AY, Sergienko R, . Acute antepartum pyelonephritis in pregnancy: a critical analysis of risk factors and outcomes. Eur J Obstet Gynecol Reprod Biol. 2012;162(1):24–7. PMID: 22381037. 10.1016/j.ejogrb.2012.01.024 22381037
19 Meis PJ, Michielutte R, Peters TJ, . Factors associated with preterm birth in Cardiff, Wales. I. Univariable and multivariable analysis. Am J Obstet Gynecol. 1995;173(2):590–6. PMID: 7645639.7645639
20 Meis PJ, Michielutte R, Peters TJ, . Factors associated with preterm birth in Cardiff, Wales. II. Indicated and spontaneous preterm birth. Am J Obstet Gynecol. 1995;173(2):597–602. PMID: 7645640.7645640
21 Matuszkiewicz-Rowinska J, Malyszko J, Wieliczko M. Urinary tract infections in pregnancy: old and new unresolved diagnostic and therapeutic problems. Arch. 2015;11(1):67–77. PMID: 25861291. 10.5114/aoms.2013.39202 25861291
22 Geerlings SE, Stolk RP, Camps MJ, . Asymptomatic bacteriuria may be considered a complication in women with diabetes. Diabetes Mellitus Women Asymptomatic Bacteriuria Utrecht Study Group. Diabetes Care. 2000;23(6):744–9. PMID: 10840989.10840989
23 Dull RB, Friedman SK, Risoldi ZM, . Antimicrobial treatment of asymptomatic bacteriuria in noncatheterized adults: a systematic review. Pharmacotherapy. 2014;34(9):941–60. PMID: 24807583. 10.1002/phar.1437 24807583
24 Macejko AM, Schaeffer AJ. Asymptomatic bacteriuria and symptomatic urinary tract infections during pregnancy. Urologic Clinics of North America. 2007;34(1):35–42. 10.1016/j.ucl.2006.10.010 17145359
25 Juthani-Mehta M. Asymptomatic bacteriuria and urinary tract infection in older adults. Clinics in Geriatric Medicine. 2007;23(3):585–94, vii. PMID: 17631235. 10.1016/j.cger.2007.03.001 17631235
26 Schneeberger C, van den Heuvel ER, Erwich JJ, . Contamination rates of three urine-sampling methods to assess bacteriuria in pregnant women. Obstet Gynecol. 2013;121(2 Pt 1):299–305. PMID: 23344279. 10.1097/AOG.0b013e31827e8cfe 23344279
27 Hooton TM, Gupta K. Urinary tract infections and asymptomatic bacteriuria in pregnancy. In: Bloom A, editor. UpToDate. https://www.uptodate.com/contents/urinary-tract-infections-and-asymptomatic-bacteriuria-in-pregnancy2017. PMID: None.
28 Rogozinska E, Formina S, Zamora J, . Accuracy of Onsite Tests to Detect Asymptomatic Bacteriuria in Pregnancy: A Systematic Review and Meta-analysis. Obstetrics & Gynecology. 2016;128(3):495–503. PMID: 27500352. 10.1097/AOG.0000000000001597 27500352
29 American Academy of Pediatrics and American College of Obstetricians and Gynecologists. Guidelines for Prenatal Care. https://www.r2library.com/Resource/Title/158110734X. Accessed: July 7, 2017.
30 Smaill F, Vazquez JC. Antibiotics for asymptomatic bacteriuria in pregnancy. Cochrane Database of Systematic Reviews. 2007(2):CD000490. PMID: 17443502. 10.1002/14651858.CD000490.pub2 17443502
31 Koves B, Cai T, Veeratterapillay R, . Benefits and Harms of Treatment of Asymptomatic Bacteriuria: A Systematic Review and Meta-analysis by the European Association of Urology Urological Infection Guidelines Panel. European Urology. 2017;72(6):865–8. PMID: 28754533. 10.1016/j.eururo.2017.07.014 28754533
32 Moore A, Doull M, Grad R, . Recommendations on screening for asymptomatic bacteriuria in pregnancy. Cmaj. 2018;190(27):E823–E30. PMID: 29986858. 10.1503/cmaj.171325 29986858
33 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services: Guide to Clinical Preventive Services: Report of the U.S. Preventive Services Task Force. 2nd edition ed. Baltimore, MD1996.
34 U.S. Preventive Services Task Force. Screening for Asymptomatic Bacteriuria: Recommendation Statement. 2004. PMID: None.
35 DerSimonian R, Kacker R. Random-effects model for meta-analysis of clinical trials: an update. Contemporary clinical trials. 2007;28(2):105–14. PMID: 16807131. 10.1016/j.cct.2006.04.004 16807131
36 Altman D, Bland J. How to obtain the confidence interval from a P value. BMJ. 2011;343:d2090. PMID: 21824904.21824904
37 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539–58. PMID: 12111919. 10.1002/sim.1186 12111919
38 Higgins J, Green S. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0: The Cochrane Collaboration; 2011.
39 Egger M, Davey Smith G, Schneider M, . Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629–34. PMID: 9310563.9310563
40 Berkman N, Lohr K, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality; 2014. p. 314–49. PMID: None.
41 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589. 10.1186/1472-6963-4-38 15615589
42 Uncu Y, Uncu G, Esmer A, . Should asymptomatic bacteriuria be screened in pregnancy? Clin Exp Obstet Gynecol. 2002;29(4):281–5. PMID: 12635746.12635746
43 Gratacos E, Torres PJ, Vila J, . Screening and treatment of asymptomatic bacteriuria in pregnancy prevent pyelonephritis. Journal of Infectious Diseases. 1994;169(6):1390–2. PMID: 8195624.8195624
44 Wren BG. Subclinical renal infection and prematurity. Med J Aust. 1969;2(12):596–600. PMID: 5388374.5388374
45 Williams GL, Campbell H, Davies KJ. Urinary concentrating ability in women with asymptomatic bacteriuria in pregnancy. British Medical Journal. 1969;3(5664):212–5. PMID: 5792611.5792611
46 Furness ET, McDonald PJ, Beasley NV. Urinary antiseptics in asymptomatic bacteriuria of pregnancy. New Zealand Medical Journal. 1975;81(539):417–9. PMID: 1099490.1099490
47 Boscia JA, Kobasa WD, Knight RA, . Therapy vs no therapy for bacteriuria in elderly ambulatory nonhospitalized women. JAMA. 1987;257(8):1067–71. PMID: 3806896. 10.1001/jama.1987.03390080057030 3806896
48 Elder HA, Santamarina BA, Smith S, . The natural history of asymptomatic bacteriuria during pregnancy: the effect of tetracycline on the clinical course and the outcome of pregnancy. American Journal of Obstetrics & Gynecology. 1971;111(3):441–62. PMID: 4937729. 10.1016/0002-9378(71)90793-9 4937729
49 Little PJ. The incidence of urinary infection in 5000 pregnant women. Lancet. 1966;2(7470):925–8. PMID: 4162367.4162367
50 Asscher AW, Sussman M, Waters WE, . The clinical significance of asymptomatic bacteriuria in the nonpregnant woman. Journal of Infectious Diseases. 1969;120(1):17–26. PMID: 5803281. 10.1093/infdis/120.1.17 5803281
51 Foley ME, Farquharson R, Stronge JM. Is screening for bacteriuria in pregnancy worthwhile? Br Med J (Clin Res Ed). 1987;295(6592):270. PMID: 3115406.3115406
52 Abrutyn E, Mossey J, Berlin JA, . Does asymptomatic bacteriuria predict mortality and does antimicrobial treatment reduce mortality in elderly ambulatory women?.[Erratum appears in Ann Intern Med 1994 Dec 1;121(11):901]. Annals of Internal Medicine. 1994;120(10):827–33. PMID: 7818631. 10.7326/0003-4819-120-10-199405150-00003 7818631
53 Pathak UN, Tang K, Williams LL, . Bacteriuria of pregnancy: results of treatment. Journal of Infectious Diseases. 1969;120(1):91–103. PMID: 5816817.5816817
54 Kincaid-Smith P, Bullen M. Bacteriuria in Pregnancy. Lancet. 1965;1(7382):395–9. PMID: 14238090.14238090
55 Harding GK, Zhanel GG, Nicolle LE, . Antimicrobial treatment in diabetic women with asymptomatic bacteriuria. New England Journal of Medicine. 2002;347(20):1576–83. PMID: 12432044. 10.1056/NEJMoa021042 12432044
56 Savage W, Hajj S, Kass E. Demographic and prognostic characteristics of bacteriuria in pregnancy. Medicine. 1967;46:385–407. PMID: CN-00234430.4864339
57 Gold E, Traub F, Daichman I, . Asymptomatic bacteriuria during pregnancy. Obstetrics and gynecology. 1966;27:206–9. PMID: 5325600.5325600
58 Brumfitt W. The effects of bacteriuria in pregnancy on maternal and fetal health. Kidney international. 1975;8:S113–s9. PMID: 00230726.00230726
59 Kazemier BM, Koningstein FN, Schneeberger C, . Maternal and neonatal consequences of treated and untreated asymptomatic bacteriuria in pregnancy: a prospective cohort study with an embedded randomised controlled trial. Lancet Infect Dis 2015;15(11):1324–33. PMID: 26255208. 10.1016/S1473-3099(15)00070-5 26255208
60 Giamarellou H, Dontas A, Zorbas P, . Asymptomatic bacteriuria in freely voiding elderly subjects. Long-term continuous vs pulse treatment with ofloxacin. Clinical drug investigation. 1998;15(3):187–95. PMID: CN-00200935. 10.2165/00044011-199815030-00003
61 Wren BG. The diagnosis of asymptomatic bacilluria in pregnancy. Medical Journal of Australia. 1969;1(22):1117–21. PMID: 4893255.4893255
62 Wren BG. Subclinical urinary infection in pregnancy. Medical Journal of Australia. 1969;1(24):1220–6. PMID: 4894855.4894855
63 Wren BG. Subclinical renal infection in pregnancy; pathogenesis, the organisms and the drugs of choice in its treatment. Medical Journal of Australia. 1969;2(18):895–8. PMID: 4901784.4901784
64 Williams J, Reeves D, Condie A, . The treatment of bacteriuria in pregnancy. Urinary tract infection Oxford University Press, London. 1968:160–9. PMID: None.
65 Nicolle LE, Zhanel GG, Harding GK. Microbiological outcomes in women with diabetes and untreated asymptomatic bacteriuria. World Journal of Urology. 2006;24(1):61–5. PMID: 16389540. 10.1007/s00345-005-0042-2 16389540
66 Haswell B, Sidaway ME, de Wardener HE. Follow-up of 164 patients with bacteriuria of pregnancy. Lancet. 1968;1(7550):990–4. PMID: 4171835.4171835
67 Elder HA, Santamarina BA, Smith SA, . Excess prematurity in tetracycline-treated bacteriuric patients whose infection persisted or returned. Antimicrob Agents Chemother. 1967;7:101–9. PMID: 4876085.4876085
68 Staszewska-Pistoni M, Dontas AS, Giamarellou H, . Effectiveness of ofloxacin therapy in preventing functional impairment and increased mortality in elderly patients with bacteriuria. Drugs. 1995;49: Suppl 2:374–5. PMID: 8549366.8549366
69 Abrutyn E, Berlin J, Mossey J, . Does treatment of asymptomatic bacteriuria in older ambulatory women reduce subsequent symptoms of urinary tract infection? Journal of the American Geriatrics Society. 1996;44(3):293–5. PMID: 8600199. 10.1111/j.1532-5415.1996.tb00917.x 8600199
70 Kazemier BM, Schneeberger C, De Miranda E, . Costs and effects of screening and treating low risk women with a singleton pregnancy for asymptomatic bacteriuria, the ASB study. BMC Pregnancy & Childbirth. 2012;12:52. PMID: 22892110. 10.1186/1471-2393-12-52 22892110
71 Asscher AW, Sussman M, Waters WE, . Asymptomatic significant bacteriuria in the non-pregnant woman. II. Response to treatment and follow-up. British Medical Journal. 1969;1(5647):804–6. PMID: 4886627. 10.1136/bmj.1.5647.804 4886627
72 Sussman M, Asscher AW, Waters WE, . Asymptomatic significant bacteriuria in the non-pregnant woman. I. Description of a population. British Medical Journal. 1969;1(5647):799–803. PMID: 5774076.5774076
73 Kincaid-Smith P. Ampicillin in Bacteriuria and Pyelonephritis of Pregnancy. Postgraduate Medical Journal. 1964;40:SUPPL:74–80. PMID: 14246855.14122905
74 Kass E. The role of asymptomatic bacteriuria in the pathogenesis of pyelonephritis. Biology of pyelonephritis. 1960:399–412. PMID: CN-00232612.
75 Condie A, Williams J, Reeves D, . Complications of bacteriuria in pregnancy. Urinary tract infection, proceedings of the first national symposium; 1968 april; london, UK. 1968:148–59. PMID: CN-00231117.
76 Wingert A, Pillay J, Featherstone R, . Screening for Asymptomatic Bacteriuria in Pregnancy: Systematic Review and Meta-analysis. Evidence Review and Synthesis Centre, Univerity of Alberta: Edmonton, Alberta; 2017.
77 Angelescu K, Nussbaumer-Streit B, Sieben W, . Benefits and harms of screening for and treatment of asymptomatic bacteriuria in pregnancy: a systematic review. BMC Pregnancy & Childbirth. 2016;16(1):336. PMID: 27806709. 10.1186/s12884-016-1128-0 27806709
78 Trestioreanu Z, Lador A, Sauerbrun-Cutler MT, . Antibiotics for asymptomatic bacteriuria. Cochrane Database Syst Rev. 2015;4:Cd009534. PMID: 25851268. 10.1002/14651858.CD009534.pub2 25851268
79 Stenqvist K, Dahlen-Nilsson I, Lidin-Janson G, . Bacteriuria in pregnancy. Frequency and risk of acquisition. Am J Epidemiol. 1989;129(2):372–9. PMID: 2912046.2912046
80 Bookstaver PB, Bland CM, Griffin B, . A review of antibiotic use in pregnancy. Pharmacotherapy: The Journal of Human Pharmacology and Drug Therapy. 2015;35(11):1052–62. PMID: 26598097.26598097
81 American College of Obstetricians and Gynecologists (ACOG). Committee Opinion No. 494: Sulfonamides, Nitrofurantoin, and Risk of Birth Defects. 2011:1484–5. PMID: 21606771. 10.1097/AOG.0b013e3182238c57 21606771
82 Pedersen TM, Stokholm J, Thorsen J, . Antibiotics in Pregnancy Increase Children’s Risk of Otitis Media and Ventilation Tubes. J Pediatr. 2017;183:153–8 e1. PMID: 28088397. 10.1016/j.jpeds.2016.12.046 28088397
83 Mulder B, Pouwels K, Schuiling-Veninga C, . Antibiotic use during pregnancy and asthma in preschool children: the influence of confounding. Clinical & Experimental Allergy. 2016;46(9):1214–26. PMID: 27159872. 10.1111/cea.12756 27159872
84 Stokholm J, Sevelsted A, Bonnelykke K, . Maternal propensity for infections and risk of childhood asthma: a registry-based cohort study. Lancet Respir Med. 2014;2(8):631–7. PMID: 25066330. 10.1016/S2213-2600(14)70152-3 25066330
85 Wu P, Feldman AS, Rosas-Salazar C, . Relative Importance and Additive Effects of Maternal and Infant Risk Factors on Childhood Asthma. 2016;11(3):e0151705. PMID: 27002979. 10.1371/journal.pone.0151705 27002979
86 Mor A, Antonsen S, Kahlert J, . Prenatal exposure to systemic antibacterials and overweight and obesity in Danish schoolchildren: a prevalence study. Int J Obes (Lond). 2015;39(10):1450–5. PMID: 26178293. 10.1038/ijo.2015.129 26178293
87 Turta O, Rautava S. Antibiotics, obesity and the link to microbes-what are we doing to our children? BMC medicine. 2016;14(1):57. PMID: 27090219. 10.1186/s12916-016-0605-7 27090219
88 Seedat F, Stinton C, Patterson J, . Adverse events in women and children who have received intrapartum antibiotic prophylaxis treatment: a systematic review. BMC Pregnancy and Childbirth. 2017;17(1):247. PMID: 28747160 10.1186/s12884-017-1432-3 28747160
89 Stokholm J, Schjorring S, Eskildsen CE, . Antibiotic use during pregnancy alters the commensal vaginal microbiota. Clin Microbiol Infect. 2014;20(7):629–35. PMID: 24118384. 10.1111/1469-0691.12411 24118384
90 Muanda FT, Sheehy O, Berard A. Use of antibiotics during pregnancy and risk of spontaneous abortion. Cmaj. 2017;189(17):E625–E33. PMID: 28461374. 10.1503/cmaj.161020 28461374
91 Muanda FT, Sheehy O, Berard A. Use of antibiotics during pregnancy and the risk of major congenital malformations: a population based cohort study. Br J Clin Pharmacol. 2017;83(11):2557–71. PMID: 28722171. 10.1111/bcp.13364 28722171
92 Sanchez GV, Fleming-Dutra KE, Roberts RM, . Core Elements of Outpatient Antibiotic Stewardship. MMWR Recomm Rep. 2016;65(6):1–12. PMID: 27832047. 10.15585/mmwr.rr6506a1 27832047
93 Pollack LA, Srinivasan A. Core elements of hospital antibiotic stewardship programs from the Centers for Disease Control and Prevention. Clin Infect Dis. 2014;59: Suppl 3:S97–100. PMID: 25261548. 10.1093/cid/ciu542 25261548
94 Centers for Disease Control and Prevention. The Core Elements of Antibiotic Stewardship for Nursing Homes. Atlanta, GA: 2015.
95 Ruiter-Ligeti J, Vincent S, Czuzoj-Shulman N, . Risk Factors, Incidence, and Morbidity Associated With Obstetric Clostridium difficile Infection. Obstet Gynecol. 2018;131(2):387–91. PMID: 29324599. 10.1097/AOG.0000000000002422 29324599
96 Kuntz JL, Yang M, Cavanaugh J, . Trends in Clostridium difficile infection among peripartum women. Infect Control Hosp Epidemiol. 2010;31(5):532–4. PMID: 20350150. 10.1086/652454 20350150
97 Cozar-Llisto A, Ramos-Martinez A, Cobo J. Clostridium difficile Infection in Special High-Risk Populations. Infectious Diseases & Therapy. 2016;5(3):253–69. PMID: 27515721. 10.1007/s40121-016-0124-z 27515721
98 Brubaker LaW, A.J. The new world of the urinary microbiota in women. American journal of obstetrics and gynecology. 2015;213(5). PMID: 26003055 10.1016/j.ajog.2015.05.032 26003055
99 Wagenlehner FM, Naber KG. Editorial commentary: asymptomatic bacteriuria-shift of paradigm. Clin Infect Dis. 2012;55(6):778–80. PMID: 22677709. 10.1093/cid/cis541 22677709
100 Soderborg TK, Borengasser SJ, Barbour LA, . Microbial transmission from mothers with obesity or diabetes to infants: an innovative opportunity to interrupt a vicious cycle. Diabetologia. 2016;59(5):895–906. PMID: 26843076. 10.1007/s00125-016-3880-0 26843076
101 Xu J, Schwartz K, Bartoces M, . Effect of antibiotics on vulvovaginal candidiasis: a MetroNet study. J Am Board Fam Med. 2008;21(4):261–8. PMID: 18612052. 10.3122/jabfm.2008.04.070169 18612052
102 Spinillo A, Capuzzo E, Acciano S, . Effect of antibiotic use on the prevalence of symptomatic vulvovaginal candidiasis. American journal of obstetrics and gynecology. 1999;180(1):14–7. PMID: 9914570.9914570
103 Thiemann S, Smit N, Strowig T. Antibiotics and the Intestinal Microbiome : Individual Responses, Resilience of the Ecosystem, and the Susceptibility to Infections. Curr Top Microbiol Immunol. 2016;398:123–46. PMID: 27738912. 10.1007/82_2016_504 27738912
104 Ianiro G, Tilg H, Gasbarrini A. Antibiotics as deep modulators of gut microbiota: between good and evil. Gut. 2016;65(11):1906–15. PMID: 27531828 10.1136/gutjnl-2016-312297 27531828
105 Verani JR, McGee L, Schrag SJ, . Prevention of perinatal group B streptococcal disease-revised guidelines from CDC, 2010. MMWR Recomm Rep. 2010;59(RR-10):1–36.
106 Canadian Task Force on Preventive Health Care (CTFPHC). Asymptomatic Bacteriuria in Pregnancy https://canadiantaskforce.ca/guidelines/published-guidelines/asymptomatic-bacteriuria/. Accessed: July 16, 2018.
107 National Institute for Health and Clinical Excellence (NICE). Urinary tract infection (lower): antimicrobial prescribing. https://www.nice.org.uk/guidance/ng109/chapter/Recommendations#managing-asymptomatic-bacteriuria. Accessed: Jan 16, 2019.
108 National Institute for Health and Clinical Excellence (NICE). Clinical Guidelines Antenatal care: routine care for the healthy pregnant woman. https://www.nice.org.uk/Guidance/CG62. Accessed: July 16, 2018.
109 American College of Obstetricians and Gynecologists (ACOG). Treatment of urinary tract infections in nonpregnant women. ACOG Practice Bulletin No. 91. 2008:785–94.
110 Kilpatrick S, American Academy of Pediatrics, American College of Obstetricians and Gynecologists. Guidelines for Perinatal Care. Elk Grove Village, IL: American Academy of Pediatrics; 2017. Available from: http://search.ebscohost.com/login.aspx?direct=true&db=nlebk&AN=1605923&site=ehost-live.
111 Scottish Intercollegiate Guidelines Network (SIGN). Management of suspected bacterial urinary tract infection in adults. Edinburg: SIGN (publication no. 88); 2012.
112 American Academy of Family Physicians (AAFP). Summary of recommendations for clinical preventive services. http://www.aafp.org/dam/AAFP/documents/patient_care/clinical_recommendations/cps-recommendations.pdf. Accessed: July 16, 2018.