# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Justin Mills, MD, MPH, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Brandy Peaker, MD, MPH, at the Centers for Disease Control and Prevention, Andrew S. Narva, MD, Carmelle Norice-Tra, MD, PhD, and A. Gretchen Buckler, MD, MPH, at the National Institutes of Health, for providing federal partner review of the draft report; Brenda Kazemier, MD, Christine Kistler, MD, Fiona Smaill, MBChB, Lindsay Nicolle, MD, and Dimitri Drekonja, MD, who provided expert review of the draft report; Jennifer S. Lin, MD, MCR, for mentoring and project oversight; Peter Miksovsky, MD, who served as a clinical consultant during the review process; Elizabeth O’Connor, PhD, and Nadia Redmond, MS, who assisted with data analysis; Leslie Perdue, MPH, who provided technical writing assistance; Smyth Lai, MLS, who conducted literature searches; and Katherine Essick for technical and editorial assistance at the Center for Health Research.