# Chapter 4 Discussion

## Summary of Evidence

Our review of the literature on ASB screening and treatment revealed limited evidence for drawing conclusions on benefits and harms of this practice for general adult populations and pregnant women and their infants (Table 11). Only one study has been published since the last USPSTF recommendation on this topic.^59^ There was limited interval validity, with considerable risk of bias in the evidence included for both pregnant and nonpregnant populations. The external validity and applicability of the evidence base, particularly in the studies of pregnant women, was also poor, as most were conducted over 40 years ago and many of the treatment protocols and medications are no longer used in clinical practice. The results of most of the studies among pregnant women included in this review do not warrant strong conclusions about effects of screening and treatment as practiced in modern U.S. clinical populations and health care settings. Nevertheless, current practice is derived from these early studies that sought to determine whether treatment of ASB (primarily with antibiotics) could improve pregnancy and birth outcomes.

Table 11 Summary of Evidence

Key Question | (Populations or Interventions) | Studies (k); Observations (n); Study Designs | Summary of Findings | Consistency and Precision | Other Limitations | Strength of Evidence | Applicability
KQ1: Screening effectiveness | Pregnant women | k=2 (n=5,289); Retrospective cohort studies; Fair quality | Fewer cases of pyelonephritis occurred in pregnant women included in a screening cohort compared with retrospective cohort of unscreened women. | Direction of effects consistent and one study with adequate precision | Fair-quality studies with risk of bias due to limited information about how cohort was identified, characteristics of women in comparison cohorts, ascertainment bias, selective reporting. | Low for a benefit of screening for prevention of pyelonephritis in pregnancy based on two fair-quality cohort studies | One study conducted in a hospital in Spain 24 years ago and another in Turkey 16 years ago – may not be entirely applicable to current U.S. hospital settings and populations.
KQ1: Screening effectiveness | General adult populations | k=0 | NA | NA | NA | NA | NA
KQ2: Screening harms | Pregnant women | k=1 (n=372); Retrospective cohort study; Fair quality | No harms of screening were identified. Number of congenital abnormalities similar between groups and none in screen-positive women. | Consistency NA Imprecise due to small n, few events | Limited reporting on potential harms of screening and treatment, low n for detecting rare harms. | Insufficient for the absence of screening harms based on one fair-quality cohort study | Small study conducted in Turkey 16 years ago – may not be entirely applicable to current U.S. hospital settings and populations
KQ2: Screening harms | General adult populations | k=0 | NA | NA | NA | NA | NA
KQ3: Treatment effectiveness | Pregnant women | k=12 RCTS (n=2,369) | Treatment of screen-detected ASB in pregnancy reduced the risk of pyelonephritis (5.5% vs 20.7%; pooled RR, 0.24 [95% CI, 0.14 to 0.41], k=12, n = 2,068) and low birthweight infants (8.3% vs 13.1%; pooled RR, 0.64 [95% CI, 0.46 to 0.90], k=7, n =1,522). Other birth outcomes were less consistently reported, and statistically significant differences were not found in pooled analyses. | Consistent and precise for pyelonephritis; Consistent but less precise for low birthweight; Imprecise and inconsistent for other perinatal outcomes, including perinatal mortality, mean birthweight, and preterm birth. | Risk of bias present or difficult to assess in all studies; limited reporting of baseline characteristics; problems with blinding, randomization, selective reporting, and outcome definitions. | Moderate for benefit of treatment on pyelonephritis from 12 fair-quality RCTS (including 5 with high risk of bias); Low for benefit of treatment on low birthweight from 7 fair-quality studies (including 3 with high risk of bias) | Most studies conducted over 40 years ago, and many of the treatment protocols and medications are no longer used in clinical practice; Rates of pyelonephritis as much as 10-fold higher in historical trials compared with estimates from modern prenatal care.
KQ3: Treatment effectiveness | General adult populations | k=5 (n=777); 4 RCTs, 1 nonrandomized CCT | Mortality: 3 trials in older adults found no difference in mortality over 6 to 100 months followup.; Mobility: 1 trial in older adults found no effect on mobility at 6 months.; Symptomatic Infection/Pyelonephritis: 4 trials (including 2 in older adults) found no difference in the rate of symptomatic infection. | Consistent for no benefit; Imprecise; Treatment ranged from a single dose of treatment to daily treatment over 3 months. | Lack of reporting of population characteristics.; Some studies lacked reporting on randomization, allocation, and outcome assessment. | Low | Evidence primarily applies to women (84–100% female in each study); Three studies limited to older adults (2 of 3 limited to older women); One study limited to women with diabetes
KQ4: Treatment harms | Pregnant women | k=7 (n=1,286) | Five studies reported congenital malformations with effect in direction of benefit, but null. All other outcomes sparsely reported and did not provide evidence of or rule out harms. | Inconsistent; Imprecise | Risk of bias present or difficult to assess in all studies; limited reporting of baseline characteristics; problems with blinding, randomization, selective reporting, and outcome definitions. | Insufficient for absence of treatment harms | Most studies conducted over 40 years ago, and many of the treatment protocols and medications are no longer used in clinical practice
KQ4: Treatment harms | General adult populations | k=4 (n=419); 4 RCTs | Minimal reporting of adverse events. Most studies reported no adverse events or only on those few patients who withdrew from the trials based on adverse events. One study of treatment of women with diabetes found higher rates of adverse events among women in the treatment arm. | Inconsistent; Imprecise | Limited data reporting. Unclear reporting bias | Insufficient | Evidence is limited to mostly women (84–100% female in each study).

Abbreviations: CCT = clinical controlled trial; KQ = Key Question; NA = not applicable; RCT = randomized controlled trial

Direct evidence on the benefits and potential harms of screening was limited in pregnant and nonpregnant populations, and the preponderance of evidence contributing to this review was on the effects of treating screen-detected ASB. Two fair-quality comparative retrospective cohort studies of screening in pregnant women (N=2,019) found fewer cases of pyelonephritis in screened than in unscreened women. No harms of screening were identified but reporting on potential harms was extremely limited.

Evidence that treatment of screen-detected ASB reduces the incidence of pyelonephritis in pregnancy was found, based on the 12 included trials (N=2,068) reporting this outcome. A reduced risk of low birthweight infants was also seen based on seven trials reporting this outcome (N=1,522), but the finding was less robust. There were fewer studies reporting low birthweight overall, and statistical significance was not retained when the three studies with high risk of bias were dropped from meta-analysis. Benefits and harms for other birth and infant outcomes were very limited. Some adverse reactions to medication, including diarrhea, rash, and nausea, were reported.

No evidence on the effect of screening for ASB in diabetic women, nonpregnant women, or older adults was identified. There was no evidence from five included studies that treatment of ASB improved mobility, mortality, or renal health outcomes among older adults, or UTIs (including pyelonephritis) among diabetic or nonpregnant women (N=777). Reporting on potential harms of treatment was very limited and nonspecific; however, two cases of patient withdrawal due to of vertigo and gastrointestinal symptoms were reported in one study.

## Comparison With Other Reviews

A recent review of the evidence on ASB screening and treatment in pregnancy for the Canadian Task Force on Preventive Health Care (CTFPHC)^76^ had very similar findings to those of our current review and was based on much of the same evidence. In pregnancy, a significant reduction on the rate of pyelonephritis was seen in studies comparing screening to no screening. In addition, trials on ASB treatment among pregnant women found similar, statistically significant reductions in the rates of pyelonephritis and low birth weight. Effects on other outcomes including preterm birth, perinatal mortality, and congenital malformations were similar to those found in the current review. The authors of the review for the Canadian Task Force noted similar limitations of the literature with regard to quality and applicability, noting that there is great uncertainty if the magnitude of the effects seen are true and to what extent they can be applied to practice today based on evidence that the incidence of pyelonephritis in untreated ASB may be substantially lower than that reported in the historical literature.^76^ The Canadian Task Force also considered evidence on patient outcome evaluations and on cost-effectiveness that were not included in our review. Overall, their findings led to a weak recommendation in favor of screening, and included recognition of patient valuations, noting that some women’s preferences may vary such that those more concerned with potential harms or risks of antibiotic use may choose not to be screened or treated for ASB.^32^

A 2015 review by the Cochrane Collaboration (conducted prior to publication of the recent Netherlands study^59^) found a similar reduction in the risk of pyelonephritis and low birth weight. This review similarly noted the low or very low quality of evidence for all outcomes with the potential for high risk of bias in many studies. Two additional recent reviews came to similar conclusions and noted that inconsistency in the evidence base and the high risk of bias noted in the older trial evidence do not provide a strong foundation for current ASB-screening practices.^31,^ ^77^

Reviews of treatment in general adult populations have similarly found that there is no evidence of clinical benefit from treating ASB.^23,^ ^31,^ ^78^ A systematic review of screening and treatment in asymptomatic adults reported only a slightly increased risk of symptomatic UTIs among individuals with ASB than those without, and treatment did not reduce the risk of subsequent UTI.^23^ The review also did not find associations of ASB with consequential health indicators or outcomes, such as kidney dysfunction, hypertension, cancer, or mortality.

## Contextual Issues for ASB Screening and Treatment in Pregnant Women

### Onsite ASB Screening Test Accuracy in Pregnancy

In its previous recommendation, the USPSTF stated that no tests available at that time had high enough sensitivity and negative predictive value in pregnant women to replace urine culture as the preferred screening test. It called for research to develop a screening test that could reduce the use of laboratory urine culture, which is more labor-intensive and costly than onsite screening urine tests. All but two of the included trials of pregnant women in this review relied on laboratory urine culture tests for screening. Two studies, including the most recent study, relied on a dipslide test that can be used for screening onsite with visual interpretation after overnight incubation and can also sent to a laboratory for culture. Recent literature on the performance of onsite urine tests, including onsite interpretation of the dipslide test, did not suggest that newer more accurate tests have become available since the previous review.

Available onsite urinalysis tests generally have higher specificity than sensitivity. A recent systematic review of onsite, point-of-care tests to detect ASB in pregnancy with urine culture as the reference standard found 27 studies of 9 different screening tests: dipstick (nitrites positive), dipstick (leucocytes or nitrites positive), chlorhexidine reaction, uriscreen catalase, Griess test, urinalysis, dipslide with gram staining, dipslide (Uricult), and dipslide (Microstix-3).^28^ Urine dipstick the most commonly reported test. The literature search was updated through June 2016 and included 27 studies published between 1981 and 2010. Seven studies were conducted in the United States, seven in India, three in Nigeria, and one each in Ethiopia, Germany, South Africa, Turkey, Pakistan, Thailand, Argentina, Spain, Venezuela, and the United Kingdom (n=13,641 pregnant women). For studies using the dipslide with gram staining (k=6, n=3201), sensitivity ranged from 0.76 to 0.92 and specificity ranged from 0.86 to 0.99. The pooled sensitivity was 0.86 (95% CI, 0.80 to 0.91) and specificity was 0.97 (95% CI, 0.93 to 0.99). For the dipstick test combining positive nitrites and leukocytes (k=8, n=5,940), sensitivity ranged from 0.45 to 0.92 and specificity ranged from 0.63 to 0.97. The pooled sensitivity was 0.73 (95% CI, 0.59 to 0.83) and specificity was 0.89 (95% CI, 0.79 to 0.94). Finally, sensitivity for the dipstick test using positive nitrates only ranged from 0.15 to 1.00 and specificity ranged from 0.71 to 1.00 (k=21, n=9491), with a pooled sensitivity of 0.55 (95% CI, 0.42 to 0.67) and specificity of 0.99 (95% CI, 0.98 to 0.99). Ideally a screening test would maximize sensitivity, but some of these studies and their pooled findings suggest that onsite testing methods could fail to identify a significant number of women with ASB. Due to the lack of sensitivity and specificity of rapid screening tests for detecting ASB in pregnant women, these are not recommended for screening and guidance from the WHO recommends use of onsite testing only for settings where culture is unavailable or resources are very limited.

### Limited Evidence on ASB Screening Test Timing and Frequency

There is little evidence available on the optimal timing and frequency of ASB screening in pregnancy. In the included studies, screening occurred anywhere from the 12^th^ week of gestation to delivery. Screening generally was conducted only once over the course of pregnancy; the first prenatal visit, ideally in the first trimester, is usually recommended. One of the included trials screened women at every prenatal visit, and found that nearly one third did not screen positive for ASB at the first visit, but were diagnosed within 2 to 7 visits. Observational evidence is limited, but suggests ASB rates may increase as pregnancy progresses toward closer to term, and that detection of ASB may increase with more frequent screening.^79^ A nonrandomized study among underserved pregnant women seen in a hospital-based midwifery practice compared women screened with culture at the first prenatal visit. Thereafter they receive screening with a urine dipstick test either on an indicated basis (symptoms or underling health condition) or routinely at every prenatal visit. Rates of pyelonephritis and UTI were no worse (based on noninferiorty statistical tests) among women with indicated rather than routine testing over the course of pregnancy, suggesting that further screening after a single culture at the first prenatal visit may not improve health outcomes. Overall, evidence on the test type, timing and frequency is limited. In the absence of more updated evidence, approaches other than culture screening at the first prenatal visit have not been supported in diagnostic accuracy or in randomized or nonrandomized comparative studies.

### Association of ASB and Pyelonephritis in Pregnancy With Health Outcomes

The most consistent and robust effect observed with ASB treatment during pregnancy was a reduction in pyelonephritis infections. More infrequent outcomes, such as low birthweight, were less precisely estimable because there were fewer trials and low birthweight event rates were lower than for pyelonephritis in most of the older trials. Some of the included pregnancy outcomes where a relationship with ASB treatment was not evident, such as intrauterine growth restriction and hypertensive disorders of pregnancy may have less direct physiologic relationships to ASB and are more likely to be confounded by factors such as maternal smoking rates and pregnancy history. Evidence on the association between ASB and pyelonephritis, and between ASB and pyelonephritis on pregnancy health outcomes is needed to interpret the historical evidence.

In most of the studies conducted prior to 1980, rates of pyelonephritis in pregnant women with untreated ASB were at least 10-fold greater than currently observed. In the two most recent studies, rates of 2.2 percent and 2.5 percent were reported, yet in eight of the studies conducted earlier, rates were above 20 percent– in two of the older studies over one-third developed pyelonephritis.^44,^ ^54^ The much lower incidence of pyelonephritis in more recent studies conducted may be owing to a range of factors. These include different health status, smoking rates, or other characteristics of enrolled populations from an earlier era, more stringent diagnostic criteria, better recognition and treatment of lower urinary tract infections, changes in behaviors, and differences in the infectious microorganisms circulating in the population. Regardless of the reasons for lower pyelonephritis incidence, it corresponds to lower absolute differences in risk, meaning higher number needed to treat (NNT) to prevent a case of pyelonephritis. Assuming 2.5 percent incidence, 25 women in 1,000 with ASB would develop pyelonephritis in the absence of treatment. Applying the pooled RR of 0.24 from this review, 19 cases (estimate ranges from 15 to 21 from RR 95% CI) of pyelonephritis would be prevented for every 1,000 women treated for ASB with antibiotics during pregnancy (NNT 53, ranging from 45 to 67 from RR 95% CI).

The one recent study included in this review, from the Netherlands, provides data on the clinical course of untreated ASB. For the trial, a low-risk cohort of asymptomatic women aged 18 or older with a singleton pregnancy ranging from 16–22 weeks’ gestation were screened using a single sample screening with dipslide culture (>10^5^ CFU/ml). While some of these women consented to be included in the randomized trial following a positive screening result, 163 women with ASB opted not to be included in the trial. These women and the 45 women with ASB randomized to placebo were compared with the 4,035 women in the cohort who did not screen positive for ASB. Most women who chose not to participate declined because they did not wish to receive antibiotics during pregnancy. The ASB-positive women who were untreated or given placebo and the ASB-negative women were similar at baseline was apart from a higher rate of smoking among ASB-positive women (11% versus 6%, p<0.004) compared with those without ASB. The incidence of pyelonephritis was higher among untreated ASB-positive women (2.4% versus 0.6%; adjusted OR, 3.9 [95% CI: 1.4 to 11.4]). There were no differences in birth outcomes, but low event rates due to the exclusion of pregnant women at risk for preterm birth and other complications limited statistical power for these outcomes. In addition, defining ASB with a single sample result may have included more women with transient ASB, potentially dampening differences between groups in the effect of treatment. Nevertheless, this pragmatic trial in a population that included women with untreated ASB for comparison offers some modern evidence points to the need for additional research to understand ASB and pyelonephritis risk in current pregnant populations.

Large observational studies have found that pyelonephritis in pregnancy is associated with negative health outcomes, including low birthweight. A large retrospective cohort study of women delivering singletons in Kaiser Permanente Southern California (KPSC) hospitals from 1993–2010 (n=546,092) found that 5.3 per 1,000 women were diagnosed with acute pyelonephritis and 0.5 percent of pregnant women were hospitalized for the condition. In this cohort, pyelonephritis was found to be independently associated with anemia, septicemia, acute renal failure, respiratory distress/adult respiratory distress syndrome, spontaneous preterm birth (<37 weeks and 33–36 weeks), low birth weight (1500–2499 g), chorioamnionitis, and primary cesarean delivery.^7^ The analysis was adjusted for maternal age, race/ethnicity, education, prenatal care, gravida, chronic hypertension, pregestational and gestational diabetes, smoking during pregnancy, and year of delivery. Another cohort study from 1988–2010 conducted among women with singleton deliveries and prenatal care in Israel (n=219,612) found that 0.07 percent of women were admitted to the hospital with acute pyelonephritis. In this cohort, pyelonephritis was associated with induction of labor, suspected fetal distress, placental abruption, preterm delivery (<37 weeks), and Apgar <7 at 1 minute. In a multivariate regression model from this cohort, acute pyelonephritis was an independent risk factor for preterm delivery (OR, 2.6 [95% CI, 1.7 to 3.9]).^18^ A prospective cohort study conducted in Texas from 2000–2001 (n=32,282) found 1.4 percent of women were admitted for acute pyelonephritis during pregnancy (14 per 1000 deliveries). Complications included anemia (23%), transient renal dysfunction (2%), respiratory insufficiency (7%), preterm birth <37 weeks (5%), preterm birth <32 weeks, and birth weight <2500 g. These rates were not higher than the usual rates observed at the study hospital, and the authors concluded that acute pyelonephritis was not associated with preterm delivery, small for gestational age, or increased rates of adverse pregnancy outcomes. The authors suggested that this could be due to improvements in treatment and aggressive followup care.^6^

This observational evidence is consistent with the premise that pyelonephritis contributes to poor maternal and fetal health outcomes but does not rule out other possibilities. Notably, observational studies indicate that ASB in pregnancy often occurs along with other risk factors associated with poor birth outcomes, including older maternal age, low socioeconomic status, multiparity, and diabetes.^4,^ ^19–21^ Associations of ASB and pyelonephritis with poor birth outcomes could therefore also in part arise from shared underlying risk factors or confounders that cannot be fully accounted for in observational studies.

### Potential Risks of Antibiotic Exposure in Pregnancy

Antibiotics account for 80 percent of all prescribed medication in pregnancy, with guidance available for clinicians on the best approaches to infection treatment in pregnancy.^11,^ ^80,^ ^81^ Information on the adverse effects of antibiotic treatment is limited, as clinical trials of medication safety are often not feasible and potentially unethical in pregnant women.^80^ Consequently, there is little direct evidence establishing the safety of antibiotic use in pregnancy, but animal studies and observational evidence, as well as clinical experience, underlie the safety profiles outlined for different classes of antibiotics in pregnancy. Penicillins, cephalosporins, and aztreonam are generally considered safe in pregnancy, with fosfoymcin and nitrofurantoin commonly used for treating ASB during pregnancy in modern practice. Other classes of antibiotics (e.g., tetracyclines, fluoroquinolones) are associated with harms and not advised, or advised only for use in midpregnancy (e.g., trimethoprim-sulfamethoxazole).^27^

Literature on potential longer-term adverse events related to antibiotic prophylaxis in pregnancy has been inconsistently reported and the studies are subject to high risk of bias. A systematic review of 30 studies of intrapartum prophylaxis for a variety of indications (e.g., GBS prevention, preterm labor) found that all of the included trials or observational studies had a high risk of bias. Results from seven cohort studies consistently showed that treatment altered the infant microbiome up to 90 days after delivery; however, it is unclear whether these alterations are related to any clinically meaningful adverse health effects. Six studies showed mixed evidence related to whether treatment led to increased antibiotic resistance in infants. Data were most limited related to long-term adverse events. One RCT comparing the results of 7-year-old children whose mothers had received treatment for preterm labor found a higher rate of cerebral palsy in mothers who had receive treatment with erythromycin (53/1611 [3%] and 27/1562 [2%]; OR, 1.93 [95% CI, 1.21 to 3.09) or amoxicillin-clavulanate (50/1587 [3%] and 30/1586 [2%]; OR, 1.69 [95% CI, 1.07 to 2.67). In addition, there was some limited evidence that rates of bowel problems and functional impairment were higher among children whose mothers were treated with erythromycin. However, the review notes that this study was limited by the multiple statistical comparisons conducted on a relatively small sample size, with additional analysis conducted on diabetes, behavioral problems, education attainment, attention deficit hyperactivity disorder, and other developmental problem not finding significance. In addition, the authors note that the biological plausibility of an increased risk of cerebral palsy is unknown.

In pregnant women, there is limited preliminary evidence pointing to possible longer term health effects for children whose mothers were exposed to antibiotics in pregnancy (for various indications). Characteristics of the microbiome as passed from mother to child may underlie risks for conditions thought to have an immune component.^80,^ ^82–85^ Obesity and asthma in childhood may be associated with changes to the microbiome,^85–88^ and recent observational data suggest that antibiotic exposure during pregnancy may lead to alterations in the maternal microbiome.^89^ A 2013 prospective cohort study conducted in Denmark (n=668) examined the effect of antibiotic administration during pregnancy on vaginal bacteria colonization at gestational week 36.^89^ Results showed that women who received oral antibiotics during any trimester had an increased rate of colonization by Staphylococcus species, compared with women who did not receive any antibiotic treatment during pregnancy (adjusted OR, 1.63 [95% CI, 1.06 to 2.52], p=0.028).^89^ Moreover, the increase in vaginal Staphylococcus species was associated with UTI antibiotics administered during any trimester in pregnancy (adjusted OR, 1.90 [95% CI, 1.08 to 3.33, p 0.026).^89^ Emerging evidence has suggested that changes in the maternal microbiome may also induce perinatal complications, such as spontaneous abortion,^90^ congenital malformations,^91^ and low birth weight. The evidence base on this topic is evolving but highlights the need for a more thorough consideration of potential longer-term adverse consequences of ASB treatment in pregnancy.

## Contextual Issues for ASB Screening in General Adult Populations

### Association of ASB With Health Outcomes in General Adult Populations

The absence of effects of ASB treatment on health outcomes in the available trials may suggest that there is not a plausible mechanism whereby ASB influences mobility or mortality, or that observed associations of ASB and declining health are not causal relationships. ASB may instead be a marker for age and immune functioning. In addition, high rates of antibiotic use in the care of older adults in contact with the health care system for a range of health conditions may subsume potential effects of ASB screening and treatment. Overall, high rates of antibiotic use in older adults may subsume potential effects ASB screening and treatment; there was evidence in the studies that despite no differences in mobility or mortality, screening was associated with more antibiotic treatment overall, even accounting for differences in days of antibiotics used for ASB treatment.

Prospective cohort studies have shown that women with ASB (including women with diabetes and premenopausal and postmenopausal women) are at increased risk for symptomatic UTIs, but the presence of ASB has not be associated with long-term adverse events. In addition, treatment of ASB has not been found to decrease the frequency of symptomatic infections or future episodes of ASB. Prospective studies of ambulatory older adult males have also found no association between ASB and adverse outcomes or changes in survival. Therefore, screening for ASB in these populations has not been indicated in other practice guidelines. Despite the recommendations not to screen, ASB remains one of the most common causes of antimicrobial overprescribing in acute and long-term care. Within a systematic review of rates of ASB treatment, 45 percent of individuals with ASB who did not have an indication for treatment received inappropriate antimicrobial treatment with women and those with a gram-negative bacteriuria having higher rates of inappropriate treatment. The CDC has stated that antibiotic resistance is among the great public health threats today, leading to an estimated 2 million infections and 23,000 deaths per year in the United States. Antibiotic stewardship is the effort to measure and improve prescribing to ensure antibiotics are used only when needed, minimize underuse of antibiotics when indicated, and ensure proper dosing when indicated. The CDC has offered guidance on the core elements of antibiotic stewardship programs in hospital, nursing home, and outpatient settings.^92–94^

While studies among adults in long-term care facilities were excluded from this review, prospective studies of antimicrobial treatment for ASB in these settings have not found an association of treatment with a decreased rate of infection or improvements in survival or symptoms; however, treatment has been associated with significantly increased rates of adverse antimicrobial effects and reinfection with treatment resistant organisms. Therefore, screening for ASB in institutionalized adults has not been indicated in other practice guidelines.^3^

## Limitations of the Evidence and Future Research Needs

We focused on English-language evidence from countries with high and very high (for pregnant women) on the Human Development Index (2016), and it is possible that relevant evidence in other languages or settings may exist. Recent evidence reviews on this topic, however, did not identify additional studies that would apply to women obtaining care in the United States. The review scope was limited to trials for assessing effects of treatment. Cohort studies could also have been included in the general adult population, but for this topic we expected too many threats to internal validity to draw conclusions about effects of ASB treatment in the absence of randomized comparisons. For harms of treatment, general studies of the effects of antibiotic treatment in pregnancy would not be sufficiently guarded against risk of bias from the health effects of underlying conditions that would require antibiotics. Thus, for treatment benefits and harms, the scope was narrowly defined for study design. We are not aware, however, of any major cohort studies evaluating effects whether antibiotic treatment of ASB during pregnancy or in general adult populations exist that would have strengthened our review conclusions if included. Only one ongoing study with limited applicability was identified (Appendix F).

The included studies were found to have substantial risk of bias, with only one good-quality study included; a study of ASB treatment in women with diabetes.^55^ Most of the trials among pregnant women were conducted over 40 years ago, using treatment protocols and scientific methods that are no longer commonly employed. In some studies, the evaluation of study quality was hindered by a lack of information, such as about the study groups at baseline, whereas in other studies the information provided raised questions about the methodologic rigor. The limited reporting on harms, including longer term harms was also a limitation of the evidence reviewed. Finally, selective outcome reporting and possibly publication bias are suggested by the limited number of included studies reporting important outcomes, such as low birthweight and preterm birth.

Our understanding of the harms of antibiotic use have greatly increased in the 40 years since the seminal trials of ASB treatment in pregnancy were conducted. The emergence of antibiotic resistant bacterium, and the rare but rising incidence of Clostridium difficile infection including during pregnancy,^95–97^ have shifted clinical science toward a more cautious approach to antibiotic use.^92^ Most recently, research on the microbiome has led to discoveries of protective bacterial colonization, including in the renal system, and growing concern that perturbations caused by antibiotic exposure may impact health.^12^ In light of this shift in understanding, selection of the type of antibiotic, duration of use, and indications for prescription have become more targeted.

Newer understandings of the human microbiome and the role of bacterial colonization in maintaining health are resulting in exploratory studies on the potential impact of antibiotic treatment on protective bacterial colonization.^98–100^ The urinary tract is not a sterile environment as once thought, and the potential for bacterial colonization to serve as a protective factor have led to new thinking about ASB.^12^ While some cases of ASB may pose a health risk, ASB is increasingly understood to be a benign condition for some adults, depending on the characteristics of the bacteria and the host environment. The effects of antibiotic use on commensal bacterial colonization of the gut and reproductive tract have also been associated with vaginal infections and inflammatory digestive conditions for adults.^101–104^ Further research is needed to better understand whether previously unrecognized consequences of antibiotic exposure at different stages of the life span may need to be mitigated or taken into account when weighing the net benefit of ASB screening programs. Theoretical and evident harms, such as the development of antibiotic resistance and increased future infection risk from elimination of protective bacteria in the urinary tract, are of particular concern for general adult populations where health benefits from treatment have not been established.

Data on current ASB screening practices in the United States was not found, and there is likely to be variation in practice across different types of primary care settings. Further research is needed to understand current screening approaches, and the extent to which screening with culture is practiced, in accordance with the trial evidence and longstanding recommendations. ASB is commonly defined as two consecutive voided urine specimens with isolation of the same bacterial species at a count of ≥10^5^ CFU/mL in both. This CFU/mL cutpoint and the requirement that it be observed for a single bacterial organism was applied in most of the included studies in this review. Several also required more than one positive culture result on subsequent samples. In current clinical practice, typically only one voided specimen is obtained, and diagnosis and treatment decisions are often made without repeat sample collection and culture.

Evidence was not found that would allow us to draw conclusions about the importance of different screening threshold and diagnostic confirmation criteria for obtaining ASB treatment benefits. None of the included studies specified a lower screening threshold for ASB; for example, GBS ASB is an indicator of vaginal colonization at a lower threshold (10^4^ CFU/mL) and is treated with intrapartum intravenous antibiotics to prevent newborn sepsis.^21,^ ^105^ Colonization with GBS is more commonly detected through recommended vaginal culture screening later in pregnancy.^21,^ ^105^ The available screening approaches and practices in prenatal care have changed over time since the evidence on ASB treatment in pregnancy was generated. Culture-based screening remains useful for guiding the selection of antibiotic treatment when the result is positive, which is particularly important during pregnancy due to the reduced number of safe treatment alternatives. The range of sensitivities and specificities reported above suggest that some tests (e.g., dipslide with gram staining) could be further investigated to assess whether they may achieve reasonable test performance for onsite for screening in certain settings when combined with reflex culture.

In the United States, where screening for ASB in pregnancy is a longstanding practice, pyelonephritis rates are low. A cohort study from 2005 estimated 1.4 percent incidence of pyelonephritis^6^ and a more recent, large KPSC cohort study reported even lower, but rising, rates of acute pyelonephritis in pregnancy (4.6 per 1,000 births to 5.9 per 1,000 births, p for trend <.001).^7^ Several risk factors associated with the condition have been identified, including younger age, nulliparity, fewer years of education, black or Hispanic race/ethnicity, smoking during pregnancy, late initiation of prenatal care, and pregestational diabetes. Women at risk of developing pyelonephritis in pregnancy, particularly women with limited access to health care, are at risk of poor birth outcomes for a host of reasons. Ensuring adequate screening and interventions for those at risk for poor outcomes may require system- and policy-level interventions to facilitate early and regular access to prenatal health care.

## Conclusions

As with previous reviews on this topic, we did not identify benefits from screening and treatment of ASB in general adult and elderly populations based on evidence that focused primarily on women. For pregnant women, evidence almost entirely from an earlier era indicated potential benefits from screening and treatment of ASB among pregnant women. Due to the historical nature of the evidence, more lenient quality rating of studies was employed to allow for changes in trial reporting standards over time. The findings are likely subject to considerable risk of bias, however, and treatment protocols used in several studies are no longer used in clinical practice. Evidence of a reduction in the risk of pyelonephritis was the most consistent and precise finding of a treatment benefit, and there was less convincing evidence that ASB treatment reduced the risk of having a low birthweight infant, and publication bias or selective reporting may have inflated the effect. Adverse reactions to medication were reported, including nausea, diarrhea and rashes, but reporting was limited. More serious harms of treatment were sparsely reported and were not statistically significant in individual studies or meta-analysis. Evidence from the only recent trial highlights a need for additional research to update the medical literature that informs ASB screening and treatment practices.