# Chapter 3 Results

## Description of Included Studies

We reviewed 4,318 abstracts and 288 full-text articles. Following review of full-text articles and critical appraisal, we included 19 studies of screening or treatment for ASB,^42–60^ reported in 36 publications (Appendix A Figure 1; Appendix B).^14,^ ^15,^ ^42–75^ Only one study was published after the last USPSTF recommendation on this topic.^59^ Fourteen of the included studies were conducted among pregnant women; 2 examining the effectiveness and/or harms of screening^42,^ ^43^ and 12 examining the effectiveness and harms of treatment.^44–46,^ ^48,^ ^49,^ ^51,^ ^53,^ ^54,^ ^56–59^ Five included studies examined the effectiveness and harms of treatment among general adult populations, primarily women and older adults (Table 2).^50,^ ^52^ ^47,^ ^55,^ ^60^

Table 2 Included Trials, by Population and Key Question (k=19)

Author, Year | QR | Population | Country | Study design | N | KQ
Gratacos, 1994^43^ | Fair | Pregnant women | ESP | Cohort | 4917^*^ | KQ1
Uncu, 2002^42^ | Fair | Pregnant women | TUR | Cohort | 372^*^ | KQ1,KQ2
Brumfit, 1975^58^ | Fair | Pregnant women | GBR | RCT | 414 | KQ3
Elder, 1971^48^ | Fair | Pregnant women | US | RCT | 289 | KQ3,KQ4
Foley, 1987^51^ | Fair | Pregnant women | IRL | RCT | 220 | KQ3
Furness, 1975^46^ | Fair | Pregnant women | AUS | RCT | 206 | KQ3,KQ4
Gold, 1966^57^ | Fair | Pregnant women | US | RCT | 65 | KQ3,KQ4
Kazemier, 2015^59^ | Fair | Pregnant women | NLD | RCT | 85 | KQ3,KQ4
Kincaid-Smith, 1965^54^ | Fair | Pregnant women | AUS | RCT | 116 | KQ3
Little, 1966^49^ | Fair | Pregnant women | GBR | RCT | 265 | KQ3,KQ4
Pathak, 1969^53^ | Fair | Pregnant women | JAM | RCT | 178 | KQ3
Savage, 1967^56^ | Fair | Pregnant women | US | RCT | 203 | KQ3,KQ4
Williams, 1969^45^ | Fair | Pregnant women | GBR | RCT | 163 | KQ3
Wren, 1969^44^ | Fair | Pregnant women | AUS | RCT | 173 | KQ3,KQ4
Abrutyn, 1994^52^ | Fair | Older adults | US | Nonrand CCT | 358 | KQ3
Asscher, 1969^50^ | Fair | Adults | WLS | RCT | 94 | KQ3,KQ4
Boscia, 1987^47^ | Fair | Older adults | US | RCT | 124 | KQ3,KQ4
Giamarellou, 1998^60^ | Fair | Older adults | GRC | RCT | 96 | KQ3,KQ4
Harding, 2002^55^ | Good | Adults with diabetes | CAN | RCT | 105 | KQ3,KQ4

* Included in cohort

Abbreviations: AUS = Australia; CAN = Canada; CCT = clinical controlled trial; ESP = Spain; GBR = Great Britain; GRC = Greece; IRL = Ireland; JAM = Jamaica; KQ = Key Question; N = number of participants; NLD = Netherlands; Nonrand = nonrandomized; QR = quality rating; RCT = randomized controlled trial; TUR = Turkey; US = United States; WLS = Wales

Of the 288 articles reviewed, the most common reasons for exclusion were; not a study (e.g., literature summaries, commentaries) (k=101), lack of relevant outcomes or incomplete outcome reporting (k=25), or study design (k= 60). Appendix C contains a list of all excluded studies and the reasons for exclusion.

## Key Question 1 Benefits of Screening for ASB

### Pregnant Women

#### Summary of Results

Two retrospective observational cohort studies,^42,^ ^43^ comparing data on pregnant women before and after a routine screening program was introduced, provided limited evidence on the effects on pregnancy outcomes of screening for and treatment of ASB. One study reported five cases of pyelonephritis over the study period with only one case in the intervention group.^42^ More cases of intrauterine death and intrauterine growth retardation were also reported in the unscreened control group in this study, but the small study n and low event rates limited statistical power for comparisons. The other study reported a statistically significant effect of screening for pyelonephritis; there were three times more cases of pyelonephritis reported in the unscreened cohort than the screened cohort.^43^ The study did not report findings for any other health outcomes. Both of these observational studies were noted to have considerable risk of bias from missing data, selective outcome reporting, and possible underlying differences in the screened and unscreened cohorts.

##### Characteristics of Included Studies

Two fair-quality cohort studies (N=5,289)^42,^ ^43^ compared a screened cohort to an unscreened comparison group to assess the effects of implementing an ASB screening program on maternal and perinatal outcomes (Table 2). A study of 4,917 pregnant women conducted in Spain analyzed hospital data on women seen in prenatal care before 25 weeks’ gestation and delivered at Hospital Clinic of Barcelona from the years 1987–1992.^43^ Women who delivered from 1987 to the end of 1990 were not routinely screened for ASB and were compared with women entering prenatal care from 1991 to the end of 1992 who were routinely screened for ASB. Similarly, a study of 372 pregnant women conducted in Bursa, Turkey, included women screened for ASB prior to 32 weeks’ gestation during 1998–1999 (n=186) and a comparative retrospective control cohort that delivered at the hospital prior to the initiation of the ASB screening program (n=186).^42^

##### Population Characteristics

The population in the Spanish study^43^ was not described apart from participant pregnancy status, and in the Turkish study a mean age of 28 was reported for both the screened and unscreened cohort.^42^

Both studies included screening at the first prenatal visit with neither reporting when exactly in pregnancy this tended to occur. In the Spanish study,^43^ screening was conducted with culture and an ASB diagnosis required two positive tests for the same organism on culture. When ASB was diagnosed, it was treated based on antibiotic sensitivity testing. In the Turkish study, a single positive urine culture with count of ≥10^5^ colony forming units (CFU)/mL was used to diagnose ASB, which was treated with ampicillin, cephalexin or nitrofurantoin.^42^

##### Study Quality

Both studies were rated fair quality, with several factors contributing to an elevated risk of bias. Neither of the included studies provided details on the source of study outcome data, the procedures used to select the comparison cohort, or the characteristics of women in the screened and unscreened groups. In both cases, the comparison group was identified retrospectively, increasing the risk of bias from missing data, selective outcome ascertainment, or differences in the study group characteristics or composition. In the Turkish study, the time period during which the unscreened control group was selected and how the retrospective control group was identified (i.e., every patient or select patients) were not specified.^42^

#### Detailed Results by Outcome

##### Pyelonephritis

The Spanish study compared 1,652 women screened for ASB with 3,265 women in an unscreened retrospective comparison cohort.^43^ In the screened cohort, 4.7 percent of pregnant women <25 weeks’ gestation were diagnosed with ASB. A smaller proportion of women in the screening cohort (9/1,652 [0.5%]) compared with the unscreened cohort (60/3,265 [1.8%]) were diagnosed with pyelonephritis during their pregnancy—such that the risk was 3 times lower after implementation of routine screening and treatment (RR, 0.30 [95% CI, 0.15 to 0.60]) (Table 3).

Table 3 Health Outcomes and Adverse Events Reported in Trials of Screening for Asymptomatic Bacteriuria in Pregnant Women (k=2)

Author, Year | Outcome | Events in Screening Cohort n/N (%) | Events in Unscreened Cohort n/N (%) | RR (95% CI)
Uncu, 2002^42^ | Fetal abnormalities | 3/186 (1.6%) | 2/186 (1.1%) | 1.5 (0.25 to 8.87)
Uncu, 2002^42^ | Hypertension | 8/186 (4.3%) | 18/186 (9.7%) | 0.44 (0.20 to 1)
Uncu, 2002^42^ | Intrauterine death^*^ | 1/186 (0.5%) | 7/186 (3.8%) | 0.14 (0.02 to 1.15)
Uncu, 2002^42^ | Intrauterine growth retardation^*^ | 1/186 (0.5%) | 5/186 (2.7%) | 0.20 (0.02 to 1.7)^†^
Uncu, 2002^42^ | Prematurity^*^ | 22/186 (11.8%) | 18/186 (9.7%) | 1.22 (0.68 to 2.2)
Uncu, 2002^42^ | Pyelonephritis^*^ | 1/186 (0.5%) | 4/186 (2.2%) | 0.25 (0.03 to 2.22)^†^
Gratacos, 1994^43^ | Pyelonephritis^‡^ | 9/1652 (0.5%) | 60/3265 (1.8%) | 0.30 (0.15 to 0.60)^§^

* Definition NR

† The study reported a statistically significant between group difference (p≤0.05), but based on the reported data and methods, it is unclear what accounted for this result

‡ Fever, flank pain, tenderness in the costovertebral angle, and positive urine culture

§ eStudy reported inverse calculation of RR: 3.37 (1.68 to 6.78)

Abbreviations: CI = confidence interval; n = number of events; mos = months; N = number of participants; NR = not reported; NS = not significant; RR = relative risk

The Turkish study of women <32 weeks’ gestation reported results of ASB screening for 186 women (with “sufficient delivery records”) compared with an unscreened control comprising 186 women.^42^ In the screened group, 9.3 percent of women were diagnosed with ASB. There was one case of pyelonephritis in the screened cohort and four cases in the unscreened control group.

##### Birth Outcomes

No birth or infant outcomes were reported in the Spanish study.^43^ The Turkish study reported no significant difference in the weight of newborns (data NR). The rate of prematurity was not found to differ between the screened and unscreened cohort (11.8% [22/186] versus 9.7% [18/186]). The authors reported fewer cases of intrauterine death (1/186 versus 7/186) and intrauterine growth retardation (1/186 compared with 5/186) in the screened cohort than in the unscreened control (Table 3).^42^ The study had low event rates and study N, and was therefore not adequately powered to detect group differences for these outcomes. Although the study text reported a statistically significant difference for intrauterine growth retardation, it is unclear from the study-reported numbers and methods what would account for this finding, and it was inconsistent with the absence of statistically significant differences reported for other outcomes with larger observed effects.

##### Hypertensive Disorders of Pregnancy

The Turkish study reported a lower rate of hypertension in pregnancy among women in the screened group than in the unscreened group (4.3% [8/186] versus 9.7% [18/186]) (Table 3).^42^ It was unclear what might account for this difference, which approached statistical significance in an unadjusted comparison (calculated RR, 0.44 [95% CI, 0.20 to 1.0]).

### General Adult Populations

No studies were identified that addressed the benefits of screening for ASB in the general adult population.

## Key Question 2 Harms of Screening for ASB

### Pregnant Women

Only one cohort study comparing screened and unscreened pregnant women reported a potential harm of the screening program, with no meaningful differences reported.^42^

This study of 372 women conducted in Turkey,^42^ described above, was included to assess potential harms of screening for ASB. Two congenital abnormalities were reported in the unscreened cohort (2/186) compared with three in the screening cohort (3/186); the three congenital abnormalities were observed among infants of women who screened ASB negative and presumably were not prescribed antibiotics to treat ASB. No other potential harms of screening for ASB and subsequent treatment with antibiotics were reported in the included studies, including no paradoxical effects on reported outcomes (Table 3).

### General Adult Populations

No studies were identified that addressed the harms of screening for ASB in the general adult population.

## Key Question 3 Benefits of Treating Screen-Detected ASB

### Pregnant Women

#### Summary of Results

Twelve fair-quality trials,^44–46,^ ^48,^ ^49,^ ^51,^ ^53,^ ^54,^ ^56–59^ most conducted over 40 years ago and many employing treatment protocols no longer used in modern clinical practice, provided evidence on the benefits of treating screen-detected ASB. Screening in the older studies was primarily conducted with an initial urine culture and a second culture test to confirm diagnosis. The only recent study, conducted in the Netherlands, used a single dipslide urine test to screen for ASB, focusing on a low risk patient population.^59^ The sparse reporting and sometimes flawed methods used in this earlier era of medical research raise the risk of potential bias. With caveats regarding the limitations of the literature, the available trials provided evidence that treatment of ASB in pregnancy reduces the risk of pyelonephritis and the finding was robust in sensitivity analyses. Other outcomes were less likely to be reported across the included studies. Seven studies of treatment on the incidence of low birthweight in infants provided evidence of a benefit in pooled analysis, and the direction of effects were nearly all in the direction of a benefit. Fewer studies reported mean birthweight and rates of preterm birth, and findings in all but one individual study and the pooled analyses for these outcomes were null. Six studies reported differences in perinatal mortality,^44,^ ^48,^ ^49,^ ^54,^ ^56,^ ^59^ with more inconsistency in the direction of effects, and a null pooled effect.

#### Characteristics of Included Studies

##### Population Characteristics

Twelve trials of pregnant women screened for ASB and randomized to either a treatment or control condition were included (N = 2,377).^44–46,^ ^48,^ ^49,^ ^51,^ ^53,^ ^54,^ ^56–59^ All but two^51,^ ^59^ were published in the 1960s or 1970s (Table 4). The two most recently published studies were conducted in the Netherlands (2015)^59^ and Ireland (1987) (N=305).^51^ Among the 10 early studies, three were conducted in the United States (N=557),^48,^ ^56,^ ^57^ and the remainder in Great Britain,^45,^ ^49,^ ^58^ Jamaica,^53^ and Australia.^44,^ ^46,^ ^54^ Most studies were conducted in the OB/GYN clinics of hospitals, with seven specifying screening at the first prenatal visit,^44–46,^ ^49,^ ^54,^ ^57,^ ^58^ two specifying screening by a certain week of gestation in pregnancy,^48,^ ^59^ and three indicating pregnant women with no mention of the timing of study recruitment.^51,^ ^53,^ ^56^

Table 4 Study and Population Characteristics of Included Studies of Treatment for Asymptomatic Bacteriuria in Pregnant Women (k=12)

Author, Year | QR | Study design | Country | Population criteria | ASB screening tool detail | ASB prevalence (N pos./N screened) | N rand | Mean age (range) | Smoker (%) | Race/Ethnicity (%)
Brumfit, 1975^58^ | Fair | RCT | GBR | Pregnant women, <32 weeks’ gestation; Exclusion criteria: Home delivery, abortion, treatment before confirmation of bacteriuria, other complicating factors (not specified) | Culture; Cutoff: NR; Detail: NR | 426/20000 (2.1%) | 414 | 26.4 (NR) | 22.2 | Asian: 9.7; Other: 10.6^*^
Elder, 1971^48^ | Fair | RCT | US | Pregnant women, <32 weeks’ gestation; Exclusion criteria: Treated for UTI prior to the first obstetric visit, delivered or aborted after registering but before first obstetric visit, transferred prenatal care after registration | Culture; Cutoff: ≥10^5 CFU/ml; Detail: Two positive tests of the same organism | 362/9156^†^ (4.0%) | 289 | 25.1 (NR) | 51.6 | White: 39.9; Other: 60.1
Foley, 1987^51^ | Fair | RCT | IRL | Pregnant women; Exclusion criteria: NR | NR; Cutoff: >10^5 CFU/ml; Detail: One positive test of a single organism | 220/6883 (3.2%) | 220 | NR | NR | NR
Furness, 1975^46^ | Fair | RCT | AUS | Pregnant women; Exclusion criteria: NR | Dipslide; Cutoff: ≥10^5 CFU/ml; Detail: One positive test of a single organism | 226/5256 (4.3%) | 206 | NR | NR | NR
Gold, 1966^57^ | Fair | RCT | US | Pregnant women; Exclusion criteria: Failed to return to the clinic, aborted, delivered at other hospitals, found to be not pregnant, ectopic pregnancy, transferred to other care, delivered by private physician | Culture; Cutoff: ≥10^5 CFU/ml; Detail: Two positive tests of the same organism | 65/1281 (5.1%) | 65 | NR | NR | White: 9.0^‡^; Hisp: 6.0^§^; Other: 85.0^ǁ^
Kazemier, 2015^59^ | Fair | RCT | NLD | Pregnant women (age ≥ 18 years), 16–22 weeks’ gestation; Exclusion criteria: Prior preterm birth (<34 weeks), symptoms of UTI, signs of preterm delivery, congenital malformations, antibiotic use at screening, known G6PD deficiency, allergy to nitrofuran | Dipslide; Cutoff: ≥10^5 CFU/ml; Detail: One positive test of a single organism | 255/5132 (5.0%) | 85 | 29^¶^ (NR) | 8.0^¶^ | White: 92.0^¶^
Kincaid-Smith, 1965^54^ | Fair | RCT | AUS | Pregnant women, <26 weeks’ gestation; Exclusion criteria: NR | Culture; Cutoff: ≥10^5 CFU/ml; Detail: Two positive tests of a single organism | 160/4000^#^ (4.0%) | 116 | NR | NR | NR
Little, 1966^49^ | Fair | RCT | GBR | Pregnant women, 12 weeks’ gestation (mean); Exclusion criteria: NR | Culture; Cutoff: ≥10^5 CFU/ml; Detail: Two positive tests of the same organism | 265/5000 (5.3%) | 265 | NR (10–40+) | NR | NR
Pathak, 1969^53^ | Fair | RCT | JAM | Pregnant women, <24 weeks’ gestation; Exclusion criteria: Blood pressure >130/90 mm Hg | NR; Cutoff: ≥10^5 CFU/ml; Detail: Two positive tests of the same organism | 217/7602 (2.9%) | 178 | NR | NR | NR
Savage, 1967^56^ | Fair | RCT | US | Pregnant women, <32 weeks’ gestation; Exclusion criteria: Clinical diagnosis of chronic renal insufficiency | Culture; Cutoff: >10^5 CFU/ml; Detail: Three positive tests of the same organism | 245/6327 (3.9%) | 203 | NR | NR | White: 52.0^**^; AA: 46.0^**^; Other: 2.0^**^
Williams, 1969^45^ | Fair | RCT | GBR | Pregnant women, <30 weeks’ gestation; Exclusion criteria: NR | Culture; Cutoff: >10^5 CFU/ml; Detail: Two positive tests of the same organism | 211/5542 (3.8%) | 163 | NR | NR | NR
Wren, 1969^44^ | Fair | RCT | AUS | Pregnant women; Exclusion criteria: NR | Culture; Cutoff: NR; Detail: Two positive tests of the same organism | 183/3604 (5.1%) | 173 | NR | NR | NR

* West Indian

† Number invited

‡ Baseline characteristics for entire screened cohort “other white”

§ Puerto Rican

ǁ Non-white

¶ IG only, CG age NR

# Calculated

** Estimated from figure

Abbreviations: AUS = Australia; CFU/ml = colony forming units/milliliter; GBR = Great Britain; IRL = Ireland; JAM = Jamaica; N = number of participants; NLD = Netherlands; NR = not reported; rand = randomized; pos = positive; QR = quality rating; RCT: randomized controlled trial; US: United States

Information on the characteristics of the study participants was very sparsely reported, but when available, reported higher smoking prevalence in earlier cohorts. There was limited reporting on race/ethnicity, and imbalances were seen. Only three studies reported the mean age of randomized women (range 25–29).^48,^ ^58,^ ^59^ Three studies reported smoking rates.^48,^ ^58,^ ^59^ In one U.S. study published in 1971,^48^ 52 percent of the pregnant women randomized were described as smokers. This study also reported race/ethnicity, described as 40 percent “white” and 60 percent “other.”^48^ In a 1975 study from Great Britain, 22 percent of pregnant women randomized were identified as smokers, with more in the control group (26%) than the intervention group (19%).^58^ This study also reported the race/ethnicity for 20 percent of the study population as Asian or West Indian, with lower percentages in the control group (14%) relative to the intervention group (21%). The recent Netherlands study reported that 8 percent of women in the intervention group were smokers.^59^ Smoking rates in the control group were not reported. This same study reported white race/ethnicity for 92 percent of the study participants. Estimates from the figure from another early U.S. study identified the race/ethnic composition of the study sample as 52 percent “white,” 46 percent “African American,” and 2 percent “other.”^56^ This study also reported fewer white participants and more high gravidity women in the control group compared with the intervention group (>5% difference).

Exclusion criteria were not specified or few (e.g., hypertensive, chronic renal insufficiency, recent UTI) in most of the included studies, and some referred to loss to study followup in describing exclusions. The most recent trial excluded women at risk of preterm birth and other health conditions with the aim of enrolling a low-risk study population.^59^

Screening procedures and definitions of ASB were variable across the included studies. Some specified the approach taken to obtain a clean-catch,^45,^ ^48,^ ^58^ midstream urine sample,^44,^ ^46,^ ^49,^ ^57,^ ^59^ while others simply described the sample as a clean catch.^51,^ ^53,^ ^54,^ ^56^ While most studies specified a midstream sample, not all were described as clean catch. Laboratory culture testing was the primary screening modality. Two studies,^46,^ ^59^ including the most recent, relied on dipslide testing. ASB positive women were most commonly defined as those with colony counts ≥10^5^ CFU/mL dilution of the same single bacterial species on two consecutive samples, with some studies defining fewer criteria (e.g., same organism not required, single sample) including the most recent trial which relied on a single sample. The percent of pregnant women screened who were diagnosed with ASB ranged from 2.1 to 5.3 percent across the included studies. The most recent study identified 5.0 percent of women screened with dipslide as ASB positive.^59^

##### Intervention Characteristics

Treatments for screen-detected ASB varied widely across the included studies with respect to timing, dosage, duration, and medication (Table 5). Antibiotics were the primary treatment in all of the studies with the exception of one that used renal antiseptics (i.e., methenamine hippurate, methenamine mandelate).^46^ Sulfonamides were the most common class of antibiotics used, but many of the specific antibiotics tested in the studies are no longer used (e.g., sulfamethizole, sulfadimethoxine). Five of the studies used nitrofurantoin alone^53,^ ^59^ or as one of several antibiotic treatment options.^44,^ ^49,^ ^51^ One study used tetracycline,^48^ which is contraindicated and no longer used during pregnancy. The treatment dosage and duration in most of the studies were higher and longer than what is more common to contemporary practice. Four studies continued treatment from the time ASB was diagnosed until delivery or postpartum,^44,^ ^46,^ ^54,^ ^57^ resulting in continuous antibiotic use for weeks or months. Only five of the studies randomized women to an initial treatment lasting a week or less,^45,^ ^51,^ ^56,^ ^58,^ ^59^ including one study using a single 2000mg dose of sulphormethoxine^58^ and another using a high dose of a sulfonamide no longer used in clinical practice (i.e., sulphadimidine, 1000mg, three times a day, seven days).^45^

Table 5 Intervention Descriptions for Included Studies of Treatment for Asymptomatic Bacteriuria in Pregnant Women (k=12)

Author, Year | IG | Intervention type | Intervention details | Treatment duration | CG Condition
Brumfit, 1975^58^ | IG1 | Antibiotic | Sulphormethoxine: 2000 mg, (1 day)^*^ | Short term (up to 1 week) | Placebo
Elder, 1971^48^ | IG1 | Antibiotic | Tetracycline: 250 mg, qid (6 weeks) | Intermediate (3 to 6 weeks) | Placebo
Foley, 1987^51^ | IG1 | Antibiotic | Sulphamethizole or Nitrofuratoin: NR^†^ | Short term (up to 1 week) | No Treatment
Furness, 1975^46^ | IG1 | Urinary antiseptic | Methenamine hippurate (Hiprex): 1000 mg, bid (until delivery) | Duration of pregnancy | No Treatment
Furness, 1975^46^ | IG2 | Urinary antiseptic | Methenamine mandelate (Mandelamine): 1000 mg, qid (throughout pregnancy) | Duration of pregnancy | No Treatment
Gold, 1966^57^ | IG1 | Antibiotics (sequential) | Sulfadimethoxine: 500 mg, qd (through week 36)^*^; Sulfadiazine: 1000 mg, tid (weeks 36 through delivery) | Duration of pregnancy | Placebo
Kazemier, 2015^59^ | IG1 | Antibiotic | Nitrofurantoin: 100 mg, bid (5 days) | Short term (up to 1 week) | Placebo
Kincaid-Smith, 1965^54^ | IG1 | Antibiotics (sequential) | Sulphamethoxydiazine: 500 mg (through week 30 of pregnancy)^*^; Sulphadimidine: 1000 mg, tid (week 30 through delivery) | Duration of pregnancy | Placebo
Little, 1966^49^ | IG1 | Antibiotic | Sulphamethoxypyridazine (sulphonamide): 500 mg, qd (30 days)^‡^ | Intermediate (3 to 6 weeks) | Placebo
Pathak, 1969^53^ | IG1 | Antibiotic | Nitrofuratoin: 100 mg, bid (3 weeks) | Intermediate (3 to 6 weeks) | Placebo
Savage, 1967^56^ | IG1 | Antibiotic | Sulfamethoxypyridazine: 500 mg, qd (1 week) | Short term (up to 1 week) | Placebo
Williams, 1969^45^ | IG1 | Antibiotic | Sulphadimidine: 1000 mg, tid (7 days) | Short term (up to 1 week) | No Treatment
Wren, 1969^44^ | IG1 | Antibiotics (sequential) | 9 week treatment rotation until 1 to 6 weeks postpartum: Nitrofurantoin: 100 mg, bid (2 weeks); Ampicillin: 250 mg qid (1 week); Sulphurazole: 500 mg, qid (4 weeks); Nalidixic acid: 500 mg, qid (2 weeks) | Duration of pregnancy | No Treatment

* Dosing frequency NR

† Starting in 1981, treatment reduced over 6 years from sulphamethizole 600 mg or nitrofurantoin 300 mg TID for 14 days to sulphamethizole 300 mg and nitrofurantoin 150 mg for three days. Trial in 1985

‡ Primary treatment was changed from sulphamethoxypridazine to nitrofurantoin part way through trial, 44 participants treated with nitrofurantoin 100 mg, qd first line

Abbreviations: bid = two times per day; CG = control group; IG = intervention group; mg = milligram; NR = not reported; qd = once per day; qid = four times per day; tid = three times per day

##### Study Quality

All included studies for this key question were rated fair quality, having considerable risk of bias related to the trial methods and reporting. With one exception,^59^ this body of evidence was generated prior to standardization in the conduct and reporting of randomized trials. Several studies did not describe how randomization was conducted, or they used a randomization and allocation technique that would potentially not be protected from bias in study implementation. Moreover, the absence of reporting on the baseline characteristics or balance in the study groups prevents assessment of the effectiveness of randomization. Definitions of study outcomes were also often limited or absent. For example, pyelonephritis was a key outcome in most studies, but a clinical definition was not always provided.^44,^ ^51,^ ^53,^ ^57^ Five studies were judged to have particularly high risk of bias due to multiple concerns related to randomization and inconsistencies or a lack of clarity regarding the participant characteristics and outcomes.^44–46,^ ^56,^ ^58^

#### Detailed Results by Outcome

##### Symptomatic UTI and Pyelonephritis

Two studies reported symptomatic lower UTIs.^51,59^ One did not provide a clear definition but reported similar numbers of UTI cases in the treatment arm (4/100) and the control arm (5/120).^51^ The other reported UTI cases treated with antibiotics during pregnancy in the treatment arm (4/40) and the control arm (8/45).^59^ Although the numbers were higher in the CG, the relative risk was not statistically significant (calculated RR, 0.56 [95% CI, 0.02 to 8.93]) (Appendix E Table 1).

Twelve studies reported rates of pyelonephritis in trial intervention and control groups among pregnant women with screen-detected ASB (Figure 2, Appendix E Table 1).^44–46,^ ^48,^ ^49,^ ^51,^ ^53,^ ^54,^ ^56–59^ Rates of pyelonephritis in the control group were 2.2 percent in the most recent study^59^ and 2.5 percent in the second most recent study,^51^ published in 1987. Rates of pyelonephritis in the older studies were considerably higher, ranging from 7 to 36 percent, with 8 of the 12 included studies reporting pyelonephritis rates greater than 20 percent among women with ASB in the untreated/placebo arm. Higher rates of pyelonephritis were observed in the control group (placebo or no treatment) than in the treated group in all but one study.^51^ Eight of the 12 studies reported statistically significant reductions in pyelonephritis,^44,^ ^45,^ ^48,^ ^49,^ ^53,^ ^54,^ ^56,^ ^58^ and overall, the pooled estimate suggested a four-fold risk reduction (pooled RR, 0.24 [95% CI, 0.14 to 0.40], k=12, n = 2,068, I^2^ 56.9%). Sensitivity analyses dropping studies from meta-analysis that were deemed to have particularly high risk of bias demonstrated a greater pooled risk reduction and lower statistical heterogeneity (pooled RR, 0.19 [95% CI, 0.11 to 0.34], k=7, n=1,184, I^2^ 15.6%) (Appendix D Figure 1). Analyses stratified by the extent to which pyelonephritis was defined using specific diagnostic criteria did not reveal a clear pattern, with statistically significant reductions seen for studies regardless of the strength of the definition provided (Appendix D Figure 2). Visual inspection of plots sorted by treatment duration suggested that findings were not driven by longer treatment protocols that are no longer used. Visual inspection of a funnel plot revealed some asymmetry, and the Egger test approached statistical significance (p = 0.08).

Figure 2 Pooled Analysis of Rates of Pyelonephritis Among Treated Pregnant Women Compared With Controls

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; N = number of participants; pyelo = pyelonephritis; RR = relative risk

Figure 2 displays a forest plot of the effect of 12 trials that reported rates of pyelonephritis among pregnant women treated for ASB compared with women in the control arm (n=2068). The pooled relative risk is 0.24 [95% CI: 0.14 to 0.40] in favor of the intervention group. The results are discussed further in the text.

##### Birth Outcomes

Overall, fewer studies reported birth outcomes, and findings were mixed. Pooled analyses, where possible, suggested a reduction in low birth weight, but the finding was tempered by the loss of statistical significance in a sensitivity analysis removing the highest-risk studies. Studies were not adequately powered to evaluate rare outcomes such as perinatal mortality.

Low birthweight. Seven studies reported differences in low birthweight infants (<2,500 grams or small for gestational age [SGA; weight below the 10th percentile for gestation age]) among women treated or untreated for ASB (Figure 3, Appendix E Table 2).^44,^ ^48,^ ^49,^ ^54,^ ^56,^ ^58,^ ^59^ The proportion of low birthweight infants ranged from 2.5 to 14.8 percent in the study intervention groups and from 6.7 to 21.4 percent in the study control groups. A statistically significant reduction in the risk of low birthweight was reported in two studies,^44,^ ^56^ and the pooled estimate was also statistically significant, with low statistical heterogeneity (pooled RR, 0.64 [95% CI, 0.46 to 0.90], k=7, n=1,522, I^2^ 15.8%). A sensitivity analysis removing studies with the highest risk of bias led to exclusion of the statistically significant studies, and loss of a significant pooled effect (pooled RR, 0.86 [95% CI, 0.57 to 1.31], k=4, n=745, I^2^ 0%) (Appendix D Figure 3). There were too few studies available for this outcome to support the Egger test or assessment of publication bias with a funnel plot. Results from five studies reporting mean birthweight^44,^ ^46,^ ^48,^ ^58,^ ^59^ were inconsistent and did not show a statistically significant effect (Figure 4, Appendix E Table 3).

Figure 3 Pooled Analysis of Rates of Low Birth Weight Among Treated Pregnant Women Compared With Controls

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; N = number of participants; RR = relative risk

Figure 3 displays a forest plot of the effect of 7 trials that reported rates of low birthweight among infants born to pregnant women treated for ASB, compared with those born to women in the control arm (n=1522). The pooled relative risk is 0.64 [95% CI, 0.46 to 0.90] in favor of the intervention group. The results are further discussed in the text.

Figure 4 Pooled Analysis of Mean Birth Weight (Grams) of Infants Born to Treated Pregnant Women Compared With Those Born to Controls

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; n = number of participants; SD = standard deviation

Figure 4 displays a forest plot of the effect of 5 trials that reported rates of low birthweight in grams among infants born to pregnant women treated for ASB, compared with those born to women in the control arm (n=1070). The pooled mean difference was not significant with a 15.51 g [95% CI: −91.17 to 122.18] greater birthweight among infants in the intervention arm. The results are discussed further in the text.

Preterm Birth. Three studies reported differences in preterm birth defined as <37 weeks’ gestation^44,^ ^57,^ ^59^ and one study used <38 weeks’ gestation^46^ to define preterm birth (Figure 5, Appendix E Table 2).^44,^ ^46,^ ^57,^ ^59^ One study considered to be at higher risk of bias reported a statistically significant benefit for the intervention group,^44^ and the remaining three trials reported nonstatistically significant differences in the direction of a control group benefit. Few small and clinically heterogeneous studies reported this outcome, limiting conclusions that can be drawn from the null pooled estimate.

Figure 5 Pooled Analysis of Rates of Preterm Birth Among Treated Pregnant Women Compared With Controls

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; N = number of participants; RR = relative risk

Figure 5 displays a forest plot of the effect of 4 trials that reported rates of preterm birth among infants born to pregnant women treated for ASB, compared with those born to women in the control arm (n=493). The pooled relative risk is was 0.81 [95% CI: 0.38 to 1.73] with no significant difference between groups. The results are further discussed in the text.

Perinatal mortality. Six studies reported perinatal mortality (Figure 6, Appendix E Table 4).^44,^ ^48,^ ^49,^ ^54,^ ^56,^ ^59^ Half of the trial effects were in the direction of treatment benefit and the other half in the direction of treatment harms, but owing to small numbers, none of the studies reported statistically significant effects, and the pooled estimate was null (pooled RR, 0.98 [95% CI, 0.29 to 3.26], k=6, n=1,103, I^2^ 52.3%). A sensitivity analysis eliminating two studies with the highest risk of bias was also null (pooled RR 1.93 [95% CI 0.84, 4.45]) (Figure 4 in Appendix D).^44,^ ^56^ The small number and size of the included studies in the sensitivity analysis, however, results in an underpowered analysis for evaluating this rare outcome.

Figure 6 Pooled Analysis of Rates of Perinatal Mortality Among Infants Born to Treated Pregnant Women Compared With Those Born to Controls

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; N = number of participants; RR = relative risk

Figure 6 displays a forest plot of the effect of 6 treatment trials that reported rates of perinatal mortality among infants born to pregnant women treated for ASB, compared with those born to women in the control arm (n=1103). The pooled relative risk is 0.98 [95% CI: 0.29 to 3.26] with no significant difference between groups. The results are discussed further in the text.

#### Hypertensive Disorders of Pregnancy

Five studies reported the occurrence of hypertensive disorders of pregnancy, primarily preeclampsia or ‘toxemia’ in the intervention and control groups (Figure 7, Appendix E Table 5),^44,^ ^48,^ ^49,^ ^59^ or noted whether there were significant differences.^54^ None of the studies reported a statistically significant difference in cases between the intervention and control groups, with most reporting more cases in the intervention group. The pooled effect across studies was null for an increased risk in the intervention group (pooled RR, 1.21 [95% CI, 0.76 to 1.93], k=5, n=889, I^2^ 0%).

Figure 7 Pooled Analysis of Rates of Hypertensive Disorders Among Treated Pregnant Women Compared With Controls

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; N = number of participants; RR = relative risk

Figure 7 displays a forest plot of the effect of 5 trials that reported rates of hypertensive disorders among pregnant women treated for ASB compared with women in the control arm (n=928). The pooled relative risk is 1.21 [95% CI: 0.76 to 1.93] with no significant difference between groups. The results are discussed further in the text.

### General Adult Populations

#### Summary of Results

One good-quality^55^ trial and four fair-quality^47,^ ^50,^ ^52,^ ^60^ trials addressed the benefits of treating screen-detected ASB in general adult populations. In general, fair-quality studies lacked reporting on the randomization and allocation of participants, as well as methods for outcome assessment. Four trials^47,^ ^50,^ ^52,^ ^55^ were conducted only in women, and the fifth trial^60^ was primarily in older women (83.9%). All studies had sparse reporting of participant characteristics. Treatment was variable across the trials ranging from a single dose to 3 months of daily antibiotics. No study found a difference the rates of symptomatic infections, mobility, or mortality between treated and untreated individuals.

#### Characteristics of Included Studies

##### Population Characteristics

We identified five trials (N=777) examining the effectiveness of antibiotic treatment in general adult populations with screen-detected ASB (Table 6).^47,^ ^50,^ ^52,^ ^55,^ ^60^ These studies were conducted in the United States (two studies),^47,^ ^52^ Canada,^55^ the United Kingdom,^50^ and Greece.^60^ Two studies of adult women (N=199) recruited individuals from medical centers.^50,^ ^55^ One study conducted in Wales included women ages 20–65 without diabetes.^50^ The study conducted in Canada was limited to women with diabetes (mean age 55.3 years) recruited from endocrinology clinics and tertiary care.^55^ Three studies were conducted among older adults (N= 578) residing in independent living facilities.^47,^ ^52,^ ^60^ Two of the three studies among older adults were limited to women,^47,^ ^52^ and the third was mostly women (83.9%).^60^ The mean age of participants across the studies among older adults ranged from 81.9 to 85.8 years.

Table 6 Study and Population Characteristics of Included Studies of Treatment for Asymptomatic Bacteriuria in General Adult Populations (k=5)

Author, Year | QR | Study design | Country | FU (mos) | Population criteria | ASB screening tool detail | ASB prevalence (N positive/N screened) | N rand | Mean age (range) | Female (%)
Abrutyn, 1994^52^ | Fair | Nonrand CCT | US | 100 | Women (mean age: 81.9 years); Exclusion criteria: Indwelling catheters or those incapable of providing mid-stream clean-catch urine specimens | Culture; Cutoff: ≥10^5 CFU/ml; Detail: Two positive tests of the same organism | NR | 358 | 81.9 (NR) | 100
Asscher, 1969^50^ | Fair | RCT | WLS | 12 | Women (age 20–65 years); Exclusion criteria: Diabetes, pregnant women, presence of urinary symptoms | Culture; Cutoff: >10^5 CFU/ml; Detail: Two positive tests of the same organism | 107/3578 (3.0%) | 94 | NR (20–65) | 100
Boscia, 1987^47^ | Fair | RCT | US | 6 | Women (age ≥65 years); Exclusion criteria: Indwelling bladder catheter or incapable of giving a midstream clean-catch urine specimen | Culture; Cutoff: >10^5; Detail: Two positive tests of the same organism | 124/603 (20.6%) | 124 | 85.8 (70–100) | 100
Giamarellou, 1998^60^ | Fair | RCT | GRC | 6 | Older adults (age ≥65 years); Exclusion criteria: Required help for activities of daily living, major musculoskeletal problems, incontinence, bladder cauterization, recent manipulations of the urinary tract, renal failure, (i.e. serum creatinine >2.0 m | Culture; Cutoff: ≥10^5 CFU/ml; Detail: Two positive tests of the same organism within 1 week | 106/455 (23.3%) | 96 | 83.3 (NR) | 83.9
Harding, 2002^55^ | Good | RCT | CAN | 36 | Women with diabetes (age >16 years); Exclusion criteria: Pregnant women, serum creatinine level >2.25 mg/dL, or could not return for regular follow-up | Culture; Cutoff: ≥10^5 CFU/ml; Detail: Two positive tests of the same organism | 135/1900 (7.1%) | 105 | 55.3 (NR) | 100

Abbreviations: CAN = Canada; CCT = clinical controlled trial; CFU/ml = colony forming units/milliliter; FU = followup; GRC = Greece; mg/dL = milligram/deciliter; mos = months; N = number of participants; NR = not reported; QR = quality rating; RCT = randomized controlled trial; US = United States; WLS = Wales

In general, population characteristics were sparsely reported across studies, with none reporting on participant race, ethnicity, or smoking status.

All five studies included individuals who had two consecutive positive screening cultures from clean catch, mid-stream urine samples using a cutoff of greater than the 10^5^ CFU/ml.

##### Intervention Characteristics

The two studies of women with and without diabetes randomized women to short-term (1–2 weeks) antibiotics or placebo treatment (Table 7).^52,^ ^55^ Within the three studies of older adults, treatment was more variable; two studies examined short-term antibiotic treatment ranging from a single dose to 3 days,^47,^ ^52^ and one study treated individuals with antibiotics either daily or intermittently for 3 months (two intervention arms).^60^ All three studies were initiated with a “no treatment” control condition; however, at the midpoint of one study the control condition was changed to a placebo.^52^ In all studies, individuals who did not clear the infection were retreated with an additional course or courses of antibiotics.

Table 7 Intervention Descriptions for Included Studies of Treatment for Asymptomatic Bacteriuria in General Adult Populations (k=5)

Author, Year | IG | Antibiotic details | CG Condition
Abrutyn, 1994^52^ | IG1 | Varied, based on susceptibility (single dose to 3 days)^*^ | Placebo
Asscher, 1969^50^ | IG1 | Nitrofurantoin: 50 mg, qid (1 week) | Placebo
Boscia, 1987^47^ | IG1 | Trimethoprim: 200 mg, qd (1 day) | No Treatment
Giamarellou, 1998^60^ | IG1 | Ofloxacin: 200 mg, bid (3 days); 200 mg, qd (3 months) | No Treatment
Giamarellou, 1998^60^ | IG2 | Ofloxacin: 200 mg, bid (3 days every other week for 3 months) | No Treatment
Harding, 2002^55^ | IG1 | Trimethoprim-Sulfamethoxazole: 160/800 mg, bid (2 weeks) | Placebo

* Treatment was selected based on susceptibility and history of drug allergy: trimethoprim, 200 mg, single dose; trimethoprim-sulfamethoxazole, 160mg/800mg, single dose; cefaclor, 500 mg, TID for 3 days; amoxicillin, 250 mg, TID for 3 days; carbenicllin indanyl sodium, dosage NR, QID for 3 days; macrodantin, 100 mg, BID for 3 days; or norfloxacin, 400 mg, single dose

Abbreviations: bid = two times per day; CG = control group; IG = intervention group; mg = milligram; NR = not reported; qd = once per day; qid = four times per day; tid = three times per day

##### Study Quality

The study of ASB treatment in diabetic women was rated as good quality,^55^ and the four remaining studies were rated fair quality. The fair-quality studies lacked information about blinding and randomization. The percentage of individuals included in followup (reported or assumed) was generally high at 12 months (87 to 100%).^47,^ ^50,^ ^60^ In one study that reported findings through 3 years of followup, fewer than half (46.7%) were retained for the entire study (mean followup 2 years).^55^ One study did not provide information allowing for calculation of the number of participants lost to followup.^52^ The Greek study, conducted in older adults,^60^ reported earlier preliminary results of the study in an extended abstract,^68^ but the reported results and time points provided in the preliminary abstract did not match those reported in the final publication. Therefore, results from the final publication were used.^60^

#### Detailed Results by Outcome

##### Symptomatic UTI and Pyelonephritis

Four studies reported on the rate of symptomatic infection or pyelonephritis; no study found a statistically significant difference. The study among nonpregnant women reported that during 1 year of followup, symptomatic infections developed in 36.7 percent of those in the treatment group and 35.6 percent of the placebo group, (RR, 1.03 [95% CI, 0.60, 1.77) (Table 8).^50^ In the study among adult women with diabetes,^55^ there were no significant difference in the rates of symptomatic UTI between the treatment (0.80 per 1,000 person days) and placebo groups (0.83 per 1,000 person days) (RR, 0.97 [95% CI, 0.61 to 1.54]) over a followup of up to 36 months (mean followup 2 years). Rates of pyelonephritis were also not different between treatment (0.13 per 1,000 person days) and placebo groups (0.28 per 1,000 person days) (RR, 0.47 [95% CI, 0.18 to 1.23]). The majority of women in both groups had no symptomatic episodes, with approximately a quarter of the women in each arm accounting for over 80 percent all reported infections. Two women in each study group developed clinically significant renal failure.

Table 8 Results of Treatment for Asymptomatic Bacteriuria on Symptomatic Infections in General Adult Populations (k=4)

Pop | Author, Year | FU (mos) | Outcome | Description | IG | Events in IG n/N (%) | Events in CG n/N (%) | RR (95% CI)
Adults | Asscher, 1969^50^ | 12 | Symptomatic UTI/Pyelonephritis | Complained of frequency and dysuria lasting 24 hr or more, or if she developed loin pain and fever | IG1 | 18/49 (36.7%) | 16/45 (35.6%) | 1.03 (0.60 to 1.77)
Adults with diabetes | Harding, 2002^55^ | 1.5 | Treated for symptomatic infection | | IG1 | 1/49 (2.0%) | 2/50 (4.0%) | 0.51 (0.05 to 5.45)
Adults with diabetes | Harding, 2002^55^ | 36 | Pyelonephritis | The presence of costovertebral-angle pain or tenderness and a positive urine culture (≥10^4 CFU of a urinary pathogen per ml) with or without systemic symptoms such as fever | IG1 | 0.13 per 1000 days | 0.28 per 1000 days | 0.47 (0.18 to 1.23)^*^
Adults with diabetes | Harding, 2002^55^ | 36 | Renal failure | Clinically significant renal failure | IG1 | 2/55 (3.6%) | 2/50 (4.0%) | 0.91 (0.13 to 6.21)
Adults with diabetes | Harding, 2002^55^ | 36 | Symptomatic UTI | Acute onset of symptoms of irritation of the lower tract, such as dysuria, urgency, and frequency, in the absence of fever or costovertebral-angle pain or tenderness, and in the presence of a positive urine culture (≥10^3 CFU of a urinary pathogen/ml) | IG1 | 0.80 per 1000 days | 0.83 per 1000 days | 0.97 (0.61 to 1.54)^†^
Older adults | Giamarellou, 1998^60^ | 6 | Sepsis or shock | NR | IG1 | 0/32 (0.0%) | 0/29 (0.0%) | NA
Older adults | Giamarellou, 1998^60^ | 6 | Sepsis or shock | NR | IG2 | 0/32 (0.0%) | 0/29 (0.0%) | NA
Older adults | Boscia, 1987^47^ | 6 | Symptomatic UTI/Pyelonephritis | Symptoms of urinary tract infection (dysuria, urgency, frequency, suprapubic pain, flank pain, and fever) | IG1 | 5/63 (7.9%) | 10/61 (16.4%) | 0.48 (0.18 to 1.33)
Older adults | Boscia, 1987^47^ | 6 | Treated for symptomatic infection | Antimicrobial therapy during the 6-month FU for symptomatic UTI infection | IG1 | 4/55 (7.3%) | 8/55 (14.5%) | 0.50 (0.16 to 1.56)

* Study reported inverse calculation of RR 2.13 (95% CI 0.81 to 5.62)

† Study reported inverse calculation of RR 1.03 (95% CI 0.65 to 1.65)

Abbreviations: CFU = colony forming units; CG = control group; CI = confidence interval; FU = followup; hr = hour; IG = intervention group; Int = intervention; ml = milliliter; n = number of events; N = number of participants; mos = months; N = number of participants; NR = not reported; NS = not significant; Pop = Population; RR = relative risk; UTI = urinary tract infection

Two studies in older adults reported symptomatic infections during followup. One study in older adult women reported that during the 6-month followup, 16.4 percent of women in the no-therapy control group and 7.9 percent of women in the treatment group developed symptoms of a UTI; however, this difference was not statistically significant (p=0.15).^47^ Another reported that there were no cases of sepsis or septic shock occurred during the 6-month study followup.^60^

##### Mobility

Only one study, in older adults, reported on mobility as an outcome and found no effect on mobility at 6 months.^60^ This study excluded individuals who needed help performing activities of daily living at enrollment and used a subjective measure of good mobility (i.e., complete independence) as classified by the physician and head nurse of the independent living pavilions.

##### Mortality

The two studies of adult nonpregnant women (with and without diabetes) did not report effects of treatment on mortality.^52,^ ^55^ All three trials specific to older adults reported on the effect of treatment on mortality, with no trial finding a difference in mortality between the treated and untreated groups (Table 9). One study examined the effect of treatment on mortality as its primary outcome and reported that 18 percent of treated women died over the course of 100 months of followup compared with 20 percent in the control group (HR, 0.92 [95% CI, 0.50 to 1.47]).^52^ Two additional studies that measured mortality as a secondary outcome found no effect on treatment at 6 months.^47,^ ^60^

Table 9 Results of Treatment for Asymptomatic Bacteriuria on Mortality in General Adult Populations (k=3)

Author, Year | FU (mos) | Int arm | Events in IG n/N (%) | Events in CG n/N (%) | RR (95% CI)
Boscia, 1987^47^ | 6 | IG1 | 2/63 (3.2%) | 3/61 (4.9%) | 0.65 (0.11 to 3.73)
Giamarellou, 1998^60^ | 6 | IG1 | 2/32 (6.3%) | 2/29 (6.9%) | 0.91 (0.14 to 6.03)
Giamarellou, 1998^60^ | 6 | IG2 | 0/32 (0.0%) | 2/29 (6.9%) | 0.18 (0.01 to 3.64)
Abrutyn, 1994^52^ | 100 | IG1 | 30/166 (18.1%) | 39/192 (20.3%) | 0.92 (0.5 to 1.47)^*^

* Hazard ratio, calculated RR: 0.89 (0.58 to 1.37)

Abbreviations: CG = control group; CI = confidence interval; FU = followup; IG = intervention group; Int = intervention; n = number of events; mos = months; N = number of participants; NR = not reported; RR = relative risk

## Key Question 4 Harms of Treating Screen-Detected ASB

### Pregnant Women

#### Summary of Results

There was no statistically significant evidence of harms associated with treatment of screen-detected ASB. Adverse reactions to antibiotics were reported, such as vaginitis and diarrhea, but there was no evidence of major fetal developmental harms related to treatment (e.g., congenital malformations). Evidence on infant and maternal harms of ASB treatment in pregnancy was sparsely and inconsistently reported (seven studies), and there was a lack of evidence on long term neonatal outcomes following antibiotic treatment of ASB in pregnancy. Overall, thefindings did not identify or rule out potential harms.

#### Detailed Results by Outcome

##### Characteristics of Included Studies

Seven of the studies included for Key Question 3 and described above reported potential harms of treatment of screen-detected ASB.^44,^ ^46,^ ^48,^ ^49,^ ^56,^ ^57,^ ^59^ One study used tetracycline,^48^ which is contraindicated and no longer used during pregnancy.

##### Infant and Fetal Harms

Five studies reported on congenital malformations in the intervention and control groups (Figure 8, Appendix E Table 6).^44,^ ^46,^ ^48,^ ^49,^ ^59^ Although the number of cases were small, all but one study reported fewer in the intervention group than in the control group.^49^ The pooled estimate was not statistically significant (pooled RR, 0.44 [95% CI, 0.16 to 1.22], k=5, n=961, I^2^ 0%). The estimate was similar, but even less precise, in a sensitivity analysis removing two high risk of bias studies.

Figure 8 Pooled Analysis of Rates of Congenital Malformations Among Infants Born to Treated Pregnant Women Compared With Those Born to Controls

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; N = number of participants; RR = relative risk

Figure 8 displays a forest plot of the effect of 5 trials that reported rates of congenital malformations among pregnant women treated for ASB, compared with those born to women in the control arm (n=961). The pooled relative risk is 0.44 [95% CI: 0.16 to 1.22] with no significant difference between groups. The results are discussed further in the text.

Two studies reported infant jaundice. One study did not report any cases in either study group.^57^ The other study using tetracycline for treatment and reported similar numbers in the intervention (4.0% [5/126]) and control group (2.8% [4/144]).^48^ This same study reported cases of respiratory distress, including respiratory distress syndrome and “other causes of respiratory embarrassment,” with more events in the intervention group (6/126) than in the CG (4/144). The difference was not statistically significant (calculated), but power was limited for drawing comparisons. The most recent of the included studies reported two cases of neonatal sepsis confirmed with culture in the control group and zero in the intervention group (Table 10).^59^

Table 10 Results of Treatment for Asymptomatic Bacteriuria in Pregnant Women on Maternal and Infant Complications (k=3)

Author, Year | Outcome | Description | Events in IG n/N (%) | Events in CG n/N (%) | RR (95% CI)
Elder, 1971^48^ | Induced labor | Cesarean section performed before the onset of labor | 19/133 (14.3%) | 21/145 (14.5%) | 0.99 (0.56 to 1.75)
Elder, 1971^48^ | Jaundice | Neonatal jaundice noted during in the first 24 hours | 5/126 (4.0%) | 4/144 (2.8%) | 1.43 (0.39 to 5.2)
Elder, 1971^48^ | Other infant complications | NR | 3/126 (2.4%) | 8/144 (5.6%) | 0.43 (0.12 to 1.58)
Elder, 1971^48^ | Other maternal complications | NR | 11/127 (8.7%) | 21/145 (14.5%) | 0.60 (0.30 to 1.19)
Elder, 1971^48^ | Premature rupture of the membranes | Rupture occurred ≥12 hours before the onset of labor | 14/127 (11.0%) | 12/145 (8.3%) | 1.33 (0.64 to 2.77)
Elder, 1971^48^ | Respiratory distress | Respiratory distress syndrome and other causes of respiratory embarrassment | 6/126 (4.8%) | 4/144 (2.8%) | 1.71 (0.49 to 5.94)
Elder, 1971^48^ | Third-trimester hemorrhage | | 4/127 (3.1%) | 4/145 (2.8%) | 1.14 (0.29 to 4.47)
Gold, 1966^57^ | Jaundice | NR | 0/35 (0.0%) | 0/30 (0.0%) | NA
Kazemier, 2015^59^ | Composite severe morbidity | Respiratory distress syndrome, necrotizing enterocolitis, intraventricular hemorrhage, bronchopulmonary disease, sepsis | 0/40 (0.0%) | 2/45 (4.4%) | 0.22 (0.01 to 4.54)^*^
Kazemier, 2015^59^ | Neonatal sepsis confirmed with culture | | 0/40 (0.0%) | 2/45 (4.4%) | 0.22 (0.01 to 4.54)^*^
Kazemier, 2015^59^ | Non-spontaneous onset of labor | | 13/40 (32.5%) | 13/45 (28.9%) | 1.13 (0.59 to 2.13)^†^
Kazemier, 2015^59^ | Thrombo-embolic events | | 0/40 (0.0%) | 0/45 (0.0%) | NA^‡^

* Study reported risk difference: −4.4 (−25.5 to 16.8)

† Study reported risk difference: 3.6 (−17.8 to 24.8)

‡ Study reported risk difference: 0 (−9.4 to 10.5)

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; n = number of events; mos = months; N = number of participants; NR = not reported; RR = relative risk

##### Maternal Harms

Complications of pregnancy and delivery were inconsistently and sparsely reported in two of the studies, but where available did not indicate potential harms of treatment for third-trimester hemorrhage,^48^ premature rupture of the membranes,^48^ nonspontaneous onset of labor,^59^ or cesarean section before onset of labor.^48^ An undefined composite variable of “other maternal complications” was reported in an older study using tetracycline,^48^ with more events in the control group (11/127) than the intervention group (21/145) but no statistical difference (calculated) (Table 10).

Two studies provided information on maternal adverse reactions to medications.^44,^ ^49^ For ampicillin treatment, vaginitis and diarrhea were reported.^44^ For nalidixic acid and nitrofurantoin treatment, rashes and nausea were reported.^44,^ ^49^

### General Adult Populations

#### Summary of Results

Four studies reported on the potential harms of treatment in nonpregnant and older adults. Overall, data was inconsistently reported and limited for drawing conclusions about potential harms.

#### Detailed Results by Outcome

##### Characteristics of Included Studies

Two studies of treatment in nonpregnant adult women^50,^ ^55^ and two studies in older adults^47,^ ^60^ reported on rates of adverse events associated with treatment of ASB.

##### Adverse Reactions

The study among nonpregnant women reported that there were no adverse drug reactions from among the 49 women treatment with nitrofurantoin therapy.^50^ The study among diabetic women (N=105) reported higher rates of treatment-related adverse events (not specified) associated with treatment with trimethoprim-sulfamethoxazole; 18.1 percent compared with 6.0 percent of women treated with placebo (RR 3.45, [95% CI, 0.90 to 14.2]).^55^

One study among older adults reported that no adverse medication reactions occurred among the 63 women treated with trimethoprim.^47^ Another reported that 6.3 percent (2/32) of women assigned to daily ofloxacin therapy withdrew due to adverse events (vertigo and gastrointestinal tract symptoms).^60^ The authors stated that in general those assigned to “pulse treatment” (i.e., treatment 3 days of every 2 weeks) generally accepted therapy more easily than those assigned to continuous therapy, but numbers of overall adverse events in each group were not reported. Treatment was found to not affect hematocrit, serum bilirubin or blood urea, but a mild reduction in serum creatinine was seen in the treatment groups.