# Chapter 2 Methods

## Scope and Purpose

This systematic review addresses the benefits and harms of screening and treatment of asymptomatic bacteriuria in adults, including pregnant women. The USPSTF will use this review to update its 2008 recommendation on this topic.^1^

## Key Questions and Analytic Framework

We developed an Analytic Framework (Figure 1) and four Key Questions (KQs) to guide the literature search, data abstraction, and data synthesis.

Figure 1 Analytic Framework

Figure 1 is the analytic framework that depicts the four Key Questions to be addressed in the systematic review. The figure illustrates how screening asymptomatic pregnant and nonpregnant adults may result in reducing the incidence of symptomatic UTI, kidney infection, and perinatal/maternal morbidity or mortality as well as improving quality of life (KQ1). Once detected, the figure shows how treatment of ASB may result in improved health outcomes (KQ3). Further, the figure illustrates whether screening and treatment for ASB are associated with any adverse events (KQ2, KQ4).

1. Does screening for asymptomatic bacteriuria improve health outcomes among adults, including pregnant women?
2. What are the harms of screening for asymptomatic bacteriuria?
3. Does treatment of screen-detected asymptomatic bacteriuria improve health outcomes?
4. What harms are associated with treatment of screen-detected asymptomatic bacteriuria?

## Data Sources and Searches

In addition to considering all studies from the previous reviews on this topic for inclusion in the current review,^1,^ ^33,^ ^34^ we performed a comprehensive search of MEDLINE, PubMed Publisher-Supplied Records, and the Cochrane Collaboration Central Registry of Controlled Trials for literature published through September 7, 2018. A research librarian developed and executed the search, which was peer-reviewed by a second research librarian (Appendix A).

We also examined the reference lists of other previously published reviews, meta-analyses, and primary studies to identify additional potential studies for inclusion. We supplemented our searches with suggestions from experts and articles identified through news and table-of-contents alerts, such as those produced by the USPSTF Scientific Resource Center LitWatch activity. We also searched ClinicalTrials.gov (https://ClinicalTrials.gov/) for ongoing trials. We managed literature search results using EndNote® X7 (Thomson Reuters, New York, NY).

## Study Selection

We developed specific inclusion criteria to guide study selection (Appendix A Table 1). Two reviewers independently screened the title and abstract of all identified articles using DistillerSR (Evidence Partners, Ottawa, Canada) to determine if the study met our a priori inclusion and exclusion criteria for design, population, intervention, and outcomes (Appendix A Table 1). Two reviewers then independently evaluated the full-text articles of all potentially relevant studies against the complete inclusion and exclusion criteria. Disagreements in the abstract and/or full-text review were resolved by discussion.

For all KQs, we included randomized controlled trials (RCTs) to assess the benefits and harms of screening (KQs 1 and 2) and treatment (KQs 3 and 4) for ASB in asymptomatic pregnant and non-pregnant adults. In addition, for KQs 1 and 3 among pregnant women, we included observational cohort studies with a comparator of no screening or no treatment. The inclusion of observational studies related to screening for and treatment of asymptomatic bacteriuria is due to prior evidence from trials and ensuing recommendations which have established a standard practice of screening and treatment. For KQs 2 and 4, we also included observational cohort studies with or without a comparison group as well as registry studies. We excluded case control studies, case series and case reports, and qualitative studies.

We included studies among asymptomatic community-dwelling adults, including those in independent or assisted living, ages 18 years and older. Asymptomatic pregnant women of any age as well as individuals with common chronic conditions, such as diabetes mellitus (type 1 or type 2), were included. Studies conducted exclusively among individuals who were hospitalized or institutionalized (e.g., nursing homes) were excluded as findings would not be generalizable to primary care. We excluded studies conducted among individuals with symptoms of or suspected UTI (cystitis or pyelonephritis), or with a history of recurrent UTIs, or individuals seen in specialty care for treatment or followup of conditions affecting the urinary tract (e.g., prostate cancer). Dialysis patients or individuals having a catheter, urinary stent, nephrostomy tube, or patients being tested in preparation for urological procedures were also excluded. In addition, we excluded studies conducted exclusively in recipients of a kidney or organ transplant, pregnant women with sickle cell disease, immunocompromised individuals as well as individuals with spinal cord injuries.

Eligible settings included primary care clinics, prenatal or reproductive health clinics, obstetrics/gynecology clinics, and independent living facilities. For general adult populations, we included studies conducted in countries categorized as “very high” on the Human Development Index (HDI). For pregnant women, we expanded the scope slightly to include studies with an HDI of “high” or “very high” because ASB screening and treatment in pregnancy are standard of care, established practice in most “very high” HDI countries and not an active area of research. For KQs 1 and 2, we included screening with urine testing (e.g., urine culture or urinalysis with microscopy, dipstick, or dipslide screening, with or without reflex urine culture). We excluded studies of suprapubic aspiration and catheterization as screening techniques as these were viewed to not represent standard screening techniques in primary care and prenatal care. For KQs 3 and 4, we included medications or treatment interventions to prevent UTIs in patients with screen-detected ASB from at least one positive culture result. We did not exclude studies using lower screening thresholds (e.g., 10^4^ CFU) or requiring specific bacterial species or numbers of species. We excluded studies of interventions to prevent ASB (e.g., cranberry extract).

General health outcomes for general adult populations and pregnant women included symptomatic UTI (e.g., cystitis and pyelonephritis), kidney failure, quality of life, and mortality. General harms included the adverse effects of treatment (e.g., allergic reactions, resistant infections). Pregnancy-specific health outcomes included complications of pregnancy associated with maternal or fetal morbidity, such as: preterm birth (before 37 weeks’ gestation); low birth weight (<2,500 g); hypertensive disorders of pregnancy (e.g., preeclampsia, eclampsia); sepsis and developmental abnormalities/malformations. Maternal and fetal or infant mortality outcomes (e.g., intrauterine death, stillbirth, neonatal death, fetal loss before term, spontaneous abortion, miscarriage, perinatal death, fetal loss after 20 weeks) were also included. In addition to the general outcomes and pregnancy-specific outcomes, fetal anomalies, stillbirth, and adverse effects of treatment were included to assess harms (KQs 2 and 4).

## Quality Assessment and Data Abstraction

Two reviewers applied USPSTF design-specific criteria (Appendix A Table 2) to assess the methodological quality of all eligible studies. We assigned each study a quality rating of “good,” “fair,” or “poor.” Discordant quality ratings were reviewed and discussed; a third reviewer adjudicated as needed.

Good-quality studies were those that met nearly all of the specified quality criteria (e.g., comparable groups assembled initially and maintained over study, adequate followup, conservative data substitution methods for missing data, no evidence of selective outcome or analysis reporting), whereas fair-quality studies did not meet these criteria. Traditionally in USPSTF methods, studies that have serious threats to their internal validity related to the design or execution of the study would be rated as poor quality and excluded from the review. However, based on discussions with the USPSTF leads and consideration of the historical nature of the studies, with some dating to the 1960s, these studies were instead categorized as fair quality due to the changing standard of study reporting over time. Those studies that appeared to have the highest risk of bias were flagged to be dropped from meta-analysis as sensitivity analyses. Criteria for these “high risk” studies included those with multiple shortcomings such as a lack of reporting of criteria for ASB, no reporting of how treatments were allocated, no definition provided for pyelonephritis or other major outcomes, a lack of information on the baseline characteristics of participants and/or a serious imbalance in baseline characteristics, or a high suspicion of selective outcome reporting.

For all included studies, one reviewer extracted key elements into standardized abstraction forms in DistillerSR (Evidence Partners, Ottawa, Canada). A second reviewer checked the data for accuracy. For each study, we abstracted general characteristics (e.g., author, year, study design), clinical and demographic characteristics of the sample and setting (e.g., age, race/ethnicity, setting, country), analytic methods, definitions of outcomes measures, and results.

## Data Synthesis and Analysis

We created summary tables for all KQs describing study, population, and intervention characteristics (if applicable) and outcomes for qualitative evidence synthesis. Studies were grouped according to population: adult men and nonpregnant women (age ≥18) and pregnant women (of any age). We used these tables along with forest plots of the results to examine data for consistency, precision, and, for intervention trials, the relationship of effect size with key potential modifiers such as the definition of pyelonephritis, treatment duration, and study risk of bias.

We synthesized data separately for each Key Question. Outcomes that were too few to support quantitative pooling due to the limited number of comparable studies are narratively summarized. For studies with enough clinically comparable outcomes reported, we conducted random-effects meta-analyses using the method of DerSimonian and Laird^35^ (DL) to calculate the pooled relative risks. When pooling fewer than 10 studies, we conducted sensitivity analyses using a restricted maximum likelihood (REML) model with Knapp-Hartung correction for small samples and reported estimates only if they differed from the DL result. When available, we favored relative risks reported by study authors, but calculated crude effect estimates and confidence intervals when only p-values, raw percentages, or other estimates of effects were given.^36^ For studies in pregnant populations we sought infant and maternal outcomes throughout pregnancy, delivery, and immediately postpartum.

For quantitative pooling of the effects of ASB treatment for pregnant women, we defined outcomes as follows: low birthweight (defined as birthweight less than 2500 grams or small for gestational age below the 10^th^ percentile), mean birthweight, pyelonephritis (as defined by the study), and preterm birth (defined as birth prior to 37 or in rare instances before 38 weeks’ gestation); if no definition was provided by the study authors (e.g., defined only as “premature birth”) the outcome was included in pooled results for preterm birth. Perinatal mortality includes fetal and infant deaths occurring >20 weeks of gestation and <1 week postpartum, and when information was provided, study outcomes were grouped accordingly. Studies used differing definitions/criteria for pyelonephritis. We stratified analyses to explore whether pyelonephritis results were influenced by the clinical definition used by the study authors, categorized as: “strong” (definitions that required fever or chills), “moderate” (those requiring loin pain with or without fever), or “weak” (no criteria given or nonspecific diagnostic criteria). Other sensitivity analyses included an examination of pooled effects with the studies considered at “high risk of bias” excluded, and exploration of the effect of the duration of antibiotic treatment on study findings.

We examined statistical heterogeneity among the pooled studies by applying standard χ^2^ tests and estimated the proportion of total variability in point estimates by using the I^2^ statistic.^37^ We followed the Cochrane Collaboration’s general overlapping ranges for interpreting heterogeneity:^38^ Less than 40 percent likely represents unimportant heterogeneity; 30 to 65 percent, moderate heterogeneity; 50 to 90 percent, substantial heterogeneity; and more than 75 percent, considerable heterogeneity. Funnel plots were used to examine outcomes for potential small-study effects (a possible indication of publication bias), and we conducted the Egger test if 10 or more studies were available, to assess the statistical significance of any imbalance in study size associated with individual study results.^39^ We used Stata version 13.1 (Stata Corp LP, College Station, TX) for all quantitative analyses. All significance testing was two-sided. Results were considered statistically significant if the p-value was 0.05 or less.

## Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each key question. We adapted the Evidence-based Practice Center approach,^40^ which is based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group.^41^ Our method explicitly addresses four of the five Evidence-based Practice Center-required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations). Issues related to reporting bias or study quality are described under “other limitations” if detected. Consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). We did not address the fifth required domain—directness—as it is implied in the structure of the key questions (i.e., pertains to whether the evidence links the interventions directly to a health outcome).

We graded the overall strength of evidence as high, moderate, or low. “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” indicates moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effect and is likely to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimate of an effect. Two independent reviewers rated each key question according to consistency, precision, reporting bias, and overall strength of evidence grade. We resolved discrepancies through consensus discussion involving more reviewers.

## Expert Review and Public Comment

A draft Research Plan for this review was available for public comment from October 4, 2017, through October 25, 2017. In response to feedback, minor changes to the Research Plan were made to clarify the included population and relevant outcomes. The full draft report was shared with invited expert reviewers and federal partners. We compiled the comments received from these invited experts and addressed them in the report as appropriate. The draft version of this report was posted for public comment on the USPSTF Web site from April 23, 2019 to May 20, 2019. Comments received during this period were reviewed and considered. Changes requested by reviewers mainly pertained to the Recommendation Statement and not the Evidence Synthesis; therefore, no changes were made to the evidence or to our conclusions.

## USPSTF Involvement

We worked with five USPSTF members at key points throughout this review, particularly when determining the scope and methods, and developing the Analytic Framework and KQs. After revisions reflecting the public comment period, the USPSTF members approved the final analytic framework, KQs, and inclusion and exclusion criteria. AHRQ funded this review under a contract to support the work of the USPSTF. An AHRQ Medical Officer provided project oversight, reviewed the draft report, and assisted in the external review of the report.