# Chapter 1 Introduction

## Purpose

This report will be used by the United States Preventive Services Task Force (USPSTF) to update its 2008 recommendation on Screening for Asymptomatic Bacteriuria in Adults.^1^

## Condition Background

### Condition Definition

Asymptomatic bacteriuria (ASB) is defined as the presence of a significant bacterial colony count present in a person without any of the typical signs or symptoms of a urinary tract infection (UTI).^2^ The typical symptoms of UTI depend on the parts of the urinary tract involved. Acute onset cystitis involves the lower urinary tract and is often accompanied by symptoms of dysuria, urinary frequency, urinary urgency, bladder pain, pyuria, and hematuria. Acute pyelonephritis is a more serious infection involving the kidneys. Typical signs and symptoms include flank pain, fever, nausea and vomiting.

The quantitative criteria for defining a significant bacterial count in a urine culture test is at least 10^5^ colony-forming units (CFU) per milliliter of a single bacterial species.^3^ Recommended sampling procedures to confirm diagnosis of ASB differ for men and women, with two consecutive voided urine specimens cultured positively a few days apart for diagnosis in women, and only one positively cultured urine specimen for diagnosis in men.^3^

### Prevalence and Burden

#### Pregnant Women

During pregnancy ASB is present in an estimated 2 to 10 percent of women.^3,^ ^4^ The risk of cystitis and pyelonephritis is higher among pregnant women with ASB, but the incidence of pyelonephritis in pregnant women is low in the United States, likely due to widespread adoption of ASB treatment in pregnancy.^5,^ ^6^ One large retrospective cohort study of insured women in the United States with singleton deliveries occurring from 1993–2010 found very low rates of pyelonephritis in pregnancy (0.5%) with incidence rising over time, which the authors attribute to increases in other risk factors in the study population (e.g., maternal age, diabetes).^7^ Another prospective study from 2000 to 2001 reported higher pyelonephritis hospitalization rates during pregnancy of 1.4 percent.^6^ The majority of cases occurred during the second trimester (53%) and a minority of cases (3%) had previously screened positive for ASB. In both studies, pyelonephritis was associated with higher rates of perinatal complications (e.g., septicemia, respiratory distress, low birthweight, spontaneous preterm birth) in adjusted analyses.^6,^ ^7^

#### General Adult Populations

The prevalence of ASB varies by age and sex, with women having the highest prevalence at all stages of life. Estimates for nonpregnant, premenopausal adult women range from 1 to 6 percent.^3,^ ^8^ Prevalence after menopause increases with age, to above 10 percent after age 70 and up to 22 percent above age 90.^3,^ ^9^ In young healthy men, ASB is rare, but increases with age to <5 percent among community-dwelling men in midlife and older age, and just above 5 percent among men over age 90. The prevalence of ASB is three to four times higher among women with diabetes than healthy women.^10^

### Etiology and Natural History

By definition, ASB occurs when the urinary tract is colonized with pathogenic bacteria from the gastrointestinal tract. Escherichia coli (E. coli) infection is most common, but other bacteria (e.g., Klebsiella spp., Proteus mirabilis) and group B streptococci [GBS] are also observed.^9,^ ^11^ These pathogenic bacteria are also associated with symptomatic infections. The presence of bacteria in the urine was until recently considered pathogenic, as urine was thought to be normally sterile. The presence of commensal non-pathogenic bacteria has been established in more science with the development of new culture media and DNA testing techniques.^12^ Thus, ASB refers to colonization of the urinary tract with noncommensal bacterial species.

#### Pregnant Women

Early observational evidence and a more recent study among pregnant females found associations of ASB with a heightened risk of UTI, including acute pyelonephritis, as well as adverse pregnancy outcomes, especially low birth weight and preterm birth.^4,^ ^13–16^

A mechanism explaining a relationship between ASB and adverse birth outcomes has not been clearly established, but there is some evidence that women with ASB are at increased risk for pyelonephritis. In turn, pyelonephritis in pregnancy has been associated with worse pregnancy outcomes in observational studies.^7,^ ^17,^ ^18^ It is unclear whether ASB in the absence of progression to symptomatic infection is related to poor birth outcomes; an observational study of nearly 40,000 births in Wales found no association between ASB and preterm birth when accounting for medical and social confounders, but the study did not describe ASB treatment protocols during the study.^19,^ ^20^ Notably, these studies and others find that ASB in pregnancy often occurs along with other risk factors associated with poor birth outcomes, including older maternal age, low socioeconomic status, multiparity, and diabetes.^4,^ ^21^ Observed associations of ASB with poor birth outcomes may thus arise in part from a constellation of risk factors, in addition to the risk for pyelonephritis.

#### General Adult Populations

Although ASB is found when screening nonpregnant individuals, and is associated with increased rates of other outcomes, evidence is mixed and the causal pathways have not been established to explain how ASB could contribute to worse health outcomes. Among women with type 2 diabetes, the risk of UTI is increased with ASB, but this association of ASB with UTI is not consistently seen for type I diabetes.^22^ ASB also has not been consistently associated with other negative health outcomes for nonpregnant adults, and treatment of ASB has not been found to be associated with decreased morbidity or mortality.^3,^ ^23^

### Risk Factors

#### Pregnant Women

During pregnancy, physiologic changes affecting the urinary tract, such as compression of the bladder, ureteral dilation, urinary stasis, and changes in urine pH, are thought to account for an increased risk of ASB and UTI.^4,^ ^24^

#### General Adult Populations

Women are predisposed to infections of the urinary tract,^4^ including ASB, owing to the location and length of the female urethra, which facilitates urinary tract colonization with bacterial strains from the gastrointestinal tract. Sexual activity also increases the risk of ASB (and UTI) in women.^8^ The risk of ASB also is greater for men and women with diabetes, owing to glycosuria and the neurologic and immunologic complications of diabetes. Aging is associated with higher rates of ASB due to physiologic changes to the urinary tract as well as rising prevalence of health conditions associated with ASB risk (e.g., diabetes, incontinence, dementia). In older women, decreasing estrogen levels and changes in vaginal pH reduce vaginal colonization with protective Lactobacilli spp, allowing for colonization from uropathogenic bacteria such as E. coli and Enterococcus spp, with consequent higher risks of ASB and UTI. Rising rates of ASB in older men are thought to be related to prostate hypertrophy and changes in urine flow, and possibly changes in bactericidal activity of prostate secretions.^25^

### Screening

#### Pregnant Women

The rationale for ASB screening at least once during pregnancy is supported by historical evidence from the 1960s and 1970s finding that antibiotic treatment of screen-detected ASB reduces cystitis and pyelonephritis in pregnancy, and prevents preterm delivery and low birthweight. Screening for and treatment of ASB is undertaken to reduce risk of symptomatic ascending infections of the urinary tract.

Urine culture is currently recommended for ASB screening in pregnancy and is necessary to definitively diagnose ASB.^1,^ ^3^ A “clean catch” urine specimen, involving cleansing of the vulva and perianal area and midstream collection, is generally sought to reduce bacterial contamination of the sample, with some evidence highlighting the importance of midstream collection.^26^ The sterility of sample collection materials and handling of the samples, including transport times and storage temperature, can also affect culture findings. A second urine specimen is recommended for confirmation of ASB in pregnancy, as transient ASB and contamination of the sample are not uncommon,^3,^ ^27^ but this may not be widely practiced. Rapid onsite urine dipstick and dipslide tests are often used for screening in clinical practice, with reflexive culture for positive findings.^28^

#### General Adult Populations

Current practice does not include routine screening of adults, other than pregnant women, for ASB in primary care. Identification and treatment of ASB is recommended prior to transurethral resection of the prostate or other urologic procedures for which mucosal bleeding is anticipated.^3^

### Treatment Approaches

#### Pregnant Women

The choice of antibacterial regimen for treatment of ASB (and UTI) during pregnancy depends on considerations of treatment effectiveness, safety in pregnancy, and observed local and regional levels of bacterial resistance.^4^ Amoxicillin, cephalexin, and nitrofurantoin are commonly used to treat ASB and lower UTI infections in pregnancy, but the evidence to weigh effectiveness, optimal routes of administration, regimen, or class is limited. Followup culture to verify cure is recommended by the American College of Obstetrics and Gynecology and American Academy of Pediatrics, but with recognition that evidence is incomplete with regard to the recommendation.^29^

#### General Adult Populations

Treatment is not recommended for screen-detected ASB in any general adult populations in primary care other than pregnant individuals.

### Current Clinical Practice and Recent Recommendations

#### Pregnant Women

Most antenatal care guidelines include routine screening for ASB early in pregnancy, but there is no consensus for the optimal timing and screening frequency.^4,^ ^30^ Screening at the first prenatal visit in the United States can include a culture test or onsite urinalysis, dipstick, or dipslide test for bacteriuria, with reflexive laboratory urine culture to confirm positive findings. Most practice guidelines recommend urine culture screening for ASB due to the suboptimal performance of currently available point of care tests.^28^ Most clinical guidelines suggest screening once, early in pregnancy or at the first prenatal visit (Table 1). Guidelines for diagnosis of ASB recommend a second sample for confirmatory culture in screened positive women, but a single screening test with reflexive culture is commonly practiced.^27^ Recent guidelines, including those from the Infectious Diseases Society of America, Canadian Task Force on Preventive Health Care and European Association of Urology have stated that these recommendations are based on limited evidence of a benefit of screening.^3,^ ^31,^ ^32^

Table 1 Recent Guidelines on the Screening and Treatment of Asymptomatic Bacteriuria

Organization, Year | Recommendation(s) for pregnant women | Recommendation(s) for non-pregnant adults
Infectious Diseases Society of America, 2019^3^ | Screen and treat pregnant women (strong recommendation, moderate-quality evidence); In pregnant women with ASB, 4–7 days of antimicrobial treatment rather than a shorter duration is recommended (weak recommendation, low-quality evidence) | Screen for and treat ASB prior to urological procedures breaching the mucosa.; Do not screen for or treat asymptomatic bacteriuria in: healthy non-pregnant women. older adults, patients with diabetes, catheterized patients, or those undergoing elective non urologic surgery.
Canadian Task Force on Preventive Health Care, 2018^106^ | Screen pregnant women once during the first trimester with urine culture for ASB (weak recommendation; very low-quality evidence) | No recommendation
National Institute for Health and Care Excellence, U.K., 2018^107^ (2008)^108^ | Routinely screen by midstream urine culture early in pregnancy; Offer an immediate antibiotic prescription to pregnant women with asymptomatic bacteriuria | Do not screen for or treat asymptomatic bacteriuria in men and non-pregnant women
European Association of Urology, 2017^31^ | Short-course treatment should continue to be recommended for pregnant women, although this is challenged by the results of a recent high-quality study finding no difference in neonatal outcomes | Screen for and treat ASB prior to urological procedures breaching the mucosa.
ACOG Committee on Obstetric Practice^109^ and American Academy of Pediatrics, 2017^110^ | No specific screening recommendation; If urine culture performed early in pregnancy, treat asymptomatic bacteriuria and do a test of cure | Screening for and treatment of asymptomatic bacteriuria is not recommended in nonpregnant, premenopausal women.
Scottish Intercollegiate Guidelines Network, 2012^111^ | Treat asymptomatic bacteriuria detected during pregnancy with an antibiotic.; Women with bacteriuria confirmed by a second urine culture should be treated and have repeated urine cultures at each antenatal visit until delivery; Women who do not have bacteriuria in the first trimester should not have repeat urine cultures | Do not treat non-pregnant women (of any age) with asymptomatic bacteriuria with an antibiotic.; Do not treat catheterized patients with asymptomatic bacteriuria with an antibiotic
American Academy of Family Physicians, 2008^112^ | Screen pregnant women at 12 to 16 weeks’ gestation or at the first prenatal visit, if after that time | Do not screen for asymptomatic bacteriuria in men and nonpregnant women

Abbreviations: ABU: asymptomatic bacteriuria; ACOG: American College of Obstetricians and Gynecologists; ASB: asymptomatic bacteriuria; UK = United Kingdom; US = United States

#### General Adult Populations

In general, guidelines do not recommend screening for ASB in non-pregnant adults (Table 1). The European Association of Urology and Infectious Diseases Society of America recommend that patients should be screened and treated for ASB prior to urological procedures breaching the mucosa.^3,^ ^31^

### Previous USPSTF Recommendation

#### Pregnant Women

Since 1996, the USPSTF has maintained an A recommendation for screening for ASB using urine culture in pregnant women once between 12 and 16 weeks’ gestation. The original 1996 recommendation was subsequently reaffirmed in 2004 and again in 2008.^1,^ ^33,^ ^34^ The most recent statement from the USPSTF for screening for ASB in pregnant women states there is a high level of certainty that the net benefit of screening pregnant women for ASB was substantial and recommended screening for ASB with urine culture for pregnant women at 12–16 weeks’ gestation, or at the first prenatal visit (A Recommendation).^1^

#### General Adult Populations

The initial recommendation in 1996 stated there was insufficient evidence to recommend for or against screening in older adult women or women with diabetes, and that screening was not recommended in other asymptomatic adults or institutionalized older adults.^33^ In 2004, these recommendations were combined into one recommendation against screening which was subsequently reaffirmed in 2008.^1,^ ^34^ The most recent statement from the USPSTF states that: the USPSTF concluded with moderate certainty that the harms of screening men and nonpregnant women for ASB outweigh the benefits and recommended against screening for ASB in men and nonpregnant women (D Recommendation).^1^