# Appendix F Ongoing Studies

Study reference Trial identifier | Study name | Location | Estimated n | Description | 2018 Status
NCT03274960 | The Effect of Screening and Treatment of Asymptomatic Bacteriuria Every Trimester During Pregnancy on Incidence of Preterm Birth in Harare, Zimbabwe | Zimbabwe (Low HDI) | 480 | Women randomized to screening/treatment for ASB or no screening/treatment. For the screening group screening will be repeated in each trimester. Primary outcome is preterm birth. | Ongoing; Est. completion date: 11/30/18

## References

1 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. 2015. PMID: None.
2 Brumfitt W. The effects of bacteriuria in pregnancy on maternal and fetal health. Kidney international. 1975;8:S113–s9. PMID: 00230726.00230726
3 Elder HA, Santamarina BA, Smith S, . The natural history of asymptomatic bacteriuria during pregnancy: the effect of tetracycline on the clinical course and the outcome of pregnancy. American Journal of Obstetrics & Gynecology. 1971;111(3):441–62. PMID: 4937729. 10.1016/0002-9378(71)90793-9 4937729
4 Foley ME, Farquharson R, Stronge JM. Is screening for bacteriuria in pregnancy worthwhile? Br Med J (Clin Res Ed). 1987;295(6592):270. PMID: 3115406.3115406
5 Furness ET, McDonald PJ, Beasley NV. Urinary antiseptics in asymptomatic bacteriuria of pregnancy. New Zealand Medical Journal. 1975;81(539):417–9. PMID: 1099490.1099490
6 Gold E, Traub F, Daichman I, . Asymptomatic bacteriuria during pregnancy. Obstetrics and gynecology. 1966;27:206–9. PMID: 5325600.5325600
7 Kazemier BM, Koningstein FN, Schneeberger C, . Maternal and neonatal consequences of treated and untreated asymptomatic bacteriuria in pregnancy: a prospective cohort study with an embedded randomised controlled trial. Lancet Infect Dis 2015;15(11):1324–33. PMID: 26255208.26255208
8 Kincaid-Smith P, Bullen M. Bacteriuria in Pregnancy. Lancet. 1965;1(7382):395–9. PMID: 14238090.14238090
9 Little PJ. The incidence of urinary infection in 5000 pregnant women. Lancet. 1966;2(7470):925–8. PMID: 4162367.4162367
10 Pathak UN, Tang K, Williams LL, . Bacteriuria of pregnancy: results of treatment. Journal of Infectious Diseases. 1969;120(1):91–103. PMID: 5816817.5816817
11 Savage W, Hajj S, Kass E. Demographic and prognostic characteristics of bacteriuria in pregnancy. Medicine. 1967;46:385–407. PMID: CN-00234430.4864339
12 Williams GL, Campbell H, Davies KJ. Urinary concentrating ability in women with asymptomatic bacteriuria in pregnancy. British Medical Journal. 1969;3(5664):212–5. PMID: 5792611.5792611
13 Wren BG. Subclinical renal infection and prematurity. Med J Aust. 1969;2(12):596–600. PMID: 5388374.5388374