# Appendix E Evidence Tables

Appendix E Table 1 Rates of Symptomatic Infection Among Treated Pregnant Women Compared With Controls

Appendix E Table 2 Rates of Low Birth Weight and Preterm Birth Among Treated Pregnant Women Compared With Controls

Appendix E Table 3 Mean Birth Weight (Grams) of Infants Born to Treated Pregnant Women Compared With Those Born to Controls

Appendix E Table 4 Rates of Perinatal Mortality Among Infants Born to Treated Pregnant Women Compared With Those Born to Controls

Appendix E Table 5 Rates of Hypertensive Disorders Among Treated Pregnant Women Compared With Controls

Appendix E Table 6 Rates of Congenital Malformations Among Infants Born to Treated Pregnant Women Compared With Those Born to Controls