# Appendix D Additional Figures

Appendix D Figure 1 Pooled Analysis of Rates of Pyelonephritis Among Treated Pregnant Women Compared With Controls – Sensitivity Analysis Removing High Risk of Bias Studies

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; N = number of participants; RR = relative risk

Appendix D, Figure 1 displays a forest plot of a sensitivity analysis of 6 treatment trials, which report the rates of pyelonephritis among pregnant women treated for ASB compared with women in the control arm (n=1184). When removing studies with high risk of bias, the pooled relative risk is 0.19 [95% CI: 0.11 to 0.34] in favor of the intervention group. The results are discussed further in the text.

Appendix D Figure 2 Pooled Analysis of Rates of Pyelonephritis Among Treated Pregnant Women Compared With Controls – By Definition of Pyelonephritis

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; N = number of participants; RR = relative risk

Appendix D, Figure 2 displays a forest plot of 12 treatment trials that report the rates of pyelonephritis among pregnant women treated for ASB compared with women in the control group (n=2068). Results are stratified by the definition of pyelonephritis used by the study. The pooled risk for studies utilizing a “weak” definition was 0.25 [95% CI: 0.09 to 0.70]; for those with a “moderate” definition the pooled relative risk was 0.30 [95% CI: 0.12 to 0.77]; for those with a “strong” definition the pooled relative risk was 0.18 [95% CI: 0.08 to 0.42]. All analysis were significant in favor of the intervention group. The results are discussed further in the text.

Appendix D Figure 3 Pooled Analysis of Rates of Low Birth Weight Among Treated Pregnant Women Compared With Controls – Sensitivity Analysis Removing High Risk of Bias Studies

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; N = number of participants; RR = relative risk

Appendix D, Figure 3 displays a forest plot of a sensitivity analysis of 4 treatment trials, which report the rates of low birthweight among infants born to pregnant women treated for ASB compared with those born to women in the control group (n=745). When removing studies with high risk of bias, the pooled relative risk is 0.86 [95% CI: 0.57 to 1.31] with no significant difference between groups. The results are discussed further in the text.

Appendix D Figure 4 Rates of Perinatal Mortality Among Infants Born to Treated Pregnant Women Compared With Those Born to Controls – Sensitivity Analysis Removing High Risk of Bias Studies

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; N = number of participants; RR = relative risk

Appendix D, Figure 4 displays a forest plot of a sensitivity analysis of 4 treatment trials, which report the rates of perinatal mortality among infants born to pregnant women treated for ASB compared with those born to women in the control group (n=739). When removing studies with high risk of bias, the pooled relative risk is 1.93 [95% CI: 0.84 to 4.45] with no significant difference between groups. The results are discussed further in the text.