# Appendix C Excluded Studies

Exclusion Criteria Code | Exclusion Criteria
1 | Relevance
2 | Design
3 | Not primary data
4 | Setting
5 | HDI exclusion
6 | Population
7 | Institutionalized population
8 | Symptomatic UTI
9 | Recurrent UTI
10 | Surgical/procedure related
11 | Intervention
12 | Comparator
13 | Comparative effectiveness
14 | No relevant outcomes
15 | Non-English publication
16 | Screening performed via catheter or suprapubic aspiration
17 | Prevention of ASB

Reference | Exclusion Code
Aarnoudse, JG, Meijer-Severs, et al. Do anaerobes cause urinary tract infection? Lancet, 1(8164) 368–9. 1980. | 6
Abduljabbar, H, Moumena, et al. Urinary tract infection in pregnancy Ann Saudi Med, 11(3) 322–4. 1991. | 2
Abramson, JH, Sacks, et al. Bacteriuria and hemoglobin levels in pregnancy JAMA, 215(10) 1631–7. 1971. | 2
Ahmad, S. Asymptomatic group B streptococcal bacteriuria among pregnant women in Saudi Arabia Br J Biomed Sci, 72(3) 135–9. 2015. | 2
Al-Wali, W. Antibiotics for urinary tract infection in pregnant women BMJ, 357() j2934. 2017. | 3
Alling, B, Brandberg, et al. Aerobic and anaerobic microbial flora in the urinary tract of geriatric patients during long-term care J Infect Dis, 127(1) 34–9. 1973. | 7
Andelman, MB, Zackler, et al. A “stick test” for detection of asymptomatic bacteriuria J Urol, 100(2) 190–4. 1968. | 14
Anderson, BL, Simhan, et al. Additional antibiotic use and preterm birth among bacteriuric and nonbacteriuric pregnant women Int J Gynaecol Obstet, 102(2) 141–5. 2008. | 12
Anderton, KJ, Abbas, et al. High dose, short course amoxycillin in the treatment of bacteriuria in pregnancy Br J Clin Pract, 37(6) 212–4. 1983. | 13
Andriole, VT. Urinary tract infections in pregnancy Urol Clin North Am, 2(3) 485–98. 1975. | 3
Andriole, VT. Advances in the treatment of urinary infections J Antimicrob Chemother, 9 Suppl A() 163–72. 1982. | 3
Anonymous. Treatment of bacteriuria in pregnancy Br Med J, 4(5736) 631–2. 1970. | 3
Asscher, AW. Screening for urinary tract infection J R Coll Physicians Lond, 4(3) 219–26. 1970. | 3
Atkinson, SM. Letter: Bacteriuria in pregnancy Obstet Gynecol, 43(1) 159–60. 1974. | 3
Atlas, E, Clark, et al. Nalidixic acid and oxolinic acid in the treatment of chronic bacteriuria Ann Intern Med, 70(4) 713–21. 1969. | 13
Avorn, J, Monane, et al. Reduction of bacteriuria and pyria with cranberry beverage: a randomized trial J Am Geriatr Soc, 41(10 Suppl) Sa13. 1993. | 11
Bailey, RR. Bacteriuria of pregnancy N Z Med J, 95(700) 56. 1982. | 2
Bailey, RR. Single-dose antibacterial treatment for bacteriuria in pregnancy Drugs, 27(2) 183–6. 1984. | 3
Bailey, RR. Urinary tract infection revisited N Z Med J, 77(489) 69–74. 1973. | 3
Bailey, RR. Urinary infection in pregnancy N Z Med J, 71(455) 216–20. 1970. | 16
Bengtsson, C, Bengtsson, et al. Bacteriuria in a population sample of women: 24-year follow-up study. Results from the prospective population-based study of women in Gothenburg, Sweden Scand J Urol Nephrol, 32(4) 284–9. 1998. | 2
Bilir, F, Akdemir, et al. Increased serum procalcitonin levels in pregnant patients with asymptomatic bacteriuria Ann Clin Microbiol Antimicrob, 12() 25. 2013. | 2
Billinson, MR, Aubry, et al. A comparative study of a screening test for bacteriuria Am J Obstet Gynecol, 108(6) 988–9. 1970. | 14
Bobeck, S, Schersten, et al. Detection and diagnosis of bacteriuria in pregnancy. A study from general practice Practitioner, 212(1268) 257–62. 1974. | 2
Bookallil, M, Chalmers, et al. Challenges in preventing pyelonephritis in pregnant women in Indigenous communities Rural Remote Health, 5(3) 395. 2005. | 2
Boscia, JA, Abrutyn, et al. Asymptomatic bacteriuria in elderly persons: treat or do not treat? Ann Intern Med, 106(5) 764–6. 1987. | 3
Boscia, JA, Kaye, et al. Asymptomatic bacteriuria in the elderly Clin Geriatr Med, 4(1) 57–70. 1988. | 3
Breidahl, P, Hurst, et al. The post-partum investigation of pregnancy bacteriuria Med J Aust, 2(21) 1174–7. 1972. | 2
Brown, N, Browder, et al. Treatment of persistent bacteriuria with a six-week course of antibiotic therapy Antimicrob Agents Chemother, () 324–333. 1961. | 10
Brumfitt, W. Asymptomatic Bacteriuria Practitioner, 192() 818–9. 1964. | 3
Brumfitt, W, Hamilton-Miller, et al. Trimethoprim Br J Hosp Med, 23(3) 281, 284–6, 288. 1980. | 3
Brumfitt, W, Pursell, et al. Trimethoprim-sulfamethoxazole in the treatment of bacteriuria in women J Infect Dis, 128() Suppl:657–65 p. 1973. | 13
Cai, T, Mazzoli, et al. The reduction of Escherichia coli resistance against ciprofloxacin is a microbiological parameter for asymptomatic bacteriuria predicting: results from a cross-sectional study European urology, supplements. Conference: 32nd annual european association of urology congress, EAU 2017. United kingdom, 16(3) e235. 2017. | 9
Cai, T, Mazzoli, et al. The role of asymptomatic bacteriuria in young women with recurrent urinary tract infections: to treat or not to treat? Clin Infect Dis, 55(6) 771–7. 2012. | 9
Cai, T, Nesi, et al. Asymptomatic bacteriuria treatment is associated with a higher prevalence of antibiotic resistant strains in women with urinary tract infections Clin Infect Dis, 61(11) 1655–61. 2015. | 9
Cameron, I. Urinary tract infection in the elderly Aust Fam Physician, 17(7) 539–41. 1988. | 3
Campbell-Brown, M, McFadyen, et al. Is screening for bacteriuria in pregnancy worth while? British Medical Journal Clinical Research Ed., 294(6587) 1579–82. 1987. | 16
Campos-Outcalt, DE, Corta, et al. Screening for asymptomatic bacteriuria in pregnancy J Fam Pract, 20(6) 589–91. 1985. | 14
Carroll, R, MacDonald, et al. The detection and treatment of bacteriuria in pregnancy. An essential part of antenatal care J Ir Med Assoc, 60(358) 115–7. 1967. | 14
Carroll, R, MacDonald, et al. Bacteriuria in pregnancy Obstet Gynecol, 32(4) 525–7. 1968. | 2
Cattell, WR. The management of urinary-tract infection Practitioner, 212(267) 27–36. 1974. | 3
Cattell, WR. Renal disease. II. Urinary tract infection in women J R Coll Physicians Lond, 31(2) 130–3. 1997. | 3
Chng, PK, Hall, et al. Antenatal prediction of urinary tract infection in pregnancy Br J Obstet Gynaecol, 89(1) 8–11. 1982. | 12
Christopher, LJ, Thompson, et al. A trial of hippramine in the treatment of bacteriuria of pregnancy Ir J Med Sci, 8(7) 331–7. 1969. | 13
Cobbs, CG, Strickler, et al. The postpartum renal status of women with untreated asymptomatic bacteriuria during pregnancy Am J Obstet Gynecol, 99(2) 221–7. 1967. | 2
Cormican, M, Murphy, et al. Interpreting asymptomatic bacteriuria BMJ, 343() d4780. 2011. | 3
Corriere, Jn, Lipshultz, et al. Bacteriuria in young women. Effect of estrogen, progestogen, and estrogen-progestogen combination Urology, 2(5) 539–541. 1973. | 1
Coulehan, JL. Screening yield in an urban low income practice Am J Public Health, 65(5) 474–9. 1975. | 2
Cunningham, FG, Lucas, et al. Urinary tract infections complicating pregnancy Baillieres Clin Obstet Gynaecol, 8(2) 353–73. 1994. | 3
Czerwinski, AW, Wilkerson, et al. Evaluation of first morning urine to detect significant bacteriuria. I Am J Obstet Gynecol, 110(1) 42–5. 1971. | 2
Dalal, S, Nicolle, et al. Long-term Escherichia coli asymptomatic bacteriuria among women with diabetes mellitus Clin Infect Dis, 49(4) 491–7. 2009. | 14
Dawborn, JK, Gurr, et al. The management of urinary infection in women Med J Aust, 1(9) 421–7. 1972. | 3
Dempsey, C, Harrison, et al. Characteristics of bacteriuria in a homogeneous maternity hospital population Eur J Obstet Gynecol Reprod Biol, 44(3) 189–93. 1992. | 2
DeShan, PW, Merrill, et al. The Griess test as a screening procedure for bacteriuria during pregnancy Obstet Gynecol, 27(2) 202–5. 1966. | 14
DeYoung, GR, Ashmead, et al. Screening for and treating asymptomiatic bacteriuria not useful in women with diabetes J Fam Pract, 52(2) 98–9. 2003. | 3
Dixon, HG, Brant, et al. The significance of bacteriuria in pregnancy Lancet, 1(7480) 19–20. 1967. | 2
Dodson, MG, Fortunato, et al. Microorganisms and premature labor J Reprod Med, 33(1 Suppl) 87–96. 1988. | 3
Drinka, P. Treatment of bacteriuria without urinary signs, symptoms, or systemic infectious illness (S/S/S) J Am Med Dir Assoc, 10(8) 516–9. 2009. | 3
Elder, HA, Santamarina, et al. Use of sulfasymazine in the treatment of bacteriuria of pregnancy Antimicrob Agents Chemother, 6() 142–8. 1966. | 14
Emmerson, AM. The use of a simple test for hypoglucosuria (uriglox) in the diagnosis of bacteriuria in pregnancy Journal of Obstetrics & Gynaecology of the British Commonwealth, 79(9) 828–32. 1972. | 14
Enbom, JA. Bacteriuria in pregnancy. Therapeutic considerations Postgrad Med, 49(5) 216–20. 1971. | 3
Eng, J, Torkildsen, et al. Bacteriuria in the puerperium: an evaluation of methods for collecting urine specimens Am J Obstet Gynecol, 131(7) 739–41. 1978. | 2
Fairley, KF, Bond, et al. The site of infection in pregnancy bacteriuria Lancet, 1(7444) 939–41. 1966. | 2
Fairley, KF, Whitworth, et al. Pregnancy bacteriuria: the significance of site of infection Med J Aust, 2(9) 424–7. 1973. | 16
Fang, LS, Tolkoff-Rubin, et al. Urinary tract infections in women Compr Ther, 5(9) 20–5. 1979. | 3
Fass, RJ, Klainer, et al. Urinary tract infection. Practical aspects of diagnosis and treatment JAMA, 225(12) 1509–13. 1973. | 3
Fatkenheuer, G, Jung, et al. Treatment of Asymptomatic Bacteriuria Clin Infect Dis, 62(9) 1190. 2016. | 3
Fihn, SD. Clinical practice. Acute uncomplicated urinary tract infection in women N Engl J Med, 349(3) 259–66. 2003. | 3
Finch, RM, Finch, et al. Bacteriological counts of urines in general practice Journal of the Royal College of General Practitioners, 19(93) 201–10. 1970. | 2
Fischbach, F, Loos, et al. Ciprofloxacin (CF) in the treatment of patients with symptomatic and asymptomatic urinary tract infections (UT): a comparative study of single dose application versus three days treatment Arch Gynecol, 237 Suppl() 92–93. 1985. | 13
Foley, ME, Farquharson, et al. Urinary tract infection in pregnancy Ir Med J, 75(6) 188–9. 1982. | 2
Ganguli, L. Serological grouping of Escherichia coli in bacteriuria of pregnancy J Med Microbiol, 3(2) 201–8. 1970. | 2
Gaymans, R, Haverkorn, et al. Aprospective study of urinary-tract infections in a Dutch general practice Lancet, 2(7987) 674–7. 1976. | 2
Geerlings, SE, Stolk, et al. Asymptomatic bacteriuria may be considered a complication in women with diabetes. Diabetes Mellitus Women Asymptomatic Bacteriuria Utrecht Study Group Diabetes Care, 23(6) 744–9. 2000. | 2
Gingell, JC. Bacteriuria again Br Med J, 2(5756) 278. 1971. | 3
Gleckman, R. The controversy of treatment of asymptomatic bacteriuria in non-pregnant women-resolved J Urol, 116(6) 776–7. 1976. | 3
Gofin, R, Palti, et al. Bacteriuria in pregnancy and growth and development of the infants Early Hum Dev, 9(4) 341–6. 1984. | 2
Golan, A, Wexler, et al. Asymptomatic bacteriuria in normal and high-risk pregnancy Eur J Obstet Gynecol Reprod Biol, 33(2) 101–8. 1989. | 12
Gonzalez Ochoa, A. Trimethoprim and sulfamethoxazole in pregnancy JAMA, 217(9) 1244. 1971. | 2
Goss, LB. Bacteriuria of Pregnancy Med Rec Ann, 57() 342–3. 1964. | 3
Goss, LB, Franklin, et al. Asymptomatic Bacteriuria of Pregnancy and Detection by a Simple Stain Am J Obstet Gynecol, 87() 493–8. 1963. | 12
Greenwood, D, Slack, et al. Urinary tract infection Br J Clin Pharmacol, 13(5) 619–30. 1982. | 2
Gringras, M, Cooper, et al. The treatment of urinary infection in women. A dip-slide comparative study Practitioner, 223(1335) 357–62. 1979. | 8
Grio, R, Porpiglia, et al. Asymptomatic bacteriuria in pregnancy: maternal and fetal complications Panminerva Med, 36(4) 198–200. 1994. | 3
Gruneberg, RN. The bacteriology of urinary tract infection: does it matter? Proc R Soc Med, 65(6) 514–6. 1972. | 3
Gruneberg, RN, Leigh, et al. Relationship of bacteriuria in pregnancy to acute pyelonephritis, prematurity, and fetal mortality Lancet, 2(7610) 1–3. 1969. | 2
Gruneberg, RN, Reeves, et al. Bacteriuria in pregnancy Br Med J, 1(5740) 107–8. 1971. | 3
Hall, DR, Theron, et al. Significance and treatment of asymptomatic bacteriuria during pregnancy Int J Gynaecol Obstet, 57(2) 179–80. 1997. | 2
Hankins, GD, Whalley, et al. Acute urinary tract infections in pregnancy Clin Obstet Gynecol, 28(2) 266–78. 1985. | 3
Harding, GK, Ronald, et al. Clinical experiences: genitourinary infections. A. Infections of the urinary tract. Efficacy of trimethoprim-sulfamethoxazole in bacteriuria J Infect Dis, 128() Suppl:641–6 p. 1973. | 8
Hargreaves, J. Investigation of bacteriuria in pregnancy and its treatment with sulphaemathizole Practitioner, 218(1307) 718–20. 1977. | 2
Harris, RE. The significance of eradication of bacteriuria during pregnancy Obstet Gynecol, 53(1) 71–3. 1979. | 12
Harris, RE. Postpartum urinary retention: role of antimicrobial therapy Am J Obstet Gynecol, 133(2) 174–5. 1979. | 6
Harris, RE. Antibiotic therapy of antepartum urinary tract infections J Int Med Res, 8(Suppl 1) 40–4. 1980. | 3
Harris, RE, Gilstrap, et al. Cystitis during pregnancy: a distinct clinical entity Obstet Gynecol, 57(5) 578–80. 1981. | 2
Harris, RE, Gilstrap, et al. Prevention of recurrent pyelonephritis during pregnancy Obstet Gynecol, 44(5) 637–41. 1974. | 8
Harris, RE, Gilstrap, et al. Single-dose antimicrobial therapy for asymptomatic bacteriuria during pregnancy Obstet Gynecol, 59(5) 546–9. 1982. | 13
Harris, RE, Thomas, et al. Asymptomatic bacteriuria in pregnancy: antibody-coated bacteria, renal function, and intrauterine growth retardation Am J Obstet Gynecol, 126(1) 20–5. 1976. | 12
Hatala, M, Prat, et al. Tetrazolium test (T.T.C.) in the screening of asymptomatic bacteriuria in pregnancy Rev Czech Med, 11(3) 198–202. 1965. | 14
Hecker, MT, Donskey, et al. Q: Is antibiotic treatment indicated in a patient with a positive urine culture but no symptoms? Cleve Clin J Med, 81(12) 721–4. 2014. | 3
Heineman, HS. Urinary infection in pregnancy Mod Treat, 7(2) 349–54. 1970. | 3
Henning, C, Bucht, et al. Results from the routine detection of bacteriuria in antenatal care in Stockholm County Acta Pathologica et Microbiologica Scandinavica - Section B, Microbiology & Immunology, 79(3) 446. 1971. | 2
Hibbard, L, Thrupp, et al. Treatment of pyelonephritis in pregnancy Am J Obstet Gynecol, 98(5) 609–15. 1967. | 8
Holland, WW. Taking stock Lancet, 2(7895) 1494–7. 1974. | 3
House, TE, Williams, et al. Pregnancy complicated by urinary tract infections Obstet Gynecol, 34(5) 670–4. 1969. | 13
Hutchings, RF, Gordon, et al. The “Uroscreen” test for significant bacteriuria in pregnancy West Indian Medical Journal, 19(2) 71–7. 1970. | 14
Institute for, Quality, Efficiency in Health, et al. IQWiG Executive Summaries of Final Reports Screening for Asymptomatic Bacteriuria Within the Framework of the German Maternity Guidelines, Under Special Consideration of Test Methods, (). 2015. | 3
Ives, JA, Abbott, et al. Bacteriuria in pregnancy and infection in amniotic fluid and infant Arch Dis Child, 46(245) 82–4. 1971. | 14
Jackson, GG. Diagnosis and importance of asymptomatic bacteriuria in adults Infection, 3(3) 175–7. 1975. | 3
John, P. A study of asymptomatic bacteriuria among the maternal care patients attending the Maternal and Child Health Clinic, Dhahran, Saudi Arabia Am J Obstet Gynecol, 111(1) 26–30. 1971. | 14
Jones, SR, Smith, et al. Localization of urinary-tract infections by detection of antibody-coated bacteria in urine sediment N Engl J Med, 290(11) 591–3. 1974. | 2
Juthani-Mehta, M. Changing Clinicians’ Behavior: To Order or Not to Order a Urine Culture JAMA Intern Med, 175(7) 1127–9. 2015. | 3
Kass, EH. Bacteriuria and excess mortality: what should the next steps be? Rev Infect Dis, 7 Suppl 4() S762–6. 1985. | 3
Kass, EH. Horatio at the orifice: the significance of bacteriuria J Infect Dis, 138(4) 546–57. 1978. | 3
Kass, EH. Pregnancy, pyelonephritis and prematurity Clin Obstet Gynecol, 13(2) 239–54. 1970. | 3
Kass, FH. Should bacteriuria be treated? Med J Aust, 1(2) Suppl:38–43. 1973. | 3
Kaye, D, Hurley, et al. Treatment of Urinary Tract Infection with Ampicillin Arch Intern Med, 115() 575–9. 1965. | 12
Keating, GM. Fosfomycin trometamol: a review of its use as a single-dose oral treatment for patients with acute lower urinary tract infections and pregnant women with asymptomatic bacteriuria Drugs, 73(17) 1951–66. 2013. | 3
Kessous, R, Weintraub, et al. Bacteruria with group-B streptococcus: is it a risk factor for adverse pregnancy outcomes? Journal of Maternal-Fetal & Neonatal Medicine, 25(10) 1983–6. 2012. | 2
Khanna, SD, Puri, et al. Asymptomatic Bacteriuria and Value of Triphenyl Tetrazolium Chloride Test as a Screening Aid Indian J Med Sci, 18() 457–60. 1964. | 5
Kincaid-Smith, P. Screening Tests for Bacteriuria in Pregnancy Lancet, 1(7383) 487. 1965. | 3
Kincaid-Smith, P. Screening for bacteriuria in pregnancy Lancet, 1(7703) 809–10. 1971. | 3
Kincaid-Smith, P, Kalowski, et al. Co-trimoxazole in urinary tract infection Med J Aust, 1(2) Suppl:49–51. 1973. | 13
Kirby, A, Simpson, et al. Testing for asymptomatic bacteriuria in pregnancy Eur J Obstet Gynecol Reprod Biol, 205() 192–4. 2016. | 1
Kovar, WR. Routine urinary tract screening Nebr Med J, 65(6) 146. 1980. | 2
Kozinn, PJ, Goldberg, et al. Bacteriuria: colonization or infection JAMA, 253(13) 1878–9. 1985. | 6
Krieger, JN. Complications and treatment of urinary tract infections during pregnancy Urol Clin North Am, 13(4) 685–93. 1986. | 3
Kumazawa, J, Momose, et al. Clinical effectiveness of lividomycin on urinary tract infections: evaluation with double-blind method Curr Ther Res Clin Exp, 15(12) 873–901. 1973. | 8
Kunin, CM. Use of antimicrobial agents in treating urinary tract infection Adv Nephrol Necker Hosp, 14() 39–65. 1985. | 3
Lautenbach, E, Babson, et al. Assessment of the use of urine samples to detect colonization with fluoroquinolone-susceptible and fluoroquinolone-resistant Escherichia coli Infect Control Hosp Epidemiol, 30(4) 396–7. 2009. | 7
Lawson, DH, Miller, et al. Screening for bacteriuria in pregnancy. A critical reappraisal Arch Intern Med, 132(6) 904–8. 1973. | 3
Lawson, DH, Miller, et al. Screening for bacteriuria in pregnancy Lancet, 1(7706) 968–9. 1971. | 3
Leblanc, AL, McGanity, et al. The Impact of Bacteriuria in Pregnancy; a Survey of 1300 Pregnant Patients Tex Rep Biol Med, 22() 336–47. 1964. | 16
Leigh, DA. Bacteriuria again Br Med J, 2(5760) 527–8. 1971. | 3
Lein, JN, Bulger, et al. Why bacteriuria in pregnancy should be treated Postgrad Med, 45(5) 201–5. 1969. | 3
Leis, JA, Rebick, et al. Reducing antimicrobial therapy for asymptomatic bacteriuria among noncatheterized inpatients: a proof-of-concept study Clin Infect Dis, 58(7) 980–3. 2014. | 6
Leveno, KJ, Harris, et al. Bladder versus renal bacteriuria during pregnancy: recurrence after treatment Am J Obstet Gynecol, 139(4) 403–6. 1981. | 2
Lin, KW, Brown, et al. Screening for asymptomatic bacteriuria in adults Am Fam Physician, 81(4) 508. 2010. | 3
Little, PJ. Treatment of bacteriuria of pregnancy Drugs, 14(5) 390–1. 1977. | 3
Lumbiganon, P, Villar, et al. One-day compared with 7-day nitrofurantoin for asymptomatic bacteriuria in pregnancy: a randomized controlled trial Obstet Gynecol, 113(2 Pt 1) 339–45. 2009. | 13
Lynn, KL, Bailey, et al. Pregnancy and the nephrologist: a review of one year’s experience N Z Med J, 96(733) 433–5. 1983. | 2
Mabeck, CE. Significance of coagulase-negative staphylococcal bacteriuria Lancet, 2(7631) 1150–2. 1969. | 8
Mabeck, CE. Treatment of uncomplicated urinary tract infection in non-pregnant women Postgrad Med J, 48(556) 69–75. 1972. | 8
Mannucci, C, Dante, et al. Vigilance on use of drugs, herbal products, and food supplements during pregnancy: focus on fosfomycin Journal of Maternal-Fetal & Neonatal Medicine, () 1–4. 2017. | 8
Marko, J. Infections of the urinaryin tract in pregnancy Canadian Family Physician, 16(5) 62–4. 1970. | 8
Maskell, R. Antibacterial agents and urinary tract infection: a paradox Br J Gen Pract, 42(357) 138–9. 1992. | 3
McAllister, TA. The day of the dipslide Nephron, 11(2) 123–33. 1973. | 3
McAllister, TA, Arneil, et al. Assessment of plane dipslide quantitation of bacteriuria Nephron, 11(2) 111–22. 1973. | 14
McFadyen, IR, Eykyn, et al. Screening for bacteriuria in pregnancy Lancet, 1(7690) 132–3. 1971. | 2
McFadyen, IR, McCallum, et al. The Treatment of Urinary Infection Journal of Obstetrics & Gynaecology of the British Commonwealth, 72() 112–9. 1965. | 13
McGeown, MG. Treatment of urinary tract infection during pregnancy Contrib Nephrol, 25() 30–5. 1981. | 3
McNeeley, SG, Jr. Treatment of urinary tract infections during pregnancy Clin Obstet Gynecol, 31(2) 480–7. 1988. | 3
Meares, EM, Jr. Asymptomatic bacteriuria. Current concepts in management Postgrad Med, 62(3) 106–11. 1977. | 3
Meiland, R, Geerlings, et al. Diabetes mellitus in itself is not a risk factor for antibiotic resistance in Escherichia coli isolated from patients with bacteriuria Diabetic Med, 21(9) 1032–4. 2004. | 2
Mekapogu, NP, Gundela, et al. Diabetes Mellitus has no Significant Influence on the Prevalence of Antenatal Asymptomatic Bacteriuria Journal of Clinical and Diagnostic Research JCDR, 10(4) DC16–20. 2016. | 2
Merrill, JA, Colmore, et al. Screening for asymptomatic bacteriuria during antepartum care Am J Obstet Gynecol, 99(2) 216–20. 1967. | 14
Mertz, HL, Ernest, et al. Antibiotics and preterm labor Curr Womens Health Rep, 1(1) 20–6. 2001. | 3
Mitra, P Kulkarni V Sengupta SSathe C. Bacteriuria in pregnancy and its treatment J Obstet Gynaecol India, 27(5) 711–718. 1977. | 5
Mocarski, V. Asymptomatic bacteriuria - a “silent” problem of pregnant women MCN, American Journal of Maternal Child Nursing, 5(4) 238–41. 1980. | 3
Morgan, MG, Brumfitt, et al. Treatment of urinary infection in the elderly Infection, 18(6) 326–31. 1990. | 3
Mulla, N. Bacteriuria in pregnancy Obstet Gynecol, 16() 89–92. 1960. | 16
Murray, ED. Early detection of asymptomatic bacteriuria in pregnancy Br Med J, 2(6099) 1418. 1977. | 2
Murray, ED. Pregnancy diagnosis and bacteriuria Journal of the Royal College of General Practitioners, 30(219) 634. 1980. | 14
Mustafa, MA, Dunbar, et al. The use of colicine typing in a study of the relationship of infecting urinary organism to the faecal flora in pregnant patients with significant bacteriuria Journal of Obstetrics & Gynaecology of the British Commonwealth, 77(6) 544–7. 1970. | 2
Nct,, Sunden, et al. Induced Asymptomatic E. Coli 83972 Bacteriuria in Patients With Recurrent Urinary Tract Infections and Bladder Dysfunction- is There a Protective Effect Against Recurrent Symptomatic Infections? A Blinded Placebo Controlled Cross-over Study Http://clinicaltrials.gov/show/nct00927316, (). 2003. | 9
Nelson, JM, Good, et al. Urinary tract infections and asymptomatic bacteriuria in older adults Nurse Pract, 40(8) 43–8. 2015. | 3
Nickel, JC, Pidutti, et al. A rational approach to urinary tract infections in older patients Geriatrics, 47(10) 49–50, 53–5. 1992. | 3
Nicolle, LE. Management of asymptomatic bacteriuria in pregnant women Lancet Infect Dis, 15(11) 1252–4. 2015. | 3
Nicolle, LE. Management of Asymptomatic UTIs in Women Medscape Womens Health, 1(3) 4. 1996. | 3
Nicolle, LE. Asymptomatic bacteriuria Curr Opin Infect Dis, 27(1) 90–6. 2014. | 3
Norden, CW. Significance of bacteriuria in pregnancy Postgrad Med, 47(1) 181–6. 1970. | 3
Norden, CW, Levy, et al. Predictive effect of urinary concentrating ability and hemagglutinating antibody titer upon response to antimicrobial therapy in bacteriuria of pregnancy J Infect Dis, 121(6) 588–96. 1970. | 14
Nordenstam, GR, Brandberg, et al. Bacteriuria and mortality in an elderly population N Engl J Med, 314(18) 1152–6. 1986. | 2
North, DH, Speed, et al. Correlation of urinary tract infection with urinary screening at the first antepartum visit J Miss State Med Assoc, 31(10) 331–3. 1990. | 2
Notelovitz, M. The antenatal detection of asymptomatic disease South African Medical Journal. Suid-Afrikaanse Tydskrif Vir Geneeskunde, 48(5) 178–84. 1974. | 5
Patterson, TF, Andriole, et al. Detection, significance, and therapy of bacteriuria in pregnancy. Update in the managed health care era Infect Dis Clin North Am, 11(3) 593–608. 1997. | 3
Patterson, TF, Andriole, et al. Bacteriuria in pregnancy Infect Dis Clin North Am, 1(4) 807–22. 1987. | 3
Paulshock, BZ, Rocco, et al. The correlation of abnormal urinalysis, urinary symptoms, and bacteria in pregnant women Del Med J, 44(10) 271–3. 1972. | 14
Pearson, BS. Urinary tract infection treated with oxolinic acid Med J Aust, 1(5) 140–1. 1975. | 8
Pels, RJ, Bor, et al. Dipstick urinalysis screening of asymptomatic adults for urinary tract disorders. II. Bacteriuria JAMA, 262(9) 1221–4. 1989. | 2
Persson, K, Christensen, et al. Asymptomatic bacteriuria during pregnancy with special reference to group B streptococci Scand J Infect Dis, 17(2) 195–9. 1985. | 2
Polk, BF. Urinary tract infection in pregnancy Clin Obstet Gynecol, 22(2) 285–92. 1979. | 3
Prio, TK, Bruunsgaard, et al. Asymptomatic bacteriuria in elderly humans is associated with increased levels of circulating TNF receptors and elevated numbers of neutrophils Exp Gerontol, 37(5) 693–9. 2002. | 2
Pulcini, C. Comment on: Staphylococcus aureus bacteremia (SAB) with associated S. aureus bacteriuria (SABU) as a predictor of complications and mortality Journal of Hospital Medicine (Online), 5(6) E11. 2010. | 4
Qureshi, F, Abdulmannan, et al. Screening for significant bacteriuria in patients with upper tract calculi using dipstick urine analysis Ann Saudi Med, 22(5–6) 381–383. 2002. | 14
Raz, R. Asymptomatic bacteriuria. Clinical significance and management Int J Antimicrob Agents, 22 Suppl 2() 45–7. 2003. | 3
Reddy, J, Campbell, et al. Bacteriuria in pregnancy Aust N Z J Obstet Gynaecol, 25(3) 176–8. 1985. | 14
Rees, DL. Urinary tract infection Clin Obstet Gynaecol, 5(1) 169–92. 1978. | 3
Reeves, DS. Treatment of bacteriuria in pregnancy with single dose fosfomycin trometamol: a review Infection, 20 Suppl 4() S313–6. 1992. | 3
Reeves, Ds. Laboratory and clinical studies with sulfametopyrazine as a treatment for bacteriuria in pregnancy J Antimicrob Chemother, 1(2) 171–186. 1975. | 13
Renneberg, J, Paerregaard, et al. Single-day treatment with trimethoprim for asymptomatic bacteriuria in the elderly patient J Urol, 132(5) 934–5. 1984. | 7
Renyi-Vamos, F. The clinical significance of asymptomatic bacteriuria Int Urol Nephrol, 3(2) 151–7. 1971. | 3
Rhode, MA, Shapiro, et al. Indicated vs. routine prenatal urine chemical reagent strip testing J Reprod Med, 52(3) 214–9. 2007. | 12
Ries, K, Kaye, et al. The current status of therapy in urinary tract infection in pregnancy Clin Perinatol, 1(2) 423–33. 1974. | 3
Ringrose, EW. Bacteriuria in Pregnancy Med J Aust, 1(16) 596–8. 1965. | 3
Robertson, JG, Livingstone, et al. The managment and complications of asymptomatic bacteriuria in pregnancy. Report of a study on 8,275 patients Journal of Obstetrics & Gynaecology of the British Commonwealth, 75(1) 59–65. 1968. | 2
Rosser, J. Antibiotics for asymptomatic bacteriuria in pregnancy Practising Midwife, 4(8) 20–1. 2001. | 3
Roy, PB, Joglekar, et al. Urinary tract infection and drug response Indian J Med Sci, 26(11) 710–7. 1972. | 8
Sabath, LD, Elder, et al. Synergistic combinations of penicillins in the treatment of bacteriuria N Engl J Med, 277(5) 232–8. 1967. | 12
Sastry, S, Clarke, et al. Clinical Appraisal of Fosfomycin in the Era of Antimicrobial Resistance Antimicrob Agents Chemother, 59(12) 7355–61. 2015. | 6
Schnarr, J, Smaill, et al. Asymptomatic bacteriuria and symptomatic urinary tract infections in pregnancy Eur J Clin Invest, 38 Suppl 2() 50–7. 2008. | 3
Schonebeck, J. Asymptomatic candiduria. Prognosis, complications and some other clinical considerations Scand J Urol Nephrol, 6(2) 136–46. 1972. | 1
Seal, DV, Cuthbert, et al. Doubtful significance of fastidious bacteriuria in the urethral syndrome Lancet, 1(8263) 115. 1982. | 2
Seidenfeld, SM, Luby, et al. Urologic sepsis Urol Clin North Am, 9(2) 259–66. 1982. | 3
Seligman, SJ, Deigh, et al. Detection of bacteriuria by a filter paper inoculating strip Am J Obstet Gynecol, 102(6) 890–5. 1968. | 2
Shaw, EJ, Clark, et al. R factors in Enterobacteriaceae causing asymptomatic bacteriuria of pregnancy J Med Microbiol, 6(4) 455–9. 1973. | 2
Simon, NV, Heaps, et al. Improving the processes of care and outcomes in obstetrics/gynecology Joint Commission Journal on Quality Improvement, 23(9) 485–97. 1997. | 12
Sivojelezova, A, Einarson, et al. Trimethoprim-sulfonamide combination therapy in early pregnancy Canadian Family Physician, 49() 1085–6. 2003. | 3
Slack, RC. Definition of urinary tract infection and assessment of efficacy in drug trials-a laboratory perspective Infection, 20 Suppl 3() S155–6. 1992. | 2
Slowinski, EJ, Smith, et al. A 10 second colorimetric test for asymptomatic bacteriuria in pregnancy. The office use of the griess test Am J Obstet Gynecol, 94(7) 966–9. 1966. | 14
Smaill, F. Genitourinary tract infections in pregnancy and low birth weight BMJ, 304(6818) 54–5. 1992. | 3
Smith, GW. Is screening for bacteriuria in pregnancy worth while? British Medical Journal Clinical Research Ed., 295(6600) 725–6. 1987. | 3
Spreer, A, Weissbach, et al. Pivmecillinam in the treatment of urinary tract infections. Clinical effects and side effects Med Welt, 31(4) 152–155. 1980. | 15
Stamm, WE. Quantitative urine cultures revisited Eur J Clin Microbiol, 3(4) 279–81. 1984. | 3
Stenqvist, K, Dahlen-Nilsson, et al. Bacteriuria in pregnancy. Frequency and risk of acquisition Am J Epidemiol, 129(2) 372–9. 1989. | 2
Stokholm, J, Schjorring, et al. Antibiotic use during pregnancy alters the commensal vaginal microbiota Clinical Microbiology & Infection, 20(7) 629–35. 2014. | 6
Stray-Pdersen, B, Blakstad, et al. Bacteriuria in the puerperium. Risk factors, screening procedures, and treatment programs Am J Obstet Gynecol, 162(3) 792–7. 1990. | 14
Taber, RL. Asymptomatic bacteriuria in the elderly Emerg Med Clin North Am, 6(3) 467–72. 1988. | 3
Takala, J, Jousimies, et al. Screening for and treatment of bacteriuria in a middle-aged female population. II. Results of short-term nitrofurantoin therapy and one-year follow-up Acta Med Scand, 202(1–2) 75–9. 1977. | 2
Thomsen, AC, Morup, et al. Antibiotic elimination of group-B streptococci in urine in prevention of preterm labour Lancet, 1(8533) 591–3. 1987. | 1
Thrupp, LD, Cotran, et al. Relationship of Bacteriuria in Pregnancy to Pyelonephritis JAMA, 189() 899–902. 1964. | 2
Turck, M. Therapeutic guidelines in the management of urinary tract infections and pyelonephritis Urol Clin North Am, 2(3) 443–50. 1975. | 3
Van Poppel, H, Boeckx, et al. Short treatment regimen of lower urinary tract infections by pivmecillinam Acta Urol Belg, 55(3) 479–84. 1987. | 8
Versi, E, Chia, et al. Bacteriuria in pregnancy: a comparison of Bangladeshi and Caucasian women Int Urogynecol J, 8(1) 8–12. 1997. | 2
Vinacur, JC, Casellas, et al. Serum anti-Escherichia coli antibodies and urinary beta-glucuronidase for the diagnosis and control of evolution of urinary infection during pregnancy Am J Obstet Gynecol, 120(6) 812–6. 1974. | 2
Virtanen, S. Colony count from mid-stream voided urine specimens as a screening method for bacteriuria in pregnant females Acta Pathol Microbiol Scand, 55() 378–83. 1962. | 2
Vousden, N, Shennan, et al. 1 day of nitrofurantoin was not as effective as 7 days for asymptomatic bacteriuria in pregnancy Evidence Based Medicine, 14(4) 113. 2009. | 13
Wagenlehner, FM, Naber, et al. Editorial commentary: treatment of asymptomatic bacteriuria might be harmful Clin Infect Dis, 61(11) 1662–3. 2015. | 3
Wagenlehner, FM, Naber, et al. Asymptomatic bacteriuria in elderly patients: significance and implications for treatment Drugs Aging, 22(10) 801–7. 2005. | 3
Waring, L. Pathology quiz. Asymptomatic bacteriuria in the elderly Aust Fam Physician, 31(1) 34, 36. 2002. | 3
Weiner, P, Kaye, et al. Urinary tract infection Adv Exp Med Biol, 224() 13–23. 1987. | 3
Weiskopf, J, Scott, et al. Asymptomatic bacteriuria, what are you treating? JAMA Intern Med, 175(3) 344–5. 2015. | 3
Wenzl, JE. Bacteriuria: detection and screening techniques J Okla State Med Assoc, 64(10) 402–6. 1971. | 3
Whalley, PJ, Martin, et al. Significance of Asymptomatic Bacteriuria Detected during Pregnancy JAMA, 193() 879–81. 1965. | 2
Whitworth, JA. Management of asymptomatic bacteriuria Aust N Z J Med, 11(3) 321–8. 1981. | 3
Whitworth, JA, Fairley, et al. The site of renal infection: pyelitis or pyelonephritis? Clin Nephrol, 2(1) 9–12. 1974. | 2
Williams, JD, Brumfitt, et al. The treatment of bacteriuria in pregnant women with sulphamethoxazole and thrimethoprim. A microbiological, clinical and toxicological study Postgrad Med J, 45() Suppl:71–6. 1969. | 2
Williams, JD, Brumfitt, et al. Eradication of Bacteriuria in Pregnancy by a Short Course of Chemotherapy Lancet, 1(7390) 831–4. 1965. | 12
Williams, JD, Leigh, et al. The Organization and Results of a Screening Programme for the Detection of Bacteriuria of Pregnancy Journal of Obstetrics & Gynaecology of the British Commonwealth, 72() 327–35. 1965. | 2
Williams, JD, Thomlinson, et al. Asymptomatic urinary tract infection in gynaecological outpatients Br Med J, 1(5635) 29–31. 1969. | 12
Wilson, DM. Tests to detect asymptomatic urinary tract infection JAMA, 271(18) 1399; author reply 1399–400. 1994. | 3
Wing, D, Rumney, et al. Cranberry for asymptomatic bacteriuria prevention in pregnancy Am J Obstet Gynecol, 197(6 Suppl 1) S73, Abstract no: 223. 2007. | 17
Wing, DA, Rumney, et al. Daily cranberry juice for the prevention of asymptomatic bacteriuria in pregnancy: a randomized, controlled pilot study J Urol, 180(4) 1367–72. 2008. | 1
Wood, CA, Abrutyn, et al. Urinary tract infection in older adults Clin Geriatr Med, 14(2) 267–83. 1998. | 3
Wu, P, Feldman, et al. Relative Importance and Additive Effects of Maternal and Infant Risk Factors on Childhood Asthma.[Erratum appears in PLoS One. 2016;11(5):e0156473; PMID: 27219510] PLoS ONE [Electronic Resource], 11(3) e0151705. 2016. | 8
Yaxley, RP. Asymptomatic bacilluria: associated factors Med J Aust, 1(23) 1175. 1970. | 3
Zacur, HA, Mitch, et al. Renal disease in pregnancy Med Clin North Am, 61(1) 89–109. 1977. | 3
Zhanel, GG, Harding, et al. Asymptomatic bacteriuria. Which patients should be treated? Arch Intern Med, 150(7) 1389–96. 1990. | 3
Zilkoski, MW, Smucker, et al. Urinary tract infections in elderly patients Postgrad Med, 84(3) 191–4, 197–8. 1988. | 3
Zweig, S. Urinary tract infections in the elderly Am Fam Physician, 35(5) 123–30. 1987. | 3