# Appendix B Included Studies

Below is a list of included studies and their ancillary publications (indented below main results publication):

- Key Question 1:
  1. Gratacos E, Torres PJ, Vila J, . Screening and treatment of asymptomatic bacteriuria in pregnancy prevent pyelonephritis. Journal of Infectious Diseases. 1994;169(6):1390–2. PMID: 8195624.8195624
- Key Question 1 and Key Question 2:
  1. Uncu Y, Uncu G, Esmer A, . Should asymptomatic bacteriuria be screened in pregnancy? Clin Exp Obstet Gynecol. 2002;29(4):281–5. PMID: 12635746.12635746
- Key Question 3:
  1. Abrutyn E, Mossey J, Berlin JA, . Does asymptomatic bacteriuria predict mortality and does antimicrobial treatment reduce mortality in elderly ambulatory women?.[Erratum appears in Ann Intern Med 1994 Dec 1;121(11):901]. Annals of Internal Medicine. 1994;120(10):827–33. PMID: 7818631. DOI:10.7326/0003-4819-120-10-199405150-00003 7818631
    a. Abrutyn E, Berlin J, Mossey J, . Does treatment of asymptomatic bacteriuria in older ambulatory women reduce subsequent symptoms of urinary tract infection? Journal of the American Geriatrics Society. 1996;44(3):293–5. PMID: 8600199. DOI: 10.1111/j.1532-5415.1996.tb00917.x 8600199
  2. Brumfitt W. The effects of bacteriuria in pregnancy on maternal and fetal health. Kidney international. 1975;8:S113–s9. PMID: 00230726.00230726
    a. Condie A, Williams J, Reeves D, . Complications of bacteriuria in pregnancy. Urinary tract infection, proceedings of the first national symposium; 1968 april; london, UK. 1968:148–59. PMID: CN-00231117.
    b. Williams J, Reeves D, Condie A, . The treatment of bacteriuria in pregnancy. Urinary tract infection Oxford University Press, London. 1968:160–9. PMID: None.
  3. Foley ME, Farquharson R, Stronge JM. Is screening for bacteriuria in pregnancy worthwhile? Br Med J (Clin Res Ed). 1987;295(6592):270. PMID: 3115406.3115406
  4. Kincaid-Smith P, Bullen M. Bacteriuria in Pregnancy. Lancet. 1965;1(7382):395–9. PMID: 14238090.14238090
    a. Kincaid-Smith P. Ampicillin in Bacteriuria and Pyelonephritis of Pregnancy. Postgraduate Medical Journal. 1964;40:SUPPL:74–80. PMID: 14246855.14122905
  5. Pathak UN, Tang K, Williams LL, . Bacteriuria of pregnancy: results of treatment. Journal of Infectious Diseases. 1969;120(1):91–103. PMID: 5816817.5816817
  6. Williams GL, Campbell H, Davies KJ. Urinary concentrating ability in women with asymptomatic bacteriuria in pregnancy. British Medical Journal. 1969;3(5664):212–5. PMID: 5792611.5792611
- Key Question 3 and Key Question 4:
  1. Asscher AW, Sussman M, Waters WE, . The clinical significance of asymptomatic bacteriuria in the nonpregnant woman. Journal of Infectious Diseases. 1969;120(1):17–26. PMID: 5803281. DOI: 10.1093/infdis/120.1.17 5803281
    a. Asscher AW, Sussman M, Waters WE, . Asymptomatic significant bacteriuria in the non-pregnant woman. II. Response to treatment and follow-up. British Medical Journal. 1969;1(5647):804–6. PMID: 4886627. 10.1136/bmj.1.5647.804 4886627
    b. Sussman M, Asscher AW, Waters WE, . Asymptomatic significant bacteriuria in the non-pregnant woman. I. Description of a population. British Medical Journal. 1969;1(5647):799–803. PMID: 5774076.5774076
  2. Boscia JA, Kobasa WD, Knight RA, . Therapy vs no therapy for bacteriuria in elderly ambulatory nonhospitalized women. JAMA. 1987;257(8):1067–71. PMID: 3806896. DOI: 10.1001/jama.1987.03390080057030 3806896
  3. Elder HA, Santamarina BA, Smith S, . The natural history of asymptomatic bacteriuria during pregnancy: the effect of tetracycline on the clinical course and the outcome of pregnancy. American Journal of Obstetrics & Gynecology. 1971;111(3):441–62. PMID: 4937729. DOI: 10.1016/0002-9378(71)90793-9 4937729
    a. Elder HA, Santamarina BA, Smith SA, . Excess prematurity in tetracycline-treated bacteriuric patients whose infection persisted or returned. Antimicrob Agents Chemother. 1967;7:101–9. PMID: 4876085.4876085
  4. Furness ET, McDonald PJ, Beasley NV. Urinary antiseptics in asymptomatic bacteriuria of pregnancy. New Zealand Medical Journal. 1975;81(539):417–9. PMID: 1099490.1099490
  5. Giamarellou H, Dontas A, Zorbas P, . Asymptomatic bacteriuria in freely voiding elderly subjects. Long-term continuous vs pulse treatment with ofloxacin. Clinical drug investigation. 1998;15(3):187–95. PMID: CN-00200935. DOI: 10.2165/00044011-199815030-00003
    a. Staszewska-Pistoni M, Dontas AS, Giamarellou H, . Effectiveness of ofloxacin therapy in preventing functional impairment and increased mortality in elderly patients with bacteriuria. Drugs. 1995;49: Suppl 2:374–5. PMID: 8549366.8549366
  6. Gold E, Traub F, Daichman I, . Asymptomatic bacteriuria during pregnancy. Obstetrics and gynecology. 1966;27:206–9. PMID: CN-00231907.5325600
  7. Harding GK, Zhanel GG, Nicolle LE, . Antimicrobial treatment in diabetic women with asymptomatic bacteriuria. New England Journal of Medicine. 2002;347(20):1576–83. PMID: 12432044. DOI: 10.1056/NEJMoa021042 12432044
    a. Nicolle LE, Zhanel GG, Harding GK. Microbiological outcomes in women with diabetes and untreated asymptomatic bacteriuria. World Journal of Urology. 2006;24(1):61–5. PMID: 16389540. DOI: 10.1007/s00345-005-0042-2 16389540
  8. Kazemier BM, Koningstein FN, Schneeberger C, . Maternal and neonatal consequences of treated and untreated asymptomatic bacteriuria in pregnancy: a prospective cohort study with an embedded randomised controlled trial. Lancet Infect Dis 2015;15(11):1324–33. PMID: 2625520826255208
    a. Kazemier BM, Schneeberger C, De Miranda E, . Costs and effects of screening and treating low risk women with a singleton pregnancy for asymptomatic bacteriuria, the ASB study. BMC Pregnancy & Childbirth. 2012;12:52. PMID: 22892110. DOI: 10.1186/1471-2393-12-52 22892110
  9. Little PJ. The incidence of urinary infection in 5000 pregnant women. Lancet. 1966;2(7470):925–8. PMID: 4162367.4162367
    a. Haswell B, Sidaway ME, de Wardener HE. Follow-up of 164 patients with bacteriuria of pregnancy. Lancet. 1968;1(7550):990–4. PMID: 4171835.4171835
  10. Savage W, Hajj S, Kass E. Demographic and prognostic characteristics of bacteriuria in pregnancy. Medicine. 1967;46:385–407. PMID: CN-00234430.4864339
    a. Kass E. The role of asymptomatic bacteriuria in the pathogenesis of pyelonephritis. Biology of pyelonephritis. 1960:399–412. PMID: CN-00232612.
    b. Kass E. Pyelonephritis and bacteriuria. A major problem in preventive medicine. Annals of internal medicine. 1962;56:46–53. PMID: CN-00232611.14454174
    c. Zinner SH, Kass EH. Long-term (10 to 14 years) follow-up of bacteriuria of pregnancy. New England Journal of Medicine. 1971;285(15):820–4. PMID: 4936826. DOI: 10.1056/NEJM197110072851502 4936826
  11. Wren BG. Subclinical renal infection and prematurity. Med J Aust. 1969;2(12):596–600. PMID: 5388374.5388374
    a. Wren BG. Subclinical renal infection in pregnancy; pathogenesis, the organisms and the drugs of choice in its treatment. Medical Journal of Australia. 1969;2(18):895–8. PMID: 4901784.4901784
    b. Wren BG. Subclinical urinary infection in pregnancy. Medical Journal of Australia. 1969;1(24):1220–6. PMID: 4894855.4894855
    c. Wren BG. The diagnosis of asymptomatic bacilluria in pregnancy. Medical Journal of Australia. 1969;1(22):1117–21. PMID: 4893255.4893255