# References

1 Daly MB, Pilarski R, Berry M, . NCCN guidelines insights: genetic/familial high-risk assessment: breast and ovarian, Version 2.2017. J Natl Compr Canc Netw. 2017 Jan;15(1):9–20. PMID: 28040716.28040716
2 Stuckey AR, Onstad MA. Hereditary breast cancer: an update on risk assessment and genetic testing in 2015. Am J Obstet Gynecol. 2015 Aug;213(2):161–5. doi: 10.1016/j.ajog.2015.03.003. PMID: 25747548.25747548
3 Easton DF, Pharoah PD, Antoniou AC, . Gene-panel sequencing and the prediction of breast-cancer risk. N Engl J Med. 2015 Jun 04;372(23):2243–57. doi: 10.1056/NEJMsr1501341. PMID: 26014596.26014596
4 Brody LC, Biesecker BB. Breast cancer susceptibility genes. BRCA1 and BRCA2. Medicine (Baltimore). 1998 May;77(3):208–26. PMID: 9653432.9653432
5 Mersch J, Jackson MA, Park M, . Cancers associated with BRCA1 and BRCA2 mutations other than breast and ovarian. Cancer. 2015 Jan 15;121(2):269–75. doi: 10.1002/cncr.29041. PMID: 25224030.25224030
6 Miki Y, Swensen J, Shattuck-Eidens D, . A strong candidate for the breast and ovarian cancer susceptibility gene BRCA1. Science. 1994 Oct 07;266(5182):66–71. PMID: 7545954.7545954
7 Wooster R, Weber BL. Breast and ovarian cancer. N Engl J Med. 2003 Jun 05;348(23):2339–47. doi: 10.1056/NEJMra012284. PMID: 12788999.12788999
8 Sherman ME, Piedmonte M, Mai PL, . Pathologic findings at risk-reducing salpingo-oophorectomy: primary results from Gynecologic Oncology Group Trial GOG-0199. J Clin Oncol. 2014 Oct 10;32(29):3275–83. doi: 10.1200/JCO.2013.54.1987. PMID: 25199754.25199754
9 Norquist BM, Garcia RL, Allison KH, . The molecular pathogenesis of hereditary ovarian carcinoma: alterations in the tubal epithelium of women with BRCA1 and BRCA2 mutations. Cancer. 2010 Nov 15;116(22):5261–71. doi: 10.1002/cncr.25439. PMID: 20665887.20665887
10 National Cancer Institute. Breast cancer. 2012. http://www.cancer.gov/cancertopics/types/breast. Accessed May 16 2019.
11 Li CI, Uribe DJ, Daling JR. Clinical characteristics of different histologic types of breast cancer. Br J Cancer. 2005 Oct 31;93(9):1046–52. doi: 10.1038/sj.bjc.6602787. PMID: 16175185.16175185
12 U.S. Cancer Statistics Working Group. U.S. Cancer Statistics Data Visualizations Tool, based on November 2017 submission data (1999-2015): U.S. Department of Health and Human Services, Centers for Disease Control and Prevention and National Cancer Institute. www.cdc.gov/cancer/dataviz. Accessed May 16 2019.
13 Siegel RL, Miller KD, Jemal A. Cancer statistics, 2018. CA Cancer J Clin. 2018 Jan;68(1):7–30. doi: 10.3322/caac.21442. PMID: 29313949.29313949
14 National Cancer Institute. Cancer Stat Facts: Female breast cancer. National Institute of Health; 2018. https://seer.cancer.gov/statfacts/html/breast.html. Accessed May 16 2019.
15 American Cancer Society. Cancer Facts & Figures 2018. Atlanta: American Cancer Society, Inc.; 2018. https://www.cancer.org/content/dam/cancer-org/research/cancer-facts-and-statistics/annual-cancer-facts-and-figures/2018/cancer-facts-and-figures-2018.pdf. Accessed May 16 2019.
16 Anglian Breast Cancer Study Group. Prevalence and penetrance of BRCA1 and BRCA2 mutations in a population-based series of breast cancer cases. Br J Cancer. 2000;83(10):1301–8. PMID: 11044354.11044354
17 Antoniou AC, Gayther SA, Stratton JF, . Risk models for familial ovarian and breast cancer. Genet Epidemiol. 2000 Feb;18(2):173–90. doi: 10.1002/(SICI)1098-2272(200002)18:2<173::AID-GEPI6>3.0.CO;2-R. PMID: 10642429.10642429
18 Antoniou AC, Pharoah PD, McMullan G, . A comprehensive model for familial breast cancer incorporating BRCA1, BRCA2 and other genes. Br J Cancer. 2002 Jan 07;86(1):76–83. doi: 10.1038/sj.bjc.6600008. PMID: 11857015.11857015
19 Peto J, Collins N, Barfoot R, . Prevalence of BRCA1 and BRCA2 gene mutations in patients with early-onset breast cancer. J Natl Cancer Inst. 1999 Jun 02;91(11):943–9. PMID: 10359546.10359546
20 Whittemore AS, Gong G, John EM, . Prevalence of BRCA1 mutation carriers among U.S. non-Hispanic Whites. Cancer Epidemiol Biomarkers Prev. 2004 Dec;13(12):2078–83. PMID: 15598764.15598764
21 Neuhausen S, Gilewski T, Norton L, . Recurrent BRCA2 6174delT mutations in Ashkenazi Jewish women affected by breast cancer. Nat Genet. 1996 May;13(1):126–8. doi: 10.1038/ng0596-126. PMID: 8673092.8673092
22 Struewing JP, Hartge P, Wacholder S, . The risk of cancer associated with specific mutations of BRCA1 and BRCA2 among Ashkenazi Jews. N Engl J Med. 1997 May 15;336(20):1401–8. doi: 10.1056/NEJM199705153362001. PMID: 9145676.9145676
23 Roa BB, Boyd AA, Volcik K, . Ashkenazi Jewish population frequencies for common mutations in BRCA1 and BRCA2. Nat Genet. 1996 Oct;14(2):185–7. doi: 10.1038/ng1096-185. PMID: 8841191.8841191
24 Weitzel JN, Lagos V, Blazer KR, . Prevalence of BRCA mutations and founder effect in high-risk Hispanic families. Cancer Epidemiol Biomarkers Prev. 2005 Jul;14(7):1666–71. doi: 10.1158/1055-9965.EPI-05-0072. PMID: 16030099.16030099
25 Weitzel JN, Lagos VI, Herzog JS, . Evidence for common ancestral origin of a recurring BRCA1 genomic rearrangement identified in high-risk Hispanic families. Cancer Epidemiol Biomarkers Prev. 2007 Aug;16(8):1615–20. doi: 10.1158/1055-9965.EPI-07-0198. PMID: 17646271.17646271
26 Mefford HC, Baumbach L, Panguluri RC, . Evidence for a BRCA1 founder mutation in families of West African ancestry. Am J Hum Genet. 1999 Aug;65(2):575–8. doi: 10.1086/302511. PMID: 10417303.10417303
27 Peelen T, van Vliet M, Petrij-Bosch A, . A high proportion of novel mutations in BRCA1 with strong founder effects among Dutch and Belgian hereditary breast and ovarian cancer families. Am J Hum Genet. 1997 May;60(5):1041–9. PMID: 9150151.9150151
28 Arason A, Jonasdottir A, Barkardottir RB, . A population study of mutations and LOH at breast cancer gene loci in tumours from sister pairs: two recurrent mutations seem to account for all BRCA1/BRCA2 linked breast cancer in Iceland. J Med Genet. 1998 Jun;35(6):446–9. PMID: 9643283.9643283
29 Thorlacius S, Olafsdottir G, Tryggvadottir L, . A single BRCA2 mutation in male and female breast cancer families from Iceland with varied cancer phenotypes. Nat Genet. 1996 May;13(1):117–9. doi: 10.1038/ng0596-117. PMID: 8673089.8673089
30 Einbeigi Z, Bergman A, Kindblom LG, . A founder mutation of the BRCA1 gene in Western Sweden associated with a high incidence of breast and ovarian cancer. Eur J Cancer. 2001 Oct;37(15):1904–9. PMID: 11576847.11576847
31 Lakhani SR, Manek S, Penault-Llorca F, . Pathology of ovarian cancers in BRCA1 and BRCA2 carriers. Clin Cancer Res. 2004 Apr 01;10(7):2473–81. PMID: 15073127.15073127
32 Evans DG, Young K, Bulman M, . Probability of BRCA1/2 mutation varies with ovarian histology: results from screening 442 ovarian cancer families. Clin Genet. 2008 Apr;73(4):338–45. doi: 10.1111/j.1399-0004.2008.00974.x. PMID: 18312450.18312450
33 Tonin PN, Maugard CM, Perret C, . A review of histopathological subtypes of ovarian cancer in BRCA-related French Canadian cancer families. Fam Cancer. 2007;6(4):491–7. doi: 10.1007/s10689-007-9152-x. PMID: 17636423.17636423
34 Crum CP, Drapkin R, Kindelberger D, . Lessons from BRCA: the tubal fimbria emerges as an origin for pelvic serous cancer. Clin Med Res. 2007 Mar;5(1):35–44. doi: 10.3121/cmr.2007.702. PMID: 17456833.17456833
35 Bolton KL, Chenevix-Trench G, Goh C, . Association between BRCA1 and BRCA2 mutations and survival in women with invasive epithelial ovarian cancer. JAMA. 2012 Jan 25;307(4):382–90. doi: 10.1001/jama.2012.20. PMID: 22274685.22274685
36 Levine DA, Argenta PA, Yee CJ, . Fallopian tube and primary peritoneal carcinomas associated with BRCA mutations. J Clin Oncol. 2003 Nov 15;21(22):4222–7. doi: 10.1200/JCO.2003.04.131. PMID: 14615451.14615451
37 Mavaddat N, Barrowdale D, Andrulis IL, . Pathology of breast and ovarian cancers among BRCA1 and BRCA2 mutation carriers: results from the Consortium of Investigators of Modifiers of BRCA1/2 (CIMBA). Cancer Epidemiol Biomarkers Prev. 2012 Jan;21(1):134–47. doi: 10.1158/1055-9965.EPI-11-0775. PMID: 22144499.22144499
38 Lindor NM, Greene MH. The concise handbook of family cancer syndromes. Mayo Familial Cancer Program. J Natl Cancer Inst. 1998 Jul 15;90(14):1039–71. PMID: 9672254.9672254
39 National Cancer Institute. PDQ® Breast Cancer Treatment. 2013. http://www.cancer.gov/cancertopics/pdq/treatment/breast/healthprofessional. Accessed May 1 2019.
40 American Society of Clinical Oncology. Li-Fraumeni Syndrome. 2016. http://www.cancer.net/cancer-types/li-fraumeni-syndrome. Accessed May 16 2019.
41 National Cancer Institute. Genetics of Breast and Gynecologic Cancers (PDQ®)–Health Professional Version. U.S. Department of Health and Human Services 2017. http://www.cancer.gov/cancertopics/pdq/treatment/breast/healthprofessional. Accessed May 16 2019.
42 Noone AM, Howlader N, Krapcho M, . (editors). SEER Cancer Statistics Review, 1975-2015. Table 4.17. Cancer of the female breast (invasive). National Cancer Institute. Bethesda, MD; 2018. https://seer.cancer.gov/csr/1975_2015/. Accessed Dec 8 2018.
43 Colditz GA, Willett WC, Hunter DJ, . Family history, age, and risk of breast cancer. Prospective data from the Nurses’ Health Study. JAMA. 1993 Jul 21;270(3):338–43. PMID: 8123079.8123079
44 Johnson N, Lancaster T, Fuller A, . The prevalence of a family history of cancer in general practice. Fam Pract. 1995 Sep;12(3):287–9. PMID: 8536831.8536831
45 Pharoah PD, Day NE, Duffy S, . Family history and the risk of breast cancer: a systematic review and meta-analysis. Int J Cancer. 1997 May 29;71(5):800–9. PMID: 9180149.9180149
46 Slattery ML, Kerber RA. A comprehensive evaluation of family history and breast cancer risk. The Utah Population Database. JAMA. 1993 Oct 06;270(13):1563–8. PMID: 8371466.8371466
47 Yang Q, Khoury MJ, Rodriguez C, . Family history score as a predictor of breast cancer mortality: prospective data from the Cancer Prevention Study II, United States, 1982-1991. Am J Epidemiol. 1998 Apr 01;147(7):652–9. PMID: 9554604.9554604
48 Antoniou A, Pharoah PD, Narod S, . Average risks of breast and ovarian cancer associated with BRCA1 or BRCA2 mutations detected in case series unselected for family history: a combined analysis of 22 studies. Am J Hum Genet. 2003 May;72(5):1117–30. doi: 10.1086/375033. PMID: 12677558.12677558
49 Chen S, Parmigiani G. Meta-analysis of BRCA1 and BRCA2 penetrance. J Clin Oncol. 2007 Apr 10;25(11):1329–33. doi: 10.1200/JCO.2006.09.1066. PMID: 17416853.17416853
50 Stratton JF, Pharoah P, Smith SK, . A systematic review and meta-analysis of family history and risk of ovarian cancer. Br J Obstet Gynaecol. 1998 May;105(5):493–9. PMID: 9637117.9637117
51 Kerber RA, Slattery ML. Comparison of self-reported and database-linked family history of cancer data in a case-control study. Am J Epidemiol. 1997 Aug 1;146(3):244–8. PMID: 9247008.9247008
52 Mai PL, Garceau AO, Graubard BI, . Confirmation of family cancer history reported in a population-based survey. J Natl Cancer Inst. 2011 May 18;103(10):788–97. doi: 10.1093/jnci/djr114. PMID: 21562245.21562245
53 Mouchawar J, Valentine Goins K, Somkin C, . Guidelines for breast and ovarian cancer genetic counseling referral: adoption and implementation in HMOs. Genet Med. 2003 Nov–Dec;5(6):444–50. doi: 10.1097/01.gim.0000093979.08524.86. PMID: 14614396.14614396
54 Hampel H, Bennett RL, Buchanan A, . A practice guideline from the American College of Medical Genetics and Genomics and the National Society of Genetic Counselors: referral indications for cancer predisposition assessment. Genet Med. 2015 Jan;17(1):70–87. doi: 10.1038/gim.2014.147. PMID: 25394175.25394175
55 de Silva D, Gilbert F, Needham G, . Identification of women at high genetic risk of breast cancer through the National Health Service Breast Screening Programme (NHSBSP). J Med Genet. 1995 Nov;32(11):862–6. PMID: 8592328.8592328
56 National Comprehensive Cancer Network. Genetic/Familial High-Risk Assessment: Breast and Ovarian. 2019. http://www.nccn.org/professionals/physician_gls/pdf/genetics_screening.pdf. Accessed May 16 2019.
57 National Breast Cancer Center. Advice about familial aspects of breast cancer and ovarian cancer - A guide for health professionals. Sydney: National Breast Cancer Center; 2000.
58 de Bock GH, Vliet Vlieland TP, Hageman GC, . The assessment of genetic risk of breast cancer: a set of GP guidelines. Fam Pract. 1999 Feb;16(1):71–7. PMID: 10321400.10321400
59 Pichert G SR. Organizing cancer genetics programs: the Swiss model. J Clin Oncol. 2000;18:(21 Suppl):65S–9S. PMID: 11060330.11060330
60 Hampel H SK, Westman JA, . Referral for cancer genetics consultation: a review and compilation of risk assessment criteria. J Med Genet. 2004;41:81–91. PMID: 14757853.14757853
61 National Comprehensive Cancer Network. NCCN Clinical Practice Guidelines in Oncology: Breast cancer screening and diagnosis. 2018. https://www.nccn.org/professionals/physician_gls/pdf/breast-screening.pdf. Accessed May 1 2019.
62 Couch FJ, DeShano ML, Blackwood MA, . BRCA1 mutations in women attending clinics that evaluate the risk of breast cancer. N Engl J Med. 1997 May 15;336(20):1409–15. doi: 10.1056/NEJM199705153362002. PMID: 9145677.9145677
63 Berry DA, Parmigiani G, Sanchez J, . Probability of carrying a mutation of breast-ovarian cancer gene BRCA1 based on family history. J Natl Cancer Inst. 1997 Feb 05;89(3):227–38. PMID: 9017003.9017003
64 Antoniou AC, Cunningham AP, Peto J, . The BOADICEA model of genetic susceptibility to breast and ovarian cancers: updates and extensions. Br J Cancer. 2008 Apr 22;98(8):1457–66. doi: 10.1038/sj.bjc.6604305. PMID: 18349832.18349832
65 Myriad. Myriad PRO BRCA1 and BRCA2 prevalence tables. Salt Lake City, Utah; 2012. http://d1izdzz43r5o67.cloudfront.net/brac/brca-prevalence-tables.pdf. Accessed May 16 2019.
66 Bowen DJ, Burke W, Yasui Y, . Effects of risk counseling on interest in breast cancer genetic testing for lower risk women. Genet Med. 2002 Sep–Oct;4(5):359–65. doi: 10.1097/00125817-200209000-00007. PMID: 12394349.12394349
67 Burke W, Culver JO, Bowen D, . Genetic counseling for women with an intermediate family history of breast cancer. Am J Med Genet. 2000 Feb 28;90(5):361–8. PMID: 10706356.10706356
68 Cull A, Miller H, Porterfield T, . The use of videotaped information in cancer genetic counselling: a randomized evaluation study. Br J Cancer. 1998 Mar;77(5):830–7. PMID: 9514066.9514066
69 Lerman C, Hughes C, Benkendorf JL, . Racial differences in testing motivation and psychological distress following pretest education for BRCA1 gene testing. Cancer Epidemiol Biomarkers Prev. 1999 Apr;8(4 Pt 2):361–7. PMID: 10207641.10207641
70 Lerman C, Narod S, Schulman K, . BRCA1 testing in families with hereditary breast-ovarian cancer. A prospective study of patient decision making and outcomes. JAMA. 1996 Jun 26;275(24):1885–92. PMID: 8648868.8648868
71 Bowen DJ, Burke W, McTiernan A, . Breast cancer risk counseling improves women’s functioning. Patient Educ Couns. 2004 Apr;53(1):79–86. doi: 10.1016/S0738-3991(03)00122-8. PMID: 15062908.15062908
72 American College of Surgeons. Cancer Program Standards 2016. Chicago, IL; 2016. http://www.facs.org/cancer/coc/programstandards2012.html. Accessed May 1 2019.
73 Rahman N, Stratton MR. The genetics of breast cancer susceptibility. Annu Rev Genet. 1998;32:95–121. doi: 10.1146/annurev.genet.32.1.95. PMID: 9928476.9928476
74 Supreme Court of the United States, Association for Molecular Pathology et al. v. Myriad Genetics, Inc., . 133 S. Ct. 2107 (June 13, 2013).
75 Petrucelli N, Daly MB, Pal T. BRCA1- and BRCA2-Associated Hereditary Breast and Ovarian Cancer. 1998 [Updated 2016 Dec 15]. In: Adam MP, Ardinger HH, Pagon RA, Wallace SE, Bean LJH, Stephens K, ., eds. GeneReviews((R)) [Internet]. Seattle, WA: University of Washington, Seattle. GeneReviews is a registered trademark of the University of Washington, Seattle. All rights reserved. Available from: https://www.ncbi.nlm.nih.gov/books/NBK1247/. Accessed May 16 2019.
76 FDA unveils a streamlined path for the authorization of tumor profiling tests alongside its latest product action. U.S. Food & Drug Administration; 2017. https://www.fda.gov/newsevents/newsroom/pressannouncements/ucm585347.htm. Accessed May 16 2019.
77 Richards S, Aziz N, Bale S, . Standards and guidelines for the interpretation of sequence variants: a joint consensus recommendation of the American College of Medical Genetics and Genomics and the Association for Molecular Pathology. Genet Med. 2015 May;17(5):405–24. doi: 10.1038/gim.2015.30. PMID: 25741868.25741868
78 Nelson HD, Fu R, McDonagh M, . Medication Use for the Risk Reduction of Primary Breast Cancer in Women: A Systematic Review for the U.S. Preventive Services Task Force [in press]. Rockville, MD: Agency for Healthcare Research and Quality: 2019.
79 Nelson HD, Fu R, McDonagh M, . Medication use for the risk reduction of primary breast cancer in women: a systematic review for the U.S. Preventive Services Task Force [in press]. JAMA. 2019.
80 Cuzick J, Forbes J, Edwards R, . First results from the International Breast Cancer Intervention Study (IBIS-I): a randomised prevention trial. Lancet. 2002 Sep 14;360(9336):817–24. PMID: 12243915.12243915
81 Powles T, Eeles R, Ashley S, . Interim analysis of the incidence of breast cancer in the Royal Marsden Hospital tamoxifen randomised chemoprevention trial. Lancet. 1998 Jul 11;352(9122):98–101. doi: 10.1016/S0140-6736(98)85012-5. PMID: 9672274.9672274
82 Fisher B, Costantino JP, Wickerham DL, . Tamoxifen for prevention of breast cancer: report of the National Surgical Adjuvant Breast and Bowel Project P-1 Study. J Natl Cancer Inst. 1998 Sep 16;90(18):1371–88. PMID: 9747868.9747868
83 Veronesi U, Maisonneuve P, Costa A, . Prevention of breast cancer with tamoxifen: preliminary findings from the Italian randomised trial among hysterectomised women. Italian Tamoxifen Prevention Study. Lancet. 1998 Jul 11;352(9122):93–7. PMID: 9672273.9672273
84 Grady D, Cauley JA, Geiger MJ, . Reduced incidence of invasive breast cancer with raloxifene among women at increased coronary risk. J Natl Cancer Inst. 2008 Jun 18;100(12):854–61. doi: 10.1093/jnci/djn153. PMID: 18544744.18544744
85 Cummings SR, Eckert S, Krueger KA, . The effect of raloxifene on risk of breast cancer in postmenopausal women: results from the MORE randomized trial. Multiple Outcomes of Raloxifene Evaluation. JAMA. 1999 Jun 16;281(23):2189–97. PMID: 10376571.10376571
86 Goss PE, Ingle JN, Ales-Martinez JE, . Exemestane for breast-cancer prevention in postmenopausal women. N Engl J Med. 2011 Jun 23;364(25):2381–91. doi: 10.1056/NEJMoa1103507. PMID: 21639806.21639806
87 Cuzick J, Sestak I, Forbes JF, . Anastrozole for prevention of breast cancer in high-risk postmenopausal women (IBIS-II): an international, double-blind, randomised placebo-controlled trial. Lancet. 2014 Mar 22;383(9922):1041–8. doi: 10.1016/S0140-6736(13)62292-8. PMID: 24333009.24333009
88 Braithwaite RS, Chlebowski RT, Lau J, . Meta-analysis of vascular and neoplastic events associated with tamoxifen. J Gen Intern Med. 2003 Nov;18(11):937–47. PMID: 14687281.14687281
89 Curtis MG. Comparative tolerability of first-generation selective estrogen receptor modulators in breast cancer treatment and prevention. Drug Saf. 2001;24(14):1039–53. PMID: 11735660.11735660
90 Kauff ND, Satagopan JM, Robson ME, . Risk-reducing salpingo-oophorectomy in women with a BRCA1 or BRCA2 mutation. N Engl J Med. 2002;346(21):1609–15. PMID: 12023992.12023992
91 Tassone F, Cheng S, Gardiner K. Analysis of chromosome 21 yeast artificial chromosome (YAC) clones. Am J Hum Genet. 1992 Dec;51(6):1251–64. PMID: 1463009.1463009
92 Rebbeck TR, Friebel T, Lynch HT, . Bilateral prophylactic mastectomy reduces breast cancer risk in BRCA1 and BRCA2 mutation carriers: the PROSE Study Group. J Clin Oncol. 2004 Mar 15;22(6):1055–62. doi: 10.1200/JCO.2004.04.188. PMID: 14981104.14981104
93 Rebbeck TR, Levin AM, Eisen A, . Breast cancer risk after bilateral prophylactic oophorectomy in BRCA1 mutation carriers. J Natl Cancer Inst. 1999 Sep 01;91(17):1475–9. PMID: 10469748.10469748
94 Wapnir IL, Rabinowitz B, Greco RS. A reappraisal of prophylactic mastectomy. Surg Gynecol Obstet. 1990 Aug;171(2):171–84. PMID: 2200150.2200150
95 Woods JE. Breast reconstruction: current state of the art. Mayo Clin Proc. 1986 Jul;61(7):579–85. PMID: 3713262.3713262
96 Goodnight JE, Jr., Quagliana JM, Morton DL. Failure of subcutaneous mastectomy to prevent the development of breast cancer. J Surg Oncol. 1984 Jul;26(3):198–201. PMID: 6330460.6330460
97 Pennisi VR, Capozzi A. Subcutaneous mastectomy data: a final statistical analysis of 1500 patients. Aesthetic Plast Surg. 1989 Winter;13(1):15–21. PMID: 2728994.2728994
98 Domchek SM, Friebel TM, Singer CF, . Association of risk-reducing surgery in BRCA1 or BRCA2 mutation carriers with cancer risk and mortality. JAMA. 2010 Sep 1;304(9):967–75. PMID: 20810374.20810374
99 Kramer JL, Velazquez IA, Chen BE, . Prophylactic oophorectomy reduces breast cancer penetrance during prospective, long-term follow-up of BRCA1 mutation carriers. J Clin Oncol. 2005 Dec 1;23(34):8629–35. PMID: 16314625.16314625
100 Olson JE, Sellers TA, Iturria SJ, . Bilateral oophorectomy and breast cancer risk reduction among women with a family history. Cancer Epidemiol Biomarkers Prev. 2004;28(5):357–60. PMID: 15542261.15542261
101 American Society of Clinical Oncology. Statement of the American Society of Clinical Oncology: genetic testing for cancer susceptibility, Adopted on February 20, 1996. J Clin Oncol. 1996 May;14(5):1730–6; discussion 7-40. doi: 10.1200/JCO.1996.14.5.1730. PMID: 8622094.8622094
102 Centers for Disease Control and Prevention (CDC). Genetic testing for breast and ovarian cancer susceptibility: evaluating direct-to-consumer marketing-Atlanta, Denver, Raleigh-Durham, and Seattle, 2003. MMWR Morb Mortal Wkly Rep. 2004 Jul 16;53(27):603–6. PMID: 15254451.15254451
103 Myers MF, Chang MH, Jorgensen C, . Genetic testing for susceptibility to breast and ovarian cancer: evaluating the impact of a direct-to-consumer marketing campaign on physicians’ knowledge and practices. Genet Med. 2006 Jun;8(6):361–70. doi: 10.1097/01.gim.0000223544.68475.6c. PMID: 16778598.16778598
104 Lowery JT, Byers T, Axell L, . The impact of direct-to-consumer marketing of cancer genetic testing on women according to their genetic risk. Genet Med. 2008 Dec;10(12):888–94. doi: 10.1097/GIM.0b013e31818de6d7. PMID: 19092441.19092441
105 Mouchawar J, Laurion S, Ritzwoller DP, . Assessing controversial direct-to-consumer advertising for hereditary breast cancer testing: reactions from women and their physicians in a managed care organization. Am J Manag Care. 2005 Oct;11(10):601–8. PMID: 16232001.16232001
106 Mouchawar J, Hensley-Alford S, Laurion S, . Impact of direct-to-consumer advertising for hereditary breast cancer testing on genetic services at a managed care organization: a naturally-occurring experiment. Genet Med. 2005 Mar;7(3):191–7. doi: 10.1097/01.Gim.0000156526.16967.7a. PMID: 15775755.15775755
107 U.S. Preventive Services Task Force. Methods and Processes. 2018. https://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes. Accessed May 1 2019.
108 Nelson HD, Fu R, Goddard K, . Risk assessment, genetic counseling, and genetic testing for BRCA-related cancer: Systematic review to update the U.S. Preventive Services Task Force recommendation Agency for Healthcare Research and Quality. Rockville (MD): 2013. https://www.ncbi.nlm.nih.gov/pubmed/24432435 PMID: 2443243524432435.
109 Nelson HD, Smith ME, Griffin JC, . Use of medications to reduce risk for primary breast cancer: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2013 Apr 16;158(8):604–14. doi: 10.7326/0003-4819-158-8-201304160-00005. PMID: 23588749.23588749
110 Hosmer DW, Lemeshow S. Applied Logistic Regression. 2nd ed. Hoboken, NJ: John Wiley & Sons, Inc.; 2000.
111 Antoniou AC, Hardy R, Walker L, . Predicting the likelihood of carrying a BRCA1 or BRCA2 mutation: validation of BOADICEA, BRCAPRO, IBIS, Myriad and the Manchester scoring system using data from UK genetics clinics. J Med Genet. 2008 Jul;45(7):425–31. PMID: 18413374.18413374
112 Ashton-Prolla P, Giacomazzi J, Schmidt AV, . Development and validation of a simple questionnaire for the identification of hereditary breast cancer in primary care. BMC Cancer. 2009;9:283. PMID: 19682358.19682358
113 Barcenas CH, Hosain GMM, Arun B, . Assessing BRCA carrier probabilities in extended families. J Clin Oncol. 2006 Jan 20;24(3):354–60. PMID: 16421416.16421416
114 Bellcross CA, Lemke AA, Pape LS, . Evaluation of a breast/ovarian cancer genetics referral screening tool in a mammography population. Genet Med. 2009 Nov;11(11):783–9. doi: 10.1097/GIM.0b013e3181b9b04a. PMID: 19752737.19752737
115 Biswas S, Atienza P, Chipman J, . A two-stage approach to genetic risk assessment in primary care. Breast Cancer Res Treat. 2016 Jan;155(2):375–83. doi: 10.1007/s10549-016-3686-2. PMID: 26786860.26786860
116 Evans DG, Eccles DM, Rahman N, . A new scoring system for the chances of identifying a BRCA1/2 mutation outperforms existing models including BRCAPRO. J Med Genet. 2004 Jun;41(6):474–80. PMID: 15173236.15173236
117 Fischer C, Kuchenbacker K, Engel C, . Evaluating the performance of the breast cancer genetic risk models BOADICEA, IBIS, BRCAPRO and Claus for predicting BRCA1/2 mutation carrier probabilities: a study based on 7352 families from the German Hereditary Breast and Ovarian Cancer Consortium. J Med Genet. 2013 Jun;50(6):360–7. doi: 10.1136/jmedgenet-2012-101415. PMID: 23564750.23564750
118 Gilpin CA, Carson N, Hunter AG. A preliminary validation of a family history assessment form to select women at risk for breast or ovarian cancer for referral to a genetics center. Clin Genet. 2000 Oct;58(4):299–308. PMID: 11076055.11076055
119 Hoskins KF, Zwaagstra A, Ranz M. Validation of a tool for identifying women at high risk for hereditary breast cancer in population-based screening. Cancer. 2006 Oct 15;107(8):1769–76. PMID: 16967460.16967460
120 Kast K, Schmutzler RK, Rhiem K, . Validation of the Manchester scoring system for predicting BRCA1/2 mutations in 9,390 families suspected of having hereditary breast and ovarian cancer. Int J Cancer. 2014 Nov 15;135(10):2352–61. doi: 10.1002/ijc.28875. PMID: 24700448.24700448
121 Oros KK, Ghadirian P, Maugard CM, . Application of BRCA1 and BRCA2 mutation carrier prediction models in breast and/or ovarian cancer families of French Canadian descent. Clin Genet. 2006 Oct;70(4):320–9. PMID: 16965326.16965326
122 Panchal SM, Ennis M, Canon S, . Selecting a BRCA risk assessment model for use in a familial cancer clinic. BMC Med Genet. 2008;9:116. PMID: 19102775.19102775
123 Parmigiani G, Chen S, Iversen ES, Jr., . Validity of models for predicting BRCA1 and BRCA2 mutations. Ann Intern Med. 2007 Oct 02;147(7):441–50. PMID: 17909205.17909205
124 Teller P, Hoskins KF, Zwaagstra A, . Validation of the Pedigree Assessment Tool (PAT) in families with BRCA1 and BRCA2 mutations. Ann Surg Oncol. 2010 Jan;17(1):240–6. PMID: 19763692.19763692
125 Albada A, van Dulmen S, Dijkstra H, . Counselees’ expressed level of understanding of the risk estimate and surveillance recommendation are not associated with breast cancer surveillance adherence. J Genet Couns. 2016 Apr;25(2):279–89. doi: 10.1007/s10897-015-9869-x. PMID: 26321750.26321750
126 Armstrong K, Micco E, Carney A, . Racial differences in the use of BRCA1/2 testing among women with a family history of breast or ovarian cancer. JAMA. 2005 Apr 13;293(14):1729–36. PMID: 15827311.15827311
127 Bennett P, Wilkinson C, Turner J, . Psychological factors associated with emotional responses to receiving genetic risk information. J Genet Couns. 2008 Jun;17(3):234–41. PMID: 18259848.18259848
128 Bennett P, Wilkinson C, Turner J, . Factors associated with intrusive cancer-related worries in women undergoing cancer genetic risk assessment. Fam Cancer. 2009;8(2):159–65. PMID: 19011994.19011994
129 Bloom JR, Stewart SL, Chang S, . Effects of a telephone counseling intervention on sisters of young women with breast cancer. Prev Med. 2006 Nov;43(5):379–84. PMID: 16916540.16916540
130 Bowen DJ, Burke W, Culver JO, . Effects of counseling Ashkenazi Jewish women about breast cancer risk. Cultur Divers Ethnic Minor Psychol. 2006 Jan;12(1):45–56. PMID: 16594854.16594854
131 Brain K, Norman P, Gray J, . A randomized trial of specialist genetic assessment: psychological impact on women at different levels of familial breast cancer risk. Br J Cancer. 2002 Original Search 6-20-03;86(2):233–8. PMID: 11870512.11870512
132 Brain K, Parsons E, Bennett P, . The evolution of worry after breast cancer risk assessment: 6-year follow-up of the TRACE study cohort. Psychooncology. 2011 Sep;20(9):984–91. PMID: 20677331.20677331
133 Braithwaite D, Sutton S, Mackay J, . Development of a risk assessment tool for women with a family history of breast cancer. Cancer Detect Prev. 2005;29(5):433–9. PMID: 16055276.16055276
134 Fry A, Cull A, Appleton S, . A randomised controlled trial of breast cancer genetics services in South East Scotland: Psychological impact. Br J Cancer. 2003;89(4):653–9. PMID: 12915873.12915873
135 Gurmankin AD, Domchek S, Stopfer J, . Patients’ resistance to risk information in genetic counseling for BRCA1/2. Arch Intern Med. 2005 Mar 14;165(5):523–9. PMID: 15767527.15767527
136 Helmes AW, Culver JO, Bowen DJ. Results of a randomized study of telephone versus in-person breast cancer risk counseling. Patient Educ Couns. 2006 Dec;64(1–3):96–103. PMID: 16427245.16427245
137 Hopwood P, Keeling F, Long A, . Psychological support needs for women at high genetic risk of breast cancer: some preliminary indicators. Psychooncology. 1998 Original Search 6-20-03;7(5):402–12. PMID: 9809331.9809331
138 Hopwood P, Wonderling D, Watson M, . A randomised comparison of UK genetic risk counselling services for familial cancer: psychosocial outcomes. Br J Cancer. 2004 Aug 31;91(5):884–92. PMID: 15305197.15305197
139 Kelly KM, Senter L, Leventhal H, . Subjective and objective risk of ovarian cancer in Ashkenazi Jewish women testing for BRCA1/2 mutations. Patient Educ Couns. 2008 Jan;70(1):135–42. PMID: 17988821.17988821
140 Lerman C, Schwartz MD, Miller SM, . A randomized trial of breast cancer risk counseling: interacting effects of counseling, educational level, and coping style. Health Psychol. 1996;15(2):75–83. PMID: 8681923.8681923
141 Lobb EA, Butow PN, Barratt A, . Communication and information-giving in high-risk breast cancer consultations: influence on patient outcomes. Br J Cancer. 2004;90(2):321–7. PMID: 14735171.14735171
142 Matloff ET, Moyer A, Shannon KM, . Healthy women with a family history of breast cancer: impact of a tailored genetic counseling intervention on risk perception, knowledge, and menopausal therapy decision making. J Womens Health. 2006 Sep;15(7):843–56. PMID: 16999640.16999640
143 Mikkelsen EM, Sunde L, Johansen C, . Risk perception among women receiving genetic counseling: a population-based follow-up study. Cancer Epidemiol Biomarkers Prev. 2007;31(6):457–64. PMID: 18061369.18061369
144 Mikkelsen EM, Sunde L, Johansen C, . Psychosocial consequences of genetic counseling: a population-based follow-up study. Breast J. 2009 Jan–Feb;15(1):61–8. PMID: 19120380.19120380
145 Pieterse AH, Ausems MG, Spreeuwenberg P, . Longer-term influence of breast cancer genetic counseling on cognitions and distress: Smaller benefits for affected versus unaffected women. Patient Educ Couns. 2011 Dec;85(3):425–31. doi: 10.1016/j.pec.2011.01.017. PMID: 21316181.21316181
146 Roshanai AH, Rosenquist R, Lampic C, . Does enhanced information at cancer genetic counseling improve counselees’ knowledge, risk perception, satisfaction and negotiation of information to at-risk relatives?-a randomized study. Acta Oncol. 2009;48(7):999–1009. PMID: 19636983.19636983
147 Smerecnik CMR, Mesters I, Verweij E, . A systematic review of the impact of genetic counseling on risk perception accuracy. J Genet Couns. 2009;18(3):217–28. PMID: 19291376.19291376
148 Watson M, Duvivier V, Wade Walsh M, . Family history of breast cancer: what do women understand and recall about their genetic risk? J Med Genet. 1998;35(9):731–8. PMID: 9733031.9733031
149 Watson M, Lloyd S, Davidson J, . The impact of genetic counselling on risk perception and mental health in women with a family history of breast cancer. Br J Cancer. 1999;79(5–6):868–74. PMID: 10070883.10070883
150 Andrews L, Meiser B, Apicella C, . Psychological impact of genetic testing for breast cancer susceptibility in women of Ashkenazi Jewish background: a prospective study. Genetic Testing. 2004;8(3):240–7. PMID: 15727246.15727246
151 Arver B, Haegermark A, Platten U, . Evaluation of psychosocial effects of pre-symptomatic testing for breast/ovarian and colon cancer pre-disposing genes: a 12-month follow-up. Fam Cancer. 2004;3(2):109–16. PMID: 15340261.15340261
152 Dagan E, Shochat T. Quality of life in asymptomatic BRCA1/2 mutation carriers. Prev Med. 2009 Feb;48(2):193–6. PMID: 19084553.19084553
153 Ertmanski S, Metcalfe K, Trempala J, . Identification of patients at high risk of psychological distress after BRCA1 genetic testing. Genet Test Mol Biomarkers. 2009 Jun;13(3):325–30. PMID: 19405874.19405874
154 Foster C, Watson M, Eeles R, . Predictive genetic testing for BRCA1/2 in a UK clinical cohort: three-year follow-up. Br J Cancer. 2007 Mar 12;96(5):718–24. PMID: 17285126.17285126
155 Geirdal AO, Dahl AA. The relationship between coping strategies and anxiety in women from families with familial breast-ovarian cancer in the absence of demonstrated mutations. Psychooncology. 2008 Jan;17(1):49–57. PMID: 17385192.17385192
156 Geirdal AO, Reichelt JG, Dahl AA, . Psychological distress in women at risk of hereditary breast/ovarian or HNPCC cancers in the absence of demonstrated mutations. Fam Cancer. 2005;4(2):121–6. PMID: 15951962.15951962
157 Godard B, Pratte A, Dumont M, . Factors associated with an individual’s decision to withdraw from genetic testing for breast and ovarian cancer susceptibility: implications for counseling. Genetic Testing. 2007;11(1):45–54. PMID: 17394392.17394392
158 Graves KD, Vegella P, Poggi EA, . Long-term psychosocial outcomes of BRCA1/BRCA2 testing: differences across affected status and risk-reducing surgery choice. Cancer Epidemiol Biomarkers Prev. 2012 Mar;21(3):445–55. PMID: 22328347.22328347
159 Julian-Reynier C, Mancini J, Mouret-Fourme E, . Cancer risk management strategies and perceptions of unaffected women 5 years after predictive genetic testing for BRCA1/2 mutations. Eur J Hum Genet. 2011 May;19(5):500–6. PMID: 21267012.21267012
160 Kinney AY, Bloor LE, Mandal D, . The impact of receiving genetic test results on general and cancer-specific psychologic distress among members of an African-American kindred with a BRCA1 mutation. Cancer. 2005 Dec 1;104(11):2508–16. PMID: 16222692.16222692
161 Lieberman S, Tomer A, Ben-Chetrit A, . Population screening for BRCA1/BRCA2 founder mutations in Ashkenazi Jews: proactive recruitment compared with self-referral. Genet Med. 2017 Jul;19(7):754–62. doi: 10.1038/gim.2016.182. PMID: 27929526.27929526
162 Low CA, Bower JE, Kwan L, . Benefit finding in response to BRCA1/2 testing. Ann Beh Med. 2008 Feb;35(1):61–9. PMID: 18347905.18347905
163 Lumish HS, Steinfeld H, Koval C, . Impact of panel gene testing for hereditary breast and ovarian cancer on patients. J Genet Couns. 2017 Oct;26(5):1116–29. doi: 10.1007/s10897-017-0090-y. PMID: 28357778.28357778
164 Manchanda R, Loggenberg K, Sanderson S, . Population testing for cancer predisposing BRCA1/BRCA2 mutations in the Ashkenazi-Jewish community: a randomized controlled trial. J Natl Cancer Inst. 2015 Jan;107(1):379. doi: 10.1093/jnci/dju379. PMID: 25435541.25435541
165 Meiser B, Butow P, Friedlander M, . Psychological impact of genetic testing in women from high-risk breast cancer families. Eur J Cancer. 2002;38(15):2025–31. PMID: 12376208.12376208
166 Metcalfe KA, Mian N, Enmore M, . Long-term follow-up of Jewish women with a BRCA1 and BRCA2 mutation who underwent population genetic screening. Breast Cancer Res Treat. 2012;133(2):735–40. PMID: 22240989.22240989
167 Reichelt JG, Heimdal K, Møller P, . BRCA1 testing with definitive results: A prospective study of psychological distress in a large clinic-based sample. Fam Cancer. 2004;3(1):21–8. PMID: 15131402.15131402
168 Reichelt JG, Moller P, Heimdal K, . Psychological and cancer-specific distress at 18 months post-testing in women with demonstrated BRCA1 mutations for hereditary breast/ovarian cancer. Fam Cancer. 2008;7(3):245–54. PMID: 18219587.18219587
169 Shochat T, Dagan E. Sleep disturbances in asymptomatic BRCA1/2 mutation carriers: women at high risk for breast-ovarian cancer. J Sleep Res. 2010 Jun;19(2):333–40. PMID: 20337906.20337906
170 Smith KR, West JA, Croyle RT, . Familial context of genetic testing for cancer susceptibility: Moderating effect of siblings’ test results on psychological distress one to two weeks after BRCA1 mutation testing. Cancer Epidemiol Biomarkers Prev. 1999;8(4 II):385–92. PMID: 10207644.10207644
171 van Dijk S, Timmermans DRM, Meijers-Heijboer H, . Clinical characteristics affect the impact of an uninformative DNA test result: the course of worry and distress experienced by women who apply for genetic testing for breast cancer. J Clin Oncol. 2006 Aug 1;24(22):3672–7. PMID: 16877736.16877736
172 van Oostrom I, Meijers-Heijboer H, Lodder LN, . Long-term psychological impact of carrying a BRCA1/2 mutation and prophylactic surgery: a 5-year follow-up study. J Clin Oncol. 2003 Oct 15;21(20):3867–74. doi: 10.1200/jco.2003.10.100. PMID: 14551306.14551306
173 Evans DGR, Baildam AD, Anderson E, . Risk reducing mastectomy: outcomes in 10 European centres. J Med Genet. 2009 Apr;46(4):254–8. PMID: 18996907.18996907
174 Flippo-Morton T, Walsh K, Chambers K, . Surgical decision making in the BRCA-positive population: institutional experience and comparison with recent literature. Breast J. 2016 Jan–Feb;22(1):35–44. doi: 10.1111/tbj.12521. PMID: 26695813.26695813
175 Hartmann LC, Schaid DJ, Woods JE, . Efficacy of bilateral prophylactic mastectomy in women with a family history of breast cancer. N Engl J Med. 1999 Original Search 6-20-03;340(2):77–84. PMID: 9887158.9887158
176 Hartmann LC, Sellers TA, Schaid DJ, . Efficacy of bilateral prophylactic mastectomy in BRCA1 and BRCA2 gene mutation carriers. J Natl Cancer Inst. 2001 Original Search 6-20-03;93(21):1633–7. PMID: 11698567.11698567
177 Heemskerk-Gerritsen BA, Menke-Pluijmers MB, Jager A, . Substantial breast cancer risk reduction and potential survival benefit after bilateral mastectomy when compared with surveillance in healthy BRCA1 and BRCA2 mutation carriers: a prospective analysis. Ann Oncol. 2013 Aug;24(8):2029–35. doi: 10.1093/annonc/mdt134. PMID: 23576707.23576707
178 Heemskerk-Gerritsen BA, Seynaeve C, van Asperen CJ, . Breast cancer risk after salpingo-oophorectomy in healthy BRCA1/2 mutation carriers: revisiting the evidence for risk reduction. J Natl Cancer Inst. 2015 May;107(5)doi: 10.1093/jnci/djv033. PMID: 25788320.25788320
179 Kotsopoulos J, Huzarski T, Gronwald J, . Bilateral oophorectomy and breast cancer risk in BRCA1 and BRCA2 mutation carriers. J Natl Cancer Inst. 2017 Jan;109(1)doi: 10.1093/jnci/djw177. PMID: 27601060.27601060
180 Mavaddat N, Peock S, Frost D, . Cancer risks for BRCA1 and BRCA2 mutation carriers: results from prospective analysis of EMBRACE. J Natl Cancer Inst. 2013 Jun 5;105(11):812–22. doi: 10.1093/jnci/djt095. PMID: 23628597.23628597
181 Rebbeck TR, Lynch HT, Neuhausen SL, . Prophylactic oophorectomy in carriers of BRCA1 or BRCA2 mutations. N Engl J Med. 2002;346(21):1616–22. doi: 10.1056/NEJMoa012158. PMID: 12023993.12023993
182 Shah P, Rosen M, Stopfer J, . Prospective study of breast MRI in BRCA1 and BRCA2 mutation carriers: effect of mutation status on cancer incidence. Breast Cancer Res Treat. 2009 Dec;118(3):539–46. PMID: 19609668.19609668
183 Skytte AB, Cruger D, Gerster M, . Breast cancer after bilateral risk-reducing mastectomy. Clin Genet. 2011 May;79(5):431–7. doi: 10.1111/j.1399-0004.2010.01604.x. PMID: 21199491.21199491
184 Struewing JP, Watson P, Easton DF, . Prophylactic oophorectomy in inherited breast/ovarian cancer families. J Natl Cancer Inst Monogr. 1995(17):33–5. PMID: 8573450.8573450
185 Alamouti R, Hachach-Haram N, Farhadi J. Multidisciplinary management of risk-reducing mastectomy and immediate reconstruction: treatment algorithm and patient satisfaction. Eur J Plast Surg. 2015;38(5):385–90. doi: 10.1007/s00238-015-1086-1.
186 Arver B, Isaksson K, Atterhem H, . Bilateral prophylactic mastectomy in Swedish women at high risk of breast cancer: a national survey. Ann Surg. 2011 Jun;253(6):1147–54. PMID: 21587115.21587115
187 Borreani C, Manoukian S, Bianchi E, . The psychological impact of breast and ovarian cancer preventive options in BRCA1 and BRCA2 mutation carriers. Clin Genet. 2014 Jan;85(1):7–15. doi: 10.1111/cge.12298. PMID: 24117034.24117034
188 Bourne T, Campell S, Reynolds K. Screening for early familial ovarian cancer with transvaginal ultra sonography and colour blood flow imaging. BMJ. 1993;306(3884):1025–29. PMID: 8490496.8490496
189 Brandberg Y, Arver B, Johansson H, . Less correspondence between expectations before and cosmetic results after risk-reducing mastectomy in women who are mutation carriers: a prospective study. Eur J Surg Oncol. 2012 Jan;38(1):38–43. PMID: 22032910.22032910
190 Brandberg Y, Sandelin K, Erikson S, . Psychological reactions, quality of life, and body image after bilateral prophylactic mastectomy in women at high risk for breast cancer: a prospective 1-year follow-up study. J Clin Oncol. 2008 Aug 20;26(24):3943–9. PMID: 18711183.18711183
191 Bresser PJC, Seynaeve C, Van Gool AR, . The course of distress in women at increased risk of breast and ovarian cancer due to an (identified) genetic susceptibility who opt for prophylactic mastectomy and/or salpingo-oophorectomy. Eur J Cancer. 2007 Jan;43(1):95–103. PMID: 17095208.17095208
192 den Heijer M, Seynaeve C, Timman R, . Body image and psychological distress after prophylactic mastectomy and breast reconstruction in genetically predisposed women: a prospective long-term follow-up study. Eur J Cancer. 2012 Jun;48(9):1263–8. PMID: 22105017.22105017
193 den Heijer M, Seynaeve C, Vanheusden K, . Long-term psychological distress in women at risk for hereditary breast cancer adhering to regular surveillance: a risk profile. Psychooncology. 2013 Mar;22(3):598–604. doi: 10.1002/pon.3039. PMID: 22315183.22315183
194 Finch A, Metcalfe KA, Chiang JK, . The impact of prophylactic salpingo-oophorectomy on menopausal symptoms and sexual function in women who carry a BRCA mutation. Gynecol Oncol. 2011 Apr;121(1):163–8. PMID: 21216453.21216453
195 Gahm J, Wickman M, Brandberg Y. Bilateral prophylactic mastectomy in women with inherited risk of breast cancer-prevalence of pain and discomfort, impact on sexuality, quality of life and feelings of regret two years after surgery. Breast. 2010 Dec;19(6):462–9. PMID: 20605453.20605453
196 Gopie JP, Mureau MA, Seynaeve C, . Body image issues after bilateral prophylactic mastectomy with breast reconstruction in healthy women at risk for hereditary breast cancer. Fam Cancer. 2013 Sep;12(3):479–87. doi: 10.1007/s10689-012-9588-5. PMID: 23224779.23224779
197 Heemskerk-Gerritsen BAM, Brekelmans CTM, Menke-Pluymers MBE, . Prophylactic mastectomy in BRCA1/2 mutation carriers and women at risk of hereditary breast cancer: long-term experiences at the Rotterdam Family Cancer Clinic. Ann Surg Oncol. 2007 Dec;14(12):3335–44. PMID: 17541692.17541692
198 Hermsen BBJ, Olivier RI, Verheijen RHM, . No efficacy of annual gynaecological screening in BRCA1/2 mutation carriers; an observational follow-up study. Br J Cancer. 2007;96:1335–42. PMID: 17426707.17426707
199 Isern AE, Tengrup I, Loman N, . Aesthetic outcome, patient satisfaction, and health-related quality of life in women at high risk undergoing prophylactic mastectomy and immediate breast reconstruction. J Plast Reconstr Aesthet Surg. 2008 Oct;61(10):1177–87. PMID: 17938010.17938010
200 Kenkhuis MJA, de Bock GH, Elferink PO, . Short-term surgical outcome and safety of risk reducing salpingo-oophorectomy in BRCA1/2 mutation carriers. Maturitas. 2010 Jul;66(3):310–4. PMID: 20409655.20409655
201 Kriege M, Brekelmans CTM, Boetes C, . Efficacy of MRI and mammography for breast-cancer screening in women with a familial or genetic predisposition. N Engl J Med. 2004;351(5):427–37+519. PMID: 15282350.15282350
202 Kriege M, Brekelmans CTM, Boetes C, . Differences between first and subsequent rounds of the MRISC breast cancer screening program for women with a familial or genetic predisposition. Cancer. 2006;106(11):2318–26. PMID: 16615112.16615112
203 Leach MO. Screening with magnetic resonance imaging and mammography of a UK population at high familial risk of breast cancer: A prospective multicentre cohort study (MARIBS). Lancet. 2005;365(9473):1769–78. PMID: 15910949.15910949
204 Le-Petross HT, Whitman GJ, Atchley DP, . Effectiveness of alternating mammography and magnetic resonance imaging for screening women with deleterious BRCA mutations at high risk of breast cancer. Cancer. 2011 Sep;117(17):3900–7. doi: 10.1002/cncr.25971. PMID: 21365619.21365619
205 Metcalfe KA, Esplen MJ, Goel V, . Psychosocial functioning in women who have undergone bilateral prophylactic mastectomy. Psychooncology. 2004;13(1):14–25. PMID: 14745742.14745742
206 Michelsen TM, Dorum A, Trope CG, . Fatigue and quality of life after risk-reducing salpingo-oophorectomy in women at increased risk for hereditary breast-ovarian cancer. Int J Gynecol Cancer. 2009 Aug;19(6):1029–36. PMID: 19820364.19820364
207 Nurudeen S, Guo H, Chun Y, . Patient experience with breast reconstruction process following bilateral mastectomy in BRCA mutation carriers. Am J Surg. 2017 Oct;214(4):687–94. doi: 10.1016/j.amjsurg.2017.06.017. PMID: 28683895.28683895
208 Portnoy DB, Loud JT, Han PK, . Effects of false-positive cancer screenings and cancer worry on risk-reducing surgery among BRCA1/2 carriers. Health Psychol. 2015 Jul;34(7):709–17. doi: 10.1037/hea0000156. PMID: 25243716.25243716
209 Rijnsburger AJ, Essink-Bot ML, Van Dooren S, . Impact of screening for breast cancer in high-risk women on health-related quality of life. Br J Cancer. 2004;91(1):69–76. PMID: 15199386.15199386
210 Spiegel TN, Esplen MJ, Hill KA, . Psychological impact of recall on women with BRCA mutations undergoing MRI surveillance. Breast. 2011 Oct;20(5):424–30. PMID: 21612928.21612928
211 Stefanek ME, Helzlsouer KJ, Wilcox PM, . Predictors of and satisfaction with bilateral prophylactic mastectomy. Prev Med. 1995 Jul;24(4):412–9. doi: 10.1006/pmed.1995.1066. PMID: 7479633.7479633
212 Wasteson E, Sandelin K, Brandberg Y, . High satisfaction rate ten years after bilateral prophylactic mastectomy- a longitudinal study. Eur J Cancer Care (Engl). 2011 Jul;20(4):508–13. doi: 10.1111/j.1365-2354.2010.01204.x. PMID: 20597955.20597955
213 Nelson HD, Pappas M, Zakher B, . Risk assessment, genetic counseling, and genetic testing for BRCA-related cancer in women: a systematic review to update the U.S. Preventive Services Task Force recommendation. Ann Intern Med. 2014 Feb 18;160(4):255–66. doi: 10.7326/M13-1684. PMID: 24366442.24366442
214 Bellcross C. Further development and evaluation of a breast/ovarian cancer genetics referral screening tool. Genet Med. 2010 Apr;12(4):240. doi: 10.1097/GIM.0b013e3181d4bc3a. PMID: 20395744.20395744
215 Vreemann S, Gubern-Merida A, Schlooz-Vries MS, . Influence of risk category and screening round on the performance of an MR imaging and mammography screening program in carriers of the BRCA mutation and other women at increased risk. Radiology. 2018 02;286(2):443–51. doi: 10.1148/radiol.2017170458. PMID: 29040037.29040037
216 Rosenthal AN, Fraser L, Manchanda R, . Results of annual screening in phase I of the United Kingdom familial ovarian cancer screening study highlight the need for strict adherence to screening schedule. J Clin Oncol. 2013;31(1):49. PMID: 23213100.23213100
217 Rosenthal AN, Fraser LSM, Philpott S, . Evidence of stage shift in women diagnosed with ovarian cancer during Phase II of the United Kingdom Familial Ovarian Cancer Screening Study. J Clin Oncol. 2017 May 1;35(13):1411–20. doi: 10.1200/jco.2016.69.9330. PMID: 28240969.28240969
218 Cortesi L, Turchetti D, Marchi I, . Breast cancer screening in women at increased risk according to different family histories: an update of the Modena Study Group experience. BMC Cancer. 2006;6:210. PMID: 16916448.16916448
219 Rijnsburger AJ, Obdeijn IM, Kaas R, . BRCA1-associated breast cancers present differently from BRCA2-associated and familial cases: long-term follow-up of the Dutch MRISC screening study. J Clin Oncol. 2010;28(36):5265–73. PMID: 21079137.21079137
220 King MC, Wieand S, Hale K, . Tamoxifen and breast cancer incidence among women with inherited mutations in BRCA1 and BRCA2: National Surgical Adjuvant Breast and Bowel Project (NSABP-P1) Breast Cancer Prevention Trial. JAMA. 2001 Nov 14;286(18):2251–6. PMID: 11710890.11710890
221 Fisher B, Costantino JP, Wickerham DL, . Tamoxifen for the prevention of breast cancer: current status of the National Surgical Adjuvant Breast and Bowel Project P-1 study. J Natl Cancer Inst. 2005;97(22):1652–62. PMID: 16288118.16288118
222 Powles TJ, Ashley S, Tidy A, . Twenty-year follow-up of the Royal Marsden randomized, double-blinded tamoxifen breast cancer prevention trial. J Natl Cancer Inst. 2007 Feb;99(4):283–90. PMID: 17312305.17312305
223 Veronesi U, Maisonneuve P, Rotmensz N, . Tamoxifen for the prevention of breast cancer: late results of the Italian randomized tamoxifen prevention trial among women with hysterectomy. J Natl Cancer Inst. 2007;99(9):727–37. PMID: 17470740.17470740
224 Cuzick J, Forbes JF, Sestak I, . Long-term results of tamoxifen prophylaxis for breast cancer—96-month follow-up of the randomized IBIS-I trial. J Natl Cancer Inst. 2007 February 21, 2007;99(4):272–82. doi: 10.1093/jnci/djk049. PMID: 17312304.17312304
225 Lippman ME, Cummings SR, Disch DP, . Effect of raloxifene on the incidence of invasive breast cancer in postmenopausal women with osteoporosis categorized by breast cancer risk. Clin Cancer Res. 2006;12(17):5242–7. PMID: 16951244.16951244
226 Vogel VG, Costantino JP, Wickerham DL, . Update of the National Surgical Adjuvant Breast and Bowel Project Study of Tamoxifen and Raloxifene (STAR) P-2 Trial: preventing breast cancer. Cancer Prev Res. 2010 Jun;3(6):696–706. PMID: 20404000.20404000
227 Cuzick J, Sestak I, Cawthorn S, . Tamoxifen for prevention of breast cancer: extended long-term follow-up of the IBIS-I breast cancer prevention trial. Lancet Oncol. 2015 Jan;16(1):67–75. doi: 10.1016/S1470-2045(14)71171-4. PMID: 25497694.25497694
228 Sestak I, Singh S, Cuzick J, . Changes in bone mineral density at 3 years in postmenopausal women receiving anastrozole and risedronate in the IBIS-II bone substudy: an international, double-blind, randomised, placebo-controlled trial.[Erratum appears in Lancet Oncol. 2014 Dec;15(13):e587]. Lancet Oncol. 2014 Dec;15(13):1460–8. doi: 10.1016/S1470-2045(14)71035-6. PMID: 25456365.25456365
229 Spagnolo F, Sestak I, Howell A, . Anastrozole-induced carpal tunnel syndrome: Results from the international breast cancer intervention study II prevention trial. J Clin Oncol. 2016 Jan 10;34(2):139–43. doi: 10.1200/JCO.2015.63.4972. PMID: 26598748.26598748
230 Maunsell E, Goss PE, Chlebowski RT, . Quality of life in MAP.3 (Mammary Prevention 3): a randomized, placebo-controlled trial evaluating exemestane for prevention of breast cancer. J Clin Oncol. 2014 May 10;32(14):1427–36. doi: 10.1200/JCO.2013.51.2483. PMID: 24711552.24711552
231 Barrett-Connor E, Mosca L, Collins P, . Effects of raloxifene on cardiovascular events and breast cancer in postmenopausal women. N Engl J Med. 2006;355(2):125–37. PMID: 16837676.16837676
232 van der Groep P, van der Wall E, van Diest P. Pathology of hereditary breast cancer. Cell Oncol (Dordr). 2011;34(2):71–88. PMID: 21336636.21336636
233 Ripperger T, Gadzicki D, Meindl A, . Breast cancer susceptibility: current knowledge and implications for genetic counselling. Eur J Hum Genet. 2009;17(6):722–31. doi: 10.1038/ejhg.2008.212. PMID: 19092773.19092773
234 Peng S, Lü B, Ruan W, . Genetic polymorphisms and breast cancer risk: evidence from meta-analyses, pooled analyses, and genome-wide association studies. Breast Cancer Res Treat. 2011;127(2):309–24. doi: 10.1007/s10549-011-1459-5. PMID: 21445572.21445572
235 Fanale D, Amodeo V, Corsini LR, . Breast cancer genome-wide association studies: there is strength in numbers. Oncogene. 2012 Apr 26;31(17):2121–8. doi: 10.1038/onc.2011.408. PMID: 21996731.21996731
236 Rosenthal ET, Evans B, Kidd J, . Increased Identification of Candidates for High-Risk Breast Cancer Screening Through Expanded Genetic Testing. J Am Coll Radiol. 2017 Apr;14(4):561–8. doi: 10.1016/j.jacr.2016.10.003. PMID: 28011157.28011157
237 Forbes JF, Sestak I, Howell A, . Anastrozole versus tamoxifen for the prevention of locoregional and contralateral breast cancer in postmenopausal women with locally excised ductal carcinoma in situ (IBIS-II DCIS): a double-blind, randomised controlled trial. Lancet. 2016 Feb 27;387(10021):866–73. doi: 10.1016/S0140-6736(15)01129-0. PMID: 26686313.26686313
238 Aromatase inhibitors versus tamoxifen in early breast cancer: patient-level meta-analysis of the randomised trials. Lancet. 2015 Oct 3;386(10001):1341–52. doi: 10.1016/s0140-6736(15)61074-1. PMID: 26211827.26211827
239 Goldvaser H, Barnes TA, Seruga B, . Toxicity of Extended Adjuvant Therapy With Aromatase Inhibitors in Early Breast Cancer: A Systematic Review and Meta-analysis. J Natl Cancer Inst. 2018 Jan 01;110(1)doi: 10.1093/jnci/djx141. PMID: 28922781.28922781
240 Sacca RE, Koeller DR, Rana HQ, . Trans-counseling: A case series of transgender individuals at high risk for BRCA1 pathogenic variants. J Genet Couns. 2019 Jan 24;28(3):708–16. doi: 10.1002/jgc4.1046. PMID: 30680866.30680866
241 Zayhowski K, Park J, Boehmer U, . Cancer genetic counselors’ experiences with transgender patients: A qualitative study. J Genet Couns. 2019;28(3):641–53. doi: 10.1002/jgc4.1092. PMID: 30720922.30720922
242 Buys SS, Partridge E, Black A, . Effect of screening on ovarian cancer mortality: The Prostate, Lung, Colorectal and Ovarian (PLCO) cancer screening randomized controlled trial. JAMA. 2011;305(22):2295–302. PMID: 21642681.21642681
243 Andresen EM, Catlin TK, Wyrwich KW, . Retest reliability of surveillance questions on health related quality of life. J Epidemiol Community Health. 2003 May;57(5):339–43. PMID: 12700216.12700216
244 Bados A, Gomez-Benito J, Balaguer G. The state-trait anxiety inventory, trait version: does it really measure anxiety? J Pers Assess. 2010 Nov;92(6):560–7. doi: 10.1080/00223891.2010.513295. PMID: 20954057.20954057
245 Bates GW, Trajstman SEA, Jackson CA. Internal consistency, Ttst-retest reliability and sex differences on the Posttraumatic Growth Inventory in an Australian sample with trauma. Psychol Rep. 2004 2004/06/01;94(3):793–4. doi: 10.2466/pr0.94.3.793-794. PMID: 15217029.15217029
246 Baxter NN, Goodwin PJ, McLeod RS, . Reliability and validity of the body image after breast cancer questionnaire. Breast J. 2006 May–Jun;12(3):221–32. doi: 10.1111/j.1075-122X.2006.00246.x. PMID: 16684320.16684320
247 Beck AT, Steer RA, Carbin MG. Psychometric properties of the Beck Depression Inventory: twenty-five years of evaluation. Clin Psychol Rev. 1988 1988/01/01/;8(1):77–100. doi: 10.1016/0272-7358(88)90050-5.
248 Berkenstadt M, Shiloh S, Barkai G, . Perceived personal control (PPC): a new concept in measuring outcome of genetic counseling. Am J Med Genet. 1999 Jan 1;82(1):53–9. PMID: 9916844.9916844
249 Bjelland I, Dahl AA, Haug TT, . The validity of the Hospital Anxiety and Depression Scale. An updated literature review. J Psychosom Res. 2002 Feb;52(2):69–77. PMID: 11832252.11832252
250 Brehaut JC, O’Connor AM, Wood TJ, . Validation of a decision regret scale. Med Decis Making. 2003 Jul–Aug;23(4):281–92. doi: 10.1177/0272989x03256005. PMID: 12926578.12926578
251 Carver CS, Scheier MF, Weintraub JK. Assessing coping strategies: a theoretically based approach. J Pers Soc Psychol. 1989 Feb;56(2):267–83. PMID: 2926629.2926629
252 Cella D, Hughes C, Peterman A, . A brief assessment of concerns associated with genetic testing for cancer: the Multidimensional Impact of Cancer Risk Assessment (MICRA) questionnaire. Health Psychol. 2002 Nov;21(6):564–72. PMID: 12433008.12433008
253 Derogatis LR, Melisaratos N. The Brief Symptom Inventory: an introductory report. Psychol Med. 1983 Aug;13(3):595–605. PMID: 6622612.6622612
254 Grandner MA, Kripke DF, Yoon I-Y, . Criterion validity of the Pittsburgh Sleep Quality Index: investigation in a non-clinical sample. Sleep Biol Rhythms. 2006 06/09;4(2):129–39. doi: 10.1111/j.1479-8425.2006.00207.x. PMID: 22822303.22822303
255 Holmes-Rovner M, Kroll J, Schmitt N, . Patient satisfaction with health care decisions: the satisfaction with decision scale. Med Decis Making. 1996 Jan–Mar;16(1):58–64. doi: 10.1177/0272989x9601600114. PMID: 8717600.8717600
256 Hopwood P, Fletcher I, Lee A, . A body image scale for use with cancer patients. Eur J Cancer. 2001 Jan;37(2):189–97. PMID: 11166145.11166145
257 Horowitz M, Wilner N, Alvarez W. Impact of Event Scale: a measure of subjective stress. Psychosom Med. 1979 May;41(3):209–18. PMID: 472086.472086
258 Jackson C. The General Health Questionnaire. Occup Med. 2007;57(1):79. doi: 10.1093/occmed/kql169.
259 Lerman C, Trock B, Rimer BK, . Psychological side effects of breast cancer screening. Health Psychol. 1991;10(4):259–67. PMID: 1915212.1915212
260 Matalqah LM, Radaideh KM, Yusoff ZM, . Health-related quality of life using EQ-5D among breast cancer survivors in comparison with age-matched peers from the general population in the state of Penang, Malaysia. Journal of Public Health. 2011 March 18;19(5):475. doi: 10.1007/s10389-011-0406-6.
261 McHorney CA, Ware JE, Jr., Lu JF, . The MOS 36-item Short-Form Health Survey (SF-36): III. Tests of data quality, scaling assumptions, and reliability across diverse patient groups. Med Care. 1994 Jan;32(1):40–66. PMID: 8277801.8277801
262 Parkerson GR, Jr., Broadhead WE, Tse CK. Validation of the Duke Social Support and Stress Scale. Fam Med. 1991 Jul;23(5):357–60. PMID: 1884930.1884930
263 Radtke JV, Terhorst L, Cohen SM. The Menopause-Specific Quality of Life Questionnaire: psychometric evaluation among breast cancer survivors. Menopause. 2011 Mar;18(3):289–95. doi: 10.1097/gme.0b013e3181ef975a. PMID: 20881889.20881889
264 Salkovskis PM, Rimes KA, Warwick HM, . The Health Anxiety Inventory: development and validation of scales for the measurement of health anxiety and hypochondriasis. Psychol Med. 2002 Jul;32(5):843–53. PMID: 12171378.12171378
265 Schmitz N, Hartkamp N, Kiuse J, . The Symptom Check-List-90-R (SCL-90-R): a German validation study. Qual Life Res. 2000 Mar;9(2):185–93. PMID: 10983482.10983482
266 Schroevers MJ, Sanderman R, van Sonderen E, . The evaluation of the Center for Epidemiologic Studies Depression (CES-D) scale: Depressed and Positive Affect in cancer patients and healthy reference subjects. Qual Life Res. 2000;9(9):1015–29. PMID: 11332223.11332223
267 Shapiro DE, Rodrigue JR, Boggs SR, . Cluster analysis of the medical coping modes questionnaire: evidence for coping with cancer styles? J Psychosom Res. 1994 Feb;38(2):151–9. PMID: 8189404.8189404
268 Stanton AL, Kirk SB, Cameron CL, . Coping through emotional approach: scale construction and validation. J Pers Soc Psychol. 2000 Jun;78(6):1150–69. PMID: 10870915.10870915
269 Steed L. Further validity and reliability evidence for Beck Hopelessness Scale Scores in a nonclinical sample. Educ Psychol Meas. 2001;61(2):303–16. doi: 10.1177/00131640121971121.
270 Stein KD, Jacobsen PB, Blanchard CM, . Further validation of the multidimensional fatigue symptom inventory-short form. J Pain Symptom Manage. 2004 Jan;27(1):14–23. PMID: 14711465.14711465
271 Sullivan M, Karlsson J, Ware JE, Jr. The Swedish SF-36 Health Survey-I. Evaluation of data quality, scaling assumptions, reliability and construct validity across general populations in Sweden. Soc Sci Med. 1995 Nov;41(10):1349–58. PMID: 8560302.8560302
272 Thirlaway K, Fallowfield L, Cuzick J. The Sexual Activity Questionnaire: a measure of women’s sexual functioning. Qual Life Res. 1996 Feb;5(1):81–90. PMID: 8901370.8901370
273 Ware J, Jr., Kosinski M, Keller SD. A 12-Item Short-Form Health Survey: construction of scales and preliminary tests of reliability and validity. Med Care. 1996 Mar;34(3):220–33. PMID: 8628042.8628042
274 Wewers ME, Lowe NK. A critical review of visual analogue scales in the measurement of clinical phenomena. Res Nurs Health. 1990 Aug;13(4):227–36. PMID: 2197679.2197679
275 Zilberg NJ, Weiss DS, Horowitz MJ. Impact of Event Scale: a cross-validation study and some empirical evidence supporting a conceptual model of stress response syndromes. J Consult Clin Psychol. 1982 Jun;50(3):407–14. PMID: 7096742.7096742