# Acknowledgments

The authors thank AHRQ Medical Officer Justin Mills, MD, MPH; as well as the U.S. Preventive Services Task Force.