# Chapter 4 Discussion

## Summary of Review Findings

Table 12 summarizes the evidence reviewed for this update. No studies directly addressed the overarching question regarding the effectiveness of risk assessment, genetic counseling, and genetic testing in reducing cancer incidence and mortality (Key Question 1).

Table 12 Summary of Evidence

Key question | Populations or interventions | Studies (k); observations (n); study designs | Summary of findings | Consistency and precision | Other limitations | Strength of evidence | Applicability
KQ 1. Benefits of risk assessment, genetic counseling, and genetic testing | Risk assessment; genetic counseling; genetic testing | No studies | Not applicable | Not applicable | Not applicable | Insufficient | Not applicable
KQ 2a. Accuracy of familial risk assessment methods by non-specialists | Risk assessment for familial BRCA1/2-related cancer risk | 14 discriminatory accuracy studies of 10 risk assessment methods (n=43,813) | Methods have moderate to good discriminatory accuracy in predicting the probability of familial BRCA1/2-related cancer risk in individuals (AUC 0.68 to 0.96) | Consistent; precise | While some studies enrolled small numbers or inadequately described methods, most studies met criteria for fair and good quality | Moderate for benefit | Moderate to high
KQ 2a. Optimal ages and intervals for risk assessment | Risk assessment for BRCA1/2-related cancer risk | No studies | Not applicable | Not applicable | Not applicable | Insufficient | Not applicable
KQ 2b. Benefits of pre-test genetic counseling | Pre-test genetic counseling | 28 studies (systematic reviews; RCTs; and cohort, case-control, and before and after studies) (n=6,446) | Genetic counseling decreases cancer worry, anxiety, and depression; increases the accuracy of risk understanding; and decreases intention for mutation testing. Face-to-face counseling was preferred in some studies. | Consistent; precise | Dissimilar comparison groups; small sizes; dissimilar interventions; heterogeneous outcome measures | High for benefit | High
KQ 2c. Optimal testing approaches | BRCA1/2 mutation testing | 1 RCT (n=1,034) | Universal testing of Ashkenazi Jews for founder mutations detected more carriers than testing only those meeting family history criteria | Not applicable | All participants had genetic counseling, so not a true population approach; not all were tested, so cannot determine the accuracy of this strategy | Low for benefit | Moderate
KQ 2d. Optimal post-test counseling approaches | Post-test genetic counseling | No studies | Not applicable | Not applicable | Not applicable | Insufficient | Not applicable
KQ 3a. Harms of risk assessment | Risk assessment for BRCA1/2-related cancer risk | No studies | Not applicable | Not applicable | Not applicable | Insufficient | Not applicable
KQ 3b. Harms of pre-test genetic counseling | Pre-test genetic counseling | 28 studies (systematic reviews; RCTs; and cohort, case-control, and before and after studies) (n=6,446) | Genetic counseling did not cause adverse effects in studies, but decreased cancer worry, anxiety, and depression; increased the accuracy of risk understanding; and decreased intention for mutation testing. | Consistent; precise | Dissimilar comparison groups; small sizes; dissimilar interventions; heterogeneous outcome measures | Moderate for harms | Moderate
KQ 3c. Harms of genetic testing | BRCA1/2 mutation testing | 18 studies (cohort, case-control, and before and after studies) (n=3,027) | Breast cancer worry and anxiety increased for women with positive results and decreased for others, while risk understanding improved | Consistent; precise | Lack of studies with comparison groups; variations in methodology and enrollment criteria; heterogeneous outcome measures; high loss to followup | Moderate for benefits and harms (varies by test result) | Moderate
3d. Harms of post-test counseling | Post-test genetic counseling | No studies | Not applicable | Not applicable | Not applicable | Insufficient | Not applicable
KQ 4. Interventions to reduce BRCA-related cancer and mortality | Intensive screening | No effectiveness trials; 6 studies of test characteristics of screening (n=5,087) | Breast MRI has higher sensitivity than mammography for screening BRCA1/2 carriers (71 vs. 41%); specificity is comparable (90 vs. 95%). Sensitivity of screening for ovarian cancer is 43% for TVUS; 71% for CA-125; specificity is 99 percent for either | Not applicable | Descriptive studies that do not provide data on effectiveness | Insufficient | Not applicable
KQ 4. Interventions to reduce BRCA-related cancer and mortality, continued | Risk-reducing medications: tamoxifen, raloxifene, aromatase inhibitors (anastrozole; exemestane) | No trials for BRCA1/2 carriers; 9 RCTs for general populations (n=74,170) | Tamoxifen, raloxifene, anastrozole, and exemestane reduced invasive breast cancer and ER+ breast cancer compared with placebo. No differences for ER- or noninvasive breast cancer; all-cause or breast cancer-specific mortality | Consistent; precise | No results for BRCA1/2 carriers specifically; clinical heterogeneity across trials from varying eligibility criteria, adherence, and ascertainment of certain outcomes | Insufficient for BRCA1/2 carriers specifically; high for benefit for general populations | High for general populations
KQ 4. Interventions to reduce BRCA1/2-related cancer and mortality, continued | Risk-reducing surgery | 6 descriptive studies of mastectomy; 7 descriptive studies of oophorectomy or salpingo-oophorectomy (n=9,938) | Bilateral mastectomy reduced breast cancer incidence 90 to 100% and breast cancer mortality 81 to 100% for high-risk women and mutation carriers. Oophorectomy or salpingo-oophorectomy reduced breast cancer 37 to 74%; salpingo-oophorectomy reduced ovarian cancer 69 to 100% | Consistent; precise | Lack of studies with comparison groups; variations in methodology and enrollment criteria; heterogeneous outcome measures | Moderate for benefit | High
KQ 5. Harms of interventions to reduce incidence of BRCA1/2-related cancer and mortality, continued | Intensive screening | 9 descriptive studies (n=5,628) | For breast cancer screening, false-positive rates, additional imaging, and benign surgeries were higher for intensive screening using MRI versus mammography; benign diagnostic surgery rate of 55% for mutation carriers screened with TVUS and CA-125 | Consistent; precise | Lack of studies with comparison groups; variations in methodology and enrollment criteria; heterogeneous outcome measures | Low for harm | High
KQ 5. Harms of interventions to reduce incidence of BRCA1/2-related cancer and mortality, continued | Risk-reducing medications: tamoxifen, raloxifene, aromatase inhibitors (anastrozole; exemestane) | No trials for BRCA1/2 carriers; 9 RCTs for general populations (n=74,170) | Tamoxifen and raloxifene increased thromboembolic events and tamoxifen increased endometrial cancer and cataracts compared with placebo; no differences for DVT; PE; CHD events; or stroke | Consistent; precise | No results for BRCA1/2 carriers specifically; clinical heterogeneity across trials from varying eligibility criteria, adherence, and ascertainment of certain outcomes | Insufficient for BRCA1/2 carriers specifically; high for harm for general populations | High for general populations
KQ 5. Harms of interventions to reduce incidence of BRCA1/2-related cancer and mortality, continued | Risk-reducing surgery | 10 descriptive studies of mastectomy; 4 descriptive studies of oophorectomy (n=3,073) | Harms include physical complications of surgery, post-surgical symptoms, and changes in body image; psychological symptoms generally improve over time and some women have improved anxiety | Inconsistent, imprecise | Lack of studies with comparison groups; variations in methodology and enrollment criteria; heterogeneous outcome measures | Low for harm | Moderate

* Per 1000 women over 5 years of use.

Abbreviations: AUC=area under the receiver operating characteristic curve; BRCA1/2=breast cancer susceptibility gene; CA-125=cancer antigen-125; CHD=coronary heart disease; CI=confidence interval; DVT=deep vein thrombosis; ER+=estrogen receptor positive; ER-=estrogen receptor negative; KQ=key question; MRI=magnetic resonance imaging; PE=pulmonary embolism; RCT=randomized control trial; RR=risk ratio; TVUS=transvaginal ultrasound; vs=versus.

Fourteen discriminatory accuracy studies, including four new studies of existing tools, met inclusion criteria for Key Question 2a. No studies evaluated optimal ages, intervals, or harms (Key Question 3a) of risk assessment. Included studies evaluated the accuracy of 10 familial risk tools to predict risk for BRCA1/2 mutations and guide referrals to genetic counseling and potential testing. These include the FHAT, MSS, RST, PAT, FHS-7, brief versions of BRCAPRO, IBIS tool (also known as Tyrer-Cuzick), and variations. Results indicated moderate to high discriminatory accuracy (AUC 0.68 to 0.96), although some tools were only evaluated in single studies. Reference standards, enrollment criteria, and methodology varied across studies, limiting comparisons. Risk was most often based on self-reported information, thus the accuracy of risk estimates was limited by the accuracy of reported family history.

Two risk prediction tools were designed and evaluated specifically in unselected patients in primary care settings (FHAT and PAT; AUC >0.70), while others were evaluated in cohorts of patients referred to cancer networks or populations with known genetic risk. The applicability of methods designed for specific groups and settings may be limited when implemented more broadly in practice. For example, the MSS was designed for use in non-Ashkenazi Jewish populations, while the RST, PAT, and IBIS tools integrate Ashkenazi Jewish ancestry into risk assessment. As genetic testing becomes more available, particularly with direct to consumer marketing, improved selection of candidates at the primary screening level as a means to refer to genetic counseling and testing becomes increasingly important. While methods validated in specific settings or among selected populations may show high accuracy in studies, their use in broader populations may require additional evaluation.

Twenty-eight studies, including one new study, evaluated the benefits and harms of genetic counseling in women without previous histories of breast or ovarian cancer (Key Questions 2b and 3b). No studies included women who were previously treated for breast or ovarian cancer. Results indicated no increases in breast cancer-related worry after genetic counseling, with decreases in seven studies and no changes in two. No studies reported increases in anxiety or depression, with decreases in three studies and no changes in three. In most studies, anxiety and depression scores were below clinical thresholds. Eight studies indicated that a woman’s understanding of her breast cancer risk improved after genetic counseling and two reported decreased intention to undergo genetic testing after genetic counseling. Face-to-face counseling was preferred in some studies. Studies were limited by differences in designs and measures, use of dissimilar comparison groups, and enrollment of small numbers of women from specialty clinics.

Only one study evaluated different testing approaches to determine the presence of BRCA1/2 mutations in women at increased risk for BRCA1/2-related cancer (Key Question 2c).^164^ Results of this RCT indicated that population-based testing of individuals with Ashkenazi Jewish ancestry detects more BRCA1/2 mutations than family-history based testing. Measures of anxiety, health anxiety, depression, distress, uncertainty, and quality of life were similar between family history and population testing groups. Whether detection of BRCA1/2 mutation carriers in families without cancer history leads to reduced cancer incidence, mortality, and long-term harms was not evaluated in this study.

Eighteen studies of potential harms of genetic testing, including four new studies, (Key Question 3c) reported that breast cancer-related worry and anxiety increased for women with positive results and decreased for others, although results differed across studies. A new study showed that women receiving test results experienced decreased breast cancer-related anxiety over the subsequent 12 months regardless of carrier status.^150^ In another study, participants withdrawing after initial pre-test genetic counseling sessions described fear about the psychological impact of test results.^157^ Understanding of a woman’s risk of cancer improved after receiving test results in several studies. Studies were limited by variations in methodology and enrollment criteria, small numbers of participants, high loss to followup, lack of comparison groups, and heterogeneous outcomes. Other relevant outcomes were not studied including false-positive or negative results, impact on decisions regarding risk-reducing interventions, and health and social outcomes, among others.

No studies specifically evaluated optimal post-test genetic counseling approaches, or harms of post-test genetic counseling (Key Questions 2d and 3d), although several studies included for Key Question 2b and 3b included discussion of management options as part of the pre-test genetic counseling process.

Studies of interventions to reduce the incidence of BRCA1/2-related cancer and mortality in BRCA1/2 mutation carriers include intensive screening, risk-reducing medications, and risk-reducing surgery (Key Question 4). No trials evaluated the effectiveness of intensive screening. Although no trials of risk-reducing medications specifically in BRCA1/2 mutation carriers are available, several RCTs that included women with various levels of risk are relevant. A systematic review and meta-analysis of placebo-controlled RCTs of tamoxifen, raloxifene, and aromatase inhibitors anastrozole and exemestane, and a head-to-head trial of tamoxifen versus raloxifene provide updated outcomes.^78,79^ Tamoxifen, raloxifene, and aromatase inhibitors are associated with reduced invasive breast cancer after 3 to 5 years of use compared with placebo; tamoxifen had a greater effect than raloxifene in the STAR trial. Risks for invasive cancer were reduced in all subgroups evaluated based on family history of breast cancer. Medications reduced ER positive, but not ER negative breast cancer, noninvasive breast cancer, or breast-cancer specific or all-cause mortality. Trials were limited by heterogeneity and data were lacking on doses, duration, and timing of use.

Six observational studies reported outcomes of risk-reducing mastectomy, two of salpingo-oophorectomy, and seven of oophorectomy. Risk-reducing bilateral mastectomy was associated with 90 to 100 percent reduction in breast cancer incidence for high-risk women and BRCA1/2 mutation carriers. Breast cancer-specific mortality was reduced by 81 to 100 percent after risk-reducing mastectomy in one study. Newer studies of oophorectomy or salpingo-oophorectomy that control for biases did not show associations between surgery and breast cancer risk, though some studies showed reduced risk among younger women after surgery. Oophorectomy or salpingo-oophorectomy was associated with 69 to 100 percent reduction in ovarian cancer risk in two studies, but no differences in all-cause mortality.

Studies of the potential adverse effects of intensive screening for breast cancer (Key Question 5) indicated that false-positive rates, additional imaging, and benign biopsies were higher for women undergoing intensive screening using MRI compared with mammography. A study of ovarian cancer screening reported a benign diagnostic surgery rate of 55 percent after screening with TVUS and CA-125. Most women experienced no anxiety after screening with MRI, mammography, or clinical breast examination, although women recalled for additional testing had transient anxiety.

Trials of risk-reducing medications indicated that tamoxifen and raloxifene are associated with increased thromboembolic events compared with placebo, and tamoxifen had a greater effect than raloxifene. Tamoxifen was associated with increased endometrial cancer and cataracts. The aromatase inhibitors did not cause these adverse effects in primary prevention trials, although followup was brief. All medications caused undesirable side effects for some women, such as vasomotor symptoms.

Case-series and before and after studies described surgical complications, physical symptoms, and psychological measures related to risk-reducing surgery. Some women experienced physical complications of surgery, postsurgical symptoms, or changes in body image, while some had improved anxiety. Studies lacked important outcomes, and the few available studies had small numbers of participants and no comparison groups.

## Limitations

Limitations of this review include using only English-language articles and studies applicable to the United States, although this focus improves its relevance to the USPSTF recommendation. Also, the number, quality, and applicability of studies evaluated in the evidence review varied widely. Limitations of studies specific to each key question are briefly described in Table 12. Most studies in this review were conducted on highly selected samples of women, some with preexisting breast or ovarian cancer or from high-risk groups that were defined in various ways, or from previously identified cancer kindred. It is not known how the results of studies based on highly selected women in research settings, particularly in non-U.S. settings, translate to a general screening populations in U.S. clinical practice.

Studies are currently not available for several key questions in this review. No studies determined the optimal age for BRCA1/2 mutation testing and how the age at testing influences benefits and harms. No studies evaluated whether testing for BRCA1/2 mutations reduces cancer incidence and cause-specific or all-cause mortality and improves quality of life. The harms associated with receiving a false-negative test result or a result indicating intermediate pathogenic categories are also not known.

This systematic review focused on five key questions that limited its scope. Several additional issues are important to consider. The prevalence of pathogenic BRCA1 and BRCA2 mutations in general screening populations in the United States is not known, and the clinical significance of a positive test in the absence of family history of cancer is unclear. The impact of modifier genes on penetrance and detection of cancer susceptibility genes other than BRCA1/2^232–235^ require a broader view of benefits and harms of population screening.

Understanding these concepts is particularly important in the context of direct to consumer advertising of genetic testing and the availability of multipanel tests. Results of testing 194,104 women using a 25-gene hereditary cancer panel at a commercial U.S. laboratory identified 9,751 pathogenic variants in 9,641women (59% BRCA1/2; 39% ATM, CHEK2, or PALB2).^236^ However, only 24.7 percent of women with pathogenic variants had greater than a 20 percent lifetime risk for breast cancer based on clinical risk models. The clinical significance of identifying pathogenic variants in multi-gene panels commonly available in practice requires further investigation. Current NCCN guidelines reflect this uncertainty by recommending that multi-gene testing be offered in the context of professional genetic expertise for pre- and post-test counseling.^56^

Although this update explicitly included women with previously treated breast and ovarian cancer, in addition to women without cancer, to address gaps in prevention recommendations and clinical practice, few studies were available. Only studies of women diagnosed with breast or ovarian cancer at least 5 years before enrollment and who completed cancer treatment were included to assure that genetic testing was intended for risk reduction. As a result, 102 studies of women with prior breast and/or ovarian cancer were excluded because the time since diagnosis was less than 5 years or not reported (Appendixes A3 and A4). Consequently, questions regarding genetic testing or risk reduction in this population have not been adequately studied.

Evidence of harms often relied on observational studies with designs that lacked quality rating criteria. Existing studies show that most women do not experience adverse effects from BRCA1/2 risk assessment, genetic counseling, and genetic testing. However, long-term impact is unknown because most studies followed patients for less than 1 year. Studies used several types of measures and scales that limited comparisons and prohibited meta-analysis. Measures of anxiety or depression often lacked clinical thresholds, and when available, few studies reported results based on the number of individuals who met thresholds. No studies were available that considered the repercussions of not participating in genetic counseling (e.g., wrong test, overdiagnosis, misinterpretation of results, failure to test for a specific familial mutation), or measured genetic discrimination or labeling as a harm of testing.

Long-term harms were also inadequately measured for other risk-reducing interventions. For example, aromatase inhibitors demonstrated increased fractures and stroke in treatment trials of noninvasive^237^ and early stage breast cancer,^238,239^ but not in trials of risk-reduction that lacked followup data.^86,87,228–230^

Treatment effects are influenced by several factors that were not evaluated in studies. Salpingo-oophorectomy is associated with reduced breast cancer in younger but not older women, however, it is not clear how and when the benefit/harm ratio shifts for women facing this decision. Younger women are subjected to additional harms related to the impact of risk-reducing surgery on reproductive life decisions. Also, the type of risk-reducing intervention a mutation carrier selects may depend on her specific mutation. For example, women with BRCA1 mutations have a higher risk of ovarian cancer than those with BRCA2 mutations. Medications are most effective in reducing risk for ER positive breast tumors, although they have not been specifically evaluated in women with BRCA1/2 mutations. The proportion of ER positive tumors varies from 28 percent of those among women with BRCA1 mutations to 63 percent with BRCA2 mutations. It is not known how these factors influence patient decision making and eventual clinical outcomes.

## Relevance for Priority Populations, Particularly Racial/Ethnic Minorities

The prevalence of specific pathogenic BRCA1/2 mutations varies across geographical, ancestry, and familial groups, yet it is currently unclear how to use this information in clinical practice to effectively counsel and test individuals. Women with family histories of cancer who are from groups with known founder mutations, such as Ashkenazi Jews, may more clearly benefit from testing. However, testing may not be beneficial for women who identify with a specific group in the absence of family cancer history. Founder mutations in different ancestry groups may require different ways of understanding and weighing benefits and harms, particularly when test results create social stigma or other types of unintended harms. Estimating and understanding risk requires a high level of numeric literacy that must be considered for patients with language and education barriers. These issues require further study to more effectively guide clinical practice.

## Future Research

In order to determine the appropriateness of risk assessment and genetic testing for BRCA1/2 mutations in primary care, more information is needed about mutation prevalence and impact in the general population. Research has focused on highly selected women in referral centers and generally reported short-term outcomes. Issues such as access to genetic testing, effectiveness of screening approaches including risk stratification, use of system supports, and patient acceptance and education require additional study. Who should perform risk assessment and genetic counseling services, how should it be done, effectiveness of different modalities, what skills are needed, and its impact on patient choices and outcomes are unresolved questions. Trials comparing types of providers and protocols could address these issues. What happens after patients are identified as high-risk in clinical settings is also not known. The consequences of genetic testing on individuals and their relatives need to be assessed. Well-designed investigations using standardized measures and enrolling subjects that reflect the general population, including minority women and transgender individuals,^240,241^ are needed. ^240,241^

An expanded database or registry of patients receiving genetic counseling and testing for BRCA1/2 mutations would provide essential information about predictors of cancer, response to interventions, and other modifying factors. Before 2013, all patients clinically tested through direct DNA sequencing in the United States utilized a single private laboratory, and patient data were inaccessible. Developing a centralized accessible database with key variables to address these issues as genetic testing practices change in the wake of the U.S. Supreme Court decision ^74^ would be a major advance in this field. Additional data from women of varying socioeconomic, racial, and ancestry groups are needed. Currently available risk prediction tools may not apply to these populations.

Additional research on interventions is also needed. Without effectiveness trials of intensive screening, practice standards have preceded supporting evidence. For example, while screening with annual TVUS and serum CA-125 is considered for high-risk women, trials have yet to demonstrate improved clinical outcomes.^32,242^ Studies of factors related to acceptance of risk-reducing interventions based on genetic information would be useful, such as determining if cancer incidence in relatives is reduced because they adopt risk-reducing interventions. This information could improve patient decision making and lead to better health outcomes.

## Conclusions

Risk assessment, genetic counseling, and genetic testing to reduce BRCA1/2-cancer incidence and mortality as a prevention service has not been directly evaluated by current research. Risk assessment with familial risk tools accurately identifies high-risk women for genetic counseling. Genetic counseling reduces breast cancer worry, anxiety, and depression; increases understanding of risk; and decreases intention for mutation testing, while testing improves accuracy of understanding of risk. The effectiveness of intensive screening is not known, but it increases false-positive results and procedures. Risk-reducing medications and surgery are associated with reduced breast and ovarian cancer, but also have adverse effects.

The process of familial risk assessment in primary care, referral and evaluation by genetic counselors, genetic testing, and use of intensive screening and risk-reducing medications and surgeries is complex. Each step of the pathway requires careful interpretation of information, consideration of future risks, and shared decision making before moving on to the next step. Services must be well integrated and highly individualized in order to optimize benefits and minimize harms for patients as well as their families. In the absence of effectiveness trials supporting steps in this pathway, additional studies are need to better inform practice, particularly in the context of widespread access to commercial testing.