# Chapter 3 Results

103 studies (110 articles) were included;^66–69,71,98–100,111–212^ 14 discriminatory accuracy studies; 15 RCTs; 59 cohort studies; 2 case-control studies; 12 before and after studies; and 1 systematic review. These include 31 new studies, 70 studies from the 2013 review,^108,213^ and one new publication of followup results of a study included in the 2013 review. ^108,213^ Appendix A3 shows the results of the literature search and selection process and Appendix A4 lists the excluded full-text papers. Included studies and quality ratings are described in Appendix B Tables.

## Key Question 1 In Women With Unknown BRCA1/2 Mutation Status, Does Risk Assessment, Genetic Counseling, and Genetic Testing Result in Reduced Incidence of BRCA1/2-Related Cancer and Cause-Specific and All-Cause Mortality?

No studies addressed Key Question 1.

## Key Question 2a What Is the Accuracy of Familial Risk Assessment for BRCA1/2-Related Cancer When Performed by A Nonspecialist in Genetics in A Clinical Setting? What Are the Optimal Ages and Intervals for Risk Assessment?

## Key Question 3a What Are the Potential Adverse Effects of Risk Assessment?

### Summary

Fourteen discriminatory accuracy studies of eight risk assessment tools met inclusion criteria (Table 1)^111–124^ including four new studies that evaluated existing tools.^115,117,120,124^ No studies evaluated optimal ages and intervals for risk assessment and no studies described harms. Most studies used results of mutation testing as reference standards, although two studies included in the 2013 review used clinical criteria that involved risk estimates from more complex models as reference standards (e.g., BRCAPRO, BOADICEA).^112,114^

Table 1 Familial Risk Tools to Predict Individual Risk for BRCA1/2 Mutations in Primary Care Settings^*^

Model | Data collection and calculation | Population (N) | Relatives with breast and ovarian cancer | Other factors | Comparison with other models | Reference standard | Performance characteristics for predicting risk for BRCA1/2 mutations | Quality Rating
BRCAPRO-LYTE, BRCAPRO-LYTE-plus, BRCAPRO-LYTE-simple^115^ | Evaluates brief versions of BRCAPRO^†^ to guide referral to genetic counseling that uses full BRCAPRO | Patients with personal and/or family cancer history in three US hospital databases (4057) | 1^st^, 2^nd^ degree relatives | Number and types of relatives with breast and ovarian cancer; ages diagnosed | BRCAPRO | Mutation testing | Estimates based on different cut points: BRCAPRO-LYTE, sensitivity 57 to 93%; specificity 10 to 56%; BRCAPRO-LYTE-plus, sensitivity 39 to 76%, specificity 40 to 83%; BRCAPRO-LYTE-simple, sensitivity 43 to 83%; specificity 29 to 79% | Fair
Seven-question Family History Screening (FHS-7)^112^ | One positive response to 7 items is referral threshold | Women visiting primary care clinics in Brazil (9218 completed FHS-7, 1246 referred, 902 completed evaluation) | 1^st^ degree | Any relatives with breast cancer age ≤50; bilateral breast cancer; breast and ovarian cancer in same person; male breast cancer; ≥2 relatives with breast and/or ovarian cancer; ≥2 relatives with breast and/or colon cancer | None | Criteria for hereditary breast cancer syndrome^‡^ | Sensitivity 88% (95% CI, 83 to 91%); specificity 56% (95% CI 54 to 59%); PPV 0.24 (95% CI, 21 to 27%); NPV 0.97 (95 to 98%); AUC 0.83 (95% CI 0.81 to 0.85) | Good
International Breast Cancer Intervention Study Model (IBIS)^111,117,122^ | Compares performance with other established models | German Hereditary Breast and Ovarian Cancer Consortium (7352 families); families in cancer genetics clinics in the UK (1889) and Canada (300) | Female 1^st^, 2^nd^ degree relatives, affected cousins and half-sisters | Environmental factors (i.e.,. parity) for female index patients only | BOADICEA; BRCAPRO; eClaus; Manchester; Penn II; Myriad II; FHAT | Mutation testing | German study: sensitivity 77%; specificity 56.5%; PPV 36%; NPV 88.5%; AUC 0.749 (95% CI 0.735 to 0.763); UK study: AUC 0.74 (95% CI 0.71 to 0.77); Canadian study: AUC 0.47 (95% CI 0.28 to 0.69) | Fair to good
Manchester scoring system^111,113,^ ^116,121,122^ | Assigns points for responses to 12 items; referral threshold ≥10 points per mutation or ≥15 collectively (≥10% mutation probability) | Developed in families with cancer history in the UK (422); evaluated in 4 additional studies in UK and Canada (2880) | 1^st^, 2^nd^, 3^rd^ degree | Type of cancer (breast, ovarian, pancreatic, or prostate), affected family members, and age at diagnosis | BOADICEA; BRCAPRO; FHAT; Myriad II | Mutation testing | Estimates based on different evaluation studies (≥10% mutation probability): sensitivity 58 to 93%; specificity 33 to 71%; AUC 0.75 to 0.80 | Fair to good
Modified Manchester scoring system (MSS-2009)^120^ | Assigns points for responses; referral threshold ≥10 points per mutation or ≥15 collectively (≥10% mutation probability) | German Hereditary Breast and Ovarian Cancer Consortium (9390 families) | 1^st^, 2^nd^, 3^rd^ degree | New version includes pathology (histology and hormone receptor status) of index patient in addition to original factors: type of cancer (breast, ovarian, pancreatic, or prostate), affected family members, age at diagnosis | Original MSS (MSS-2004) without pathology; recalibrated MSS (MSS-recal) with pathology for study sample | Mutation testing | ≥10% mutation probability: MSS-2004, AUC 0.77 (95% CI 0.75 to 0.79); MSS-2009, AUC 0.80 (95% CI 0.78 to 0.82); MSS-recal, AUC 0.82 (95% CI 0.80 to 0.83) | Fair
Ontario Family History Assessment Tool (FHAT)^118,^ ^121–123^ | Assigns points for responses to 17 items; referral threshold ≥10 (≥22 lifetime risk for breast or ovarian cancer) | Developed in families with cancer history in Canada (184); evaluated in 3 additional studies in Canada and the US (3566) | 1^st^, 2^nd^, 3^rd^ degree | Age at diagnosis; bilateral breast cancer; breast and ovarian cancer in same person; male breast cancer; colon and prostate cancer | Claus; BRCAPRO | Mutation testing | Estimates based on different evaluation studies (≥22 lifetime risk): sensitivity 91 to 94%; specificity 15 to 51%; PPV 31%; AUC 0.68 to 0.83 | Fair to good
Pedigree Assessment Tool (PAT)^119,^ ^124^ | Assigns points for responses to 5 items; referral threshold ≥8 points (≥10% mutation probability) | Developed in 3906 women without breast cancer presenting for screening mammography at a US community hospital; evaluated in families in US (520 families) | 1^st^, 2^nd^, 3^rd^ degree | Breast cancer age ≤50 or >50; ovarian cancer at any age; male breast cancer; Ashkenazi Jewish ancestry | Myriad II, Penn II, | Mutation testing; Myriad II | Mutation testing as reference standard (≥10% mutation probability): sensitivity 95.9%; specificity 20.1%; PPV 0.319; NPV 0.926; AUC 0.705; Myriad II as reference standard (≥10% mutation probability): sensitivity 100%; specificity 93%; PPV 0.63; NPV 1.00; AUC 0.96 | Fair
Referral Screening Tool (RST)^114,^ ^214^ | ≥2 positive responses to 13 items is referral threshold (≥10% mutation probability) | Unselected women undergoing screening mammogram (2464 completed RST, 296 randomly evaluated) | 1^st^, 2^nd^ degree | Breast cancer age ≤50 (self or relatives); ovarian cancer at any age (self or relatives); ≥2 breast cancer cases age >50 on same side of family; male breast cancer; Jewish ancestry | None | Pedigree analysis and estimates of mutation risk based on models (BOADICEA; BRCAPRO; FHAT; Myriad II)^§^ | ≥10% mutation probability: sensitivity 81%; specificity 92%; PPV 0.80; NPV 0.92; AUC 0.87; revised version: AUC 0.90 (95% CI 0.85 to 0.95) | Good

* Individual clinical scoring instruments are detailed in Appendix C1 and quality ratings in Appendix B Table 1.

† BRCAPRO-LYTE applies the BRCAPRO model using only information on the numbers and types of first- and second-degree relatives, which relatives are affected with breast and ovarian cancer, and their ages of diagnosis; BRCAPRO-LYTE-plus does not collect data on ages of affected relatives, but imputes ages based on a large external dataset; BRCAPRO-LYTE-simple imputes the number of relatives for each type of cancer and ages of unaffected relatives.

‡ Based on evaluation including pedigree analysis, lifetime risk estimates from established models (Claus; Gail; Tyrer-Cuzick; Penn II), American Society of Clinical Oncology criteria, and review by two clinical geneticists.

§ Detailed four-generation cancer pedigrees analyzed using four established hereditary risk models (BRCAPRO, Myriad II, BOADICEA, FHAT), with a ≥10% BRCA1/2 mutation probability or a FHAT score of ≥10 as the definition of “high risk.”

Abbreviations: AUC=area under the receiver operating characteristic curve; BOADICEA=breast and ovarian analysis of disease incidence and carrier estimation algorithm; FHS-7=seven-question Family History Screening; FHAT=family history assessment tool; IBIS= International Breast Cancer Intervention Study Model; NPV=negative predictive value; PAT=pedigree assessment tool; PPV=positive predictive value; RST=referral screening tool; UK=United Kingdom

The new studies further evaluated existing tools including the Manchester Scoring System (MSS),^120^ Pedigree Assessment Tool (PAT),^124^ International Breast Cancer Intervention Study (IBIS) risk model (also known as Tyrer-Cuzick),^117^ and brief versions of BRCAPRO, a complex model typically used by genetic counselors.^115^ Results indicated that a revised version of the MSS that integrated pathology data of the family member diagnosed with cancer had higher sensitivity than the original model.^120^ In new validation studies, AUC values were 0.71 for the PAT^124^ and 0.74 (95% CI, 0.71 to 0.77) for IBIS,^117^ and were comparable to other more complex tools that were also evaluated. Another study demonstrated that the accuracy of brief versions of BRCAPRO were comparable to the full BRCAPRO and a sequential approach did not improve accuracy over BRCAPRO alone (i.e., brief version followed by the full BRCAPRO if indicated).^115^

Results of the four new studies were consistent with the 10 studies of eight familial risk assessment tools included in the 2013 review.^108,213^ In these studies, results generally indicated moderate to high diagnostic accuracy (AUC 0.68 to 0.96) in predicting BRCA1/2 mutations in individuals when compared against results of mutation testing or clinical criteria. However, results varied across studies and some tools were only evaluated in single studies. No studies in the 2013 review addressed harms of risk assessment.

### Evidence

Familial risk prediction tools that address this key question are primarily intended for use by nonspecialists in genetics to guide patient referrals to genetic counselors for more comprehensive evaluations. These tools specifically predict familial risk of genetically related cancer risk, and do not include tools that predict the overall probability of developing breast cancer, such as the Gail model. Risk tools generally include variations of key risk factors including BRCA1/2 mutations previously detected in relatives; Ashkenazi Jewish heritage; numbers, ages, and types of relatives affected with breast or ovarian cancer; and presentations of cancer that are highly suggestive of BRCA1/2 mutations, such as male or bilateral breast cancer, breast and ovarian cancer in the same person, and young age at cancer onset (<50 years old). Several tools have been developed and evaluated in patients, including the Ontario Family History Assessment Tool (FHAT), FHS-7 (7-question Family History Screening), MSS, PAT, and Referral Screening Tool (RST).

Four new fair-quality studies describing performance characteristics of existing tools met inclusion criteria for this update^115,117,120,124^ in addition to 10 studies of eight tools included in the 2013 review (Table 1 and Appendix C).^111–114,116,118,119,121–123^ All studies met criteria for fair- or good-quality (Appendix B Table 1). Most studies used results of mutation testing as reference standards, although two studies included in the 2013 review used clinical criteria that involved risk estimates from more complex models as reference standards (e.g., BRCAPRO, BOADICEA).^112,114^ Overall, risk tools demonstrated moderate to good discriminatory accuracy in predicting the probability of familial BRCA1/2-related cancer risk in individuals (AUC 0.68 to 0.96). Details of each tool are further described below.

#### Ontario Family History Assessment Tool (FHAT)

The FHAT is a 17-question instrument developed to assist Canadian clinicians in selecting patients for referral to genetic counseling.^118^ The referral threshold is equivalent to doubling of the general population lifetime risk for breast or ovarian cancer (22%). With FHAT, points are assigned according to the number of relatives, third-degree or closer, diagnosed with breast, ovarian, colon, or prostate cancer; age at diagnosis; and type and number of primary cancers. Patients with scores of 10 or more points meet the referral threshold.

In a study of 184 women with incident familial and non-familial breast cancer, the sensitivity and specificity of FHAT for a pathogenic BRCA1/2 mutation were 94 and 51 percent, respectively.^118^ This compares with sensitivity and specificity of 74 and 79 percent using BRCAPRO, and 74 and 54 percent using Claus methods. The 2013 review included three additional studies of FHAT that replicated its accuracy.^121–123^

#### Manchester Scoring System (MSS)

The MSS was developed in the United Kingdom for use in clinical practice to predict BRCA1/2 mutations at the 10 percent threshold for mutation probability,^116^ a level often used clinically.^101^ Points are assigned depending on type of cancer (breast, ovarian, pancreatic, or prostate), affected family members, and age at diagnosis. The tool provides scores for BRCA1 and BRCA2 mutations separately and combined.

A new fair-quality study validated the MSS by testing models with and without pathology information in 9,390 families in the German Hereditary Breast and Ovarian Cancer Consortium.^120^ Mutation analysis for BRCA1/2 was performed for each index patient as the reference standard. Three different models of the MSS were evaluated. The original model, MSS-2004, included 12 components representing the numbers of breast, ovarian, pancreatic, and prostate cancers identified at different ages among relatives in the pedigree, with specific sub scores for each BRCA1/2 mutation. The MSS-2009 was similar to the MSS but included histology and hormone receptor status from the breast cancer of the index case in a family. The MSS-recal was a recalibrated model using logistic regression to assess whether the components of the MSS were significantly predictive in the validation population and how the weights of the components compared with the original scores.

The use of pathological parameters in high-risk families’ histories increased predictive performance and recalibration improved specificity (MSS-2004, AUC, 0.77; 95% CI, 0.75 to 0.79; MSS-2009, AUC, 0.80; 95% CI, 0.78 to 0.82; MSS-recal, AUC, 0.82; 95% CI, 0.80 to 0.83). Methodologic limitations of this study include unclear exclusion criteria, incomplete pathology information for some index patients, and limited applicability resulting from selective sampling conditions of the cohort.

In the 2013 review, the MSS was evaluated in five studies in the United Kingdom and Canada and compared with other existing tools.^111,113,116,121,122^ In these studies, the MSS (for combined BRCA1/2) had 58 to 93 percent sensitivity, 33 to 71 percent specificity, and AUC values of 0.75 to 0.80, comparing well with the other tools tested.^111,113,116,121,122^ Importantly, the MSS is not designed to assess families with Ashkenazi Jewish ancestry, and may have more limited applications in clinical settings in the United States.

#### Referral Screening Tool (RST)

The RST was developed to help primary care clinicians make appropriate referrals for genetic counseling in response to the USPSTF’s 2005 recommendation.^114,214^ The RST uses a checklist of risk information, including breast cancer at age 50 or younger in self or relatives; ovarian cancer at any age in self or relatives; two or more breast cancer cases at age older than 50 on the same side of the family; male breast cancer; and Jewish ancestry. The referral threshold of 10 percent or higher mutation probability is reached with two or more positive responses. It was designed for simplicity and is the least complicated model to administer for screening purposes.

In an evaluation study in the 2013 review, the RST was administered to 2,464 unselected women undergoing screening mammography in a U.S. healthcare system.^114^ Results were compared against a reference standard that included detailed four-generation cancer pedigrees analyzed using four established hereditary risk models (BRCAPRO, Myriad II, BOADICEA, FHAT), with a 10 percent or higher BRCA1/2 mutation probability or a FHAT score of 10 or more as the definition of “high-risk.” The RST demonstrated sensitivity 81 percent, specificity 92 percent, and AUC 0.87. A revised model (B-RST) was further refined and is available on a website.^114,214^ In a followup analysis using the same risk data from participants of the original study, the revised tool demonstrated increased sensitivity and slightly decreased specificity when compared against the other tools (BRCAPRO, Myriad II, BOADICEA, FHAT) and had an overall AUC of 0.90 (95% CI, 0.85 to 0.95). ^214^

#### Pedigree Assessment Tool (PAT)

The PAT was specifically designed to identify women at increased risk for BRCA1/2-related cancer in U.S. primary care settings.^119^ The PAT uses a point scoring system based on information from first, second, and third-degree relatives regarding breast cancer onset at ages younger or older than 50 years; ovarian cancer at any age; male breast cancer; and Ashkenazi Jewish ancestry. The referral threshold is 8 or more points indicating 10 percent or higher mutation probability.

A new fair-quality study evaluated PAT scores using results of mutation testing as the reference standard.^124^ Participants were identified retrospectively through a high-risk clinic for cancer genetic counseling in the United States. Using the referral threshold score of 8 or more and mutation probability of 10 percent, PAT had sensitivity 96 percent and specificity 20 percent, with an AUC value of 0.705, comparable to Myriad II and Penn II models that were also evaluated. Methodologic limitations include uncertain applicability in the general population and enrollment methods using retrospective data collection from chart reviews.

In the 2013 review, a study of the performance characteristics of PAT using Myriad II as the reference standard indicated sensitivity of 100 percent, specificity of 93 percent, and AUC 0.96.^119^

#### FHS-7 (7-Question Family History Screening)

The FHS-7 is a 7-question instrument about family history of breast, ovarian, and colorectal cancer.^112^ It was developed as a simple instrument for primary care settings for screening and referral purposes. The questions include first-degree relatives with breast or ovarian cancer; and any relatives with breast cancer age 50 and younger, bilateral breast cancer, breast and ovarian cancer in the same person, male breast cancer, two or more relatives with breast and/or ovarian cancer, and two or more relatives with breast and/or colon cancer. A single positive response is the threshold for referral.

An evaluation of the FHS-7 was included in the 2013 review. The FHS-7 was administered to 9,218 women during routine visits to primary care clinics in Brazil. The reference standard was based on clinical criteria for hereditary breast cancer syndrome involving an evaluation with pedigree analysis, lifetime risk estimates from established models (Claus; Gail; Tyrer-Cuzick; PennII), American Society of Clinical Oncology criteria, and review by two clinical geneticists. In this study, the FHS-7 had a sensitivity of 88 percent, specificity of 56 percent, and AUC value of 0.83.^112^

#### International Breast Cancer Intervention Study (IBIS)

The IBIS instrument was developed from eligibility criteria for the IBIS-I placebo-controlled trial of tamoxifen to reduce risk for primary breast cancer. It includes personal history information (current age, age at menopause, menarche, childbirth history, menopausal status, use of menopausal hormone therapy), personal breast history (breast density [optional], prior breast biopsy, history of breast or ovarian cancer), genetic testing, Ashkenazi Jewish ancestry, and information about relatives (breast or ovarian cancer, age at diagnosis, genetic testing). IBIS uses information from female index patients only, and incorporates information from female first and second-degree relatives and affected cousins and half-sisters.

In a new fair-quality study, the IBIS instrument was compared with more comprehensive risk assessment models in a large study of 7,352 families using mutation testing results as the reference standard.^117^ Families were recruited through health centers participating in a high-risk consortium (German Consortium for Hereditary Breast and Ovarian Cancer) with eligibility based on risk for heredity cancer. IBIS had a sensitivity of 77 percent, specificity of 56.5 percent, and AUC of 0.749 (95% CI 0.735 to 0.763). These results were similar to more comprehensive models including BOADICEA (sensitivity 82.1%, specificity 56.8%, AUC, 0.791; 95% CI, 0.779 to 0.804), BRCAPRO (sensitivity 84.3%, specificity 55%, AUC, 0.796; 95% CI, 0.784 to 0.808), and eClaus (sensitivity 98%, specificity 9.6%, AUC, 0.745; 95% CI, 0.732 to 0.759).

### BRCAPRO-LYTE, Plus, Simple

BRCAPRO is a statistical model that uses software to assess the probability that an individual carries BRCA1/2 mutations based on family history of breast and ovarian cancer. The full BRCAPRO model is complex and generally used for genetic counseling. Brief variations of BRCAPRO were developed to use as screening tools prior to genetic counseling as part of a two-stage approach to genetic risk assessment in primary care.^115^

The basic BRCAPRO-LYTE version uses information on the numbers and types of first and second-degree relatives, which relatives are affected with breast or ovarian cancer, and ages of diagnosis. BRCAPRO-LYTE-Plus includes factors in the basic version, but imputes the ages of unaffected relatives (i.e., a value is calculated to provide an estimate). BRCAPRO-LYTE-Simple collects the least amount of data (age and relationships of each person with cancer) and imputes information on the numbers of each type of relative including age.

The accuracy of the brief BRCAPRO variations was evaluated in a new fair-quality study.^115^ Participants were enrolled from high-risk families in the United States referred from three different cancer centers for genetic counseling. Results of mutation testing served as the reference standard and data were analyzed retrospectively. BRCAPROLYTE had higher sensitivity but lower specificity than the other models (sensitivity 57%, specificity 56%); BRCAPRO-LYTE-Plus (sensitivity 39%, specificity 83%); BRCAPROLYTE-Simple (sensitivity 43%, specificity 79%).

The sensitivity and specificity of the two stage approaches (i.e. brief version followed by the full BRCAPRO for those at high risk on the initial instrument) were similar to BRCAPRO alone (46% and 75%). In this study, BRCAPRO-LYE overestimated risk of mutation; BRCAPRO-LYTE-Plus underestimated risk; and the Simple version provided the closest estimate and was the most stable across varying cutoffs.

## Key Question 2b, 3b What Are the Benefits and Adverse Effects of Pre-Test Genetic Counseling in Determining Eligibility for Genetic Testing for BRCA1/2-Related Cancer?

### Summary

Twenty-eight studies (in 30 publications) were included,^66–69,71,125–149^ including one new before and after study.^125^ This study showed that agreement between a woman’s understanding of her breast cancer risk and her genetic counselor’s appraisal decreased 1 year after counseling compared with immediately after (49% agreement vs. 35%) among 89 women in the Netherlands. In the 2013 review, 16 of 23 studies indicated improved patient understanding of level of risk after genetic counseling. ^125^

Twenty-seven studies included in the 2013 review reported additional outcomes related to genetic counseling. Seventeen of 18 studies indicated that genetic counseling is associated with decreases in measures of breast cancer worry or is not associated with breast cancer worry. Of 13 studies reporting anxiety outcomes and seven reporting depression, none indicated increased measures after genetic counseling. Of five studies evaluating genetic counseling’s association with intention for mutation testing, one showed increased intention in black, but not white women; while four showed decreased intention.

### Evidence

Twenty-eight studies (in 30 publications) met inclusion criteria, including one published since the 2013 review^125^ and 27 included previously^66–69,71,126–149^ (Table 2 and Appendix B Tables 2-7). No studies included women treated for breast or ovarian cancer. Studies reported measures of breast cancer worry, anxiety, and depression associated with genetic counseling for BRCA1/2-related cancer. Additional outcomes included intention for genetic testing and women’s understanding of their levels of risk. Overall, results indicated that genetic counseling was associated with decreased breast cancer worry, anxiety, and depression; increased understanding of risk; and decreased intention for inappropriate mutation testing.^66–69,71,126–149^

Table 2 Studies of Genetic Counseling

Author, year | N | Provider of genetic counseling | Setting | Measures | Quality rating | Breast cancer worry | Breast cancer worry | Anxiety | Anxiety | Depression | Depression | Risk perception | Risk perception | Intent to participate in testing | Intent to participate in testing
| | | | | | Increase | Decrease | Increase | Decrease | Increase | Decrease | More accurate | Less accurate | Increase | Decrease
Current Review
Albada et al., 2016^125^ | 89 | Geneticists (including residents) and genetic counselors (including in training) | Cancer Genetics Service Center | NSI | NA | NR | NR | NR | NR | NR | NR | NR | 0^‖^ | NR | NR
2013 Review
Bennett et al., 2008^127^ | 128 | Genetic counselor | Cancer Genetics Service Center | DUKE-SSQ, HADS, IES, MCMQ, NSI | NA | 0 | X | 0 | 0 | 0 | 0 | NR | NR | NR | NR
Bennett et al., 2009^128^ | 128 | Genetic counselor | Cancer Genetics Service Center | DUKE-SSQ, IES, MCMQ | NA | 0 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Bloom et al., 2006^129^ | 163 | Master’s level counselor | Telephone counseling | NSI | Poor | 0 | 0 | NR | NR | NR | NR | 0 | 0 | NR | NR
Bowen et al., 2002^66,^* | 354 | Genetic counselor or trained health counselor | NR | NSI | Fair | NR | NR | NR | NR | NR | NR | NR | NR | 0 | X
Bowen et al., 2004^71,^* | 354 | Genetic counselor or trained health counselor | NR | NSI | Fair | 0 | 0 | 0 | X | 0 | 0 | X | 0 | NR | NR
Bowen et al., 2006^130^ | 221 | Psychologist, genetic counselor | University | BSI, NSI | Fair | 0 | X^¶^ | NR | NR | NR | NR | X^**^ | 0 | 0 | X^**^
Brain et al., 2002^131,†^ | 740^‡^ | Clinical geneticist and genetic nurse specialist | NR | NSI, STAI | Good | 0 | X^††^ | 0 | X | NR | NR | X | 0 | NR | NR
Brain et al., 2011^132,†^ | 263 | Clinician | NR | CWS-R | NA | 0 | X^‡‡^ | NR | NR | NR | NR | NR | NR | NR | NR
Braithwaite et al., 2005^133^ | 72 | Clinical nurse specialist | NR | HADS, NSI, STAI | Fair | 0 | X^§§^ | 0 | X^‖‖^ | NR | NR | X^¶¶^ | 0 | NR | NR
Burke et al., 2000^67^ | 356 | Genetic counselor | Medical office | NSI | Fair | 0 | 0 | NR | NR | NR | NR | X | 0 | NR | X
Cull et al., 1998^68,§^ | 144^‡^ | Geneticist and breast surgeon | Breast cancer family clinic | GHQ, NSI, STAI | Good | NR | NR | 0 | 0 | 0 | 0 | X^***^ | X^†††^ | NR | NR
Fry et al., 2003^134^ | 263 | Genetics consultant and specialist breast surgeon vs. Geneticist and genetics nurse specialist | Familial Breast Cancer Clinic | CWS | Fair | 0 | X | NR | NR | NR | NR | X | 0 | NR | NR
Gurmankin et al., 2005^135^ | 125 | Health care provider | University breast and ovarian cancer risk evaluation program | NSI, STAI | NA | NR | NR | NR | NR | NR | NR | X^§§^ | 0 | NR | NR
Helmes et al., 2006^136^ | 340^‡^ | Board certified genetic counselor | NR | NSI | Fair | 0 | X^‡‡‡^ | NR | NR | NR | NR | X^‡‡‡^ | 0 | 0 | X^‡‡‡^
Hopwood et al., 1998^137^ | 174 | Family History Clinics | Family history clinics | GHQ, NSI, PAS | Fair | 0 | 0 | 0 | 0 | NR | NR | X | 0 | NR | NR
Hopwood et al., 2004^138^ | 256 | Genetic counselor | Cancer Genetics Service Center | CWS, GHQ, NSI | NA | 0 | X | 0 | 0 | NR | NR | 0 | 0 | NR | NR
Kelly et al., 2008^139^ | 78 | Genetic counselor | NR | NSI | NA | NR | NR | NR | NR | NR | NR | 0 | X^§§^ | NR | NR
Lerman et al., 1996^140^ | 227 | Genetic counselor | Cancer centers | IES | Fair | 0 | 0 | NR | NR | NR | NR | X | 0 | NR | NR
Lerman et al., 1999^69^ | 364 | Oncology nurses or genetic counselor | Hospital cancer center | IES | Fair | 0 | 0 | NR | NR | NR | NR | NR | NR | X^‖‖‖^ | 0
Lobb et al., 2004^141^ | 193 | Clinical geneticists, an oncologist, and genetic counselors. | Not reported | HADS, IES, NSI | Good | NR | NR | 0 | 0 | 0 | 0 | 0 | 0 | NR | NR
Matloff et al., 2006^142^ | 64^‡^ | Certified genetic counselor | Not reported | NSI | Fair | NR | NR | NR | NR | NR | NR | X^¶¶¶^ | 0 | NR | NR
Mikkelsen et al., 2007^143,^ ^§§§^ | 1971 | Physicians | Clinical department | IES | Fair | NR | NR | NR | NR | NR | NR | 0^****^ | 0 | NR | NR
Mikkelsen et al., 2009^144,^ ^§§§^ | 1971 | Physicians | Clinical department | HADS | Fair | 0 | X | 0 | 0 | 0 | 0 | NR | NR | NR | NR
Pieterse et al., 2011^145^ | 77^‡^ | Clinical geneticists, residents in clinical genetics, genetic counselors | Department of medical genetics | IES, NSI, PPC, STAI, VAS | NA | NR | NR | 0 | X | NR | NR | X | 0 | NR | NR
Roshanai et al., 2009^146^ | 163 | Specialist nurse | Cancer genetic clinic | HADS, SPIKES | Fair | NR | NR | 0 | X | 0 | X | X^††††^ | 0 | NR | NR
Watson et al., 1998^148^ | 115 | Clinical geneticist | Hospitals | CWS, GHQ-12, VAS | Good | 0 | 0 | 0 | 0 | 0 | 0 | X^‡‡‡‡^ | 0 | NR | NR
Watson et al., 1999^149^ | 283 | Clinical geneticists | In genetic counseling centers | GHQ, IES, NSI, STAI | Good | 0 | 0 | 0 | 0 | NR | NR | 0 | 0 | NR | NR

X=significant relationship; 0=studied, but not significant

* Studies use the same population (Bowen, 2002 and Bowen, 2004)

† Brain, 2011 uses the moderate risk group from Brain, 2002

‡ Randomized

§ Study done in a country other than the United States (e.g. The Netherlands, Scotland, Australia, or England)

‖ 1 year after counseling fewer women had accurate risk perception vs. immediately after counseling (34.6% vs. 48.6%)

¶ Both intervention groups vs. control group

** Both treatment groups vs. control group

†† Women at low- and moderate-risk decreased, while those at high-risk did not

‡‡ Significant affect was observed immediately after, by 9 months affect was gone

§§ Pre vs. post

‖‖ Pre vs. post; and A vs. B

¶¶ For counseling vs. GRACE

*** Both treatment groups at treatment end

††† Video after counseling subjects at 1 month followup

‡‡‡ Both intervention groups long-term

§§§ Studies use the same population (Mikkelsen, 2007 and Mikkelsen, 2009)

‖‖‖ African American subjects only

¶¶¶ Time effect - change from pre- to post

**** Interventions vs. control

†††† At 2 week followup; NS by 8 months

‡‡‡‡ Risk provided as odds ratio

Abbreviations: BSI=Brief Symptom Inventory; CWS=Cancer Worry Scale; CWS-R=Cancer Worry Scale- Revised; DUKE-SSQ=Duke Social Support Questionnaire; GHQ=General Health Questionnaire; GHQ-12=12-item General Health Questionnaire; HADS=Hospital Anxiety and Depression Scale; IES=Impact of Event Scale; MCMQ=Medical Coping Modes Questionnaire; NA=rating criteria not available; NR=not reported; NSI=Non Standard Instrument; PAS=Psychiatric Assessment Schedule; PPC=Perceived Personal Control; SPIKES=Setting, Patient’s perception, Invitation, Knowledge, Exploring/Empathy, Strategy/Summary; STAI=State-Trait Anxiety Inventory; VAS=Visual Analog Scale

Across all studies, enrollment ranged from 64 to 1,971 women with family histories of breast and ovarian cancer who were seeking genetic counseling and interested in receiving genetic testing for BRCA1/2 mutations. Several studies compared different types of genetic counseling^130,133,134,136,146^ and genetic counseling versus no counseling,^126,129,142–144^ while others compared outcomes before and after genetic counseling.^125,127,128,132,135,138,139,145^ The types of genetic counseling services varied across studies and are summarized in Table 3.

Table 3 Types of Genetic Counseling Provided in Included Studies

Author, year | Setting | Provider of genetic counseling | Components of genetic counseling
Current Review
Albada et al., 2016^125^ | Cancer Genetics Service Center | Geneticists (including residents) and genetic counselors (including in training) | Dutch Breast Cancer guidelines, personal risk estimate (if enough data was available), no other information described
2013 Review
Armstrong et al., 2005^126^ | Not reported | Not reported | Genetic counseling not specified.
Bennett et al., 2008^127^ | Cancer Genetics Service Center | Genetic counselor | Women with family history of breast/ovarian cancer referred by general practitioner or other medical specialists into the service. After assessment of information in family health questionnaire by genetic specialists, individual genetic risk of developing familial breast and ovarian cancer was calculated as a percentage of lifetime risk and stratified into high, moderate and “population” risk levels. Women considered high risk for breast/ovarian cancer were offered counseling, genetic testing, and annual mammography; women at moderate risk were offered annual mammography.
Bennett et al., 2009^128^ | Cancer Genetics Service Center | Genetic counselor | See Bennett et al., 2008^126^
Bloom et al., 2006^129^ | Telephone counseling | Master’s level counselor | Telephone counseling session included: establishment of rapport and determination of special concerns, emotional readiness, risk notification by providing modified Gail model lifetime risk estimate and discussing in terms of her pre-test self-assessment of risk, de-escalation of tension regarding breast cancer check-up, evaluation of coping skills, reinforcement of problem solving and coping skills; information on health protective behaviors, early detection through American Cancer Society screening, and information on genetic testing when requested.
Bowen et al., 2002^66^ | Not reported | Genetic counselor or trained health counselor | Individual genetic counseling: telephone contact with genetic counselor to review pedigree information and 1 2-hour session following protocol based on standard genetic practice, with a letter sent to participant within 2 weeks summarizing the session.; Group psychosocial counseling: group of 4 to 6 participants met for 4, 2-hour sessions with trained health counselor, participants received risk assessment sheet, personalizing the group discussion to her own risk status, main topics: risk assessment, perception, screening, stress management and problem solving, and social support.
Bowen et al., 2004^71^ | Not reported | Genetic counselor or trained health counselor | See Bowen et al, 2002^65^
Bowen et al., 2006^130^ | University | Psychologist, genetic counselor | Group psychological counseling: psychologist led 4 2-hour, weekly sessions of 5-6 women per group, with each session including a 20-min group cohesion activity followed by 1 of 4 major intervention components: risk assessment and perception, education, stress management, and problem solving and social support.; Individual genetic counseling: genetic counselor provided 1-hour counseling sessions and sessions covered several topics, including participant’s family background, breast cancer risk assessment, BRCA1 and BRCA2 mutations in the Ashkenazi Jewish population, non-genetic risk factors for breast cancer, and breast screening.
Brain et al., 2002^131^ | Not reported | Clinical geneticist and genetic nurse specialist | Breast cancer surveillance, option to enter U.K. Tamoxifen Prevention Trial, annual surgical followup with surveillance and advice, genetic risk assessment and counseling.
Brain et al., 2011^132^ | Not reported | Clinician | Women with a family history of breast cancer receive a specialist genetic assessment service. Control group received general risk level (low/population, moderate, or high) based on age, reproductive history and minimal family history; Intervention group received a specific percentage based on Claus model based on detailed family pedigree; genetic testing was available to women in Intervention group at high risk (≥ 25% risk).
Braithwaite et al., 2005^133^ | Not reported | Clinical nurse specialist | Risk counseling: received pedigree with information from family history and assessed risk as low, moderate, or high based on GRACE guidelines, and participants were mailed letters summarizing content afterward.; GRACE: completed pedigrees in GRACE and assessed their risk, learning their risk assessment and how to manage their risk, they received a numerical estimate of lifetime risk, a visual display of cumulative risk with general population as comparator, and a qualitative description, the clinical nurse specialists then offered to book mammography and arrange meetings with geneticists, where appropriate.
Burke et al., 2000^67^ | Unclear | Genetic counselor | Adapted genetic counseling protocol for women with intermediate risk included pre-counseling telephone call gathering a complete family history, in-person genetic counseling session discussing breast cancer risk factors, focusing on issues relevant to the participant, reviewed pedigree information, communicated likelihood of mutation in participant’s family, risk estimate sheet given to participant based on the Gail and Claus models and National Cancer Institute statistics for average risk, information about genetic testing, recommendations for breast cancer screening, and a followup letter summarizing the genetic counseling session.
Cull et al., 1998^68,^* | Breast cancer family clinic | Geneticist and breast surgeon | Individual meeting with geneticist to discuss individual risk and with breast surgeon to discuss risk management, participants either received a copy of the educational video about 10 days before the clinic consultation or took the video home after the post-clinic assessment.
Fry et al., 2003^134^ | Familial Breast Cancer Clinic | Genetics consultant and specialist breast surgeon; Geneticist and genetics nurse specialist | Standard (regional) service: self-report family history and baseline questionnaire completed by all women; genetics consultant and genetics nurse specialist assigned categorical risk via Cancer Research Campaign. Women at low risk received a letter; women at moderate or high risk were offered an appointment at familiar breast cancer clinic where a genetics consultant discussed risk status and breast surgeon discussed risk management. Where appropriate, clinical exams and mammography were included in the appointment. Patients’ general practitioners received summary data, and patients received followup questionnaires 4 weeks and 6 months later.; Novel (Community-based) service: all women sent an appointment for a community-based clinic near their residence. Meetings run by genetics nurse specialist where family history was collected and compared to published criteria (Cancer Research Campaign) to determine risk. Women at low risk offered information, reassurance, and discharged. Women at increased risk (moderate or high) were offered an appointment at a regional center with a geneticist and genetics nurse specialist, and asked to complete followup questionnaires at 4 weeks and 6 months.
Gurmankin et al., 2005^135^ | University breast and ovarian cancer risk evaluation program | Health care provider | Pre-counseling interview: assessed patient’s breast cancer risk perception, BRCA mutation risk perception, worry about breast cancer, family history of cancer, breast cancer risk reduction behaviors, and demographic information.; Post counseling interview: assessed patient’s breast cancer risk, BRCA mutation risk, recall of actual risk information, and worry about breast cancer.
Helmes et al., 2006^136^ | Not reported | Board certified genetic counselor | In-person counseling: review of family history, discussion of breast cancer risk, and education about breast cancer genes, discussed genetic testing considerations, including implications of results, testing strategies, potential risks and benefits of test, costs and psychological effects of test, gave information packet with personal risk information comparing woman’s risk with average woman’s risk, personal computer-drawn 3-generation pedigree, brochures on self-breast exams, pap test, and mammography; genetics visual aids, and list of community resources.; Telephone counseling: information packet was sent in the mail with instructions to open at the beginning of the telephone counseling, which was identical in content and structure to in-person counseling.
Hopwood et al., 1998^137^ | Family history clinics | Unclear | Family history consultation, not otherwise described.
Hopwood et al., 2004^138^ | Cancer genetic service centers | Genetic counselor | Genetic counseling prior to testing varied by participating center, but offered or recommended some of the following: risk estimation (based on molecular genetic analysis or more often on family history), genetic risk counseling, clinical examination, screening/surveillance for early tumor detection (mammography, endoscopy, etc.), information on preventative strategies (surgery, diet, etc.), family planning advice, and referral for psychological assessment/support.
Kelly et al., 2008^139^ | Not reported | Genetic counselor | Review of family cancer history, personal risk factors for breast and ovarian cancer, mechanisms of cancer inheritance, meaning of a positive and negative test result, and risks and benefits associated with testing.
Lerman et al., 1996^140^ | Comprehensive cancer centers | Genetic counselor | Discussion of individual factors contributing to elevated risk, presentation of individualized risk data, recommendations for annual mammography and clinical breast exams, and instruction in breast self-exam.
Lerman et al., 1999^69^ | Hospital and cancer center | Oncology nurses or genetic counselor | Education only: topics discussed included individual risk factors for breast and ovarian cancer and patterns of inheritance for breast and ovarian cancer susceptibility, subjects given qualitative estimates of risk of developing breast and ovarian cancer, and pedigrees reviewed, potential benefits, limitations, and risks of genetic testing for inherited breast and ovarian cancer susceptibility reviewed.; Education plus counseling: provided the same education and materials described above and subjects were guided through questions exploring personal issues related to cancer and genetic testing, discussed the emotional impact of having a family history of cancer, psychosocial implications of genetic testing for inherited breast and ovarian cancer susceptibility, anticipated reactions to positive and negative test result, and intentions to communicate test results to family members and friends.
Lobb et al., 2004^141^ | Not reported | Clinical geneticists, an oncologist, and genetic counselors | Counselors provided counseling at their discretion and study was to assess the different aspects of counseling, which included information giving concerning: breast cancer genetics, genetic testing, family history and risk, prophylactic surgery, breast cancer prevention, screening and management; communication style including: facilitating patient involvement, facilitating understanding, patient centeredness and partnership building, and supportive and counseling communications.
Matloff et al., 2006^142^ | Not reported | Certified genetic counselor | Personalized letter summarizing patient data.
Mikkelsen et al., 2007^143^ | University clinical departments | Physicians | Information on incidence of sporadic breast cancer, genetics, inheritance patterns, and estimated personal lifetime risk of inherited cancer.
Mikkelsen et al., 2009^144^ | University clinical departments | Physicians | See Mikkelsen et al., 2007^137^
Pieterse et al., 2011^145^ | Department of medical genetics | Clinical geneticists, residents in clinical genetics, genetic counselors | Session topics included family’s occurrence of breast and other cancers, inheritance, and criteria on probability of inherited breast cancer, and the likelihood of hereditary breast cancer running in the family was estimated.
Roshanai et al., 2009^146^ | University cancer genetic clinic | Specialist nurse | Included pedigree explanation, Buckman’s Breaking Bad News model to inform at-risk relatives, pamphlet, videotape, copies of pedigree, and medical records.
Watson et al., 1998^148^ | Hospitals | Clinical geneticist | Consultation provided information on pedigree based on risk calculation and information regarding management options based on risk level, with instructions offered on self-exam and clinical exam, with the intervention group also receiving an audiotape of the consultation to take home.
Watson et al., 1999^149^ | Genetic counseling centers | Clinical geneticists | Not described.

Abbreviations: BRCA=breast cancer susceptibility gene; GRACE=Genetic Risk Assessment in the Clinical Environment; U.K.=United Kingdom

Studies used various measures including the Cancer Worry Scale (CWS) and the State-Trait Anxiety Inventory (STAI) to measure breast cancer worry; the Hospital Anxiety and Depression Scale (HADS), Impact of Events Scale (IES), General Health Questionnaire (GHQ), and Visual Analogue Scale (VAS) to measure anxiety and depression; and general Likert scales to measure intention for genetic testing and understanding of risk. These measures are described in Table 4.

Table 4 Standardized Measures Used to Assess Distress

Measure | Abbreviation | Description
Beck Depression Inventory^247^ | BDI | A 21-question multiple-choice self-report inventory for measuring the severity of depression. Scores of 0 to 9 indicate minimal depression, 10 to 18 mild depression, 19 to 29 moderate depression, 30 to 63 severe depression.
Beck Hopelessness Scale^269^ | BHS | A 20-item scale to quantify hopelessness with scores ranging from 0 to 20 and a score above 9 indicating suicidal ideations.
Body Image after Breast Cancer^246^ | BIBC | A 53-item questionnaire to assess the long term impact of breast cancer on body image in 6 key areas: vulnerability, body stigma, limitations, body concerns, transparency, arm concerns.
Body Image Scale^256^ | BIS | A 10-item questionnaire for assessing body image changes in patients with cancer.
Brief Symptom Inventory^253^ | BSI | A 53-item self-reported psychological symptom scale.
Center for Epidemiologic Studies-Depression^266^ | CES-D | Measures symptoms of depression on a 20-item scale with scores ranging from 0 to 60; scores above 15 indicating high levels of depressive symptoms.
Coping Orientation to Problems Experienced Scale^253^ | COPE | Covers 14 coping strategies as potential responses to stressors.
Decision Regret Scale^250^ | DRS | A 5-item questionnaire to measure dissatisfaction or misgiving after making a medical decision.
DUKE Social Support Questionnaire^262^ | DUKE-SSQ | Used to measure access to and satisfaction with social support on 8 items with scores ranging from 1 to 5. Affective subscale (DUKE-SSQ-A) includes items 1, 2, & 8; confident subscale (DUKE-SSQ-C) includes items 3 to 7.
Emotional Approach Coping Scale^268^ | None | A 52-item questionnaire to measure both problem-solving (items 1-20) and emotion based (items 21 to 32) coping strategies. An additional 4 questions pertain to alcohol and drug use.
EuroQoL-5 Dimensions^260^ | EQ-5D | A short, self reported questionnaire designed to evaluate an individual’s state of overall health in 5 areas: mobility, self-care, usual activities, pain/discomfort, and anxiety/depression.
General Health Questionnaire^258^ | GHQ | A 60-item questionnaire to screen individuals for psychiatric disorders, scores are given as means and scores above 3 indicate disorders; a 30-item version of the same questionnaire uses a threshold of 6 to indicate general psychological distress.
Health Anxiety Inventory^264^ | HAI score | The short version of the full Health Anxiety Inventory used to measure health anxiety.
Health-Related Quality of Life^243^ | HR-QOL | A 14-item self-report questionnaire to assess an individual’s quality of life based on: healthy days (items 1 to 4), activity limitations (items 5-9), and symptoms (items 10 to 14).
Hospital Anxiety and Depression Scale^249^ | HADS | A 14-item self-report scale for the detection of depression and anxiety in hospitalized patients. Scores range from 1 to 21 interpreted as: normal (0 to 7), mild (8 to 10), moderate (11 to 14), severe (15 to 21). Subscales for anxiety (HADS-A) and depression (HADS-D).
Impact of Events Scale^275,^ ^257^ | IES | A 15-item or 17-item questionnaire to measure an individual’s level of distress in relation to a specific event or condition. Scores range from 0 to 75, scores 9 to 25 indicate moderate difficulties and above 26 indicate clinical adaptation difficulties. Several variations are also used: Impact of Events Scale Revised (IES-R) 22-items (items A-V); Impact of Events Subscale- Intrusive Events (IES-I) items: A, B, C, F, I, N, P, T; Impact of Events Subscale-Avoidance (IES-A) items: E, G, H, K, L, M, Q, V; Impact of Events Subscale-Hyper arousal (IES-H) items: d, j, o, r, s, u.
Lerman Breast Cancer Worry Scale^259^ | CWS or LCWS | A 3-item questionnaire to measure how frequently an individual worries about getting breast cancer, and the impact of worrying on mood and performance of daily activities. A 6-item version of the same questionnaire has scores ranging from 6 to 24; higher scores mean greater levels of worry
Medical Coping Modes Questionnaire^267^ | MCMQ | A 19-item self-report questionnaire to quantify coping styles into 1 of 4 categories: confrontive, avoidant, resigned, nondominant
Medical Outcomes Study 36-Item Short Form^261^ 12-Item Short Form^273^ Swedish Short Term-36 Health Survey^271^ | SF-36 or MOS SF-36 | A 36 question health questionnaire for measuring health and well being in 8 core areas: physical functioning, role limitations due to physical health, bodily pain, general health perceptions, vitality, social functioning, role limitations due to emotional problems, mental health. The 12-item Short Form and Swedish Short Term-36 Health Survey are two of many variations.
Menopause-Specific Quality of Life Questionnaire^263^ | MENQOL | A 29-item self-administered questionnaire to assess health-related quality of life post-menopause.
Multidimensional Impact of Cancer Risk Assessment^252^ | MICRA | A measure of the impact of genetic test result disclosure in terms of distress, uncertainty, and positive–experience scales
Multidimensional Fatigue Symptom Inventory-Short Form^270^ | MFSI-SF | A 30-item questionnaire to measures perceived sleep disturbance.
Perceived Personal Control scale^248^ | PPC | A measure of genetic counseling outcomes, assesses counselees’ perceptions of the degree of control they have over their genetic condition.
Pittsburgh Sleep Quality Index^254^ | PSQI | A measure of subjective sleep disturbance in clinical populations.
Post-Traumatic Growth Inventory^245^ | PTGI | An instrument for assessing positive outcomes reported by persons who have experienced traumatic events.
Satisfaction with Decision Scale^255^ | SWD | A 6-item scale that measures satisfaction with health care decisions.
Sexual activity questionnaire^272^ | SAQ | A 3 section self-reported questionnaire to assess sexual functioning, including: hormonal status, reasons for sexual inactivity, sexual functioning.
State-Trait Anxiety Inventory^244^ | STAI | Measures an individual’s current anxiety feelings. Scores range from 10 to 40. Scores above 22 indicate high anxiety.
Symptom Checklist-90^265^ | SCL-90 | A 90 question self-reported questionnaire to assess psychological status in the following categories: somatization (https://en.wikipedia.org/wiki/Somatization), obsessive-compulsive (https://en.wikipedia.org/wiki/Obsessive-compulsive), interpersonal sensitivity, depression (https://en.wikipedia.org/wiki/Depression_%28mood%29), anxiety (https://en.wikipedia.org/wiki/Anxiety), hostility (https://en.wikipedia.org/wiki/Hostility), phobic anxiety, paranoid ideation (https://en.wikipedia.org/wiki/Paranoid_ideation), psychoticism (https://en.wikipedia.org/wiki/Psychoticism).
Visual Analogue Scale^274^ | VAS | Any of a number of pain self-assessment tools where subjects indicate their level of pain in response to a continuous visual scale (no pain to worst pain ever experienced).

#### Breast Cancer Worry/Distress

Of 17 studies evaluating breast cancer worry, one reported increased measures after genetic counseling, but only in women at high-risk;^131^ eight reported decreases;^127,130,132–134,136,138,144^ and eight reported no associations.^67,69,71,129,137,140,148,149^ Some studies showed mixed results that varied by subgroup or type of counseling.^69,128,131,132^

Most studies compared genetic counseling with no counseling, or changes before and after counseling.^69,127–129,131–133,137,138,140,144,149^ A fair-quality prospective cohort study found that cancer-specific distress of high-risk women undergoing counseling decreased more from baseline to 1 year post-counseling (from 52 to 41% of women) than high-risk women without genetic counseling (from 41 to 35% of women), or a random sample of women from the general population without counseling (from 32 to 30%).^144^ Similarly, two before and after studies, using a modified CWS, reported reductions in cancer worry after genetic counseling compared with baseline.^132,138^ ^138^,^132^ Cancer worry also decreased after genetic counseling in a before and after study using the IES,^127,128^ and a fair-quality RCT of women at moderate- or high-risk.^134^

Some studies compared different types of genetic counseling.^67,71,130,134,136,148^ A fair-quality RCT reported that women who received either in-person or telephone counseling had decreased CWS worry scores 3 months after counseling compared with a control group that did not receive counseling.^136^ More women in the in-person counseling group felt they could discuss their concerns during counseling sessions compared with women who received telephone counseling (77.4 vs. 67.3%, respectively, p<0.05). A fair-quality RCT reported decreases in cancer worry 6 months after both group and individual genetic counseling compared with a noncounseling control group.^130^ Another study comparing a computer intervention with an in-person counseling session reported decreased worry in both groups 3 months after counseling, with no differences between groups.^133^

#### Anxiety and Depression

Of 13 studies evaluating anxiety associated with genetic counseling, none reported increases, five reported decreases,^71,131,133,145,146^ and eight reported no associations.^68,127,137,138,141,144,148,149^ Seven studies of depression also showed no increases in measures of depression, while one study indicated decreases,^146^ and six reported no associations.^68,71,127,141,144,148^

Results were consistent regardless of the type of counseling provided,^68,71,148^ as demonstrated in a good-quality RCT that compared enhanced services with usual care.^146^ In this study, women receiving genetic counseling from a nurse specialist in addition to resources about informing at-risk relatives, a pamphlet, and a videotape were compared with women receiving genetic counseling with no additional resources. Both groups reported significant decreases in mean anxiety and depression scores, as measured by the HADS, at 2 weeks and 8 months after counseling, with no significant differences between groups. None of the mean scores reached the clinical threshold (score of 8 or more) for diagnosing either anxiety or depression.

#### Understanding of Risk

Of 22 studies evaluating genetic counseling’s association with women’s understanding of their level of cancer risk, 14 reported increased understanding,^67,71,130,131,133–137,140,142,145,146,148^ one reported decreased understanding,^139^ six reported no associations,^125,129,138,141,143,149^ and one reported mixed results.^68^ Only one study assessed risk for ovarian cancer and found that women underestimated their risks by 5 percent at 6 months after counseling.^139^ Most studies measured women’s understanding of risk by comparing a woman’s perceived risk of cancer (higher risk vs. same or lower than other women their age) with an objective measure; or agreement of a woman’s understanding of risk with the genetic counselor’s appraisal.

The new before and after study of 89 women in the Netherlands showed that agreement of a woman’s understanding of breast cancer risk with her genetic counselor’s appraisal decreased 1 year after counseling compared with immediately after (49% agreement vs. 35%).^125^ However, this study did not describe details of the counseling intervention, and may not be applicable to U.S. practice.

In the 2013 review, a fair-quality systematic review included 19 studies published before February 2007 of women’s understanding of risk after genetic counseling.^147^ In these studies, outcomes were measured by changes in the proportion of women who accurately perceived their risk, and by the degree of overestimation or underestimation of risk. Overall, the proportion of women who accurately perceived their risk increased from an average of 42 percent before to 58 percent after counseling. Women who overestimated their risks did so by approximately 18 percent (range 6 to 40%) after counseling, which was an improvement from 25 percent before counseling. Seven studies indicated counseling that delivered information about family history, heredity, and personal risk estimates improved understanding of risk. Improvement was also measured in three of five studies that included education about heredity; and in three of six studies when counseling facilitated informed decision making and adaptation to personal risk.

#### Intent to Participate in Genetic Testing

Five studies in the 2013 review evaluated genetic counseling’s associations with intention for genetic testing; one study reported increased intention,^69^ four reported decreased intention,^67,130,131,136^ and none reported no associations. A study comparing telephone counseling versus in-person counseling versus no counseling determined that participants’ intentions to pursue genetic testing were similar between groups at baseline.^136^ Three months after genetic counseling, intention scores increased for the control group, but decreased for the two counseling groups. Three fair-quality RCTs reported decreased interests in genetic testing 6 months after group and/or individual counseling.^66,67,130^ Interest in testing for women randomized to counseling decreased more than those in the control group in two of the studies.^67,130^ The third study showed decreases in all groups at 6 months followup.^66^ One fair-quality RCT reported increased interests in genetic testing 1 month after individual counseling among black women, but not for white women who had decreased interests in genetic testing.^69^

## Key Question 2c What Are Optimal Testing Approaches to Determine the Presence of Pathogenic BRCA1/2 Mutations in Women at Increased Risk for BRCA1/2-Related Cancer?

## Key Question 3c What Are Adverse Effects of Genetic Testing?

### Summary

One new good-quality RCT evaluated outcomes of different testing approaches. This study indicated that population-based testing detected more BRCA1/2 mutations than family-history based testing among Ashkenazi Jews, however, it did not determine health outcomes related to increased detection.^164^ Measures of anxiety, health anxiety, depression, distress, uncertainty, and quality of life were similar between groups.

Five new studies reported adverse effects of genetic testing for BRCA1/2 mutations^150,157,161,163,170^ including two studies not included in the 2013 review because they enrolled women previously treated for breast or ovarian cancer or men. In one study, women who chose to receive their test results experienced decreased breast cancer related worry over the subsequent 12 months regardless of carrier status. Of two new studies of generalized anxiety after genetic testing, one showed higher generalized anxiety for mutation carriers compared with noncarriers after testing, while one did not. Another study found that men and women who declined testing after initial pre-test counseling sessions did so because of fear of the psychological impact of the test results.

The new studies are generally consistent with the 2013 review indicating genetic testing is associated with increased distress in the short-term. In these studies, breast cancer worry and anxiety increased for women with positive results and decreased for others, although results varied across studies. Women’s understanding of their risk generally improved after receiving test results.

### Evidence

Seven new studies^150,157,161,163,164,170,172^ (Table 5 and Appendix B Table 8) and 14 observational studies (in 16 publications) in the 2013 review^151–156,158–160,162,165–169,171^ met inclusion criteria for these key questions. One study evaluated approaches to testing for BRCA1/2-related cancer, and the others determined psychological benefits and harms of genetic testing for BRCA1/2-related cancer measured as changes in worry, anxiety, depression, and understanding of risk. Two studies were not included in the 2013 review because they enrolled women previously treated for breast or ovarian cancer or men.^150,170^ No studies described other adverse effects of testing, such as the impact of false-positive or negative results or use of additional risk-reducing interventions.

Table 5 Studies of Distress After Genetic Testing

Author, year Quality rating | N, study design | Mutation status | Genetic counseling | Comparison | Measures | Breast cancer worry | Anxiety | Depression
Current Review
Andrews et al., 2004^150^; Fair | 60; pre-post | Positive or negative | Not described | A) Pretest (n=49); B) 7 to 10 days post results (n=31); C) 4 months post results (n=32); D) 12 months post results (n=27) | BDI, IES, STAI | 0 A vs. B X decrease C & D vs. A | 0 | 0
Lieberman et al., 2017^161^; Good | 1771; prospective cohort | Positive or negative | Low risk noncarriers received a letter including test results and routine surveillance recommendations; high risk noncarriers received in-person genetic counseling; | A) Carriers (n=19); B) Noncarriers (n=604); C) Self-referral (n=398); D) Recruited (n=417) | IES, PPC, STAI, SWD | X higher A vs. B & C vs. D | X higher A vs. B 0 C vs. D | NR
Lumish et al., 2017^163^; Fair | 103; prospective cohort | Positive or negative | Unknown | A) Carriers (n=14); B) Noncarriers (n=69); C) VUS (n=20) | IES, MICRA, SWD | X higher A vs. B & C | NR | NR
Manchanda et al., 2015^164^; Good | 1017; RCT | Positive or negative | Qualified genetic counselor with supervision from Regional Genetics Centre and a clinical fellow with experience in cancer genetics and management; structured to meet the goals of genetic counseling and cancer risk assessment. | A) FH-based strategy for testing; B) Population-based strategy | HADS, HAI score, MICRA, SF-12 | NR | 0 | 0
Smith et al., 1999^170^; Good | 125,^*^ prospective cohort | Positive or negative | Not described | A) Carrier (n=47); B) Noncarriers (n=78) | IES | X higher A vs. B | NR | NR
2013 Review
Arver et al., 2004^151^; NA | 63; pre-post | Positive or negative | Genetically trained oncologist and oncology nurse | A) Pretest; B) 2 months post results; C) 1 year post results | HADS, SF-36 | NR | X decrease C & B vs. A | 0
Dagan and Shochat, 2009^152^; Fair | 73; case-control | Positive or negative | Unknown | A) Carriers (n=17); B) Noncarriers (n=20); C) Age-matched controls (n=36) | BSI, CRW, HR-QOL | X higher A & B vs. C | 0 | 0
Ertmanski et al., 2009^153^; NA | 56; pre-post | Positive | Unknown | A) Pretest; B) 1 month post results; C) 1 year post results | IES, STAI | NR | 0 | NR
Foster et al., 2007^154^; Fair | 154; prospective cohort | Positive or negative | Unknown | A) Carriers (n=53); B) Noncarriers (n=101) | CWS-R, GHQ | X decrease over time for A & B | X increase over time for A & B | NR
Geirdal et al., 2005^156,†^; Good | 10,244; prospective cohort | Positive or unknown | Unknown | A) Positive (n=68); B) Not tested but FBOC (n=176); C) Not tested, age-matched controls (n=10,000) | BHS, GHQ, HADS, IES | NR | X higher B vs. A | X higher B vs. A
Geirdal and Dahl, 2008^155,†^; Good | 242; prospective cohort | Positive or unknown | Unknown | A) Positive (n=68); B) Not tested, but FBOC (n=174) | COPE, HADS | NR | X higher B vs. A | NR
Low et al., 2008^162^; Fair | 47; prospective cohort | Positive, true negative, or uncertain (grouped with true negative) | Genetic counselor | A) Positive (n=7); B) True negative + uncertain (n=40) | COPE, IES-R, PTGI | NR | X higher A vs. B | NR
Meiser et al., 2002^165^; Good | 143 prospective cohort | Positive or negative | Unknown | A) Carriers (n=30); B) Noncarriers (n=59); C) Not tested (n=51) | BDI, IES, MBSS, NSI, STAI | X higher A vs. C | X lower B vs. A & C | X lower B vs. A & C
Metcalfe et al., 2012^166^; NA | 17; pre-post | Positive | Unknown | A) Pretest; B) 1 year post results; C) 2 years post results | IES | X increase B vs. A & C | NR | NR
Reichelt et al., 2004^167,‡^; Good | 209; prospective cohort | Positive, negative, or unknown | Medical geneticist or experienced genetic counselor | A) Carriers (n=141); B) Noncarriers (68) | BHS, GHQ, HADS, IES | NR | 0 | 0
Reichelt et al., 2008^168,‡^; NA | 181; pre-post | Positive or true negative | Genetic counselor | A) Pretest; B) 6 weeks post results; C) 18 months post results | HADS, IES | NR | 0 | 0
van Dijk et al., 2006^171^; Good | 132; prospective cohort | Positive, true negative, or uninformative | Unknown | A) Positive (n=22); B) True negative (n=41); C) Uninformative (n=69) | IES, NSI | X higher A vs. B & C | X higher A vs. B & C | NR

X = statistically significant; 0 = studied but not significant

* The study included 87 males which are described in the evidence table and text, but not on this table.

† Studies use the same population (Geirdal et al,, 2005 and Geirdal and Dahl, 2008)

‡ Studies used the same population (Reichelt et al., 2004 and Reichelt et al., 2008)

Abbreviations: BDI=Beck Depression Inventory; BHS=Beck Hopelessness Scale; BSI=Brief Symptom Inventory; COPE=Emotional Approach Coping Scale; CRW=Cancer-Related Worry Scale; CWS-R=Cancer Worry Scale-Revised; FBOC=familial breast and/or ovarian cancer; GHQ=General Health Questionnaire; HADS=Hospital Anxiety and Depression Scale; HR-QOL=Health Related-Quality of Life; IES=Impact of Events Scale; IES-R=Impact of Events Scale-Revised; MICRA=Multi-dimensional Impact of Cancer Risk Assessment; MBSS=Miller Behavioral Style Scale; MICRA=Multidimentsional Impact of Cancer Risk Assessment; NA=not applicable; NR=not reported; NSI=not standardized instrument; PPC=Percieved Personal Control; PTGI=Post-Traumatic Growth Inventory; SF-36=Swedish SF-36 Health Survey; STAI=State-Trait Anxiety Inventory; SWD=Satisfaction with Decision Instrument; VUS=variant of uncertain significance

Of the six new studies, four met criteria for good-quality^157,161,164,170^ and two for fair.^150,163^ One poor-quality study is not discussed further in this report.^172^ Of eight cohort studies included in the 2013 review, five met criteria for good-quality,^155,156,159,165,167,171^ two for fair,^154,162^ and one for poor.^160^ The remaining studies include a fair-quality case-control study,^152,169^ and five studies with before and after designs for which quality rating criteria are not available.^151,153,158,166,168^ Limitations include unclear enrollment information,^154,160,162^ high loss to followup,^162^ and differences between groups at baseline or lack of reporting of baseline characteristics of participants.^154,160,162^

Fourteen studies (in 16 publications) from the 2013 review, including cohort, case-control, and before and after designs, reported breast cancer worry and anxiety and women’s understanding of risk related to BRCA1/2 testing. In these studies, breast cancer worry and anxiety increased for women with positive results and decreased for others, although results varied across studies. Understanding of risk generally improved after receiving genetic test results. Limitations of studies included lack of studies with comparison groups, variations in methodology and enrollment criteria, and high loss to followup (Appendix B Tables 2-5).

Studies used a variety of metrics to measure worry related to genetic testing. These included the Cancer Related Worry (CRW) Scale and CWS-R (CWS-Revised), STAI, HADS, IES, GHQ, Swedish Short Form 36-item (SF-36) Health Survey, Short Form 12-question (SF-12) Health Survey including the Physical Health Component Scale (PCS) and Mental Health Component Scale (MCS) of the SF-12, Health Anxiety Inventory (HAI) scale, Coping Orientation to Problems Experienced Scale, Emotional Approach Coping Scale (COPE), Beck Depression Inventory (BDI), Post-Traumatic Growth Inventory (PTGI), Miller Behavioral Style Scale (MBSS), Multidimensional Impact of Cancer Risk Assessment (MICRA) scale, Multidimensional Fatigue Symptom Inventory-Short Form (MSFI-SF), Beck Hopelessness Scale (BHS), Brief Symptom Inventory (BSI), Perceived Personal Control (PPC) scale, Satisfaction With Decision (SWD) Instrument, and Center for Epidemiologic Studies-Depression Scale (CES-D). These measures are described in Table 4. Studies also used general Likert scales to measure perceived personal control, knowledge of breast cancer testing, satisfaction with health decisions, and general satisfaction with the decision to undergo testing, as well as qualitative methods to understand reasoning behind choices to not pursue testing.

#### Genetic Testing Approaches

A large, good-quality trial in the United Kingdom randomized 691 women and 343 men of Ashkenazi Jewish ancestry to population-based BRCA1/2 mutation testing versus family history-based testing.^164^ The study evaluated the prevalence of mutations identified, psychological outcomes, and quality of life for each testing approach. Volunteers with self-reported Ashkenazi Jewish ancestry (4 grandparents) were recruited through community charities, religious groups, pharmacy chains, and a website. Those with known BRCA1/2 mutations, previous BRCA1/2 testing, or first-degree relatives with BRCA1/2 mutations were excluded.

All participants received structured, nondirective pretest genetic counseling. After genetic counseling, those who decided to undergo testing were randomized to testing groups. Genetic testing was performed on all participants randomized to population-based testing, and only on participants meeting criteria for high-risk randomized to family-history based testing. Testing involved sequencing analysis of BRCA1 exons 1 and 20 and a segment of BRCA2 exon 11 for three Jewish founder mutations performed by a National Health Service (NHS) clinical genetics laboratory. Mutation carriers were notified in person and advised to seek referral to an NHS regional genetics clinic for confirmatory testing and risk-management services. Mutation-negative volunteers who met family history criteria for high-risk were also referred to genetic clinics.

The detected prevalence of BRCA1/2 mutations among participants was 2.45 percent overall, with 13 BRCA1/2 carriers identified by population testing and 9 by family history. However, over 3 years of followup, 210 of the 438 family history negative participants opted to complete testing. This subsequent testing identified an additional five carriers among family history negative participants. Thus, a family history based testing approach would miss 56 percent of carriers in the population (15 of 27 carriers).^164^ However, whether detection of BRCA1/2 carriers in families without cancer history leads to improved clinical outcomes, such as reduced cancer incidence and mortality, was not evaluated in this study.

This study used the MICRA scale to assess distress, uncertainty, and experience after genetic testing; and the MCS and PCS subscales of the SF-12 to measure quality of life. Measures of anxiety, health anxiety, depression, distress, uncertainty, and quality of life were similar between family history and population testing groups at 7 days and 3 months after testing.^164^

#### Breast Cancer Worry/Distress

Of nine studies evaluating breast cancer worry, seven reported increases after genetic testing,^152,161,163,165,166,170,171^ particularly for mutation carriers; two reported decreases;^150,154^ and none reported no associations.

Two studies that were not part of the 2013 review because they included women previously treated for breast or ovarian cancer or men were included in this update.^150,170^ A study of 60 Ashkenazi Jewish women in the United Kingdom (10 with previous breast or ovarian cancer and 50 without) who received risk assessment and counseling about advantages and disadvantages of genetic testing assessed breast cancer worry, depression, and anxiety outcomes over 12 months of followup.^150^ Forty-three women chose to learn their testing results and 79 percent of them returned a 12-month followup questionnaire. Women without previous breast or ovarian cancer who chose to receive their results had a statistically significant decrease in breast cancer worry at 12 months regardless of their carrier status.^150^

A good-quality cohort study of 212 members of an established Utah-based BRCA1 kindred (K2082 has more than 750 living adult members) demonstrated that male and female mutation carriers experienced more distress than noncarriers.^170^ Also, female carriers had more distress than female noncarriers and male carriers or noncarriers. Short-term (1 week) reactions to results of genetic testing varied by gender and were influenced by the results of siblings, including whether siblings had been tested and were carriers.

A fair-quality cohort study of 103 women with family histories of breast and ovarian cancer in a genetics clinic assessed understanding and psychological outcomes after BRCA1/2 mutation testing.^163^ Satisfaction with the decision to undergo testing did not differ between women identified with positive (pathogenic BRCA1/2 mutations), VUS, or negative (no mutation) results. Distress measured by MICRA and IES was highest among women with positive versus VUS or negative results. Women with positive or VUS results had higher positive experience MICRA subscale scores than women with negative results.

Six studies from the 2013 review reported breast cancer-related worry after receiving BRCA1/2 test results;^152,154,158,165,166,171^ five reported increased worry. In a good-quality prospective cohort study, women with positive results had increased worry compared with women with true negative or uninformative results 1 and 7 months after disclosure of results.^171^ A fair-quality case-control study found no differences in worry between carriers and noncarriers with high family history risk after a mean of 8 years since receiving test results as measured by the CRW scale.^152^ However, carriers and high-risk noncarriers had higher levels of worry than low-risk women who were not tested (p=0.022). In a study of 17 mutation carriers, breast cancer worry increased from baseline to 1 year after disclosure of genetic test results and decreased at 2 years, though scores remained in the mild distress range (IES 5.2 vs. 23.8 vs. 17.2; p=0.05).^166^ Two additional cohort studies indicated higher levels of breast cancer distress for carriers compared with noncarriers or women not tested, 1 year^165^ and 3 years or more after genetic testing. ^158^ A decrease in breast cancer worry for both carriers and noncarriers from baseline to 3 years after disclosure of genetic test results was reported in one study (CRW-R scale mean decrease of 1.3 and 2.2 respectively).^154^

#### Anxiety

Of 13 studies evaluating anxiety, four reported increases after genetic testing;^154,161,162,171^ two reported higher anxiety scores for women who did not get tested compared with those tested;^155,156,165^ two reported decreases after genetic testing;^151,165^ and six reported no associations.^150,152,153,164,167,168^

Three new studies evaluated generalized anxiety after genetic testing,^150,161^ including the RCT of population versus risk-based testing described previously.^164^ A prospective cohort study of 1,771 Ashkenazi Jews enrolled through clinic recruitment and self-referral reported higher generalized anxiety for carriers compared with noncarriers 6 months after testing (STAI-6 score 12.6 for carriers vs. 9.9 for noncarriers, p=0.016; IES 19.9 for carriers vs. 4.9 for noncarriers, p<0.001).^161^ Another new study found no changes in anxiety 1 year after genetic testing for either carriers or noncarriers, regardless of whether they had a personal history of BRCA1/2-related cancer.^150^

In the 2013 review, studies were inconsistent regarding whether anxiety increases after genetic testing for carriers and noncarriers. The largest study, a good-quality prospective cohort study, reported higher anxiety scores in women with family histories of breast cancer who were not tested compared with tested women 6 weeks after receiving positive results (HADS mean 5.3 vs. 4.2, respectively, p<0.05).^155,156^ However, there were no differences between groups in the prevalence of HADS-defined anxiety (24% in both groups). In a good-quality cohort study, noncarriers, compared with carriers and women who did not get tested, had lower anxiety scores at 7 to 10 days followup (STAI mean 31.6 vs. 38.5 vs. 36.8, respectively, p=0.024), though all scores indicated high anxiety.^165^ Three additional studies reported increased anxiety among carriers 6 months ^171^ and 8 years after testing,^162^ and among both carriers and noncarriers 3 years after testing.^154^

Four studies reported no differences in anxiety either over time^153,168^ or between carriers, noncarriers, and age-matched controls,^152,167^ with all scores below the case cutoff threshold. A small study reported decreased anxiety scores 1 year after women received results compared with pretest evaluations regardless of carrier status (HADS mean 5.6 pretest vs. 4.2, p<0.001).^151^

#### Depression

Of eight studies evaluating depression, none reported increases after genetic testing; one reported decreases;^165^ one reported higher depression scores for untested versus tested women;^156^ and six reported no associations.^150–152,164,167,168^ Two new studies reported no changes in measures of depression after testing for carriers, noncarriers, and women with previous breast or ovarian cancer,^150^ and for those tested based on family-history or Ashkenazi Jewish ancestry.^164^

In the 2013 review, a good-quality prospective cohort study reported higher depression scores in untested women with family histories of breast cancer compared with tested women 6 weeks after receiving positive results (HADS mean 2.9 vs. 1.7, respectively, p<0.05), though scores did not reach the threshold for clinical depression.^156^ Four studies reported no differences in depression over time^151,168^ or between carriers, noncarriers, and age-matched controls,^152,167^ with all measures below the case cutoff threshold. In a good-quality cohort study, noncarriers, compared with carriers and untested women, had lower depression scores at 4 months followup (BDI mean 3.6 vs. 6.2 vs. 6.4, respectively, p=0.024), though scores did not reach the threshold for clinical depression.^165^

#### Other Psychological Responses

A new good-quality prospective cohort study described reasons for declining BRCA1/2 mutation testing using qualitative analysis of comments.^157^ In this study, 1,220 men and women from 385 high-risk families were offered testing, 886 received results, and 364 withdrew either before or after genetic testing. Most who withdrew stated that they were afraid of the psychological impacts of testing and saw no advantage to genetic counseling or testing, despite many having family members with known mutations.^157^

From the 2013 report, a fair-quality case-control study reported more subjective sleep problems in BRCA1/2 mutation carriers compared with noncarriers and age-matched controls 8 years after testing (Pittsburgh Sleep Quality Index mean 7.29 vs. 3.94 vs. 4.21, respectively, p=0.013).^169^ However, actual sleep duration, latency, and wakefulness, as measured by a wrist monitor, showed no differences between groups.

#### Understanding of Risk

A fair-quality prospective cohort study assessed risk perception among 103 women with mutation positive, VUS, or mutation negative results.^163^ Of women with positive results, 80 percent interpreted their result as indicating higher risk of breast cancer, and none interpreted results as indicating certainty of breast cancer. Most of the mutation negative group (67%) interpreted their negative result to mean they had lower risk of developing breast cancer. However, 19 percent with negative results indicated that their results did not clarify their perceived risk, and 4 percent interpreted the negative result as indication that they had no risk of breast cancer. Seven of the 20 patients with VUS results indicated that their result was likely to impact their decision to have additional or more frequent screening.

In a good-quality prospective cohort study of 246 women from the 2013 review, the number perceiving their risk of breast cancer as high or very high increased 18 percent 5 years after receiving a positive result compared with before receiving results (p=0.016).^159^ The number of noncarriers perceiving their risk as high or very high decreased 47 percent (p<0.001). Also, 20 percent more mutation carriers perceived their risk of ovarian cancer as high or very high (p=0.007) while 27 percent of noncarriers perceived their risk to be low (p<0.001).

## Key Question 2d What Are Optimal Post-Test Counseling Approaches to Interpret Results and Determine Eligibility for Interventions to Reduce Risk of BRCA1/2-Related Cancer?

## Key Question 3d What Are Adverse Effects of Post-Test Genetic Counseling?

No studies were identified that specifically addressed post-test counseling. Several studies included for Key Question 2b and 3b included discussion of management options as part of the pre-test counseling process, although none of them discussed testing results or evaluated benefits or harms of counseling conducted after receiving test results.

## Key Question 4 Do Interventions Reduce the Incidence of BRCA1/2-Related Cancer and Mortality for Women With Increased Risk?

### Summary

No effectiveness trials of intensive screening for breast or ovarian cancer in BRCA1/2 mutation carriers that report cancer or mortality outcomes have been published. Studies of performance characteristics of intensive screening may be useful in clinical decision making, but these studies do not directly address this key question. In two studies including 1,364 total BRCA1/2 mutation carriers, sensitivity of screening for breast cancer was 63 to 69 percent for MRI, 25 to 62 percent for mammography, and 66 to 70 percent for combined; specificity was 91 percent or higher for either modality alone or combined. In a study of 459 BRCA1/2 mutation carriers, sensitivity of screening for ovarian cancer was 43 percent for TVUS, 71 percent for CA-125, and 71 percent for combined; specificity was 99 percent for either modality alone or combined.

No trials of risk-reducing medications report results specifically for BRCA1/2 mutation carriers. A systematic review and meta-analysis of placebo-controlled RCTs of tamoxifen, raloxifene, and aromatase inhibitors anastrozole and exemestane, and a head-to-head trial of tamoxifen versus raloxifene provide efficacy outcomes for women at various risk levels.^78,79^ Trials are clinically heterogeneous and data are not available to compare doses, duration, and timing of use. Tamoxifen, raloxifene, and aromatase inhibitors reduced invasive breast cancer after 3 to 5 years of use compared with placebo; tamoxifen had a greater effect than raloxifene in the head-to-head trial. Risks for invasive cancer were reduced in all subgroups evaluated based on family history of breast cancer. Reduction was significant for ER positive, but not ER negative breast cancer. Noninvasive breast cancer and mortality were not significantly reduced and did not differ between medications.

Six observational studies reported outcomes of risk-reducing mastectomy, two of salpingo-oophorectomy, and seven of oophorectomy. Risk-reducing bilateral mastectomy was associated with 90 to 100 percent reduction in breast cancer incidence for high-risk women and BRCA1/2 mutation carriers. Breast cancer-specific mortality was reduced by 81 to 100 percent after risk-reducing mastectomy in one study. Newer studies of oophorectomy or salpingo-oophorectomy that control for biases did not show associations between surgery and breast cancer risk, though some studies showed reduced risk among younger women after surgery. Oophorectomy was associated with 69 to 100 percent reduction in ovarian cancer risk in two studies, but no differences in all-cause mortality.

### Evidence

#### Intensive Screening

Although searches identified multiple studies of intensive screening that included women with BRCA1/2 mutations, none reported changes in clinical outcomes (cancer incidence or mortality) attributable to screening. Most studies described performance characteristics of intensive screening, such as sensitivity and specificity that are relevant to screening decisions, however, these studies do not directly address this key question. These include three new studies of breast^215^ and ovarian cancer screening;^216,217^ and five observational studies (six publications) in the 2013 review.^198,201,203,204,218,219^ In these studies, prevalent cases were defined as cancer detected on the first round of screening, and incident cases were those detected on subsequent rounds (Table 6 and Appendix B Table 9).

Table 6 Studies of Test Characteristics of Mammography Versus MRI for Breast Cancer Screening^*^

Author, year | Risk categories, n | Inclusion criteria | Mean age at entry, years (range) | Screening interval | Followup, months | Mutation status | Mammography vs. MRI Sensitivity, % | Mammography vs. MRI Specificity, %
Breast Cancer
Current Review
Vreeman et al., 2018^215^ | BRCA1: 471; BRCA2: 299; All participants: 2773 | BRCA carrier; Positive FH of breast cancer; Personal history of breast cancer; Other (e.g. history of radiation, high-risk lesions) | BRCA1: 39 (23 to 75); BRCA2: 41 (23 to 73) | Annual | NR (retrospective) | BRCA1; BRCA2 | 45 vs. 63; C=66; 36 vs. 67; C=70 | 98 vs. 95; C=94; 98 vs. 94; C=94
2013 Review
Cortesi, et al., 2006^218^ | Mutation carrier: 48; High: 674; Intermediate: 257; Slight increase: 346 | BRCA carrier; Positive FH; Male breast cancer; Suspected positive FH | 42 (20 to 75); 42 (15 to 75); 43 (19 to 67); 40 (18 to 75) | Varied by risk category and age | Median 55 | Mutation carrier^†^ | 50 vs. 100 | NR
Leach, 2005^203^; MARIBS study | BRCA1: 39; BRCA2: 86; High: 424 | BRCA1 carrier/relative; BRCA2 carrier/relative; FH positive/other mutation/syndrome | Median 40 (31 to 55) | Annual | Variable, ≥2 scans per woman | BRCA1; BRCA2; All women | 23 vs. 92^‡^; C=92; 50 vs. 58; C=92; 40 vs. 77^‡^; C=94 | 92 vs. 79^‡^; C=74; 94 vs. 82^‡^; C=78; 93 vs. 81^‡^; C=77
Le-Petross, et al., 2011^204^ | BRCA1: 37; BRCA2: 36 | BRCA1 carrier/relative; BRCA2 carrier/relative | Median 44 (23 to 75) | Bi-annual, alternating | Median 24 | BRCA1/2 | Unable to report^§^ vs. 92 | 82 vs. 87
Rijnsburger, et al., 2010^219^; Dutch MRISC study | BRCA1: 422; BRCA2: 172; High: 1069; Moderate: 489; Other: 5 | BRCA1 carrier; BRCA2 carrier; 30 to 50% lifetime risk for BC^‖^ (high-risk); 15 to 30% lifetime risk for BC^‖^ (moderate-risk); Other mutation carrier | BRCA1: 39; BRCA2: 40; High-risk: 41; Moderate risk: 40 | Annual | 48 | BRCA1; BRCA2; High Moderate | 25 vs. 67^‡^; 62 vs. 69; 46 vs. 77; 47 vs. 67 | 95 vs. 91; 94 vs. 92; 95 vs. 89; 95 vs. 90

* Includes women from families with known mutations or breast cancer

† MRI was not used to screen other risk categories

‡ p<0.05

§ All screen-detected cancers were detected by MRI only, mammography was not performed after detection with MRI to calculate sensitivity

‖ Based on modified Claus tables

Abbreviations: BC=breast cancer; BRCA=breast cancer susceptibility gene; C=mammography plus MRI; FH=family history; MARIBS=Magnetic Resonance Imaging Breast Screening; MRI=magnetic resonance imaging; MRISC=Magnetic Resonance Imaging Screening Study; NA=not applicable; NR=not reporte

##### Breast Cancer

A new retrospective study included 471 BRCA1 and 299 BRCA2 mutation carriers screened at a single academic hospital in the Netherlands with annual breast MRI beginning at age 25 years, and annual mammography beginning at age 30 years.^215^ Diagnoses among BRCA1/2 carriers included 62 screen-detected breast cancers (invasive cancer and ductal carcinoma in situ), 11 symptomatic interval cancers, and 19 occult cancers detected at risk-reducing mastectomy. For BRCA1 carriers, sensitivity was 45 percent for mammography, 63 percent for MRI, and 66 percent for combined modalities. For BRCA2 carriers, sensitivity was 36 percent for mammography, 67 percent for MRI, and 70 percent for combined modalities. For all BRCA1/2 carriers, specificity was 94 percent or higher with either single or combined modalities.

Included in the 2013 review, the Dutch MRI Screening Study (MRISC), a prospective study including 594 BRCA1/2 mutation carriers, evaluated performance characteristics of biannual clinical breast examinations and annual concurrent contrast enhanced MRI and mammography.^219^ Digital mammography replaced film during the study period. The average age of participants at study entry was 40 years, and they were followed for a mean of 4 years. For BRCA1 mutation carriers diagnosed with breast cancer, sensitivities were 67 percent for MRI versus 25 percent for mammography (p=0.0129); for BRCA2 mutation carriers, sensitivities were 69 percent for MRI versus 62 percent for mammography (p=1.0).

The Magnetic Resonance Imaging Breast Screening (MARIBS) study, a prospective multicenter study conducted in the United Kingdom, evaluated screening of high-risk women including 120 BRCA1/2 mutation carriers using annual contrast enhanced MRI and mammography.^203^ Median age at entry of 40 years and duration of followup varied, but each woman completed at least two annual screens. For BRCA1 mutation carriers or women related to carriers, sensitivity of MRI alone (92%) or combined with mammography (92%) was higher than mammography alone (23%), but less specific (79% MRI vs. 74% combined modalities vs. 92% mammography). For BRCA2 carriers or women related to carriers, sensitivity of MRI combined with mammography (92%) was higher than either method alone (MRI 58%, mammography 50%); specificity of mammography alone (94%) was higher than MRI alone (82%) or combined modalities (78%).

Two additional studies were limited by small numbers of participants. A retrospective chart review of 73 BRCA1/2 mutation carriers or first-degree relatives at a high-risk cancer clinic in the United States evaluated outcomes after screening with MRI alternating with mammography every 6 months in addition to 6-monthly clinical breast examinations.^204^ Women had at least two screening cycles and were followed for a median of 2 years. All 11 screen-detected cancers were found on MRI (92% sensitivity, 87% specificity), and estimates for mammography could not be calculated. A prospective study including 48 BRCA1/2 mutation carriers in Italy evaluated screening with mammography, ultrasound, and clinical breast examinations.^218^ However, only four mutation carriers developed breast cancer in this study.

##### Ovarian Cancer

A new study in the United Kingdom reported performance measures of an ovarian cancer screening protocol combining CA-125 and TVUS.^217^ Among 804 BRCA1/2 mutation carriers, 14 invasive ovarian, tubal, or peritoneal cancers were identified (nine screen-detected and five occult cancers at risk-reducing surgery in screen-negative women). Sensitivity of combined CA-125 and TVUS ranged from 64 to 100 percent depending how occult tumors were classified, with 99 percent specificity.

Included in the 2013 review, a prospective European study evaluated annual CA-125 measurement and TVUS in 459 BRCA1/2 mutation carriers.^198^ Seven ovarian cancers were diagnosed (excluding occult cancers found at surgery) indicating 71 percent sensitivity for CA-125, 43 percent for TVUS, and 71 percent for combined modalities. Corresponding specificities were 99 percent for each modality alone and combined. An additional study of TVUS screening in 1,601 women with family histories of ovarian cancer provided limited data indicating only that 6 of 61 women with abnormal scans had ovarian cancer.^188^

#### Risk-Reducing Medications

No new studies and no studies in the 2013 review evaluated the benefits of risk-reducing medications specifically in mutation carriers, although the National Surgical Adjuvant Breast and Bowel Project (NSABP P-1) trial of tamoxifen described results for 288 mutation carriers who developed breast cancer during the trial.^220^ Of the eight women with breast cancer who had BRCA1 mutations, five received tamoxifen and three placebo (RR 1.67, 95% CI, 0.32 to 10.70). Of 11 women with breast cancer and BRCA2 mutations, three received tamoxifen and eight placebo (RR 0.38, 95% CI 0.06 to 1.56). Also, 86 percent (6/7) of women with BRCA1 mutations had ER negative breast cancer, and 67 percent (6/9) with BRCA2 mutations had ER positive. Tamoxifen is only effective in reducing risk for ER positive breast cancer.

Although no RCTs evaluated risk-reducing medications specifically in BRCA1/2 mutation carriers, several RCTs of women at various levels of risk have been published and summarized in meta-analyses for the USPSTF.^78,79^ Most trials enrolled women with increased risk for breast cancer including unidentified BRCA1/2 mutation carriers.

Four placebo-controlled trials of tamoxifen include the NSABP P-1 trial,^221^ Royal Marsden trial,^222^ Italian Randomized Tamoxifen Prevention Trial,^223^ and the International Breast Cancer Intervention Study (IBIS-I).^224^ Placebo-controlled trials of raloxifene include the Raloxifene Use for the Heart Trial (RUTH)^84^ and Multiple Outcomes of Raloxifene Evaluation (MORE) trial with its followup study, the Continuing Outcomes Relevant to Evista (CORE).^225^ The Study of Tamoxifen And Raloxifene (STAR)^226^ is a head-to-head trial that compared raloxifene with tamoxifen. New studies added to a USPSTF updated meta-analysis include long term results from the placebo-controlled IBIS-I trial of tamoxifen^227^ and two placebo-controlled trials of aromatase inhibitors, IBIS-II of anastrozole^87,228,229^ and the Mammary Prevention.3 (MAP.3) trial of exemestane.^86,230^

Results of the updated meta-analysis^78,79^ indicated clinically significant reductions in invasive breast cancer for tamoxifen (RR, 0.69; 95% CI, 0.59 to 0.84; 7 fewer cases per 1,000 women over 5 years of use [95% CI, 4 to 12]; 4 trials), raloxifene (RR, 0.44; 95% CI, 0.24 to 0.80; 9 fewer cases [95% CI 3 to 15]; 2 trials), and aromatase inhibitors (RR, 0.45; 95% CI, 0.26 to 0.70; 16 fewer cases [95% CI, 8 to 24]; 2 trials) (Table 7). Tamoxifen reduced invasive breast cancer more than raloxifene in the STAR head-to-head trial (RR, 1.24; 95% CI, 1.05 to 1.47). Effects did not differ by age of initiation (before or after age 50 years), or duration of use (3 to 5 years) although this effect was not directly compared. Risk reduction persisted at least 8 years after discontinuation in the two tamoxifen trials providing long-term followup data. All medications reduced ER positive, but not ER negative invasive breast cancer; tamoxifen reduced noninvasive cancer in two trials. Breast cancer specific and all-cause mortality were not reduced.

Table 7 Meta-Analysis of Results of Placebo-Controlled Trials of Risk-Reducing Medications—Benefits^77^

Outcome | RR for tamoxifen vs. placebo (95% CI) | Trials, n^*^ | Placebo rate (±SE)^†^ | Events reduced or increased with tamoxifen (95% CI), n^‡^ | RR for raloxifene vs. placebo (95% CI) | Trials, n^*^ | Placebo rate (±SE)^†^ | Events reduced or increased with raloxifene (95% CI), n^‡^ | RR for AIs vs. placebo (95% CI) | Trials, n^*^ | Placebo rate (±SE)^†^ | Events reduced or increased with AIs (95% CI), n^‡^
Breast cancer
Invasive | 0.69 (0.59 to 0.84) | 4 | 4.58 ± 0.96 | 7 (4 to 12) fewer | 0.44 (0.24 to 0.80) | 2 | 3.19 ± 0.59 | 9 (3 to 15) fewer | 0.45 (0.26 to 0.70) | 2 | 5.90 ± 0.64 | 16 (8 to 24) fewer
ER+ | 0.58 (0.42 to 0.81) | 4 | 3.62 ± 0.76 | 8 (4 to 13) fewer | 0.33 (0.15 to 0.70) | 2 | 2.45 ± 0.42 | 8 (4 to 13) fewer | 0.37 (0.19 to 0.63) | 2 | 4.55 ± 0.53 | 15 (8 to 20) fewer
ER− | 1.18 (0.93 to 1.53) | 4 | – | – | 1.25 (0.60 to 2.58) | 2 | – | – | 0.79 (0.35 to 1.79) | 2 | – | –
Noninvasive | 0.72 (0.56 to 1.41)^§^ | 4 | – | – | 1.47 (0.61 to 3.85) | 2 | – | – | 0.46 (0.16 to 1.42) | 2 | – | –
Mortality
Breast cancer | 1.20 (0.79 to 1.79) | 4 | – | – | NR^‖^ | – | – | – | NR | – | – | –
All-cause | 1.07 (0.91 to 1.23) | 4 | – | – | 0.90 (0.63 to 1.05) | 2 | – | – | 1.02 (0.58 to 1.82) | 2 | – | –
Fracture
Vertebral | 0.75 (0.48 to 1.15)^¶^ | 1 | – | – | 0.61 (0.53 to 0.73) | 2 | 3.45 ± 0.35^**^ | 7 (5 to 9) fewer | 1.28 (0.59 to 2.75) | 2 | – | –
Nonvertebral | 0.66 (0.45 to 0.98)^¶^ | 1 | 1.55 ± 0.20 | 3 (0.2 to 5) fewer | 0.97 (0.86 to 1.12) | 2 | – | – | 1.05 (0.87 to 1.28) | 2 | – | –

* Number of trials included in meta-analysis.

† Per 1000 women, estimated from a meta-analysis of rates from the placebo groups from the same trials included in the RRs.

‡ Numbers of events reduced for benefits or increased for harms compared with placebo per 1000 women assuming 5 years of use.

§ The RR was significantly reduced in NSABP P-1, 2005 (60 vs. 93 events; RR, 0.63 [CI, 0.45–0.89]).^221^

‖ 2 breast cancer deaths in 7,601 women for raloxifene vs. 0 in 7,633 women for placebo.^84,^ ^225^

¶ NSABP P-1, 2005.^221^

** Estimated from the placebo group of the RUTH trial, 2006.^231^

Abbreviations: AIs=aromatase inhibitors; CI=confidence interval; ER−=estrogen receptor–negative; ER+=estrogen receptor–positive; NR=not reported; NSABP=National Surgical Adjuvant Breast and Bowel Project; RR=risk ratio; RUTH=Raloxifene Use for the Heart; SE=standard error

Although no trials evaluated breast cancer incidence specifically for BRCA1/2 mutation carriers, all trials evaluated breast cancer incidence by family history, except the IBIS-I trial, in which 97 percent of participants reported some degree of family history.^224^ Trials defined a positive family history as breast cancer in any first-degree relative, except the Royal Marsden trial that also included second-degree relatives.^222^ Risks for invasive breast cancer were reduced in all subgroups evaluated based on family history of breast cancer. No trials evaluated breast cancer or all-cause mortality outcomes based on familial risk.

#### Risk-Reducing Surgery

##### Mastectomy

Six studies met inclusion criteria, four from the 2013 review (in five publications)^98,173,175,176,183^ and two from updated searches^174,177^ (Table 8 and Appendix B Table 10). Overall, studies indicate that risk-reducing bilateral mastectomy is associated with reduced breast cancer incidence for high-risk women and mutation carriers. However, studies are observational and limited by small sizes, selection bias, comparability of control groups, ascertainment of outcomes, and inadequate followup.

Table 8 Studies of Risk-Reducing Surgery

Author, year, quality rating | Inclusion criteria | Risk factors Enrolled, n | Mean age at surgery, years | Breast cancer incidence Risk estimate (95% CI) | Ovarian cancer incidence Risk estimate (95% CI) | Mortality Risk estimate (95% CI) | Mean followup^*^, years
Mastectomy
Current Review
Surgery vs. no surgery
Flippo-Morton et al., 2016^174^; Fair | BRCA 1/2 carrier; Female; No malignancy other than breast ± ovarian cancer | BRCA1 positive^†^ n=123; BRCA2 positive n=122; Both BRCA1 and BRCA2 positive n=1 | Age at testing:; >35: 59% (51/87); ≤35: 41% (36/87) | RRM vs. RRSO alone vs. surveillance (among patients without cancer diagnosis): 0/38 vs. NR vs. 5/36; HR NA | NR | NR | 2.5
Heemskerk-Gerritsen et al., 2013^177^; Fair | BRCA 1/2 carrier; No history of cancer, mastectomy, or oophorectomy | BRCA1 positive: n=405; BRCA2 positive: n=165 | 35 (median) | BRRM vs. surveillance: 0/1379 PYO vs. 57/2017 PYO; HR NA | NR | BRRM vs. surveillance; All-cause mortality (PYO): 6/2253 vs. 1/1384; HR 0.20 (0.02 to 1.68); Breast cancer mortality (PYO): 4/2253 vs. 1/1384; HR 0.29 (0.03 to 2.61) | 8.5 vs. 6.3 (median)
2013 Review
Surgery vs. no surgery
Domchek et al., 2010^98^; Fair | BRCA 1 carrier; No history of salpingo-oophorectomy | BRCA1 positive n=415^‡^ | 37 | 0/43 vs. 19/372; HR NA | NR | NR | 2.7
Domchek et al., 2010^98^; Fair | BRCA 2 carrier; No history of salpingo-oophorectomy | BRCA2 positive n=245^§^ | 39 | 0/32 vs. 15/213; HR NA | NR | NR | 2.5
Skytte et al., 2011^183^; Good | BRCA1/ 2 carrier; No history of mastectomy or salpingo-oophorectomy | BRCA1 positive n=201; BRCA2 positive n=10 | NR | 3/96 vs. 16/211; HR 0.39 (0.12 to 1.36) | NR | NR | NR^‖^
Mastectomy
2013 Review
Surgery group (observed vs. expected) ^¶^
Evans et al., 2009^173,^**; NA | Lifetime risk of breast cancer >25% | High-risk; BRCA1/2 positive^††^; n=202 | NR | 0/307 vs. 21.3; HR NA | NR | NR | 7.5
Mastectomy
2013 Review
Surgery group (observed vs. expected) ^¶^
Hartmann et al., 1999^175^; Hartmann et al., 2001^176^; NA | Family history of breast cancer | High risk; n=214 | 42 | 3/214 vs. 37 expected^‡‡^; Risk reduction 92% (77 to 98%) | n=2 | Breast cancer: 2/214 vs.10 expected^‡‡^; Risk reduction 81% (31 to 98%) | 14 (median)
Hartmann et al., 1999^175^ and 2001^176^; (continued) | (continued) | Moderate risk; n=425 | 42 | 4/425 vs. 37 expected^§§^; Risk reduction 89.5% (p<0.001) | n=0 | Breast cancer: 0/425 vs. 10 expected^§§^; Risk reduction 100% (70 to 100%) | 14 (median)
Hartmann et al., 1999^175^ and 2001^176^; (continued) | (continued) | BRCA1 or BRCA2 positive^‖‖^; n=18 | 41 | 0/18 vs. 6.1/18 expected^¶¶^; Risk reduction 100% (51 to 100); 0/18 vs. 4.5/18 expected^***^; Risk reduction 100% (33 to 100%) | NR | NR | 13.4 (median)
Salpingo-oophorectomy or oophorectomy
Current Review
Surgery vs. no surgery
Heemskerk-Gerritsen et al., 2015^178^; HEBON study; Fair | BRCA 1/2 carrier; Female; No history of cancer, mastectomy, or oophorectomy | BRCA1 positive: n=589; BRCA2 positive: n=233 | Median age at start of study: RRSO: 44 Non-RRSO: 33 | 12.1% (42/346) vs. 9.9% (47/476); HR 1.09 (0.67 to 1.77); BRCA1: HR 1.21 (0.72 to 2.06); BRCA2: HR 0.54 (0.17 to 1.66); Age < 51: HR 1.11 (0.65 to 1.90); Age ≥ 51: HR 1.78 (0.52 to 6.15) | NR | NR | 3.2 (median)
Kotsopoulos et al., 2017^179^; Fair | BRCA1/2 carrier; Female; No history of any cancer or BRRM | BRCA1 positive: n=2969; BRCA2 positive: n=725 | Mean age at baseline; Surgery: 46.2; No surgery: 33.4 | Annual incidence, all women: 1.87% vs. 1.59%, HR 0.89 (0.69 to 1.14); Any age at diagnosis: BRCA1: HR 0.97 (0.73 to 1.29); BRCA2: HR 0.68 (0.38 to 1.21); Age <50y at diagnosis:; BRCA1: HR 0.84 (0.58 to 1.21); BRCA2: HR 0.17 (0.05 to 0.61) | NR | NR | 5.6
Mavaddat et al., 2013^180^; EMBRACE study; Fair | BRCA1/2 carriers; Female; No breast or ovarian cancer history (reported here), or history of unilateral breast cancer | BRCA1 positive: n=501; BRCA2 positive: n=485 | Age at enrollment: 41.2 | 5.8% (18/309) vs. 6.8% (46/679), HR 0.62 (0.35 to 1.09); BRCA1: HR 0.52 (0.24 to 1.13); BRCA2: HR 0.79 0.35 to 1.80); Age < 45: HR 0.39 (0.17 to 0.87); Age ≥ 45: HR 1.14 (0.50 to 2.61) | NR | NR | 3.3
Rebbeck et al., 2002^181^; Fair | BRCA1/2 carriers; Female; No history of ovarian cancer or unilateral oophorectomy; for study of breast cancer, no history of breast cancer or mastectomy | BRCA1 positive: n=459; BRCA2 positive: n=94 | Surgery: 42.0; No surgery: 40.9 | 21.2% (21/99) vs. 42.3% (60/142), HR 0.47 (0.29 to 0.77); Age < 35: HR 0.39 (0.15 to 1.04); Age 35 to 50: HR 0.49 (0.26 to 0.90); Age ≥ 50: HR 0.52 (0.10 to 2.70) | 0.8% (2/259) vs. 19.9% (58/292), HR 0.04 (0.01 to 0.16); No history of breast cancer: HR 0.06 (0.01 to 0.25); Age 35 to 50: HR 0.03 (<0.01 to 0.20); Age ≥ 50: HR 0.11 (0.02 to 0.76) | NR | 8.2 vs. 8.8
Shah et al., 2009^182^; Fair | BRCA1/2 carriers or mutation probability > 75%; Female | BRCA1 positive: n=51; BRCA2 positive: n=41 | 47 at enrollment (median) | Any oophorectomy: 11%; (9/80) vs. 15% (2/13), p=NS; Oophorectomy ≤ 40 years: 12%; (3/25) vs. 12% (8/68), p=NS | NR | NR | 3.2 (median)
Salpingo-oophorectomy or oophorectomy
2013 Review
Surgery vs. no surgery
Domchek et al., 2010^98,^**; Fair | BRCA1 carrier; No history of salpingo-oophorectomy | BRCA1 positive; n=1003^‡^ | 42 | 14% (32/236) vs. 20% (129/633); HR 0.63 (0.41 to 0.96) | 2% (6/342) vs. 7% (49/661); HR 0.31 (0.12 to 0.82) | All cause: 2% (8/327) vs. 7% (43/608); HR 0.52 (0.24 to 1.14) | 5.6
Domchek et al., 2010^98,^**; Fair; (continued) | BRCA2 carrier; No history of salpingo-oophorectomy | BRCA2 positive; n=554^§^ | 46 | 7% (7/100) vs. 23% (94/401); HR 0.36 (0.16 to 0.82) | 0/123 vs. 14/431; HR NA | All cause: 0/120 vs. 17/403; HR NA | 5.8
Kramer et al., 2005^98,†††^; Fair | BRCA1-positive family^§§^; No history of bilateral mastectomy | BRCA1 positive; n=98 | NR | 18% (6/33) vs. 42% (27/65); HR 0.38 (0.15 to 0.97) | NR | NR | 16.5
Kramer et al., 2005^99,†††^; Fair; (continued) | BRCA1-negative family^§§^; No history of bilateral mastectomy | BRCA1 negative; n=353 | NR | 3% (1/34) vs. 1% (4/319); HR NR | NR | NR | 16.5
Kramer et al., 2005^99,†††^; Fair; (continued) | BRCA1-positive family^§§^; No history of bilateral mastectomy | Undetermined mutation status; n=222 | NR | 0/18 vs. 2.5% (5/204); HR NA | NR | NR | 16.5
Struewing et al.,1995^184^; Poor | Families with ≥3 cases of ovarian cancer or ≥2 cases ovarian cancer and ≥1 case breast cancer before age 50 | First-degree relatives of breast or ovarian cancer cases; n=390; n=12 families | NR | 3/44 vs. 14/346; Risk estimate: NR | 2/44 vs. 8/346^‡‡‡^; Risk estimate: NR | NR | NR^§§§^
Salpingo-oophorectomy or oophorectomy
2013 Review
Surgery group (observed vs. expected) ^‖‖‖^
Olson et al., 2004^100,†††^; NA | Women with bilateral oophorectomy | High-risk^¶¶¶^; Surgery <60 years; n=55 | <60 | 3/55 vs. 5.4; RR 0.56 (0.11 to 1.33) | NR | NR | NA
Olson et al., 2004^100,†††^; NA; (Continued) | Women with bilateral oophorectomy | Surgery <50 years; n=41 | <50 | 1/41 vs. 3.9; RR 0.26 (0.001 to 0.99) | NR | NR | NA
Olson et al., 2004^100,†††^; NA; (continued) | Women with bilateral oophorectomy | Moderate risk^****^; Surgery <60 years; n=193 | <60 | 9/193 vs. 10.9; RR 0.83 (0.38 to 1.44) | NR | NR | NA
Olson et al., 2004^100,†††^; NA; (continued) | Women with bilateral oophorectomy | Surgery <50 years; n=130 | <50 | 5/130 vs. 7.7; RR 0.65 (0.21 to 1.32) | NR | NR | NA

* Based on followup to censoring date

† Mutation status reported for patients with and without a pre-existing breast cancer diagnosis when tested, and before exclusions for male sex and other cancer history (N=246); after exclusions, N=205, of whom n=87 had no cancer diagnosis.

‡ BRCA1 carriers evaluated in group including those with and without surgery

§ BRCA2 carriers evaluated in group including those with and without surgery

‖ Total at-risk time in surgery group was 378.7 years versus 934.6 years in the no surgery group

¶ Expected incidence based on life tables

** Study included women with prior breast cancer; only data on women with no prior breast cancer included in evidence review

†† Total number of women with BRCA1/2 mutation, regardless of breast cancer history; study did not provide the number of women with a mutation and without a prior history of breast cancer

‡‡ Based on control group of sisters

§§ Families testing positive for BRCA1 mutation; families had multiple breast and ovarian cancer cases prior to testing

‖‖ Subgroup of high-risk group

¶¶ Based on high-penetrance model

*** Based on low-penetrance model

††† Oophorectomy performed

‡‡‡ Incidence includes post-oophorectomy ovarian carcinomatosis

§§§ Followup for ovarian cancer incidence was 1665 p-y for no surgery group, 460 p-y for surgery group; Followup for breast cancer incidence was 1587 p-y for no surgery group, 484 p-y for surgery group

‖‖‖ Expected incidence based on Gail model

¶¶¶ One first-degree relative with breast cancer before age 50 years or one first-degree relative with ovarian cancer at any age and at least one other first or second-degree relative with either diagnosis at any age

**** One first-degree relative with breast cancer at any age

Abbreviations: BRCA=breast cancer susceptibility gene; BRRM=bilateral risk-reducing mastectomy; CI=confidence interval; EMBRACE= Epidemiological Study of Familial Breast Cancer; HR=hazard ratio; NA=not applicable; NR=not reported; PYO=person-years of observation; p-y=person-years; RR=relative risk; RRSO=risk-reducing salpingo-oophorectomy

In a new fair-quality retrospective study in the United States, none of the 38 women undergoing risk-reducing mastectomy developed breast cancer, compared with 5 of the 36 women under surveillance.^174^ Similarly, in another new study of 570 Dutch women with BRCA1/2 mutations and no cancer history, none of 212 women undergoing bilateral risk-reducing mastectomy developed breast cancer over 6 years following surgery.^177^ Of 358 women under surveillance for 4 years, 57 developed breast cancer. Very few women in this study died, and reductions in all-cause and breast cancer specific mortality were not statistically significant.

The 2013 review included a retrospective study based on data from medical records of 639 Mayo Clinic patients.^175,176^ Among women who underwent risk-reducing mastectomy, breast cancer incidence was lower by 92 percent for high-risk women compared with sister controls, and by 89.5 percent for moderate-risk women compared with expected population rates.^176^ Postmastectomy breast cancer related deaths were lower by 81 percent for high-risk women compared with sister controls, and by 100 percent for moderate-risk women compared with expected population rates.^175^ When the high-risk group was evaluated for BRCA1/2 status, none of the 18 mutation carriers developed postmastectomy breast cancer compared with the 4.5 (low-penetrance model) and 6.1 (high-penetrance model) cases expected.^176^

A fair-quality study included in the 2013 review included 2,482 women with BRCA1/2 mutations from 22 North American and European centers; 1,458 without previous breast cancer.^98^ During 2.7 years of followup, no women with risk-reducing mastectomies were diagnosed with breast cancer compared with 34 of 585 (5.8%) women without mastectomies. In a good-quality study of mutation carriers in Denmark, 3 of 96 (0.8% per person-year) women who underwent mastectomy were diagnosed with breast cancer versus 16 of 211 (1.7% per person-year) who did not, although this difference was not statistically significant.^183^ Another study compared observed with expected breast cancer cases in women with BRCA1/2 mutations or otherwise considered high-risk. Results indicated that none of the 307 women who had bilateral mastectomies were diagnosed with breast cancer, while 21.3 were expected.^173^

##### Salpingo-Oophorectomy or Oophorectomy

Nine studies met inclusion criteria; four from the 2013 review^98–100,184^ and five from updated searches.^178–182^ These include two studies of risk-reducing salpingo-oophorectomy^98,178^ and seven of oophorectomy alone^99,100,179–182,184^ (Table 8 and Appendix B Table 10). One poor-quality study included in the 2013 review^184^ is not discussed in this update.

Five new fair-quality cohort studies estimated associations between risk-reducing surgery and breast cancer incidence in BRCA1/2 carriers;^178–182^ none reported mortality outcomes. The newer studies advance understanding of the relationship between risk-reducing salpingo-oophorectomy or oophorectomy and breast cancer by considering potential biases of observational methods in their analysis of outcomes. As a result, these studies indicate either no or weaker associations.

The Hereditary Breast and Ovarian Cancer in the Netherlands (HEBON) study evaluated outcomes of salpingo-oophorectomy in 822 Dutch women with BRCA1/2 mutations.^178^ In the initial analysis, the analytic methods of previous studies were replicated in the HEBON cohort and breast cancer risk reduction was estimated at approximately 50 percent after surgery, similar to previous studies. A revised analysis was designed to minimize bias by excluding patients with cancer history at the time of BRCA1/2 mutation testing, and allocating person-time before surgery to the non-surgical comparison group. The revised analysis indicated no associations between salpingo-oophorectomy and breast cancer for all patients (hazard ratio [HR], 1.09; 95% CI, 0.67 to 1.77), BRCA1 or BRCA2 subgroups, and patients younger than 51 years at the time of surgery (HR, 1.11; 95% CI, 0.65 to 1.90).

A new prospective cohort study of 3,722 BRCA1/2 carriers from 12 countries including the United States also excluded patients with cancer history and allocated time before surgery to the non-surgical group (oophorectomy status was a time-dependent variable).^179^ Like the HEBON study, this analysis found no association between oophorectomy and breast cancer incidence for all women (HR, 0.89; 95% CI, 0.69 to 1.14) or those with either BRCA1 or BRCA2 mutations. However, women with BRCA2 mutations who were younger than age 50 had lower rates of breast cancer with surgery compared with women without surgery (HR, 0.17; 95% CI, 0.05 to 0.61).

The Epidemiological Study of BRCA1 and BRCA2 mutation carriers (EMBRACE) that enrolled 988 women in the United Kingdom found that oophorectomy was associated with reduced breast cancer incidence for women younger than age 45 years (HR, 0.39; 95% CI, 0.17 to 0.87), but not older women (HR, 1.14; 95% CI, 0.50 to 2.61),^180^ similar to the previous study.^179^ An additional new study of 93 U.S. women showed no reductions in breast cancer with oophorectomy.^182^

An older prospective cohort study of 551 BRCA1/2 carriers from 11 North American and European registries met revised inclusion criteria for this update.^181^ In this study, oophorectomy was associated with reduced breast (HR, 0.47; 95% CI, 0.29 to 0.77) and ovarian or peritoneal cancer (HR, 0.04; 95% CI, 0.01 to 0.16).

Included in the 2013 review, a fair-quality prospective cohort study evaluated the outcomes of 2,482 BRCA1/2 mutation carriers at 22 North American and European centers; 1,458 with no history of breast cancer.^98^ In this study, salpingo-oophorectomy was associated with reduced ovarian or primary peritoneal cancer (1.3 vs. 5.8%; HR, 0.28; 95% CI, 0.12 to 0.69), reduced breast cancer incidence (11.6 vs. 21.6%; HR, 0.54; 95% CI, 0.37 to 0.79) and all-cause mortality (1.8 vs. 5.9%; HR, 0.45; 95% CI, 0.21 to 0.95). Reductions in breast cancer-specific and ovarian cancer-specific mortality were not statistically significant.

Another fair-quality prospective cohort study included 673 U.S. women from families with known BRCA1 mutation carriers.^99^ Among 98 BRCA1 carriers, oophorectomy was associated with reduced breast cancer incidence (18 vs. 42%; HR, 0.38; 95% CI, 0.15 to 0.97) with more reduction for women who had the procedure at younger ages. A retrospective U.S. study compared observed with expected breast cancer incidence rates among 634 women undergoing oophorectomy at the Mayo Clinic, 419 of whom were at high or moderate breast cancer risk.^100^ In this study, oophorectomy was associated with reduced risks that were more pronounced in high-risk women who were under 50 years of age and premenopausal at time of surgery (observed to expected ratio [O/E] = 1/3.9; RR, 0.26; 95% CI, 0.001 to 0.99), compared with older postmenopausal women (O/E = 3/5.4; RR, 0.56; 95% CI, 0.11 to 1.33).

## Key Question 5 What Are Adverse Effects of Interventions to Reduce Risk for BRCA1/2-Related Cancer?

### Summary

For breast cancer screening, false-positive rates, additional imaging, and benign biopsies were higher for women undergoing intensive screening using MRI versus mammography, though studies were small. A Dutch study reported a diagnostic surgery rate of 55 percent with benign results for BRCA1/2 mutation carriers after combined TVUS and CA-125 screening. Most women experienced no anxiety or depression after 5 to 8 years of screening with MRI, mammography, or clinical breast examination, and breast cancer worry decreased over time. One new before and after study that included survivors of breast or ovarian cancer reported no increase in breast cancer worry for women receiving a false-positive result with screening that included serum CA-125, TVUS, mammography, and breast MRI.

Although there are no trials of risk-reducing medications specifically in BRCA1/2 mutation carriers, adverse effects would be expected to be similar to noncarriers. A systematic review and meta-analysis of four tamoxifen, two raloxifene, and two aromatase inhibitor placebo-controlled RCTs and one head-to-head trial of raloxifene and tamoxifen provided adverse event outcomes for women at various levels of risk. Trials were limited by heterogeneity, and data on long-term effects were incomplete, particularly for aromatase inhibitors. Tamoxifen and raloxifene increased thromboembolic events compared with placebo; tamoxifen had a greater effect than raloxifene. Tamoxifen increased endometrial cancer and cataracts. All medications caused undesirable side effects for some women, such as vasomotor and musculoskeletal symptoms.

Case-series and before and after studies described surgical complications, physical symptoms, and psychological measures related to risk-reducing surgery. Studies lacked important outcomes, enrolled small numbers of participants, and had no comparison groups. Some women experienced physical complications of surgery, had postsurgical symptoms, or changes in body image, while some women had improved anxiety.

### Evidence

#### Intensive Screening

##### Breast Cancer

No new studies of false-positive and negative results, recall rates, and additional procedures were identified. Two new studies of breast cancer worry, anxiety, and depression,^193,208^ including updated long-term results of a previously included study,^209^ met inclusion criteria (Table 9 and Appendix B Table 11). The 2013 review included three studies (in four publications) of false-positive and negative results, recall rates, and additional procedures^201–204^ (Appendix B Table 12), and two studies of discomfort, pain, and anxiety.^209,210^

Table 9 Distress Due to Intensive Screening for Breast Cancer Among Mutation Carriers

Author, year, quality rating | N, study design | Mutation status | Comparison | Measures | Breast cancer worry | Anxiety | Depression | Sexual activity | Body image | General QOL
Current Review
den Heijer et al., 2013^193,^*; Fair | 197; longitudinal cohort | 25 BRCA 1/2 mutation positive | A) Baseline (n=197); B) Long-term followup (5-8 years; n=197) | HADS, IES | X decreased A vs. B^†^ | 0 | 0 | NR | NR | NR
Portnoy et al., 2015^208,‡^; NA | 170; pre-post | 100% BRCA 1/2 mutation positive | A) False positive on screening (n=27); B) No false positive result (n=143) | BSI | 0^§^ | NR | NR | NR | NR | NR
2013 Review
Rijnsburger, et al., 2004^209^; Fair | 288; prospective cohort and pre-post | 35 BRCA1/2 mutation positive | A) CBE (n=287); B) CBE + mammography (n=134); C) CBE + MRI (n=109) | EQ-5D, SCL-90, SF-36, VAS | NR | 0 | NR | NR | NR | 0
Spiegel, et al., 2011^210^; NA | 55; pre-post | BRCA1: 54.5% (30/55); BRCA2: 45.5% (25/55) | A) Recall examinations (n=18); B) No recall examinations (n=37) | HADS, WIS | NR | X increase A vs. B^‖^ | 0 | NR | NR | 0

X=statistically significant difference; 0 = studied but not significant; NR=not reported.

* Long-term followup results of Rijnsburger et al., 2004^209^

† Intrusion and avoidance scales of IES decreased between baseline and long-term followup.

‡ 13% (22/170) of participants had a history of breast cancer, but had completed treatment; <1% (1/170) of participants had a history of ovarian cancer.

§ Increased in group A at 3 months, but returned to baseline by 1 year followup, no significant difference with comparison.

‖ At 4-6 weeks after screening only, returned to baseline levels by 6 months.

Abbreviations: BRCA=breast cancer susceptibility gene; BSI=Brief Symptom Inventory; CBE=clinical breast exam; EQ-5D=EuroQoL-5 Dimensions; HADS=Hospital Anxiety and Depression Scale; IES=Impact of Events Scale; MRI=magnetic resonance imaging; NA=not applicable; NR=not reported; QOL=quality of life; SCL-90=Symptom Checklist-90; SF-36=Short Form (36) Health Survey; VAS=Visual Analogue Scale; WIS=Breast Cancer Worry Interference Scale

False-positive and negative results, recall rates, and additional procedures. In the 2013 review, studies of false-positive and negative results, recall rates, and additional procedures included women with increased familial risk of breast cancer recruited from the Netherlands, the United Kingdom, and the United States. Two studies used prospective designs,^201–203^ and one retrospectively analyzed data from a completed prospective study.^204^ Sample sizes ranged from 73 to 1,909, and included from 18 to 100 percent BRCA1/2 mutation carriers. Mean or median age at entry was 40 to 44 years, and mean or median followup was approximately 2 years or at least two annual scans by the time of analysis.^201,202^

Two studies reported false-positive rates of mammography compared with MRI.^202,204^ The Dutch MRISC study reported results by screening round, and defined the false-positive rate as the number of positive test results for women who did not have cancer. The false-negative rate was defined as the number of negative test results for women who had cancer. This study reported higher false-positive rates for MRI compared with mammography on the first and subsequent imaging rounds (first round with prior mammography: 14 vs. 5.5%; subsequent rounds: 8.2 vs. 4.6%; p<0.001 for both rounds).^202^ False-negative results for MRI were lower than mammography, although numbers were small.

In a U.S. study of 6-monthly breast cancer screening using MRI alternating with mammography, a result was considered a false-positive if initial findings on screening appeared suspicious, but followup clinical examination, imaging, or biopsy resulted in a final benign assessment. This study reported similar false-positive results for both modalities (11% MRI, 15% mammography), and did not report false-negative findings.^204^

Recall rates for annual MRI were higher than annual mammography in a study conducted in the United Kingdom that included BRCA1/2 mutation carriers (11% per woman-year MRI, 3.9% mammography, 13% combined).^203^ In this study, 245 of 279 recalls were for benign findings, amounting to 8.5 recalls per cancer detected.

The Dutch MRISC and U.S. studies also reported the number of benign additional imaging procedures or biopsies resulting from screening.^201,204^ The Dutch MRISC study determined the need for additional procedures using the Breast Imaging Reporting and Data System (BI-RADS) score from the screening examination. Women with BI-RADS scores of 3 (probably benign) or 0 (need additional imaging evaluation) underwent further evaluations using ultrasound with or without fine-needle aspiration, or repeat mammography, or repeat MRI. Women with BI-RADS scores of 4 (suspicious abnormality) or 5 (highly suggestive of malignancy) underwent biopsy. Results indicated that 43 percent of biopsies after MRI were benign (24 of 56 showed no cancer), compared with 28 percent of biopsies after mammography that were benign (7 of 25).^201^

In the U.S. study, alternating MRI with mammography screening every 6 months yielded a greater proportion of additional imaging (targeted ultrasound) for women screened with mammography (8/11) than MRI (4/8).^204^ However, rates of benign biopsies were similar (3/11 for mammography, 2/8 for MRI).

Screening discomfort, breast cancer worry, anxiety, and depression. A new before and after study evaluating the effects of false-positive screening results on cancer worry, as measured by the BSI, compared baseline scores with followup at 3 months and 1 year.^208^ This study included 22 (13%) survivors of breast cancer and one survivor of ovarian cancer. Women receiving a false-positive result had increased cancer worry at the 3 month followup, but scores dropped below baseline levels by the 1 year followup (1.70 vs. 1.80 vs. 1.45, respectively).

In the 2013 review, a fair-quality prospective cohort study found no differences in discomfort, pain, and anxiety between women undergoing intensive screening with annual mammography, MRI, and biannual clinical breast exams and women receiving only biannual clinical breast exams.^209^ In a new study, after 5 to 8 years of followup, levels of intrusion and avoidance decreased, as measured by the IES, in the 197 women receiving intensive screening.^193^

In a before and after study of MRI plus mammography, ultrasound, and clinical breast exams, women who were recalled reported higher anxiety scores compared with women who were not recalled at 4 to 6 weeks after screening (8.8 vs. 5.9, respectively, p=0.03).^210^ These represent mid-range scores measured by the HADS. Between group differences were not statistically significant by 6 months (7.1 vs. 5.9, respectively).

##### Ovarian Cancer

Two studies met inclusion criteria, both from the 2013 review.^188,198^ In a prospective study, 1,601 self-referred asymptomatic women with at least one relative diagnosed with ovarian cancer were screened with TVUS.^188^ Forty-three percent of women were screened with only one ultrasound. In this study, 3.8 percent (61/1601) of screened women had suspicious findings on TVUS and were referred to surgery. Cancer was detected in 6 of 61 referred cases, yielding a false-positive rate of 3.4 percent (95% CI, 2.6 to 4.5%). Addition of color flow imaging to ultrasound reduced the number of false-positive cases to 6 from 55.

The second study reported the number of benign diagnostic surgeries associated with ovarian cancer screening using annual serum CA-125 measurements and annual TVUS in 459 BRCA1/2 mutation carriers in the Netherlands.^198^ Abnormalities were detected in 9 percent (40/459) of women with complete data, which included 3 percent (38/1116) of screening visits, as well as visits for symptomatic complaints. Of 26 diagnostic procedures, cancer was not detected in 67 percent (4/6) following abnormal CA-125 measurement compared with 100 percent (9/9) following abnormal TVUS findings. Combined modalities resulted in a benign diagnostic surgery rate of 55 percent (6/11).

#### Risk-Reducing Medications

No studies evaluated the adverse effects of risk-reducing medications specifically in BRCA1/2 mutation carriers, although adverse effects were reported in several RCTs of women at various levels of risk and have been summarized in meta-analyses for the USPSTF.^78,79^ Studies include four placebo-controlled trials of tamoxifen,^221–224^ two placebo-controlled trials of raloxifene,^84,225^ a head-to-head RCT of tamoxifen versus raloxifene,^226^ and two placebo-controlled trials of aromatase inhibitors, anastrozole^87,228,229^ and exemestane.^86,230^

In these trials, thromboembolic events were increased for tamoxifen (RR, 1.93; 95% CI, 1.33 to 2.68; 4 trials; 4 cases/1,000 women over 5 years) and raloxifene (RR, 1.56; 95% CI, 1.11 to 2.60; 2 trials; 7/1,000) compared with placebo (Table 10).^78,79^ Raloxifene caused fewer events than tamoxifen in the STAR trial (RR, 0.75; 95% CI, 0.60 to 0.93; 4/1,000).^226^ Coronary heart disease events or stroke were not increased in placebo-controlled trials, and did not differ in STAR, although women randomized to raloxifene had higher stroke mortality than placebo in the RUTH trial (RR, 1.49; 95% CI, 1.00 to 2.24).^231^ The aromatase inhibitors caused no cardiovascular adverse effects in these trials.

Table 10 Meta-Analysis of Results of Placebo-Controlled Trials of Risk-Reducing Medications—Harms^77^

| RR for tamoxifen vs. placebo (95% CI) | Trials, n^*^ | Placebo rate (±SE)^†^ | Events reduced or increased with tamoxifen (95% CI), n^‡^ | RR for raloxifene vs. placebo (95% CI) | Trials, n^*^ | Placebo rate (±SE)^†^ | Events reduced or increased with raloxifene (95% CI), n^‡^ | RR for AIs vs. placebo (95% CI) | Trials, n^*^ | Placebo rate (±SE)^†^ | Events reduced or increased with AIs (95% CI), n^‡^
Vascular
VTE^§^ | 1.93 (1.33 to 2.68) | 4 | 0.91 ± 0.19 | 5 (2 to 9) more | 1.56 (1.11 to 2.60) | 2 | 2.34 ± 0.25 | 7 (0.3 to 17) more | 1.24 (0.65 to 2.16) | 2 | – | –
DVT | 1.45 (0.73 to 2.59) | 2 | – | – | 1.66 (0.79 to 5.14) | 2 | – | – | NR | – | – | –
PE | 2.69 (0.54 to 8.13) | 2 | – | – | 2.11 (0.82 to 6.12) | 2 | – | – | NR | – | – | –
CHD events | 1.00 (0.75 to 1.30) | 4 | – | – | 0.95 (0.80 to 1.10) | 2 | – | – | 0.76 (0.41 to 1.49) | 2 | – | –
Stroke | 1.36 (0.78 to 2.20) | 4 | – | – | 1.04 (0.64 to 1.36) | 2 | – | – | 0.98 (0.27 to 2.56) | 2 | – | –
Other
Endometrial cancer | 2.25 (1.17 to 4.41) | 3 | 0.62 ± 0.10 | 4 (1 to 8) more | 1.14 (0.54 to 2.17) | 2 | – | – | 0.60 (0.09 to 3.07) | 1 | – | –
Cataracts | 1.22 (1.08 to 1.48) | 3 | 22.85 ± 0.75^‖^ | 26 (5 to 50) more | 0.93 (0.82 to 1.06) | 2 | – | – | 0.94 (0.70 to 1.27) | 1 | – | –

* Number of trials included in meta-analysis.

† Per 1000 women, estimated from a meta-analysis of rates from the placebo groups from the same trials included in the RRs.

‡ Number of events reduced for benefits or increased for harms compared with placebo per 1,000 women assuming 5 years of use.

§ Includes DVT and PE.

‖ The placebo rate was from NSABP P-1, 2005.^221^

Abbreviations: AI=aromatase inhibitors; CHD=coronary heart disease; CI=confidence interval; DVT=deep vein thrombosis; n=number; NR=not reported; NSABP=National Surgical Adjuvant Breast and Bowel Project; PE=pulmonary embolism; RR=risk ratio; SE=standard error; VTE=venous thromboembolis

Tamoxifen caused more cases of endometrial cancer (RR, 2.25; 95% CI, 1.17 to 4.41; 3 trials; 4/1,000), and was related to more benign gynecologic conditions, surgical procedures including hysterectomy, and uterine bleeding than placebo.^78,79^ Raloxifene and aromatase inhibitors did not increase risk for endometrial cancer or uterine bleeding. In the STAR trial, raloxifene caused fewer cases of endometrial cancer (RR, 0.55; 95% CI, 0.36 to 0.83; 5/1,000), hyperplasia, and procedures than tamoxifen.^226^ Women using tamoxifen had more cataract surgeries than placebo in the NSABP P-1 trial.^221^ Raloxifene did not increase risk for cataracts or cataract surgery compared with placebo, and caused fewer cataracts than tamoxifen in STAR (RR, 0.80; 95% CI, 0.72 to 0.95; 15/1,000).^226^

Most common side effects were vasomotor symptoms and vaginal discharge, itching, or dryness for tamoxifen and vasomotor symptoms and leg cramps for raloxifene. In STAR, raloxifene users reported more musculoskeletal problems, dyspareunia, and weight gain, while tamoxifen users had more gynecological problems, vasomotor symptoms, leg cramps, and bladder control symptoms.^226^

#### Risk-Reducing Surgery

##### Mastectomy

Four observational studies (in five publications) of surgical complications, physical symptoms, or psychological outcomes related to risk-reducing mastectomy were included in the 2013 review^189,190,195,205,212^ and nine new studies met inclusion for this update^185,186,192,196,197,199,207,211^ (Table 11 and Appendix B Tables 13 and 14). One new poor-quality study is not discussed.^185^

Table 11 Distress Due to Risk-Reducing Surgery

Author, year | N, study design | Mutation status | Comparison | Measures | Anxiety | Depression | Sexual activity | Body image | General QOL
Mastectomy
Current Review
Borreani et al., 2014^187^ | 27, cohort | 74.1% (20/27) BRCA1; 25.9% (7/27) BRCA2 | A) Surveillance (n=19); B) Surgery (n=8) | CWS, HADS, MOS SF-12, NSI | 0 | 0 | NR | 0 | 0
den Heijer et al., 2012^192,^* | 36; pre-post | 75% BRCA 1/2 | A) Before surgery (n=36); B) 6 months after (n=36); C) 6-9 years after (n=36) | BIS, HADS, IES | NR | NR | NR | X Decrease B vs. A and increase C vs. B | X decrease B vs. A and C vs. B
Gopie et al., 2013^196^ | 50; pre-post | 88% BRCA 1/2 | A) Before surgery (n=50); B) 6 months after (n=32); C) 1 year after (n=32) | BIS, IES, NRV, SF-36 | NR | NR | 0 | X decrease B vs. A 0 C vs. A | X decrease on PCS B vs. A increase on MCS B vs. A 0 A vs. C
Isern et al., 2008^199^ | 28; case-series | NR | A) Surgery (n=28); B) Reference group (n=968) | HADS, SF-36 | 0 | 0 | NR | NR | X^†^
Stefanek, 1995^211^ | 14; case-series | NR | A) Surgery (n=14); B) Surveillance control (n=150) | CES-D, NSI | NR | 0 | NR | NR | X^‡^
2013 Review
Brandberg, et al., 2008^190^ Brandberg, et al., 2012^189^ | 90; pre-post | 41.1% (37/90) BRCA1 14.4% (13/90) BRCA2 2.2% (2/90) unknown mutation | A) Before surgery (n=81); B) 6 months after (n=71); C) 1 year after (n=65) | BIS, HADS, NSI, SAQ, SF-36 | X decrease B & C vs. A | 0 | X^§^ decrease C vs. A & B | 0 | NR
Gahm, et al., 2010^195^ | 1784; case-series | NR | A) Surgery (n=59); B) Control (n=1725) | DRS, NSI, SF-36 | NR | NR | NR | NR | 0
Metcalfe, et al., 2004^205^ | 60; case-series | 21.7% BRCA1/2 | A) Age <50 years (n=46); B) Age ≥50 years (n=14) | BIBC, BSI, IES, SAQ | 0 | NR | 0 | NR | NR
Mastectomy vs. Oophorectomy
Current Review
Bresser et al., 2007^191,‖^ | 78; cohort | 69% BRCA 1/2 | A) Mastectomy (n=52); B) Oophorectomy (n=26) | HADS, IES | 0 | 0 | NR | NR | 0
Salpingo-oophorectomy
2013 Review
Finch et al., 2011^194^ | 67; pre-post | BRCA1 or BRCA2 | A) Before surgery; B) After surgery | MENQOL, SAQ | NR | NR | X decrease B vs. A | NR | NR

X=statistically significant difference; 0=studied but not significant

* 33% (12/36) of women had a history of breast cancer, but had completed treatment. 3% (1/36) of women had a history of ovarian cancer. This is also the same population that Bresser et al., 2007^191^ is drawn from.

† This was only significant for the SF-36 subscales of physical functioning (p<0.0001), vitality (p=0.042), and social functioning (p=0.007).

‡ 86% (surgery) vs. 60% (surveillance), p<0.001 noted their breast cancer worry was at least a moderate problem.

§ For pleasure subscale of SAQ only

‖ 35% (27/78) of women had a history of breast cancer but had completed treatment, and 1% (1/78) if women had history of ovarian cancer. This is also the same population that den Heijer, 2012^192^ is drawn from.

Abbreviations: BIBC=Body Image after Breast Cancer; BIS=Body Image Scale; BRCA=breast cancer susceptibility gene; BSI=Brief Symptom Inventory; CES-D=Center for Epidemiologic Studies-Depression; DRS=Decision Regret Scale; HADS=Hospital Anxiety and Depression Scale; IES=Impact of Events Scale; MCS=Mental Component Summary of SF-36; MENQOL=Menopause-Specific Quality of Life-Intervention; NR=not reported; NRV=Nederlandse Relateie Vragenlijst (Dutch Relationship Questionnaire); NSI=not standard instrument; PCS=Physical Component Summary of SF-36; QOL=quality of life; SAQ=Sexual Activity Questionnaire; SF-36=Short Form (36) Health Survey

Surgical complications and physical symptoms. Three new fair-quality, single-arm retrospective cohort studies described surgical complications of risk-reducing mastectomy experienced by BRCA1/2 mutation carriers. A study of 104 BRCA1/2 mutation carriers (59 BRCA1 and 45 BRCA2) in the United States reported a complication rate of 69.3 percent, including 27 complications requiring surgery.^207^ The most common complication was skin necrosis (11 cases), followed by infection, seroma, hematoma, and implant removal. Unplanned surgical revisions were required to complete reconstruction in 59 patients. In a study of 223 high-risk women (58% BRCA1/2 mutation carriers) in Sweden, 52 percent had complications within 30 days.^186^ Skin necrosis occurred in 30 percent, wound infection in 17 percent, late wound infections (more than 30 days after surgery) in 10 percent, and implant complications in 30 percent (62 of 208) with implant reconstruction. Complications were similar for 358 Dutch women including 145 BRCA1/2 mutation carriers without breast cancer.^197^ Complications occurred among 82 women (49%), with one third occurring within 6 weeks of reconstructive surgery (most commonly bleeding, necrosis, and infection), and two thirds more than 6 weeks after reconstruction (capsule formation and poor cosmetic result) often requiring corrective surgery.

Three additional studies reported similar types of surgical complications,^195,196,205^ while another study found no differences between women’s reports of pain before mastectomy versus 6 months or 1 year after.^190^

Psychological outcomes. Four studies of psychological outcomes related to risk-reducing mastectomy are new to this update.^192,196,199,211^ A before and after study of 50 high-risk women (44 BRCA1/2 mutation carriers) reported decreased body image 6 months after surgery that returned to baseline by 1 year, and no differences in satisfaction with sexual relationships.^196^ While general mental health improved and physical health declined at 6 months, both returned to baseline by 1 year. Additional small studies indicated decreased body image at 6 months after surgery that returned to baseline by 6 to 9 years, and decreased general and breast cancer specific distress over time;^192^ no reduction in general wellbeing;^199^ and high satisfaction with risk-reducing mastectomy.^211^

In the 2013 review, a before and after study of 90 high-risk women (37 BRCA1, 13 BRCA2) indicated decreased anxiety scores, as measured by the HADS, 6 months and 1 year after surgery (mean 3.80 vs. 3.83 vs. 5.59, respectively, p=0.0004).^189,190^ The study also reported decreased pleasure in sexual activity, as measured by the pleasure subscale of the Sexual Activity Questionnaire (SAQ), 1 year after surgery compared with 6 months after surgery and before surgery (mean 11.18 vs. 12.21 vs. 12.28, respectively, p=0.005). Depression scores, body image concerns, or other portions of the SAQ were not significantly different. Additional small case-series studies reported no significant differences on psychological or sexual activity measures.^195,205^

#### Salpingo-Oophorectomy

One observational study of surgical complications, physical symptoms, or psychological outcomes related to risk-reducing salpingo-oophorectomy or oophorectomy was included in the 2013 review,^194^ and four new studies^187,191,200,206^ met inclusion for this update (Table 11 and Appendix B Tables 13 and 14).

Surgical complications and physical symptoms. In a new good-quality, single-arm retrospective study of 159 Dutch women (81% BRCA1/2 mutations), intraoperative complications occurred in 1.3 percent (2 patients) and postoperative complications within 6 weeks of surgery in 3.1 percent (pain, infection, and hematoma).^200^ In the 2013 review, a before and after study of mutation carriers (67 women without previous breast cancer) indicated that most women reported worsening of vasomotor symptoms (p<0.01), measured by the Menopause-Specific Quality of Life-Intervention scale, and decreased sexual functioning (p<0.05), measured by the SAQ, after risk-reducing salpingo-oophorectomy.^194^

Psychological outcomes. Three new studies met inclusion criteria for the update.^187,191,206^ A cross-sectional study of 205 women (56 BRCA1/2 mutation carriers) had high levels of fatigue, with 13 percent (27/205) diagnosed with chronic fatigue syndrome.^206^ A cohort study of 78 women (54 BRCA1/2 mutation carriers) compared 52 women with risk-reducing mastectomy with 26 women with risk-reducing oophorectomy.^191^ Groups did not differ in anxiety, depression, or cancer specific distress, though both groups showed significant decreases in anxiety scores between 6 months and 1 year after surgery. Another small cohort study of 27 women (20 BRCA1 mutation carriers and 7 BRCA2) compared eight women with either risk-reducing mastectomy, risk-reducing oophorectomy, or both with 19 women who underwent surveillance.^187^ Groups did not differ in anxiety, depression, quality of life, or body image concerns. However, the combined surgery group had statistically significant decreases in breast cancer worry from baseline to 15 months after surgery, while the surveillance group did not reach statistical significance (difference from baseline: −0.11, 95% CI, −0.70 to 0.49 vs. −2.75, 95% CI, −5.15 to −0.35).