# Chapter 2 Methods

## Key Questions and Analytic Framework

Using methods developed by the USPSTF,^107^ the USPSTF and the Agency for Healthcare Research and Quality (AHRQ) determined the scope and key questions for this review. Investigators created an analytic framework outlining the key questions and the patient populations, interventions, and outcomes included in the review (Figure 1).

Figure 1 Analytic Framework

* Clinically significant pathogenic mutations in the BRCA1 and BRCA2 genes associated with increased risk for breast and/or ovarian cancer.

^†^ Includes women who may have a previous diagnosis of breast or ovarian cancer, but have completed treatment.

^‡^ Descriptions of genetic counseling, scope of services, and appropriate providers are described in the text.

^§^ Testing may be done on the index patient, her relative with cancer, or her relative with highest risk, as appropriate.

^‖^ Includes interpretation of results, determination of eligibility for risk-reducing interventions, and patient decision making.

^¶^ Interventions include early detection through intensive screening (earlier and more frequent screening; use of additional screening methods), use of risk-reducing medications (aromatase inhibitors; tamoxifen; raloxifene), and risk-reducing surgery (mastectomy; salpingo-oophorectomy; other procedures) when performed for prevention purposes.

Figure 1 is a flow diagram of risk assessment, genetic counseling, and genetic testing. Women with unknown BRCA mutation status, which includes women who may have a previous diagnosis of breast or ovarian cancer but have completed treatment, are assessed for their BRCA mutation risk. These women may experience adverse effects as they are determined to have either no increased risk or increased risk for BRCA mutations. Women with an increased risk for deleterious mutations are referred for genetic counseling, during which they may experience adverse effects. Following genetic counseling, women are determined to either have no increased risk or an increased risk for BRCA mutations. Women with an increased risk for BRCA mutations are referred for genetic testing, during which they may experience adverse effects. Women with increased risk for BRCA mutations may be referred directly to genetic testing, with no genetic counseling prior to testing. Testing may be done on the index patient, her relative with cancer, or relative with highest risk as appropriate. Women who undergo genetic testing may be found to have benign results or likely benign, which means that the genetic tests showed no indications of a deleterious mutation in BRCA; or they may be found to have a result that is pathogenic, likely pathogenic, or of uncertain significance. Women may undergo post-test counseling, which includes interpretation of results, determination of eligibility for risk-reducing interventions, and patient decision making. Women eligible for risk reduction may be referred for interventions, which may include increased early detection through intensive screening (earlier and more frequent mammography, breast MRI), use of risk-reducing medications (aromatase inhibitors, tamoxifen), and risk-reducing surgery (mastectomy, salpingo-oophorectomy). Women who undergo interventions may experience adverse effects. Women who undergo interventions may also have reduced incidence of BRCA-related cancer and reduced cause-specific and all-cause mortality.

The target population for screening includes women with unknown BRCA1/2 mutation status who have either not been previously diagnosed with breast or ovarian cancer or have completed treatment and are considered cancer-free. The USPSTF recommendations are intended for routine preventive health care in predominantly primary care settings in which cancer survivors often receive care after cancer treatment. The inclusion of women with previously treated breast or ovarian cancer is new for this update and is intended to address BRCA1/2 mutation testing among women who were not evaluated for testing at the time of diagnosis, but could benefit from prevention interventions. For example, a woman with previously treated breast cancer may consider risk-reducing salpingo-oophorectomy if her test indicates a pathogenic mutation. Important subpopulations specifically considered for this update include non-white women, premenopausal women, and women with co-morbidities. The conditions of interest are BRCA1/2 mutation carrier status and BRCA1/2-related cancer (predominantly breast, ovarian, fallopian tube, and peritoneal).

Key questions for this update are similar to the 2013 review except that a question on the clinical validity of mutation testing, which is established, has been replaced by a question on optimal testing approaches (Key Question 2c).

### Key Questions

1 In women with unknown BRCA1/2 mutation status, does risk assessment, genetic counseling, and genetic testing result in reduced incidence of BRCA1/2-related cancer and cause-specific and all-cause mortality?
2a What is the accuracy of familial risk assessment for BRCA1/2-related cancer when performed by a nonspecialist in genetics in a clinical setting? What are the optimal ages and intervals for risk assessment?
2b What are the benefits of pre-test genetic counseling in determining eligibility for genetic testing for BRCA1/2-related cancer? (Includes improved accuracy of risk assessment and pretest probability for testing and improved patient knowledge, understanding of benefits and harms of interventions to reduce risk, risk perception, satisfaction, and health and psychological outcomes.)
2c What are optimal testing approaches to determine the presence of pathogenic BRCA1/2 mutations in women at increased risk for BRCA1/2-related cancer? (Includes testing other high-risk family members, including men, before testing the index patient and using specific types of tests or multigene panels.)
2d What are optimal post-test counseling approaches to interpret results and determine eligibility for interventions to reduce risk of BRCA1/2-related cancer? (Includes improved patient knowledge, understanding of benefits and harms of interventions to reduce risk, risk perception, satisfaction, and health and psychological outcomes.)
3 What are adverse effects of a) risk assessment, b) pre-test genetic counseling, c) genetic testing, and d) post-test counseling for BRCA1/2-related cancer? (Includes inaccurate risk assessment; inappropriate testing; false-positive and false-negative results; adverse effects on the patient’s family relationships; overdiagnosis and overtreatment; false reassurance; incomplete testing; misinterpretation of test results; anxiety; cancer worry; and ethical, legal, and social implications.)
4 Do interventions reduce the incidence of BRCA1/2-related cancer and mortality in women at increased risk? (Includes intensive screening [earlier and more frequent screening; use of additional screening methods], use of risk-reducing medications [aromatase inhibitors; tamoxifen; raloxifene], and risk-reducing surgery [mastectomy; salpingo-oophorectomy; other procedures] when performed for prevention purposes.)
5 What are adverse effects of interventions to reduce risk for BRCA1/2-related cancer? (Includes immediate and long-term harms associated with screening, risk-reducing medications, and risk-reducing surgery and ethical, legal, and social implications.)

## Search Strategies

A research librarian searched the Cochrane Central Register of Controlled Trials and Cochrane Database of Systematic Reviews, MEDLINE, PsycINFO, and EMBASE for relevant English-language studies, systematic reviews, and meta-analyses. Searches included studies published in January 1, 2013 to March 6, 2019 to update previous key questions; and studies published since January 1, 1994 (when BRCA1/2 genes were discovered) for new key questions and to include women with previously treated breast or ovarian cancer. Studies published before 2013 were identified from prior systematic reviews for the USPSTF.^108,109^ Search strategies are listed in Appendix A1. Search terms for existing systematic reviews and meta-analyses included “BRCA1/2,” “breast cancer,” “genetic counseling,” “risk assessment,” and “genetic testing,” among other terms. Investigators also reviewed reference lists of relevant articles to identify studies.

## Study Selection

Selection criteria for studies were developed for each key question based on the patient populations, interventions, comparisons, outcome measures, and types of evidence (Appendix A2). Investigators reviewed abstracts and full-text articles using prespecified eligibility criteria.^107^ second reviewer independently confirmed results of the initial review and discrepancies were resolved by consensus with a third reviewer if needed. Study selection is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists excluded studies with reasons for exclusion.

Randomized clinical trials (RCTs), systematic reviews, prospective and retrospective cohort studies, case-control studies, and diagnostic accuracy evaluations that addressed Key Questions were eligible. These included studies of the accuracy of risk assessment tools (Key Question 2a), outcomes of genetic counseling and testing (Key Questions 1, 2b c d), and effectiveness studies of interventions to reduce risk of BRCA1/2-related cancer among mutation carriers (Key Question 4). Interventions include intensive screening (e.g., earlier and more frequent mammography, breast MRI, TVUS), risk-reducing medications (e.g., tamoxifen, raloxifene, aromatase inhibitors), and risk-reducing surgery (e.g., mastectomy, salpingo-oophorectomy).

Risk assessment tools were included only if they were intended for use by nonspecialists in genetics to guide referrals and were applicable to U.S. primary care clinical settings (i.e., brief, nontechnical, did not require special training to administer or interpret). Evaluation of complex models used in genetic counseling was outside the scope of this review. Only studies reporting discriminatory accuracy of the tools were included. Discriminatory accuracy is a measure of how well the tool can correctly classify individuals at higher risk from those at lower risk and is measured by the tool’s concordance statistic or c-statistic. The c-statistic is determined by the area under the receiver operating characteristic curve (AUC), a plot of sensitivity (true-positive rate) versus 1 – specificity (false-positive rate). Perfect discrimination is a c-statistic of 1.0, whereas a c-statistic of 0.5 would result from chance alone. An acceptable level of discrimination is between 0.70 and 0.79, excellent is between 0.80 and 0.89, and outstanding is 0.90 or greater,^110^ although these thresholds vary depending on the clinical condition and purpose of the test. Studies of individual risk factors, laboratory tests, or models designed primarily to evaluate risk for breast or ovarian cancer rather than risk for pathogenic mutation were excluded.

Studies of any design were included to describe potential harms of risk assessment, genetic counseling, mutation testing, and risk-reducing interventions (Key Questions 3 and 5). Potential adverse effects include inaccurate risk assessment; inappropriate testing; false-positive and false-negative results; false reassurance; incomplete testing; misinterpretation of the test result; anxiety; cancer worry; immediate and long-term harms associated with breast imaging, among others.

Studies that included women with histories of breast or ovarian cancer were excluded completely from the 2013 review. For this update, these women were included because they may also benefit from genetic risk assessment, counseling, and testing, and, if indicated, further risk-reducing interventions. Only studies that included women who were diagnosed with breast or ovarian cancer at least 5 years before enrollment and completed cancer treatment were included in order to assure that genetic testing was intended for risk reduction rather than treatment purposes. Studies that did not report the time since breast or ovarian cancer diagnosis were excluded.

## Data Abstraction and Quality Rating

For included RCTs and observational studies, investigators abstracted the following data: study design; setting; population characteristics (age, ethnicity, and diagnosis); eligibility criteria; interventions (dose and duration); numbers enrolled and lost to followup; method of outcome ascertainment; and results for each outcome. For studies of risk assessment, investigators abstracted: study design; population characteristics; eligibility criteria; reference standards; risk factors included in the models; and performance measures. A second investigator reviewed accuracy of abstracted data.

Two investigators independently applied criteria developed by the USPSTF^107^ to rate the quality of each study as good, fair, or poor (Appendix A5). Discrepancies were resolved through a consensus process.

## Data Synthesis

For all key questions, the overall quality of evidence was determined using the approach described in the USPSTF Procedure Manual.^107^ Evidence was rated good, fair, or poor, based on study quality, consistency of results between studies, precision of estimates, study limitations, risk of reporting bias, and applicability; and summarized in a table.^107^ No statistical meta-analysis was performed.

## External Review

The draft report was reviewed by content experts (Appendix A6), USPSTF members, AHRQ Project Officers, and collaborative partners and was posted for public comment from February 19, 2019 to March 18, 2019.