# Chapter 1 Introduction and Background

## Purpose

This report will be used by the U.S. Preventive Services Task Force (USPSTF) to update the 2013 recommendation on risk assessment, genetic counseling, and genetic testing for BRCA1/2-related cancer in women. The target population for screening includes women with unknown BRCA1/2 mutation status who have either not been previously diagnosed with breast or ovarian cancer or have completed treatment and are considered cancer-free. Women with previously treated breast or ovarian cancer were not included in previous USPSTF reviews. This report focuses on BRCA1/2 mutations because they are more prevalent and penetrant than other types, estimates of cancer risk are available, and interventions to reduce risk for carriers have been studied.^1–3^

## Condition Background

### Condition Definition

Pathogenic mutations in breast cancer susceptibility genes BRCA1 and BRCA2 are associated with increased risks for breast, ovarian, fallopian tube, and peritoneal cancer in women, breast cancer in men, and to a lesser degree, pancreatic and early onset prostate cancer;^4–9^ BRCA2 is also associated with melanoma.^6,7^ BRCA1/2 mutations cluster in families, exhibiting an autosomal dominant pattern of transmission in either the maternal or paternal lineage. Penetrance, the probability of developing cancer in BRCA1/2 mutation carriers, is variable and many carriers never develop cancer.

Breast cancer is a malignancy that develops in tissues of the breast. Ductal carcinoma is the most common invasive histology, followed by lobular carcinoma.^10,11^ Ovarian, fallopian tube, and peritoneal carcinomas are overlapping epithelial malignancies in which the designation of the three primary sites is often arbitrary. For the purpose of this review, the three disease sites will be collectively referred to as ovarian carcinoma.

### Prevalence and Burden of Disease/Illness

Excluding nonmelanoma skin cancer, breast cancer is the most common cancer in women in the United States and the second leading cause of cancer death in women after lung cancer.^12^ In 2018, an estimated 266,120 women developed breast cancer in the United States and 40,920 died from the disease.^13^ Ovarian cancer is the fifth leading cause of cancer death among women in the United States with an estimated 22,240 new cases and 14,070 deaths in 2018.^13^

The 5-year relative survival rate for all stages of breast cancer in the United States is 91 percent. Rates are 99 percent for localized, 85 percent for regional, and 27 percent for distant disease.^14^ The 5-year relative survival rate for ovarian cancer in the United States is 47 percent overall, and 92 percent for early stages.^15^ However, up to 79 percent of women with ovarian cancer have non-localized disease at the time of diagnosis. Five-year relative survival rates for women with regional and distant disease are 73 percent and 29 percent, respectively.^15^

### Etiology and Natural History

Pathogenic mutations in BRCA1 and BRCA2 are associated with increased risks for breast, ovarian, fallopian tube, and peritoneal cancer in women, breast cancer in men, pancreatic and early onset prostate cancer,^4–9^ and melanoma.^6,7^ Although all of these types of cancer are considered during familial risk assessment, studies of male breast cancer, pancreatic cancer, prostate cancer, and melanoma are otherwise outside the scope of this review.

Pathogenic BRCA1/2 mutations are estimated to occur in 1 in 300 to 500 in the general population^16–19^ and account for 5 to 10 percent of breast and 15 percent of ovarian cancer.^16,20^ Specific BRCA1/2 mutations, known as founder mutations, are clustered among certain groups including Ashkenazi Jews,^21–23^ specific populations of blacks^24^ and Hispanics,^25,26^ and among families in the Netherlands,^27^ Iceland,^28,29^ and Sweden,^30^ among others.

Specific cancer phenotypes are associated with BRCA1/2 mutations, even in the absence of family history, including triple negative breast cancer and high-grade ovarian or fallopian tube cancer.^31–36^ Pathologic and clinical characteristics of tumors also differ by the type of mutation. In a series of 3797 cases of breast cancer among BRCA1 carriers, 78 percent were estrogen receptor (ER) negative, 79 percent progesterone receptor (PR) negative, 90 percent human epidermal growth factor receptor 2 (HER2) negative, and 69 percent triple negative.^37^ The proportion of ER negative cases decreased with increasing age. In a series of 2392 cases of breast cancer among BRCA2 carriers, 23 percent were ER negative, 36 percent PR negative, 87 percent HER2 negative, and 16 percent triple negative.^37^ These receptor characteristics are important in determining cancer treatment and prognosis.

Several additional mutations not included in this review are also associated with hereditary susceptibility to breast and ovarian cancer, such as CDH1, PTEN, STK11, TP53, ATM, CHEK2, PALB2, but they are less prevalent or penetrant than BRCA1/2 mutations.^1,7,38,39^ For example, in addition to the BRCA1/2 mutations, the National Comprehensive Cancer Network (NCCN) identifies two other genes with “known high-penetrance mutations:” TP53 (Li-Fraumeni syndrome) and PTEN (Cowden syndrome).^1^ However, these mutations are rare, and the associated syndromes vary and generally affect individuals at young ages. The population prevalence is estimated at 1 in 5,000 to 20,000 for Li-Fraumeni syndrome,^40^ and 1 in 200,000 for Cowden syndrome.^41^

### Risk Factors

In the general population, lifetime risks of developing cancer are 12 percent for breast cancer and 1.3 percent for ovarian cancer.^42^ These risks are higher for BRCA1/2 mutation carriers and women with family histories of these cancer types regardless of carrier status. Approximately 5 to 10 percent of women with breast cancer have a mother or sister with breast cancer, and up to 20 percent have either a first-degree or a second-degree relative with breast cancer.^43–47^ Although most of these women do not have BRCA1/2 mutations, some women report family history patterns that suggest their presence. In general, breast cancer risk increases to 45 to 65 percent by age 70 years for pathogenic mutations in either BRCA1/2 genes;^48,49^ ovarian, fallopian tube, or peritoneal cancer risk increases to 39 percent for mutations in BRCA1 and 10 to 17 percent in BRCA2.^48,49^,^48,49^

### Rationale for Screening/Screening Strategies

Genetic risk assessment, counseling, and BRCA1/2 mutation testing involve determining risk for pathogenic BRCA1/2 mutations followed by mutation testing of high-risk individuals. Mutation testing of appropriate candidates could lead to increased awareness of cancer risk and effective use of interventions to reduce BRCA1/2-related cancer incidence and mortality, as well as reduced interventions for individuals and their family members who are not mutation carriers.

Family history of BRCA1/2-related cancer is important in estimating individual risk for a pathogenic BRCA1 or BRCA2 mutation in a woman without cancer or known family mutation. Although BRCA1/2 mutation probability is linked to family history, this only partially explains familial aggregation of breast cancer and hereditable variance in risk in a population. ^45^,^50^ Decisions about referral, testing, and risk-reducing interventions are often based on self-reports of family histories that include types of cancer, relationships within the family, and ages of onset. Appropriate decisions rely on family histories that are accurately reported by women and correctly obtained by clinicians.

The accuracy of family cancer history information was evaluated in studies that validated self-reported family histories with medical records. In one study, a report of breast cancer in a first-degree relative of a healthy individual had a sensitivity of 82 percent, specificity of 91 percent, positive likelihood ratio of 8.9 (95% CI, 5.4 to 15.0), and negative likelihood ratio of 0.20 (95% CI 0.08, to 0.49).^51^ A population-based study in the United States indicated the accuracy of self-reported breast cancer history in a first-degree relative as 64.9 percent sensitivity and 99.0 percent specificity.^52^ In this study, the accuracy for first-degree relatives was higher than for second-degree. A report of ovarian cancer in a first-degree relative had a sensitivity of 50 percent, specificity of 99 percent, positive likelihood ratio of 34.0 (95% CI, 5.7 to 202.0), and negative likelihood ratio of 0.51 (95% CI, 0.13 to 2.10).^51^

Referral guidelines have been developed by health maintenance organizations (HMOs),^53^ professional organizations,^54^ cancer programs,^55,56^ State and National health programs,^57–59^ and researchers^60^ to assist non specialists in genetics in identifying women at potentially increased risk for pathogenic BRCA1/2 mutations. Most guidelines are intended to lead to referrals for more extensive risk assessment and counseling, not directly to testing. The effectiveness of referral guidelines in improving cancer clinical outcomes has not been evaluated. Although specific items vary, most guidelines include questions about personal and family history of BRCA1/2 mutations, types of cancer, age of diagnosis, bilateral breast cancer, and Ashkenazi Jewish ancestry.^56^

Genetic counseling is the process of identifying and advising individuals with potential inherited cancer susceptibility and is recommended before and after BRCA1/2 mutation testing.^54,56,61^ Services include comprehensive assessment of familial risk for inherited disorders using kindred analysis and models to estimate risk that are based on logistic regression,^62^ Bayesian analysis,^49,63,64^ and other methods.^65^ Genetic counseling also includes identification of candidates for testing, patient education, discussion of the benefits and harms of genetic testing to facilitate decision making, interpretation of results after testing, discussion of management options, and psychosocial counseling and support. Some genetic counseling programs offer their services by telephone and other telemedicine technology. Providers of genetic counseling may be genetic counselors,^66–68^ specifically trained physicians and nurse educators,^69,70^ or other health professionals with comparable skills.^71^ Accreditation standards from specialty groups specifically outline essential training and skills for genetics professionals.^72^

The NCCN provides specific criteria for genetic testing in their genetic/familial high-risk assessment breast and ovarian cancer guidelines^56^ These guidelines recommend that mutation testing begin with a relative with known BRCA1/2-related cancer, including male relatives, to determine if a pathogenic mutation is segregating in the family before testing individuals without cancer.^56^ If an affected family member is not available, then the relative with the highest probability of mutation should be tested. Ideally, results of the initial test will guide testing decisions of other family members. However, the optimal candidate may not be available for testing, limiting the interpretation of results. Individuals without cancer meeting NCCN criteria for testing include those from families with known BRCA1/2 mutations or from families with extensive cancer history.

The type of mutation analysis required depends on family history. A small number of pathogenic BRCA1/2 mutations have been found repeatedly in different families, such as the three founder mutations detected in the Ashkenazi Jewish population. However, most identified pathogenic mutations have been found in only a few families.^73^ Individuals from families with known mutations, or from groups with common mutations, can be tested specifically for them. Several clinical laboratories in the United States test for specific mutations or sequence specific exons. The sensitivity and specificity of analytic techniques are determined by the laboratories and are not generally available.

Individuals without linkages to families or groups with known mutations undergo different types of testing. Testing options have recently changed since the U.S. Supreme Court ruling in 2013 that determined human genes are not patentable (Association for Molecular Pathology et al. v. Myriad Genetics).^74^ Up to this point, most BRCA1/2 mutation testing in the United States was conducted by Myriad Genetics Inc. Currently, a search of the GeneTests™ database shows 82 multi-gene panels that include BRCA1 offered by multiple U.S. laboratories, and 97 panels that include BRCA2.^75^ The specific genes analyzed in multi-gene panels vary and include moderate-risk genes that may be difficult to interpret and are not clinically actionable. The U.S. Food and Drug Administration (FDA) does not currently regulate laboratory-developed tests (i.e., those “designed, manufactured, and used within a single laboratory”). However, tests manufactured in kits marketed to other laboratories are FDA-regulated as devices, and approval requires evidence of efficacy and safety. For example, in 2017, the FDA authorized Memorial Sloan Kettering Cancer Center’s (MSK) IMPACT (Integrated Mutation Profiling of Actionable Cancer Targets) tumor profiling test.^76^

The interpretation of mutation testing is complicated by the terminology used to report results. Guidelines from the American College of Medical Genetics and Genomics (ACMG) updated in 2015 recommend new standard terminology for reporting sequence variants identified by genetic tests that apply to BRCA1/2 mutations.^77^ Guidelines include a 5-tier system using the terms pathogenic, likely pathogenic, uncertain significance, likely benign, and benign. The ACMG also defines criteria for translating results from published studies, population and disease databases, and the patient’s clinical and family history into pathogenic and benign categories. The category of variant of uncertain significance (VUS) used in both current and previous classifications either does not fulfil these criteria or represents conflicting results regarding pathogenicity. The ACMG states that a VUS should not be used in clinical decision making, and categories indicating pathogenic and benign designations should be used to inform patient management.

### Interventions/Treatment

Interventions to reduce risk for cancer in BRCA1/2 mutation carriers include earlier, more frequent, or intensive cancer screening; use of risk-reducing medications; and risk-reducing surgery. The NCCN recommends that BRCA1/2 mutation carriers be aware of breast changes beginning at age 18 years; have clinician breast examinations every 6 to 12 months beginning at age 25 years; and have annual mammography and breast magnetic resonance imaging (MRI) beginning at age 25 years or based on family history when breast cancer is diagnosed in a relative before age 30 years.^56^ The NCCN also recommends risk-reducing mastectomy and salpingo-oophorectomy; monitoring with transvaginal ultrasound (TVUS) and cancer antigen-125 (CA-125) levels at the provider’s discretion for women not undergoing salpingo-oophorectomy; and risk-reducing medications.

Tamoxifen and raloxifene (selective estrogen receptor modulators [SERMs]) and exemestane and anastrozole (aromatase inhibitors) reduce primary breast cancer in women at increased risk in placebo-controlled trials.^78–87^ However, these medications also have adverse effects, including thromboembolism (tamoxifen and raloxifene), endometrial cancer and cataracts (tamoxifen), and vasomotor and other symptoms.^78,79,88,89^ While SERMS are FDA approved for breast cancer risk reduction, aromatase inhibitors are approved only for breast cancer treatment. None of these trials reported results specifically for BRCA1/2 mutation carriers and it is unclear whether efficacy differs.

Risk-reducing mastectomy and salpingo-oophorectomy reduce risk for breast and ovarian cancer in BRCA1/2 mutation carriers.^90–93^ Bilateral total simple mastectomy with or without reconstruction and with or without nipple preservation is currently the most common approach.^94,95^ This procedure provides more complete removal of breast tissue than the previously used subcutaneous mastectomy, although, no procedure completely removes all breast tissue^96^ and breast cancer can still occur postmastectomy.^97^ Bilateral oophorectomy reduces risk for both breast and ovarian cancer.^98–100^ Recognition of the importance of the fallopian tube as a site of cancer origin has led to including salpingectomy in addition to oophorectomy. The role of hysterectomy to reduce cancer risk remains controversial.

### Current Clinical Practice/Recommendations of Other Groups

Guidelines recommend testing for cancer susceptibility mutations when 1) an individual has personal or family cancer history suggestive of inherited cancer susceptibility; 2) the test can be adequately interpreted; and 3) results will aid in management.^54,101^ However,^56^ actual practices for BRCA1/2 testing in the United States are unclear. The lack of screening effectiveness trials, differing interpretations of existing research among specialties, variability of insurance coverage, and direct-to-consumer advertising targeting patients, physicians, and health systems^102–106^ have resulted in highly variable clinical practices.