# Appendix C Supplemental Materials

## Appendix C1 Familial Risk Assessment Tools

Ontario Family History Assessment Tool (FHAT)^118,^ ^121–123^

Referral with score ≥10 corresponds to doubling of lifetime risk for breast cancer (22%)

Risk Factor | | Points
Breast and ovarian cancer | Mother; Sibling; 2/3^rd^ degree relative | 10; 7; 5
Breast cancer relatives | Parent; Sibling; 2/3^rd^ degree; Male relative (add to above) | 4; 3; 2; 2
Breast cancer characteristics | Onset age 20-29; Onset age 30-39; Onset age 40-49; Pre (peri) menopausal; Bilateral/multifocal | 6; 4; 2; 2; 3
Ovarian cancer relatives | Mother; Sibling; 2/3^rd^ degree relative | 7; 4; 3
Ovarian cancer onset age | <40; 40-60; >60 | 6; 4; 2
Prostate cancer onset | Age <50 | 1
Colon cancer onset | Age <50 | 1
Family Total | Referral | ≥10

Manchester Scoring System (MSS)^111,^ ^113,^ ^116,^ ^121–123^

Risk Factor (age of onset for relative in direct lineage) | BRCA 1 Score | BRCA 2 Score
Female breast cancer
<30 | 6 | 5
30-39 | 4 | 4
40-49 | 3 | 3
50-59 | 2 | 2
≥60 | 1 | 1
Male breast cancer
<60 | 5^*^ | 8^†^
≥60 | 5^*^ | 5^†^
Ovarian cancer
<60 | 8 | 5
≥60 | 5 | 5
Pancreatic cancer
Pancreatic cancer | 0 | 1
Prostate cancer
<60 | 0 | 2
≥60 | 0 | 1
Total individual genes | 10 | 10
Total for combined=15

Probability of ≥10% chance of BRCA1 or BRCA2 mutation individually or combined

Abbreviation: BRCA=breast cancer susceptibility gene

* If BRCA 2 tested.

† If BRCA 1 tested.

Referral Screening Tool (RST)^114^

History of breast or ovarian cancer in the family? If yes, complete checklist.

Risk Factor | Breast cancer age ≤50 | Ovarian cancer at any age
Yourself
Mother
Sister
Daughter
Mother’s side
Grandmother
Aunt
Father’s side
Grandmother
Aunt
≥2 cases of breast cancer after age 50 on the same side of the family
Male breast cancer at any age in any relative
Jewish ancestry

Referral if ≥2 checks in table

Pedigree Assessment Tool (PAT)^119,124^

Risk Factor | Score for every family member with breast or ovarian cancer diagnosis, including 2^nd^/3^rd^ degree
Breast cancer at age ≥50 | 3
Breast cancer at age <50 | 4
Ovarian cancer at any age | 5
Male breast cancer at any age | 8
Ashkenazi Jewish heritage | 4
Total

Score ≥8 is the optimal referral threshold

Seven-question Family History Screening (FHS-7)^112^

Number | Questions
1. | Did any of your 1st degree relatives have breast or ovarian cancer?
2. | Did any of your relatives have bilateral breast cancer?
3. | Did any man in your family have breast cancer?
4. | Did any woman in your family have breast and ovarian cancer?
5. | Did any woman in your family have breast cancer before the age of 50 years?
6. | Do you have 2 or more relatives with breast and/or ovarian cancer?
7. | Do you have 2 or more relatives with breast and/or bowel cancer?

One positive response initiates referral

International Breast Cancer Intervention Study Model (IBIS)^117^

Number | Risk Factor
1. | Personal history: current age, age at menopause, menarche, childbirth history, menopausal status, use of menopausal hormone therapy.
2. | Personal breast history, breast density (optional), prior breast biopsy, history of cancer (breast or ovarian), genetic testing.
3. | Ashkenazi inheritance
4. | Family history (genetic risk) – relatives with breast or ovarian cancer, age at diagnosis, genetic testing.