# Appendix B Quality Tables and Evidence Tables

Appendix B Table 1 Quality Assessment of Diagnostic Accuracy Studies

Author, year | Was a consecutive or random sample of patients enrolled? | Was a case-control design avoided? | Did the study avoid inappropriate exclusions? | Were the index test results interpreted without knowledge of the results of the reference standard? | If a threshold was used, was it pre-specified? | Is the reference standard likely to correctly classify the target condition? | Were the reference standard results interpreted without knowledge of the results of the index text? | Was there an appropriate interval between index test(s) and reference standard? | Did all patients receive a reference standard? | Did patients receive the same reference standard? | Were all patients included in the analysis? | Quality rating
Current Review
Biswas et al., 2016^115^ | Yes | Yes | Yes | Unclear | Yes | Yes | Unclear | NA | Yes | Yes | Yes | Fair
Fischer et al., 2013^117^ | Yes | Yes | Yes | Unclear | Yes | Yes | Unclear | NA | Yes | Yes | Yes | Fair
Kast et al., 2014^120^ | Yes | Yes | Unclear | Yes | Yes | Yes | Unclear | NA | Yes | Yes | Yes | Fair
Teller et al., 2010^124^ | No | Yes | Yes | Unclear | Yes | Yes | Unclear | NA | Yes | Yes | Yes | Fair
2013 Review
Antoniou et al., 2008^111^ | Yes | Yes | Yes | Unclear | Yes | Yes | Unclear | NA | Yes | Yes | Yes | Good
Ashton-Prolla et al., 2009^112^ | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | NA | Yes | Yes | Yes | Good
Barcenas et al., 2006^113^ | Yes | Yes | Yes | Unclear | Yes | Yes | Unclear | Unclear | Yes | Yes | Yes | Fair
Bellcross et al., 2009^114^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | NA | Yes | Yes | Yes | Good
Evans et al., 2004^116^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | NA | Yes | Yes | Yes | Good
Gilpin, 2000^118^ | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | NA | Yes | Yes | Yes | Good
Hoskins, 2006^119^ | Yes | Yes | Yes | Unclear | Yes | Yes | Unclear | NA | Yes | Yes | Yes | Fair
Oros et al., 2006^121^ | Unclear | Yes | Unclear | Unclear | Yes | Yes | Yes | NA | Yes | Yes | Yes | Fair
Panchal et al., 2008^122^ | Yes | No | Unclear | Unclear | Yes | Yes | Unclear | NA | Yes | Yes | Yes | Fair
Parmigiani et al., 2007^123^ | No | Yes | Unclear | Unclear | Yes | Yes | Unclear | NA | Yes | Yes | Yes | Fair

Appendix B Table 2 Quality Assessment of Randomized, Controlled Trials

Author, Year | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Eligibility criteria specified? | Outcome assessors masked? | Care provider masked? | Patient masked? | Reporting of attrition, crossovers, adherence, and contamination | Loss to followup: differential/ high | Analyze people in the groups in which they were randomized? | Quality rating
Current Review
Manchanda et al., 2015^164^ | Yes | Unclear | Yes | Yes | Unclear | Yes | No | Yes | No | Yes | Good
2013 Review
Bloom et al., 2006^129^ | Unclear | NR | NR | No | NR | NR | No | Yes | No | Yes | Poor
Bowen et al., 2002^66^ | Yes | NR | Yes | Yes | No | No | No | Yes | No | No | Fair
Bowen et al., 2004^71^ | Yes | Yes | Yes | Yes | No | No | No | Yes | NR | No | Fair
Bowen et al., 2006^130^ | NR | NR | Yes | Yes | No | No | No | Yes | No | Yes | Fair
Brain et al., 2002^131^ | Yes | Yes | Yes | Yes | Unclear | Unclear | Unclear | Yes | No | Yes | Good
Braithwaite et al., 2005^133^ | NR | NR | Yes | Yes | NR | Yes | No | Yes | No | No | Fair
Burke et al., 2000^67^ | Yes | NR | Yes | Yes | No | No | No | Yes | No | NR | Fair
Cull et al., 1998^68^ | Yes | Yes | Yes | Yes | No | No | No | Yes | No/Yes | NR | Good
Fry et al., 2003^134^ | Yes | Yes | Yes | Yes | No | No | No | Yes | No/Yes | No | Fair
Helmes, 2006^136^ | NR | NR | Yes | Yes | NR | No | No | Yes | No | Yes | Fair
Lerman et al., 1996^140^ | Yes | NR | Yes | Yes | Yes | No | No | Yes | No | NR | Fair
Lerman et al., 1999^69^ | Yes | NR | Yes | Yes | Yes | No | No | Yes | No/Yes | NR | Fair
Matloff et al., 2006^142^ | No | No | Yes | Yes | NR | No | No | Yes | No | No | Fair
Roshanai et al., 2009^146^ | Unclear | Yes | Yes | Yes | NR | Yes | No | Yes | No | No | Fair
Watson et al., 1998^148^ | Yes | Yes | Yes | Yes | No | No | No | Yes | No | Yes | Good

Appendix B Table 3 Quality Assessment of Cohort Studies

Author, Year | Did the study attempt to enroll all (or a random sample of) patients meeting inclusion criteria, or a random sample (inception cohort)? | Were the groups comparable at baseline on key prognostic factors (e.g., by restriction or matching)? | Did the study maintain comparable groups through the study period? | Did the study use accurate methods for ascertaining exposures and potential confounders? | Were outcome assessors and/or data analysts blinded to the exposure being studied? | Did the article report attrition? | Did the study perform appropriate statistical analyses on potential confounders? | Is there important differential loss to followup or overall high loss to followup? | Were outcomes pre-specified and defined, and ascertained using accurate methods? | Quality rating
Current Review
Borreani et al., 2014^187^ | Unclear | Not reported for our groups of interest | Not reported | Yes | Not reported | Not applicable | Unclear | Not applicable | Yes | Fair
Bresser et al., 2007^191^ | Unclear | Yes | Yes | Yes | Unclear | Not applicable | Yes | Unclear | Yes | Fair
Evans et al., 2009^173^ Manchester site | Yes | Yes - matching | Not reported | Not reported | Not reported | Yes | No | Unclear | Unclear | Fair
Flippo-Morton et al., 2016^174^ | Yes | Not reported | Not reported | Not reported | Not reported | Yes | No | No | Not reported | Fair
Heemskerk- Gerritsen, 2013^177^ | Yes | Unclear | Not reported | Yes | Not reported | No, but Cox model censored at last contact | Yes, though race not included | Not reported | Yes | Fair
Heemskerk- Gerritsen, 2015^178^ | Yes: nationwide cohort | Unclear | Not reported | Yes | Not reported | No, but Cox model censored at last contact | Yes, though race not included | Not reported | Yes | Fair
Kotsopoulos et al., 2017^179^ | Unclear | No | No | Unclear | NR | No, but Cox model censored at last contact | Yes | NR | Yes | Fair
Kramer et al., 2005^99^ | Unclear | Not reported | Not reported | Yes for exposure | Not reported | No | Age only | Not reported | Yes | Fair
Lumish et al., 2017^163^ | Yes | Unclear | Not applicable | Yes | Not reported | Not applicable | Yes | Not applicable | Yes | Fair
Mavaddat et al., 2013^180^ EMBRACE | Yes | Not reported for oophorectomy groups | Not reported | Yes | Not reported | Yes | Yes | Yes | Yes | Fair
Rebbeck et al., 2002^181^ | Unclear | Yes - matching | Not reported | Unclear, self-report for exposure | Not reported | Not applicable, retrospective | Yes | Not applicable, retrospective | Yes | Fair
Shah et al., 2009^182^ | Yes | Not reported for oophorectomy groups | Not reported | Not reported | Not reported | Yes | Yes | No | Not reported | Fair
Isern et al., 2008^199^ | Unclear | Unclear | Unclear | Yes | Unclear | Not applicable | Yes | Unclear | Yes | Fair
van Oostrom, 2003 et al.,^172^ | Unclear | Yes | Unclear | Yes | Unclear | Yes | Unclear | Unclear differential, but high overall (24% dropped) | Yes | Poor
2013 Review
Domchek et al., 2010^98^ | Yes | Not reported | Not reported | Yes for exposure, unclear for confounders (Domchek 2006) | Not reported | No | Yes, though race not included | Not reported | Yes | Fair
Foster et al., 2007^154^ | Unclear | Not reported | Not reported | Yes | No | Yes | Yes | No | Yes | Fair
Geirdal et al., 2005^156^ | Yes | Yes | Yes | Yes | No | Yes | Unclear | No | Yes | Good
Geirdal and Dahl, 2008^155^ | Yes | No | No | Yes | No | Yes | Yes | No | Yes | Good
Hopwood et al., 1998^137^ | Unclear | Yes | Yes | Yes | No | Yes | Yes | No | Yes | Fair
Julian-Reynier et al., 2011^159^ | Unclear | Yes | Yes | Yes | No | Yes | Yes | No | Yes | Good
Kinney et al., 2005^160^ | No | Not reported | Not reported | Yes | No | No | Yes | Not reported | Yes | Poor
Kramer et al., 2005^99^ | Yes | Not reported | Not reported | Yes | No | No | Yes | Not reported | Yes | Fair
Lobb et al., 2004^141^ | Unclear | Yes | Yes | Yes | No | Yes | Yes | No | Yes | Good
Low et al., 2008^162^ | Unclear | No | Not reported | Yes | No | Yes | Yes | Yes | Yes | Fair
Meiser et al., 2002^165^ | Unclear | Yes | Yes | Yes | No | Yes | Yes | No | Yes | Good
Mikkelsen et al., 2007^143^ | Yes | No | No | Yes | No | Yes | Yes | No | Yes | Fair
Mikkelsen et al., 2009^144^ | Yes | No | No | Yes | No | Yes | Yes | No | Yes | Fair
Reichelt et al., 2004^167^ | Yes | Not reported | Not reported | Yes | No | Yes | Yes | No | Yes | Good
Rijnsburger et al., 2004^209^ | No | No | Not reported | Yes | Unclear - Not reported | Yes | Yes | No | Yes | Fair
Skytte et al., 2011^183^ | Yes | No - rates of RRSO differed | Not reported | Yes | Not reported | Yes | Age only | No | Yes | Fair
Struewing et al., 1995^184^ | Unclear | Not reported | Not reported | Not reported | Not reported | No (by individual) | No | Unclear - 4 of 16 families identified were lost to followup | Not reported | Poor
van Dijk et al., 2006^171^ | Yes | Not reported | Not reported | Yes | No | Yes | Yes | No | Yes | Good
Watson et al, 1999^149^ | Unclear | Yes | Yes | Yes | No | Yes | Yes | No | Yes | Good

Appendix B Table 4 Quality Assessment of Single Arm Cohort Studies

Author, Year | Did the study attempt to enroll all (or a random sample of) patients meeting inclusion criteria, or a random sample (inception cohort)? | Did the study use accurate methods for ascertaining exposures and potential confounders? | Were outcome assessors and/or data analysts blinded to the exposure being studied? | Did the article report attrition? | Is there high attrition? | Were outcomes pre-specified and defined, and ascertained using accurate methods? | Quality rating
Current Review
Alamouti et al., 2015^185^ | Unclear | Not reported | Not reported | No | Not reported | Unclear | Poor
Andrews et al., 2004^150^ | Yes | Yes | Not reported | Yes | Yes | Yes | Fair
Arver et al., 2011^186^ | Yes: national inventory | Unclear | Not reported | Not applicable | Not applicable | Unclear | Fair
den Heijer et al., 2013^193^ | Unclear | Yes | Unclear | Not applicable | Not applicable | Yes | Fair
Godard et al., 2007^157^ | Yes | Yes | Not reported | Yes | Yes | Yes | Good
Heemskerk- Gerritsen et al., 2007^197^ | Yes | Yes | Not reported | No | Not reported | Yes | Fair
Kenkhuis et al., 2010^200^ | Yes | Yes | Not reported | Not applicable | Not applicable | Yes | Good
Lieberman et al., 2017^161^ | Yes | Yes | Not reported | Yes | Yes | Yes | Good
Nurudeen, 2017^207^ | Unclear | Yes | Not reported | No | Not reported | Yes | Fair
Smith et al., 1999^170^ | Yes | Yes | Not reported | Yes | Yes | Yes | Good
Stefanek et al., 1995^211^ | Unclear | Unclear | Unclear | Not applicable | Not applicable | Yes | Poor
2013 Review
Evans et al., 2009^173^; All sites | Yes | Not reported | Not reported | Yes | No (2%) | Unclear | Fair
Hartmann et al., 1999^175^; Hartmann et al., 2001^176^ | Yes | Yes | Not reported | Not applicable | Not applicable | Yes for cancer, unclear for death | Fair
Olson et al., 2004^100^ | Yes | Yes | Not reported | Not applicable | Not applicable | Unclear | Fair

Appendix B Table 5 Quality Assessment of Case-Control Studies

Author, year | Did the study attempt to enroll all or random sample of cases using pre- defined criteria? | Were the controls derived from the same population as the cases? | Were the groups comparable at baseline on key prognostic factors? | Were enrollment rates similar in cases and controls invited to participate? | Did the study use accurate methods for identifying outcomes? | Did the study use accurate methods for ascertaining exposures and potential confounders? | Did the study perform appropriate statistical analyses on potential confounders? | Quality rating
2013 Review
Armstrong et al., 2005^126^ | Yes | No | No | No | Yes | Yes | Yes | Good
Dagan and Shochat, 2009^152^; Shochat and Dagan, 2010^169^ | Yes | Unclear | Matched | No | Yes | Yes | Yes | Fair

Appendix B Table 6 Quality Assessment of Systematic Review

Author, year | Research questions and inclusion include components of PICO | Explicit statement of a priori development of methods | Any deviations from protocol, if so are they so justified | Explanation of study design inclusion | Comprehensive literature search | Duplicate study selection and data abstraction
2013 Review
Smerecnick et al., 2009^147^ | Yes | Yes | Not reported | Yes | Yes | Selection: Yes; Abstraction: Yes

Author, year | List of studies (included and excluded) provided | Characteristics of the included studies provided | Satisfactory technique used for assessing risk of bias in individual studies | Conflict of interest (including funding sources); a) Systematic Review; b) Individual Studies | If meta-analysis performed, were appropriate methods used for combination of results
2013 Review
Smerecnick et al., 2009^147^ | Excluded: No Included: Yes | Yes | No | Review: Yes Studies: No | Not applicable

Author, year | If meta-analysis performed, were potential impacts of risk of bias on meta-analysis or other evidence synthesis assessed | Was risk of bias taken into account when interpreting/discussing results | Satisfactory explanation for, and discussion of, any heterogeneity observed in the results | If quantitative synthesis, was there adequate investigation of publication bias (small study bias) and discuss its likely impact on the results | Rating
2013 Review
Smerecnick et al., 2009^147^ | Not applicable | No, quality not assessed | Unclear | Yes | Moderate

Abbreviation: PICO=Patients, Intervention, Comparison, and Outcomes

Appendix B Table 7 Evidence Table of Genetic Counseling Studies

Appendix B Table 8 Evidence Table of Genetic Testing Studies

Appendix B Table 9 Evidence Table of Studies of Intensive Screening Interventions

Appendix B Table 10 Evidence Table of Risk-Reducing Surgery Studies

Appendix B Table 11 Evidence Table of Psychological and Sexual Functioning Harms of Intensive Screening Interventions

Appendix B Table 12 Evidence Table of Physical Harms of Intensive Screening Interventions

Appendix B Table 13 Evidence Table of Psychological and Sexual Functioning Harms of Risk-Reducing Surgery

Appendix B Table 14 Evidence Table of Harms of Risk-Reducing Surgery