# Appendix A Detailed Methods

## Appendix A1 Search Strategies

### OVID MEDLINE^®^ Database Searches

#### Risk Assessment – General Screening

Search Strategy:

------------------------------------------------------------

1. exp Preventive Medicine/
2. exp Family Practice/
3. exp Primary Health Care/
4. exp General Practice/
5. exp general practitioners/
6. exp physicians, primary care/
7. 1 or 2 or 3 or 4 or 5 or 6
8. exp Breast Neoplasms/ or exp ovarian cancer/
9. exp disease susceptibility/
10. exp mass screening/
11. 8 and (9 or 10)
12. exp Breast Neoplasms/ge or exp ovarian cancer/ge
13. exp GENES, BRCA1/ or exp BRCA1 PROTEIN/ or brca1.mp.
14. exp GENES, BRCA2/ or exp BRCA2 PROTEIN/ or brca2.mp.
15. 11 or 12 or 13 or 14
16. 7 and 15

#### Risk Assessment – Prediction Models

Search Strategy:

------------------------------------------------------------

1. (gail adj model$).mp.
2. (claus adj model$).mp.
3. 1 or 2
4. exp Models, Statistical/
5. exp risk/
6. exp Breast Neoplasms/ge
7. 4 and 5 and 6
8. 3 or 7

#### Genetic Counseling

Search Strategy:

------------------------------------------------------------

1. exp Genetic Counseling/ or Genetic counseling.mp. or genetic counselling.mp.
2. decision making.mp. or exp Decision Making/
3. exp risk/
4. risk$.mp.
5. exp Breast Neoplasms/ or breast neoplasm$.mp. or Breast cancer$.mp. or exp ovarian neoplasms/ or ovarian cancer$.mp. or ovarian neoplasm$.mp.
6. 1 and (2 or 3 or 4) and 5

#### Genetic Testing – General

Search Strategy:

------------------------------------------------------------

1. exp Breast Neoplasms/mo, pc, ep, eh or exp ovarian neoplasms/mo, pc, ep, eh
2. exp GENES, BRCA1/ or exp BRCA1 PROTEIN/ or brca1.mp.
3. exp GENES, BRCA2/ or exp BRCA2 PROTEIN/ or brca2.mp.
4. 2 or 3
5. exp Breast Neoplasms/ge or exp ovarian neoplasms/ge
6. (sensitivity and specificity).mp.
7. exp “Sensitivity and Specificity”/
8. risk$.mp. or exp RISK/
9. 5 and (6 or 7 or 8)
10. 1 and 4 and 9
11. (201612* or 2017*).ed.
12. 10 and 11

#### Genetic Testing – Harms

Search Strategy:

------------------------------------------------------------

1. exp Breast Neoplasms/ or exp ovarian neoplasms/
2. exp genetic screening/ae or exp genetic services/ae or exp genetic counseling/ae or exp genetic screening/px or exp genetic services/px or genetic counseling/px
3. exp Breast Neoplasms/ge or exp ovarian neoplasms/ge
4. exp stress, psychological/
5. ((psycholog$ or emotion$ or mental$) adj3 (stress$ or strain$ or burden$ or toll)).mp.
6. exp anxiety/ or anxious$.mp. or anxiet$.mp.
7. 4 or 5 or 6
8. (1 and 2) or (3 and 7)

#### Risk-Reducing Interventions – General

Search Strategy:

------------------------------------------------------------

1. exp Breast Neoplasms/nu, pc, dh, rt, dt, rh, su, th, tr or exp ovarian Neoplasms/nu, pc, dh, rt, dt, rh, su, th, tr
2. exp Treatment Outcome/ or treatment outcome$.mp.
3. exp “Outcome Assessment (Health Care)”/ or outcome assessment$.mp.
4. 1 or 2 or 3
5. exp Breast Neoplasms/mo, ep, eh or exp ovarian Neoplasms/mo, ep, eh
6. exp Breast Neoplasms/ or exp ovarian neoplasms/
7. exp MORTALITY/ or mortal$.mp. or mortality.fs.
8. exp INCIDENCE/ or incidence$.mp. or epidemiology.fs. or ethnology.fs.
9. 7 or 8
10. 6 and 9
11. 5 or 10
12. exp RISK/
13. risk$.mp.
14. exp Genetic Predisposition to Disease/ or genetic predisposition to disease$.mp.
15. pedigree.mp. or exp PEDIGREE/
16. 12 or 13 or 14 or 15
17. exp Breast Neoplasms/ge or exp ovarian neoplasms/ge
18. exp GENES, BRCA1/ or exp BRCA1 PROTEIN/ or brca1.mp.
19. exp GENES, BRCA2/ or exp BRCA2 PROTEIN/ or brca2.mp.
20. 17 or 18 or 19
21. 4 and 11 and 16 and 20

#### Risk-Reducing Interventions – Surgery Specific

Search Strategy:

------------------------------------------------------------

1. exp Breast Neoplasms/pc
2. exp Ovarian Neoplasms/pc
3. (mastectom$ or oophoectom$ or ovariectom$).mp.
4. 1 or 2
5. 3 and 4
6. (family adj5 histor$).mp.
7. exp Genetic Predisposition to Disease/
8. brca.mp.
9. (brca1 or brca2).mp.
10. 6 or 7 or 8 or 9
11. 5 and 10

#### Risk-Reducing Interventions – Harms

Search Strategy:

------------------------------------------------------------

1. exp Breast Neoplasms/dt, su or exp ovarian neoplasms/dt, su
2. exp Breast Neoplasms/pc or exp ovarian neoplasms/pc
3. chemoprevention.mp. or exp CHEMOPREVENTION/
4. primary prevention.mp. or exp Primary Prevention/
5. 2 or 3 or 4
6. postoperative complications.mp. or exp Postoperative Complications/
7. intraoperative complications.mp. or exp Intraoperative Complications/
8. ae.xs. or ct.fs.
9. exp stress, psychological/
10. ((psycholog$ or emotion$ or mental$) adj3 (stress$ or strain$ or burden$ or toll)).mp.
11. ((psycholog$ or emotion$ or mental$) adj3 (stress$ or strain$ or burden$ or fear$ or toll)).mp.
12. exp anxiety/ or anxiet$.mp. or anxious$.mp.
13. 9 or 10 or 11 or 12
14. 6 or 7 or 8 or 13
15. 1 and 5 and 14

#### BRCA – Case-Control Studies

Search Strategy:

------------------------------------------------------------

1. exp case control studies/
2. brca$.mp.
3. 1 and 2
4. exp breast neoplasms/
5. exp ovarian neoplasms/
6. 4 or 5
7. 3 and 6

#### Ethical, Legal, and Social Implications

Search Strategy:

------------------------------------------------------------

1. ((breast$ or mammar$ or ovar$) adj3 (cancer$ or carcino$ or adenocarcin$ or tumor$ or tumour$ or malig$ or neoplas$)).mp. (261591)
2. screen*.mp. (443410)
3. (gene or genes or genetic$ or genotyp$ or genom$ or brca or dna).mp. (2509492)
4. 2 or 3 (2814223)
5. 1 and 4 (98623)
6. (law or laws or lawful$ or unlawful$ or legal$ or illegal$ or jurispru$ or legislat$ or litigat$ or liabil$ or malpract$).mp. (152351)
7. (prejudic$ or disqualif$ or deny or denying or denial or coerc$ or stigma$ or ((race* or racial* or ethnic* or minorit*) adj5 (discriminat* or segregat$))).mp. (47389)
8. (ethic$ or bioethic$ or moral$ or (human$ adj2 right$)).mp. (114469)
9. 6 or 7 or 8 (286960)
10. 5 and 9 (951)
11. bias$.mp. (118961)
12. 5 and 11 (999)
13. 10 or 12 (1921)

### Additional Databases Searched for Overall Project

#### PsycINFO

Search Strategy:

------------------------------------------------------------

1. ((Breast$ or mammar$ or ovar*) adj5 (cancer$ or tumor$ or tumour$ or neoplas$ or carcino$ or adenocarcino$ or malig$ or metasta$) adj15 (((brca* or gene*) adj5 (screen* or test* or assay)) or ((brca* or gene* or heredit*) adj5 (risk* or predispos* or suscept* or counsel*)))).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
2. ((Breast$ or mammar$) adj5 (cancer$ or tumor$ or tumour$ or neoplas$ or carcino$ or adenocarcino$ or malig$ or metasta$) adj15 (((brca* or gene*) adj5 (screen* or test* or assay)) or ((brca* or gene* or heredit*) adj5 (risk* or predispos* or suscept* or counsel*)))).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
3. 1 not 2
4. exp Breast Neoplasms/
5. genetic counseling/
6. exp Genetic Testing/
7. 5 or 6
8. 4 and 7
9. exp GENETICS/
10. exp RISK ASSESSMENT/ or exp AT RISK POPULATIONS/ or exp RISK MANAGEMENT/ or exp RISK FACTORS/
11. 4 and 9 and 10
12. 8 or 11
13. 1 or 12

#### EBM Reviews - Cochrane Database of Systematic Reviews

Search Strategy:

------------------------------------------------------------

1. ((Breast$ or mammar$ or ovar*) adj5 (cancer$ or tumor$ or tumour$ or neoplas$ or carcino$ or adenocarcino$ or malig$ or metasta$) adj15 (((brca* or gene*) adj5 (screen* or test* or assay)) or ((brca* or gene* or heredit*) adj5 (risk* or predispos* or suscept* or counsel*)))).mp. [mp=title, abstract, full text, keywords, caption text]
2. ((Breast$ or mammar$) adj5 (cancer$ or tumor$ or tumour$ or neoplas$ or carcino$ or adenocarcino$ or malig$ or metasta$) adj15 (((brca* or gene*) adj5 (screen* or test* or assay)) or ((brca* or gene* or heredit*) adj5 (risk* or predispos* or suscept* or counsel*)))).mp. [mp=title, abstract, full text, keywords, caption text]
3. 1 not 2

#### EBM Reviews - Cochrane Database of Systematic Reviews

Search Strategy:

------------------------------------------------------------

1. ((Breast$ or mammar$ or ovar*) adj5 (cancer$ or tumor$ or tumour$ or neoplas$ or carcino$ or adenocarcino$ or malig$ or metasta$) adj15 (((brca* or gene*) adj5 (screen* or test* or assay)) or ((brca* or gene* or heredit*) adj5 (risk* or predispos* or suscept* or counsel*)))).mp. [mp=title, abstract, full text, keywords, caption text]
2. ((Breast$ or mammar$) adj5 (cancer$ or tumor$ or tumour$ or neoplas$ or carcino$ or adenocarcino$ or malig$ or metasta$) adj15 (((brca* or gene*) adj5 (screen* or test* or assay)) or ((brca* or gene* or heredit*) adj5 (risk* or predispos* or suscept* or counsel*)))).mp. [mp=title, abstract, full text, keywords, caption text]
3. 1 not 2

#### Elsevier Embase^®^

Search Strategy:

------------------------------------------------------------

(((brca:ab,ti) OR ((‘breast cancer’/exp OR ‘ovary cancer’/exp) AND (‘tumor suppressor gene’/exp))) AND (‘risk assessment’/exp OR ‘genetic screening’/exp OR ‘genetic counseling’/exp)) AND [embase]/lim NOT [medline]/lim AND [english]/lim AND [humans]/lim

## Appendix A2 Inclusion and Exclusion Criteria

Category | Included | Excluded
Setting | Primary care settings or clinical settings referable from primary care; settings comparable to U.S. practice | Other settings not applicable to the U.S.
Populations | KQs 1–3: Women with unknown BRCA mutation status.; KQs 4, 5: Women with pathogenic BRCA1 or BRCA2 genes.; For women with prior breast cancer and/or ovarian cancer: Studies that report the time since treatment completion (any time), or report the time since diagnosis with the minimum in the range ≥5 years. | All KQs: Women under treatment for breast or ovarian cancer, or for whom the intention of testing is to determine treatment rather than prevention interventions.^*^ Assessment of mutations other than BRCA1 and BRCA2. Intention of testing is to determine treatment for cancer.; KQs 1–3: Women with known BRCA mutation carrier status unless the study is designed to address questions for women with unknown status (e.g., case-control, retrospective study); All KQs, except KQ 2c: Men
Interventions | KQ 1: Risk assessment initiated by a nonspecialist in genetics, pre-test genetic counseling, genetic testing, post-test counseling.; KQs 2a, 3a: Risk assessment initiated by a nonspecialist in genetics.; KQs 2b, 3b: Pre-test genetic counseling^†^ delivered by a provider trained in genetics using methods meeting current standards of practice in the United States (described in text).; KQs 2c, 3c: Genetic testing; KQs 2d, 3d: Post-test counseling^†^; KQs 4, 5: Intensive screening (earlier and more frequent screening; use of additional screening methods), use of risk-reducing medications (aromatase inhibitors; tamoxifen; raloxifene), and risk-reducing surgery (mastectomy; salpingo-oophorectomy; other procedures) when performed for prevention purposes. | All KQs: No intervention or intervention not described.; KQ 2a, 3a: Assessments conducted solely by specialists (i.e., BRCAPRO, BOADICEA) or risk assessments for lifetime risk of breast and/or ovarian cancer.; KQ 2b, 2d, 3b, 3d: Genetic counseling for risk management or decision aids.; KQs 4, 5: Intervention not listed as included.
Comparisons | KQ 1: Risk assessment, pre-test genetic counseling, genetic testing, post-test counseling vs. usual care or alternative approaches.; KQs 2a, 3a: Risk assessment by a nonspecialist in genetics vs. usual care or risk assessment by alternative approaches.; KQs 2b, 3b: Pre-test genetic counseling vs. usual care or alternative approaches.; KQs 2c, 3c: Genetic testing vs. usual care or alternative approaches.; KQ 2d, 3d: Post-test counseling vs. usual care or alternative approaches.; KQs 4, 5: Intensive screening, risk-reducing medications, or risk-reducing surgery vs. no intervention or alternative approaches. | Benefits KQs: No comparison or comparison not described.
Outcomes | KQs 1, 4: Incidence of BRCA-related cancer; disease-specific and all-cause mortality; KQ 2a: Measures of test performance (sensitivity, specificity, positive and negative likelihood ratios, c statistic); KQ 2b: Patient outcomes of pre-test genetic counseling (improved accuracy of risk assessment and pretest probability for testing and improved patient knowledge, understanding of benefits and harms of interventions to reduce risk, risk perception, satisfaction, and health and psychological outcomes); KQ 2c: Patient health, implications of non-BRCA findings detected on multigene panels, psychological outcomes of testing; KQ 2d: Patient outcomes of post-test counseling (improved patient knowledge, understanding of benefits and harms of interventions to reduce risk, risk perception, satisfaction, and health and psychological outcomes); KQ 3a: Inaccurate risk assessment, false-positive and false-negative results; adverse effects on the patient’s family relationships; false reassurance; anxiety; cancer worry; and ethical, legal, and social implications; KQ 3b: Inaccurate risk assessment; inappropriate testing; false-positive and false-negative results; adverse effects on the patient’s family relationships; overdiagnosis and overtreatment; false reassurance, anxiety, decision regret; cancer worry; and ethical, legal, and social implications; KQ 3c: Inappropriate testing; false-positive and false-negative results; adverse effects on the patient’s family relationships; overdiagnosis and overtreatment; false reassurance; incomplete testing; misinterpretation of test results; anxiety, depression; cancer worry; and ethical, legal, and social implications; KQ 3d: Inaccurate risk assessment; inappropriate testing; false-positive and false-negative results; adverse effects on the patient’s family relationships; overdiagnosis and overtreatment; false reassurance, anxiety, decision regret; cancer worry; and ethical, legal, and social implications; KQ 5: Immediate and long-term harms associated with screening (false-positive and false-negative results, overdiagnosis, and overtreatment; nonadherence); risk-reducing medications (thromboembolic and cardiovascular events, metabolic disorders, musculoskeletal symptoms, ophthalmologic disorders, and quality of life, others); risk-reducing surgery (surgical complications, sexual dysfunction, menopausal symptoms, mood changes, and quality of life); and ethical, legal, and social implications | Other outcomes not listed, including cost and cost-effectiveness, intermediate lab outcomes, individual risk factors not associated with a risk assessment tool, prevalence and penetrance data, risk estimates, predictors of outcomes, uptake of testing or interventions, and time to interventions.
Study Design | All KQs: Randomized, controlled trials; observational studies, with or without comparison groups; KQ 2: Discriminatory accuracy studies; KQ 2c: Modeling studies | All KQs: Case reports, case series; Benefits KQs: Non-comparative studies; All KQs, except KQ 2c: Modeling studies
Study Quality | Studies rated good- and fair-quality for meta-analyses using USPSTF quality criteria | Poor-quality studies

* We excluded studies if they did not report the time since treatment completion or time since diagnosis, or they did report the time since diagnosis, but the minimum was <5 years, or if the standard deviation would include <5 years.

† Genetic counseling component requirements:

[underlined: Pre-test]

1. Comprehensive evaluations of familial risk for inherited disorders using kindred analysis and models to estimate risk
2. Identification of candidates for testing
3. Patient education
4. Discussion of the benefits and harms of genetic testing

[underlined: Post-test]

1. Interpretation of results after testing
2. Discussion of management options

Abbreviations: BRCA=breast cancer susceptibility gene; BRCAPRO=breast cancer susceptibility gene prediction model; BOADICEA=Breast and Ovarian Analysis of Disease Incidence and Carrier Estimation Algorithm; KQ=key question; U.S.=United States; USPSTF=United States Preventive Services Task Force.

## Appendix A3 Literature Flow Diagram

* Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

^†^ 2 studies were included for KQ 2c and KQ 4 in the 2013 review, these studies were reviewed with the set of papers from the non KQ 2c pile.

^‡^ See Appendix A4 for the list of excluded studies and Appendix A2 for the list of exclusion criteria.

^§^ In this exclusion group are 82 studies that included women with prior breast and/or ovarian cancer, but did not report the time since cancer diagnosis and 21 studies that reported time since breast and/or ovarian cancer diagnosis, but the minimum was <5 years, or the standard deviation would include <5 years. The rest of the studies were excluded because they included women with current breast or ovarian cancer, women currently under treatment for breast or ovarian cancer, women undergoing testing to determine treatment planning, and men (except if applicable to testing approaches).

^║^ Studies that provided data and contributed to the body of evidence were considered ‘included.’

^¶^ 1 new publication was a paper on the long-term results of a study included in the 2013 review.

1 Nelson HD, Fu R, Goddard K, Mitchell JP, Okinaka-Hu L, Pappas M, . Risk Assessment, Genetic Counseling, and Genetic Testing for BRCA-Related Cancer: Systematic Review to Update the U.S. Preventive Services Task Force Recommendation. Rockville (MD): Agency for Healthcare Research and Quality; 2013.

Appendix A3 is a literature flow diagram depicting the search and selection of articles for the review. The diagram shows that 3,875 abstracts of potentially relevant articles were identified through MEDLINE, Cochrane databases (including the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews), and EMBASE. An additional 3,837 abstracts from the prior report were reviewed for inclusion in this report. Of these abstracts, 6,475 citations were excluded for not being relevant to the key questions. The remaining 1,237 articles were retrieved and reviewed at the full-text level. An additional 344 full-text articles from the prior report were reviewed for inclusion in this report. Of these, 1,547 were excluded for the following reasons: background information only (170), population not applicable (450), intervention not applicable (183), wrong outcomes (464), non-systematic or outdated review (55), wrong study design for key question (41), wrong publication type (177), non-English language paper (6), or companion paper, data not used (1). An additional 67 full-text articles from the prior report that were included for the previous Key Question 2c and 78 full-text articles previously included for Key Questions 2a, 2b/3b, 3c, 4, and 5 were reviewed for inclusion in this report. Of these 67 were excluded for wrong outcome, prevalence/penetrance studies included for the old KQ2c and 2 were excluded for wrong outcome, included for old KQ4. After exclusion of these studies, 103 studies in 110 publications were included that provide evidence for the key questions, as follows: 0 studies for Key Question 1, 4 new publications and 10 publications from the prior report for Key Question 2a, 1 new study in 1 publication and 27 studies in 29 publications from the prior report for Key Questions 2b and 3b, 1 new study and 0 studies from the prior report for Key Question 2c, 6 new studies and 14 studies in 16 publications from the prior report for Key Question 3c, 0 studies for Key Question 3a, 0 studies for Key Question 2d and 3d, 7 new and 7 studies in 8 publications from the prior report for Key Question 4, and 12 new studies in 14 publications and 12 studies in 14 publications from the prior report for Key Question 5.

## Appendix A4 Excluded Studies List

Studies included from prior report, excluded in current report

Exclusion Codes:
2 = Background information only
3 = Wrong population; 3a = Wrong population – did not report the time since treatment completion or time since diagnosis, AND the percent of women affected by (or with a personal history of) breast and/or ovarian cancer combined is >30% (or not reported at all); 3b = Wrong population - reported the time since diagnosis, with the minimum in the range <5 years (or range not reported), or if SD would include <5 years, AND the percent of women affected by (or with a personal history of) breast and/or ovarian cancer combined is >30% (or not reported at all); H1 = Wrong population - reported the time since diagnosis with the minimum in the range <5 years (or range not reported), or if SD would include <5 years, AND the percent of women affected by (or with a personal history of) breast and/or ovarian cancer combined is ≤30%; H2 = Wrong population – did not report the time since diagnosis, but did report the percent of women affected by (or with a personal history of) breast and/or ovarian cancer combined is ≤30%
4 = Wrong intervention
5 = Wrong outcome
6 = Wrong publication type
7 = Wrong study design
8 = Not in English
9 = Non-systematic review or outdated review
10 = Companion paper with outdated data, data not used

Abeliovich D, Kaduri L, Lerer I, . The founder mutations 185delAG and 5382insC in BRCA1 and 6174delT in BRCA2 appear in 60% of ovarian cancer and 30% of early-onset breast cancer patients among Ashkenazi women. Am J Hum Genet. 1997 Mar;60(3):505–14. PMID: 9042909. Exclusion: E59042909
Al-Mulla F, Bland JM, Serratt D, . Age-dependent penetrance of different germline mutations in the BRCA1 gene. J Clin Pathol. 2009;62(4):350–6. doi: 10.1136/jcp.2008.062646. PMID: 19329713. Exclusion: E519329713
Anglian Breast Cancer Study Group. Prevalence and penetrance of BRCA1 and BRCA2 mutations in a population-based series of breast cancer cases. Br J Cancer. 2000;83(10):1301–8. PMID: 11044354. Exclusion: E511044354
Anton-Culver H, Cohen PF, Gildea ME, . Characteristics of BRCA1 mutations in a population-based case series of breast and ovarian cancer. Eur J Cancer. 2000;36(10):1200–8. PMID: 10882857. Exclusion: E510882857
Antoniou AC, Durocher F, Smith P, . BRCA1 and BRCA2 mutation predictions using the BOADICEA and BRCAPRO models and penetrance estimation in high-risk French-Canadian families. Breast Cancer Res. 2006;8(1):R3. PMID: 16417652. Exclusion: E516417652
Antoniou AC, Pharoah PD, McMullan G, . A comprehensive model for familial breast cancer incorporating BRCA1, BRCA2 and other genes. Br J Cancer. 2002 Jan 07;86(1):76–83. doi: 10.1038/sj.bjc.6600008. PMID: 11857015. Exclusion: E511857015
Beristain E, Martinez-Bouzas C, Guerra I, . Differences in the frequency and distribution of BRCA1 and BRCA2 mutations in breast/ovarian cancer cases from the Basque country with respect to the Spanish population: implications for genetic counselling. Breast Cancer Res Treat. 2007 Dec;106(2):255–62. PMID: 17262179. Exclusion: E517262179
Bernholtz S, Laitman Y, Kaufman B, . Phenocopy breast cancer rates in Israeli BRCA1 BRCA2 mutation carrier families: is the risk increased in non-carriers? Breast Cancer Res Treat. 2012 Apr;132(2):669–73. PMID: 22113258. Exclusion: E522113258
Boyd J, Sonoda Y, Federici MG, . Clinicopathologic features of BRCA-linked and sporadic ovarian cancer. JAMA. 2000 May 03;283(17):2260–5. PMID: 10807385. Exclusion: E510807385
Brose MS, Rebbeck TR, Calzone KA, . Cancer risk estimates for BRCA1 mutation carriers identified in a risk evaluation program. J Natl Cancer Inst. 2002;94(18):1365–72. PMID: 12237282. Exclusion: E512237282
Chen J, Pee D, Ayyagari R, . Projecting absolute invasive breast cancer risk in white women with a model that includes mammographic density. J Natl Cancer Inst. 2006 Sep 06;98(17):1215–26. doi: 10.1093/jnci/djj332. PMID: 16954474. Exclusion: E516954474
Chen S, Iversen ES, Friebel T, . Characterization of BRCA1 and BRCA2 mutations in a large United States sample. J Clin Oncol. 2006 Feb 20;24(6):863–71. PMID: 16484695. Exclusion: E516484695
Cortesi L, Turchetti D, Marchi I, . Breast cancer screening in women at increased risk according to different family histories: an update of the Modena Study Group experience. BMC Cancer. 2006;6:210. PMID: 16916448. Exclusion: E516916448
Couch FJ, DeShano ML, Blackwood MA, . BRCA1 mutations in women attending clinics that evaluate the risk of breast cancer. N Engl J Med. 1997 May 15;336(20):1409–15. doi: 10.1056/NEJM199705153362002. PMID: 9145677. Exclusion: E59145677
Domchek SM, Gaudet MM, Stopfer JE, . Breast cancer risks in individuals testing negative for a known family mutation in BRCA1 or BRCA2. Breast Cancer Res Treat. 2010 Jan;119(2):409–14. PMID: 19885732. Exclusion: E519885732
Eccles DM, Englefield P, Soulby MA, . BRCA1 mutations in southern England. Br J Cancer. 1998;77(12):2199–203. PMID: 9649133. Exclusion: E59649133
Evans DG, Shenton A, Woodward E, . Penetrance estimates for BRCA1 and BRCA2 based on genetic testing in a Clinical Cancer Genetics service setting: risks of breast/ovarian cancer quoted should reflect the cancer burden in the family. BMC Cancer. 2008;8:155. PMID: 18513387. Exclusion: E518513387
Finkelman BS, Rubinstein WS, Friedman S, . Breast and ovarian cancer risk and risk reduction in Jewish BRCA1/2 mutation carriers. J Clin Oncol. 2012 Apr 20;30(12):1321–8. PMID: 22430266. Exclusion: E522430266
FitzGerald MG, MacDonald DJ, Krainer M, . Germ-line BRCA1 mutations in Jewish and non-Jewish women with early-onset breast cancer. N Engl J Med. 1996 Testing Search 4.12.04;334(3):143–9. PMID: 8531968. Exclusion: E58531968
Fodor FH, Weston A, Bleiweiss IJ, . Frequency and carrier risk associated with common BRCA1 and BRCA2 mutations in Ashkenazi Jewish breast cancer patients. Am J Hum Genet. 1998 Reference Search 3-17-04;63(1):45–51. PMID: 9634504. Exclusion: E59634504
Ford D, Easton DF, Stratton M, . Genetic heterogeneity and penetrance analysis of the BRCA1 and BRCA2 genes in breast cancer families. Am J Hum Genet. 1998;62(3):676–89. PMID: 9497246. Exclusion: E59497246
Frank TS, Deffenbaugh AM, Reid JE, . Clinical characteristics of individuals with germline mutations in BRCA1 and BRCA2: Analysis of 10,000 individuals. J Clin Oncol. 2002;20(6):1480–90. PMID: 11896095. Exclusion: E511896095
Gayther SA, Mangion J, Russell P, . Variation of risks of breast and ovarian cancer associated with different germline mutations of the BRCA2 gene. Nat Genet. 1997 4/7/05;15(1):103–5. PMID: 8988179. Exclusion: E58988179
Gayther SA, Russell P, Harrington P, . The contribution of germline BRCA1 and BRCA2 mutations to familial ovarian cancer: no evidence for other ovarian cancer-susceptibility genes. Am J Hum Genet. 1999;65(4):1021–9. PMID: 10486320. Exclusion: E510486320
Gershoni-Baruch R, Dagan E, Fried G, . Significantly lower rates of BRCA1/BRCA2 founder mutations in Ashkenazi women with sporadic compared with familial early onset breast cancer. Eur J Cancer. 2000 May;36(8):983–6. PMID: 10885601. Exclusion: E510885601
Gronwald J, Cybulski C, Lubinski J, . Phenocopies in breast cancer 1 (BRCA1) families: implications for genetic counselling. J Med Genet. 2007 Apr;44(4):e76. PMID: 17400795. Exclusion: E517400795
Hartge P, Struewing JP, Wacholder S, . The prevalence of common BRCA1 and BRCA2 mutations among Ashkenazi Jews. Am J Hum Genet. 1999 Original Search 6-20-03;64(4):963–70. PMID: 10090881. Exclusion: E510090881
Harvey SL, Milne RL, McLachlan SA, . Prospective study of breast cancer risk for mutation negative women from BRCA1 or BRCA2 mutation positive families. Breast Cancer Res Treat. 2011 Dec;130(3):1057–61. PMID: 21850394. Exclusion: E521850394
Hopper JL, Southey MC, Dite GS, . Population-based estimate of the average age-specific cumulative risk of breast cancer for a defined set of protein-truncating mutations in BRCA1 and BRCA2. Australian Breast Cancer Family Study. Cancer Epidemiol Biomarkers Prev. 1999;8(9):741–7. PMID: 10498392. Exclusion: E510498392
Janezic SA, Ziogas A, Krumroy LM, . Germline BRCA1 alterations in a population-based series of ovarian cancer cases. Hum Mol Genet. 1999;8(5):889–97. PMID: 0196379. Exclusion: E510196379
Kauff ND, Mitra N, Robson ME, . Risk of ovarian cancer in BRCA1 and BRCA2 mutation-negative hereditary breast cancer families. J Natl Cancer Inst. 2005 Sep 21;97(18):1382–4. PMID: 16174860. Exclusion: E516174860
King MC, Marks JH, Mandell JB. Breast and ovarian cancer risks due to inherited mutations in BRCA1 and BRCA2. Science. 2003 Oct 24;302(5645):643–6. doi: 10.1126/science.1088759. PMID: 14576434. Exclusion: E514576434
Konecny M, Milly M, Zavodna K, . Comprehensive genetic characterization of hereditary breast/ovarian cancer families from Slovakia. Breast Cancer Res Treat. 2011 Feb;126(1):119–30. PMID: 21203900. Exclusion: E521203900
Korde LA, Mueller CM, Loud JT, . No evidence of excess breast cancer risk among mutation-negative women from BRCA mutation-positive families. Breast Cancer Res Treat. 2011 Jan;125(1):169–73. PMID: 20458532. Exclusion: E520458532
Kurian AW, Gong GD, John EM, . Breast cancer risk for noncarriers of family-specific BRCA1 and BRCA2 mutations: Findings from the Breast Cancer Family Registry. J Clin Oncol. 2011;29(34):4505–9. doi: 10.1200/jco.2010.34.4440. PMID: 22042950. Exclusion: E522042950
Langston AA, Malone KE, Thompson JD, . BRCA1 mutations in a population-based sample of young women with breast cancer. N Engl J Med. 1996;334:137–42. PMID: 8531967. Exclusion: E58531967
Liede A, Karlan BY, Baldwin RL, . Cancer incidence in a population of Jewish women at risk of ovarian cancer. J Clin Oncol. 2002;20(6):1570–7. PMID: 11896106 Exclusion: E511896106
Lubinski J, Huzarski T, Byrski T, . The risk of breast cancer in women with a BRCA1 mutation from North America and Poland. Int J Cancer. 2012 Jul 1;131(1):229–34. doi: 10.1002/ijc.26369. PMID: 21834074. Exclusion: E521834074
Malone KE, Daling JR, Neal C, . Frequency of BRCA1/BRCA2 mutations in a population-based sample of young breast carcinoma cases. Cancer. 2000;88(6):1393–402. PMID: 10717622. Exclusion: E510717622
Marroni F, Aretini P, D’Andrea E, . Penetrances of breast and ovarian cancer in a large series of families tested for BRCA1/2 mutations. Eur J Hum Genet. 2004 Nov;12(11):899–906. PMID: 15340362. Exclusion: E515340362
Metcalfe K, Lubinski J, Lynch HT, . Family history of cancer and cancer risks in women with BRCA1 or BRCA2 mutations. J Natl Cancer Inst. 2010 Dec 15;102(24):1874–8. PMID: 21098759. Exclusion: E521098759
Metcalfe KA, Finch A, Poll A, . Breast cancer risks in women with a family history of breast or ovarian cancer who have tested negative for a BRCA1 or BRCA2 mutation. Br J Cancer. 2009 Jan 27;100(2):421–5. PMID: 19088722. Exclusion: E519088722
Metcalfe KA, Poll A, Royer R, . Screening for founder mutations in BRCA1 and BRCA2 in unselected Jewish women. J Clin Oncol. 2010;28(3):387–91. PMID: 20008623. Exclusion: E520008623
Milne RL, Osorio A, Cajal TRY, . The average cumulative risks of breast and ovarian cancer for carriers of mutations in BRCA1 and BRCA2 attending genetic counseling units in Spain. Clin Cancer Res. 2008 May 1;14(9):2861–9. PMID: 18451254. Exclusion: E518451254
Modan B, Hartge P, Hirsh-Yechezkel G, . Parity, oral contraceptives, and the risk of ovarian cancer among carriers and noncarriers of a BRCA1 or BRCA2 mutation. N Engl J Med. 2001;345(4):235–40. PMID: 11474660. Exclusion: E511474660
Moslehi R, Chu W, Karlan B, . BRCA1 and BRCA2 mutation analysis of 208 Ashkenazi Jewish women with ovarian cancer. Am J Hum Genet. 2000 Apr;66(4):1259–72. doi: 10.1086/302853. PMID: 10739756. Exclusion: E510739756
Nanda R, Schumm LP, Cummings S, . Genetic testing in an ethnically diverse cohort of high-risk women: a comparative analysis of BRCA1 and BRCA2 mutations in American families of European and African ancestry. JAMA. 2005 Oct 19;294(15):1925–33. PMID: 16234499. Exclusion: E516234499
Neuhausen SL, Ozcelik H, Southey MC, . BRCA1 and BRCA2 mutation carriers in the Breast Cancer Family Registry: An open resource for collaborative research. Breast Cancer Res Treat. 2009;116(2):379–86. PMID: 18704680. Exclusion: E518704680
Newman B, Mu H, Butler LM, . Frequency of breast cancer attributable to BRCA1 in a population-based series of American women. JAMA. 1998 Testing Search 4-12-04;279(12):915–21. PMID: 9544765. Exclusion: E59544765
Oddoux C, Struewing JP, Clayton CM, . The carrier frequency of the BRCA2 6174delT mutation among Ashkenazi Jewish individuals is approximately 1%. Nat Genet. 1996 June 20;14(2):188–90. PMID: 8841192. Exclusion: E58841192
Peto J, Collins N, Barfoot R, . Prevalence of BRCA1 and BRCA2 gene mutations in patients with early-onset breast cancer. J Natl Cancer Inst. 1999 Jun 02;91(11):943–9. PMID: 10359546. Exclusion: E510359546
Rijnsburger AJ, Obdeijn IM, Kaas R, . BRCA1-associated breast cancers present differently from BRCA2-associated and familial cases: long-term follow-up of the Dutch MRISC screening study. J Clin Oncol. 2010;28(36):5265–73. PMID: 21079137. Exclusion: E521079137
Risch HA, McLaughlin JR, Cole DE, . Prevalence and penetrance of germline BRCA1 and BRCA2 mutations in a population series of 649 women with ovarian cancer. Am J Hum Genet. 2001;68(3):700–10. PMID: 11179017. Exclusion: E511179017
Risch HA, McLaughlin JR, Cole DEC, . Population BRCA1 and BRCA2 mutation frequencies and cancer penetrances: a kin-cohort study in Ontario, Canada. J Natl Cancer Inst. 2006 Dec 6;98(23):1694–706. PMID: 17148771. Exclusion: E517148771
Roa BB, Boyd AA, Volcik K, . Ashkenazi Jewish population frequencies for common mutations in BRCA1 and BRCA2. Nat Genet. 1996 Oct;14(2):185–7. doi: 10.1038/ng1096-185. PMID: 8841191. Exclusion: E58841191
Robson M, Gilewski T, Haas B, . BRCA-associated breast cancer in young women. J Clin Oncol. 1998 May;16(5):1642–9. doi: 10.1200/jco.1998.16.5.1642. PMID: 9586873. Exclusion: E59586873
Rowan E, Poll A, Narod SA. A prospective study of breast cancer risk in relatives of BRCA1/BRCA2 mutation carriers. J Med Genet. 2007 Aug;44(8):e 89; author reply, e 8. PMID: 17673443. Exclusion: E517673443
Satagopan JM, Offit K, Foulkes W, . The lifetime risks of breast cancer in Ashkenazi Jewish carriers of BRCA1 and BRCA2 mutations. Cancer Epidemiol Biomarkers Prev. 2001 May;10(5):467–73. PMID: 11352856. Exclusion: E511352856
Seymour IJ, Casadei S, Zampiga V, . Results of a population-based screening for hereditary breast cancer in a region of North-Central Italy: contribution of BRCA1/2 germ-line mutations. Breast Cancer Res Treat. 2008 Nov;112(2):343–9. PMID: 18092194. Exclusion: E518092194
Smith A, Moran A, Boyd MC, . Phenocopies in BRCA1 and BRCA2 families: evidence for modifier genes and implications for screening. J Med Genet. 2007;44:10–5. PMID: 17079251. Exclusion: E517079251
Stratton JF, Gayther SA, Russell P, . Contribution of BRCA1 mutations to ovarian cancer. N Engl J Med. 1997;336(16):1125–30. PMID: 9099656. Exclusion: E59099656
Struewing JP, Hartge P, Wacholder S, . The risk of cancer associated with specific mutations of BRCA1 and BRCA2 among Ashkenazi Jews. N Engl J Med. 1997 May 15;336(20):1401–8. doi: 10.1056/NEJM199705153362001. PMID: 9145676. Exclusion: E59145676
Sutcliffe S, Pharoah PD, Easton DF, . Ovarian and breast cancer risks to women in families with two or more cases of ovarian cancer. Int J Cancer. 2000;87:110–17. PMID: 10861460. Exclusion: E510861460
Tamboom K, Kaasik K, Aršavskaja J, . BRCA1 mutations in women with familial or early-onset breast cancer and BRCA2 mutations in familial cancer in Estonia. Hered Cancer Clin Pract. 2010;8(1) PMID: 20380699. Exclusion: E520380699
Tommasi S, Crapolicchio A, Lacalamita R, . BRCA1 mutations and polymorphisms in a hospital-based consecutive series of breast cancer patients from Apulia, Italy. Mutat Res. 2005 Oct 15;578(1–2):395–405. PMID: 16026807. Exclusion: E516026807
van der Kolk DM, de Bock GH, Leegte BK, . Penetrance of breast cancer, ovarian cancer and contralateral breast cancer in BRCA1 and BRCA2 families: high cancer incidence at older age. Breast Cancer Res Treat. 2010 Dec;124(3):643–51. PMID: 20204502. Exclusion: E520204502
Vaziri SA, Krumroy LM, Rostai M, . Frequency of BRCA1 and BRCA2 mutations in a clinic-based series of breast and ovarian cancer families. Hum Mutat. 2001;17(1):74. PMID: 11139249. Exclusion: E511139249
Warner E, Foulkes W, Goodwin P, . Prevalence and penetrance of BRCA1 and BRCA2 gene mutations in unselected Ashkenazi Jewish women with breast cancer. J Natl Cancer Inst. 1999 Jul 21;91(14):1241–7. PMID: 10413426. Exclusion: E510413426
Weitzel JN, Lagos V, Blazer KR, . Prevalence of BRCA mutations and founder effect in high-risk Hispanic families. Cancer Epidemiol Biomarkers Prev. 2005 Jul;14(7):1666–71. doi: 10.1158/1055-9965.EPI-05-0072. PMID: 16030099. Exclusion: E516030099

Full-Text Papers Excluded From Searches

Exclusion Codes:
2 = Background information only
3 = Wrong population; 3a = Wrong population – did not report the time since treatment completion or time since diagnosis, AND the percent of women affected by (or with a personal history of) breast and/or ovarian cancer combined is >30% (or not reported at all); 3b = Wrong population - reported the time since diagnosis, with the minimum in the range <5 years (or range not reported), or if SD would include <5 years, AND the percent of women affected by (or with a personal history of) breast and/or ovarian cancer combined is >30% (or not reported at all); H1 = Wrong population - reported the time since diagnosis with the minimum in the range <5 years (or range not reported), or if SD would include <5 years, AND the percent of women affected by (or with a personal history of) breast and/or ovarian cancer combined is ≤30%; H2 = Wrong population – did not report the time since diagnosis, but did report the percent of women affected by (or with a personal history of) breast and/or ovarian cancer combined is ≤30%
4 = Wrong intervention
5 = Wrong outcome
6 = Wrong publication type
7 = Wrong study design
8 = Not in English
9 = Non-systematic review or outdated review
10 = Companion paper with outdated data, data not used

Supreme Court of the United States, Association for Molecular Pathology et al. v. Myriad Genetics, Inc., . 133 S. Ct. 2107 (June 13, 2013). Exclusion: 2
StatBite: BRCA mutations increase risk of breast/ovarian cancer. J Natl Cancer Inst. 2010 Jun 2;102(11):755. PMID: 20498426. Exclusion: E620498426
BRCA1 and BRCA2: Cancer Risk and Genetic Testing. Bethesda, MD: National Cancer Institute; 2015. https://www.cancer.gov/about-cancer/causes-prevention/genetics/brca-fact-sheet. Accessed May 12 2019. Exclusion: E6
Aromatase inhibitors versus tamoxifen in early breast cancer: patient-level meta-analysis of the randomised trials. Lancet. 2015 Oct 3;386(10001):1341–52. doi: 10.1016/s0140-6736(15)61074-1. PMID: 26211827. Exclusion: 226211827
Aalfs CM, Mollema ED, Oort FJ, . Genetic counseling for familial conditions during pregnancy: An analysis of patient characteristics. Clin Genet. 2004;66(2):112–21. PMID: 15253761. Exclusion: E515253761
Abdollahian M, Das TK. A MDP model for breast and ovarian cancer intervention strategies for BRCA1/2 mutation carriers. IEEE J Biomed Health Inform. 2015 Mar;19(2):720–7. doi: 10.1109/JBHI.2014.2319246. PMID: 24771600. Exclusion: E724771600
Adams I, Christopher J, Williams KP, . What black women know and want to know about counseling and testing for BRCA1/2. J Cancer Educ. 2015 Jun;30(2):344–52. doi: 10.1007/s13187-014-0740-9. PMID: 25301325. Exclusion: E425301325
Adams S, Greeder L, Reich E, . Expression of cancer testis antigens in human BRCA-associated breast cancers: potential targets for immunoprevention? Cancer Immunol Immunother. 2011 Jul;60(7):999–1007. PMID: 21465317. Exclusion: E421465317
Adams-Campbell LL, Makambi KH, Palmer JR, . Diagnostic accuracy of the Gail model in the Black Women’s Health Study. Breast J. 2007 Jul–Aug;13(4):332–6. PMID: 17593036. Exclusion: E417593036
Adank MA, van Mil SE, Gille JJP, . PALB2 analysis in BRCA2-like families. Breast Cancer Res Treat. 2011 Jun;127(2):357–62. PMID: 20582465. Exclusion: E320582465
Adejumo PO. Overview of genetic counselling in cancer care. JMBR. 2014;13(2):38–47. Exclusion: E6
Adonizio CS, Grana G, Sharan K, . Recurrent early-stage triple-negative breast cancer. Semin Oncol. 2010 Oct;37(5):419–28. PMID: 21074055. Exclusion: E721074055
Adrover E, Esteban I, Llort G, . Famosa: Evaluation of a multigene panel in patients with suspected HBOC. Ann Oncol. 2016;27 doi: 10.1093/annonc/mdw364.32. Exclusion: E6
Agalliu I, Gern R, Leanza S, . Associations of high-grade prostate cancer with BRCA1 and BRCA2 founder mutations. Clin Cancer Res. 2009 Feb 1;15(3):1112–20. PMID: 19188187. Exclusion: E319188187
Ager B, Butow P, Jansen J, . Contralateral prophylactic mastectomy (CPM): a systematic review of patient reported factors and psychological predictors influencing choice and satisfaction. Breast. 2016 Aug;28:107–20. doi: 10.1016/j.breast.2016.04.005. PMID: 27290619. Exclusion: E327290619
Aguas F, Martins A, Gomes TP, . Prophylaxis approach to a-symptomatic post-menopausal women: Breast cancer. Maturitas. 2005 Nov;52(Suppl1):S23–S31. doi: 10.1016/j.maturitas.2005.06.015. PMID: 16126355. Exclusion: E916126355
Ahmad K. Cancer prophylaxis for women with Lynch syndrome. Lancet Oncol. 2006 Mar;7(3):200. PMID: 16538784. Exclusion: E316538784
Albada A, Ausems MG, van Dulmen S. Counselee participation in follow-up breast cancer genetic counselling visits and associations with achievement of the preferred role, cognitive outcomes, risk perception alignment and perceived personal control. Soc Sci Med. 2014 Sep;116:178–86. doi: 10.1016/j.socscimed.2014.07.012. PMID: 25016325. Exclusion: E3a25016325
Albada A, van Dulmen S, Ausems MGEM, . A pre-visit website with question prompt sheet for counselees facilitates communication in the first consultation for breast cancer genetic counseling: findings from a randomized controlled trial. Genet Med. 2012 May;14(5):535–42. doi: 10.1038/gim.2011.42. PMID: 22241101. Exclusion: 222241101
Albada A, van Dulmen S, Bensing JM, . Effects of a pre-visit educational website on information recall and needs fulfilment in breast cancer genetic counselling, a randomized controlled trial. Breast Cancer Res. 2012;14(2):R37. PMID: 22394647. Exclusion: E3a22394647
Albada A, van Dulmen S, Lindhout D, . A pre-visit tailored website enhances counselees’ realistic expectations and knowledge and fulfils information needs for breast cancer genetic counselling. Fam Cancer. 2012 Mar;11(1):85–95. PMID: 21901499. Exclusion: 221901499
Albada A, van Dulmen S, Spreeuwenberg P, . Follow-up effects of a tailored pre-counseling website with question prompt in breast cancer genetic counseling. Patient Educ Couns. 2015 Jan;98(1):69–76. doi: 10.1016/j.pec.2014.10.005. PMID: 25455796. Exclusion: E3a25455796
Albada A, Vernooij M, van Osch L, . Does and should breast cancer genetic counselling include lifestyle advice? Fam Cancer. 2014 Mar;13(1):35–44. doi: 10.1007/s10689-013-9672-5. PMID: 23934600. Exclusion: E3a23934600
Alexakos FM. Rhode Island primary care physicians’ attitudes toward genetic testing for breast cancer. Med Health R I. 1999 May;82(5):171. PMID: 10343495. Exclusion: E510343495
Ali E, Athanasopoulos PG, Forouhi P, . Cowden syndrome and reconstructive breast surgery: case reports and review of the literature. J Plast Reconstr Aesthet Surg. 2011 Apr;64(4):545–9. PMID: 20627761. Exclusion: E320627761
Alkner S, Bendahl PO, Grabau D, . AIB1 is a predictive factor for tamoxifen response in premenopausal women. Ann Oncol. 2010 Feb;21(2):238–44. PMID: 19628566 Exclusion: E319628566
Aloraifi F, Alshehhi M, McDevitt T, . Phenotypic analysis of familial breast cancer: comparison of BRCAx tumors with BRCA1-, BRCA2-carriers and non-familial breast cancer. Eur J Surg Oncol. 2015 May;41(5):641–6. doi: 10.1016/j.ejso.2015.01.021. PMID: 25736863. Exclusion: E325736863
Alsop K, Fereday S, Meldrum C, . BRCA mutation frequency and patterns of treatment response in BRCA mutation-positive women with ovarian cancer: a report from the Australian Ovarian Cancer Study Group. J Clin Oncol. 2012 Jul 20;30(21):2654–63. doi: 10.1200/jco.2011.39.8545. PMID: 3413277. Exclusion: E322711857
Alsop K, Fereday S, Meldrum C, . Germ-line BRCA mutations in high-grade ovarian cancer: A case for routine BRCA mutation screening after a diagnosis of invasive ovarian cancer. J Clin Oncol. 2011;29(15). Exclusion: E3
Al-Tuama A, Bolger JC, Roche T, . Predicting risk in breast cancer: An assessment of screening tools. Ir J Med Sci. 2014;183(1):S54–S5. doi: 10.1007/s11845-013-1062-3. Exclusion: E6
Amara N, Blouin-Bougie J, Jbilou J, . The knowledge value-chain of genetic counseling for breast cancer: an empirical assessment of prediction and communication processes. Fam Cancer. 2016 Jan;15(1):1–17. doi: 10.1007/s10689-015-9835-7. PMID: 26334522. Exclusion: E526334522
American Cancer Society. Cancer Facts & Figures 2016. Atlanta: American Cancer Society, Inc.; 2016. http://www.cancer.org/research/cancerfactsstatistics/cancerfactsfigures2016/. Accessed May 16 2019. Exclusion: 2
American Cancer Society. Cancer Facts & Figures 2018. Atlanta: American Cancer Society, Inc.; 2018. https://www.cancer.org/content/dam/cancer-org/research/cancer-facts-and-statistics/annual-cancer-facts-and-figures/2018/cancer-facts-and-figures-2018.pdf. Accessed May 16 2019. Exclusion: 2
American College of Surgeons. Cancer Program Standards 2016. Chicago, IL; 2016. http://www.facs.org/cancer/coc/programstandards2012.html. Accessed May 1 2019. Exclusion: 2
American Society of Clinical Oncology. Statement of the American Society of Clinical Oncology: genetic testing for cancer susceptibility, Adopted on February 20, 1996. J Clin Oncol. 1996 May;14(5):1730–6; discussion 7-40. doi: 10.1200/JCO.1996.14.5.1730. PMID: 8622094. Exclusion: 28622094
American Society of Clinical Oncology. Li-Fraumeni Syndrome. 2016. http://www.cancer.net/cancer-types/li-fraumeni-syndrome. Accessed May 16 2019. Exclusion: 2
Andersen M, Drescher CW, Zheng Y, . Changes in cancer worry associated with participation in ovarian cancer screening. Psychooncology. 2007 Sep;16(9):814–20. doi: 10.1002/pon.1151. PMID: 17225260. Exclusion: E317225260
Andersen MR, Thorpe J, Buist DS, . Cancer risk awareness and concern among women with a family history of breast or ovarian cancer. Behav Med. 2016;42(1):18–28. doi: 10.1080/08964289.2014.947234. PMID: 25062114. Exclusion: E525062114
Anderson CK, Wallace S, Guiahi M, . Risk-reducing salpingectomy as preventative strategy for pelvic serous cancer. Int J Gynecol Cancer. 2013;23(3):417–21. PMID: 23385282. Exclusion: E623385282
Anderson E, Berg J, Black R, . Prospective surveillance of women with a family history of breast cancer: auditing the risk threshold. Br J Cancer. 2008;98(4):840–4. doi: 10.1038/sj.bjc.6604155. PMID: 30000894. Exclusion: E518283300
Anderson EE, Tejeda S, Childers K, . Breast cancer risk assessment among low-income women of color in primary care: a pilot study. J Oncol Pract. 2015 Jul;11(4):e460–7. doi: 10.1200/JOP.2014.003558. PMID: 26036266. Exclusion: E426036266
Anderson K, Jacobson JS, Heitjan DF, . Cost-effectiveness of preventive strategies for women with a BRCA1 or a BRCA2 mutation.[Summary for patients in Ann Intern Med. 2006 Mar 21;144(6):I40; PMID: 16549849]. Ann Intern Med. 2006 Mar 21;144(6):397–406. PMID: 16549852. Exclusion: E516549852
Andersson I, Janzon L. Reduced breast cancer mortality in women under age 50: updated results from the Malmo Mammographic Screening Program. J Natl Cancer Inst Monogr. 1997;22:63–7. PMID: 9709278. Exclusion: E39709278
Andrieu N, Easton DF, Chang-Claude J, . Effect of chest X-rays on the risk of breast cancer among BRCA1/2 mutation carriers in the international BRCA1/2 carrier cohort study: a report from the EMBRACE, GENEPSO, GEO-HEBON, and IBCCS Collaborators’ Group. J Clin Oncol. 2006 Jul 20;24(21):3361–6. PMID: 16801631. Exclusion: E516801631
Andrykowski MA, Boerner LM, Salsman JM, . Psychological response to test results in an ovarian cancer screening program: a prospective, longitudinal study. Health Psychol. 2004 Nov;23(6):622–30. doi: 10.1037/0278-6133.23.6.622. PMID: 15546230. Exclusion: E315546230
Andrykowski MA, Carpenter JS, Studts JL, . Psychological impact of benign breast biopsy: a longitudinal, comparative study. Health Psychol. 2002 Sep;21(5):485–94. PMID: 12211516. Exclusion: E312211516
Ang P, Lim IHK, Lee TC, . BRCA1 and BRCA2 mutations in an Asian clinic-based population detected using a comprehensive strategy. Cancer Epidemiol Biomarkers Prev. 2007;16(11):2276–84. PMID: 18006916. Exclusion: E518006916
Angelos P, Bedrosian I, Euhus DM, . Contralateral prophylactic mastectomy: Challenging considerations for the surgeon. Ann Surg Oncol. 2015 Oct;22(10):3208–12. doi: 10.1245/s10434-015-4758-y. PMID: 26259752. Exclusion: E626259752
Annunziata MA, Muzzatti B, Narciso D, . Mood state profile and coping strategies after BRCA-1/2 genetic test disclosure: a retrospective study in Italy. Support Care Cancer. 2011 Jun;19(6):733–5. PMID: 21267604. Exclusion: E321267604
Antill Y, Reynolds J, Young M-A, . Risk-reducing surgery in women with familial susceptibility for breast and/or ovarian cancer. Eur J Cancer. 2006 Mar;42(5):621–8. PMID: 16434187. Exclusion: E316434187
Antoniou A, Pharoah PD, Narod S, . Average risks of breast and ovarian cancer associated with BRCA1 or BRCA2 mutations detected in case series unselected for family history: a combined analysis of 22 studies. Am J Hum Genet. 2003 May;72(5):1117–30. doi: 10.1086/375033. PMID: 12677558. Exclusion: 212677558
Antoniou AC, Cunningham AP, Peto J, . The BOADICEA model of genetic susceptibility to breast and ovarian cancers: updates and extensions. Br J Cancer. 2008 Apr 22;98(8):1457–66. doi: 10.1038/sj.bjc.6604305. PMID: 18349832. Exclusion: 218349832
Antoniou AC, Gayther SA, Stratton JF, . Risk models for familial ovarian and breast cancer. Genet Epidemiol. 2000 Feb;18(2):173–90. doi: 10.1002/(SICI)1098-2272(200002)18:2<173::AID-GEPI6>3.0.CO;2-R. PMID: 10642429. Exclusion: 210642429
Antoniou AC, Pharoah PDP, Easton DF, . BRCA1 and BRCA2 cancer risks. J Clin Oncol. 2006 Jul 10;24(20):3312–3; author reply 3-4. PMID: 16829658. Exclusion: E616829658
Antoniou AC, Pharoah PDP, Narod S, . Breast and ovarian cancer risks to carriers of the BRCA1 5382insC and 185delAG and BRCA2 6174delT mutations: a combined analysis of 22 population based studies. J Med Genet. 2005 Jul;42(7):602–3. PMID: 15994883. Exclusion: E615994883
Antoniou AC, Shenton A, Maher ER, . Parity and breast cancer risk among BRCA1 and BRCA2 mutation carriers. Breast Cancer Res. 2006;8(6):R72. PMID: 17187672. Exclusion: E517187672
Antoniou AC, Wang X, Fredericksen ZS, . A locus on 19p13 modifies risk of breast cancer in BRCA1 mutation carriers and is associated with hormone receptor-negative breast cancer in the general population. Nat Genet. 2010 Oct;42(10):885–92. PMID: 20852631. Exclusion: E520852631
Antonucci I, Provenzano M, Sorino L, . Comparison between CaGene 5.1 and 6.0 for BRCA1/2 mutation prediction: A retrospective study of 150 BRCA1/2 genetic tests in 517 families with breast/ovarian cancer. J Hum Genet. 2017;62(3):379–87. doi: 10.1038/jhg.2016.138. PMID: 27928164. Exclusion: E527928164
Apicella C, Peacock SJ, Andrews L, . Determinants of preferences for genetic counselling in Jewish women. Fam Cancer. 2006;5(2):159–67. PMID: 16736286. Exclusion: E516736286
Arai M, Miki Y, Yamaguchi T, . [Clinical genetics for hereditary cancers: from the viewpoint of physicians working at a hospital specialized in cancer]. Gan to Kagaku Ryoho [Japanese Journal of Cancer & Chemotherapy]. 2005 Jul;32(7):948–53. PMID: 16044953. Exclusion: 216044953
Arason A, Jonasdottir A, Barkardottir RB, . A population study of mutations and LOH at breast cancer gene loci in tumours from sister pairs: two recurrent mutations seem to account for all BRCA1/BRCA2 linked breast cancer in Iceland. J Med Genet. 1998 Jun;35(6):446–9. PMID: 9643283. Exclusion: 29643283
Ardern-Jones A, Kenen R, Eeles R. Too much, too soon? Patients and health professionals’ views concerning the impact of genetic testing at the time of breast cancer diagnosis in women under the age of 40. Eur J Cancer Care (Engl). 2005 Jul;14(3):272–81. PMID: 15952973. Exclusion: E315952973
Armakolas A, Ladopoulou A, Konstantopoulou I, . BRCA2 gene mutations in Greek patients with familial breast cancer. Hum Mutat. 2002;19(1):81–2. PMID: 11754111. Exclusion: E311754111
Armel SR, McCuaig J, Finch A, . The effectiveness of family history questionnaires in cancer genetic counseling. J Genet Couns. 2009 Aug;18(4):366–78. doi: 10.1007/s10897-009-9228-x. PMID: 19459037. Exclusion: E519459037
Armel SR, McCuaig J, Gojska N, . All in the family: Barriers and motivators to the use of cancer family history questionnaires and the impact on attendance rates. J Genet Couns. 2015 Oct;24(5):822–32. doi: 10.1007/s10897-014-9813-5. PMID: 25558824. Exclusion: E525558824
Armstrong AC, Evans GD. Management of women at high risk of breast cancer. BMJ. 2014;348:g2756. doi: 10.1136/bmj.g2756. PMID: 24778341. Exclusion: E624778341
Armstrong J, Toscano M, Kotchko N, . Utilization and outcomes of BRCA genetic testing and counseling in a national commercially insured population: the about study. Obstet Gynecol Surv. 2016;71(5):287–8. doi: 10.1097/01.ogx.0000482583.01182.ea. PMID: 26426480. Exclusion: E426426480
Armstrong J, Toscano M, Kotchko N, . American BRCA Outcomes and Utilization of Testing (ABOUT) study: a pragmatic research model that incorporates personalized medicine/patient-centered outcomes in a real world setting. J Genet Couns. 2015 Feb;24(1):18–28. doi: 10.1007/s10897-014-9750-3. PMID: 25209347. Exclusion: E625209347
Armstrong K, Quistberg DA, Micco E, . Prescription of tamoxifen for breast cancer prevention by primary care physicians. Arch Intern Med. 2006 Nov 13;166(20):2260–5. PMID: 17101945. Exclusion: E517101945
Arnold AG, Otegbeye E, Fleischut MH, . Assessment of individuals with BRCA1 and BRCA2 large rearrangements in high-risk breast and ovarian cancer families. Breast Cancer Res Treat. 2014 Jun;145(3):625–34. doi: 10.1007/s10549-014-2987-6. PMID: 24825132. Exclusion: E524825132
Artioli G, Borgato L, Cappetta A, . Overall survival in BRCA-associated ovarian cancer: case-control study of an Italian series. Eur J Gynaecol Oncol. 2010;31(6):658–61. PMID: 21319511. Exclusion: E521319511
Arts-de Jong M, Manders CM, Hoogerbrugge N, . Added value of family history in counseling about risk of BRCA1/2 mutation in early-onset epithelial ovarian cancer. Int J Gynecol Cancer. 2013 Oct;23(8):1406–10. doi: 10.1097/IGC.0b013e3182a1cf71. PMID: 23975082. Exclusion: E323975082
Arun B, Mohsin S, Miller A, . Acquisition of breast tissue in a biomarker modulation study using bexarotene in women at high risk of breast cancer [abstract]. J Clin Oncol. 2005;23(106). Exclusion: E6
Atkin CK, Smith SW. Improving communication practices to reduce breast cancer environmental risks. J Health Commun. 2010 Sep;25(6–7):587–8. doi: 10.1080/10410236.2010.496836. PMID: 20845154. Exclusion: E620845154
Audrain J, Schwartz MD, Lerman C, . Psychological distress in women seeking genetic counseling for breast-ovarian cancer risk: the contributions of personality and appraisal. Ann Behav Med. 1997 Fall;19(4):370–7. doi: 10.1007/bf02895156. PMID: 9706364. Exclusion: E59706364
Auranen A, Song H, Waterfall C, . Polymorphisms in DNA repair genes and epithelial ovarian cancer risk. Int J Cancer. 2005 Nov 20;117(4):611–8. PMID: 15924337. Exclusion: E515924337
Awadelkarim KD, Aceto G, Veschi S, . BRCA1 and BRCA2 status in a Central Sudanese series of breast cancer patients: interactions with genetic, ethnic and reproductive factors. Breast Cancer Res Treat. 2007 Apr;102(2):189–99. PMID: 17333343. Exclusion: E417333343
Aygin D, Cengiz H. Life quality of patients who underwent breast reconstruction after prophylactic mastectomy: systematic review. Breast Cancer. 2018 Sep;25(5):497–505. doi: 10.1007/s12282-018-0862-8. PMID: 29721811. Exclusion: E329721811
Ayme A, Viassolo V, Rapiti E, . Determinants of genetic counseling uptake and its impact on breast cancer outcome: a population-based study. Breast Cancer Res Treat. 2014 Apr;144(2):379–89. doi: 10.1007/s10549-014-2864-3. PMID: 24519389. Exclusion: E424519389
Aziz S, Kuperstein G, Rosen B, . A genetic epidemiological study of carcinoma of the fallopian tube. Gynecol Oncol. 2001;80:341–5. PMID: 11263928. Exclusion: E411263928
Azzollini J, Scuvera G, Bruno E, . Mutation detection rates associated with specific selection criteria for BRCA1/2 testing in 1854 high-risk families: A monocentric Italian study. Eur J Intern Med. 2016;32:65–71. doi: 10.1016/j.ejim.2016.03.010. PMID: 27062684. Exclusion: E527062684
Azzouzi A-R, Stoppa-Lyonnet D, Roupret M, . BRCA2 mutation screening is clinically relevant in breast and early prostate cancer families. Int J Urol. 2007 May;14(5):445–6. PMID: 17511731. Exclusion: E617511731
Baandrup L, Faber MT, Christensen J, . Nonsteroidal anti‐inflammatory drugs and risk of ovarian cancer: Systematic review and meta‐analysis of observational studies. Acta Obstet Gynecol Scand. 2013;92(3):245–55. PMID: 23240575. Exclusion: E523240575
Baars JE, Ausems MG, van Riel E, . Communication between breast cancer patients who received inconclusive genetic test results and their daughters and sisters years after testing. J Genet Couns. 2016 Jun;25(3):461–71. doi: 10.1007/s10897-015-9889-6. PMID: 26446011. Exclusion: E3a26446011
Babb SA, Swisher EM, Heller HN, . Qualitative evaluation of medical information processing needs of 60 women choosing ovarian cancer surveillance or prophylactic oophorectomy. J Genet Couns. 2002;11(2):81–96. doi: 10.1023/A:1014571420844. PMID: 26141655. Exclusion: E526141655
Bacha OM, Gregoire J, Grondin K, . Effectiveness of risk-reducing salpingo-oophorectomy in preventing ovarian cancer in a high-risk French Canadian population. Int J Gynecol Cancer. 2012 Jul;22(6):974–8. doi: 10.1097/IGC.0b013e318257b936. PMID: 22740003. Exclusion: E3a22740003
Baer HJ, Brawarsky P, Murray MF, . Familial risk of cancer and knowledge and use of genetic testing. J Gen Intern Med. 2010;25(7):717–24. PMID: 20361271. Exclusion: E520361271
Baldwin LM, Trivers KF, Andrilla CH, . Accuracy of ovarian and colon cancer risk assessments by U.S. physicians. J Gen Intern Med. 2014 May;29(5):741–9. doi: 10.1007/s11606-014-2768-2. PMID: 24519100. Exclusion: E324519100
Balleine RL, Provan PJ, Pupo GM, . Familial concordance of breast cancer pathology as an indicator of genotype in multiple-case families. Genes Chromosomes Cancer. 2010 Dec;49(12):1082–94. PMID: 20815029. Exclusion: E520815029
Balmana J, Diez O, Campos B, . Sex ratio distortion in offspring of families with BRCA1 or BRCA2 mutant alleles: an ascertainment bias phenomenon? Breast Cancer Res Treat. 2005 Aug;92(3):273–7. PMID: 16155798. Exclusion: E516155798
Bancroft EK, Locke I, Ardern-Jones A, . The carrier clinic: an evaluation of a novel clinic dedicated to the follow-up of BRCA1 and BRCA2 carriers-implications for oncogenetics practice. J Med Genet. 2010 Jul;47(7):486–91. doi: 10.1136/jmg.2009.072728. PMID: 20472659. Exclusion: E520472659
Bandera CA, Muto MG, Schorge JO, . BRCA1 gene mutations in women with papillary serous carcinoma of the peritoneum Obstet Gynecol. 1998;92(4):596–600. PMID: 9764635. Exclusion: E39764635
Bane AL, Beck JC, Bleiweiss I, . BRCA2 mutation-associated breast cancers exhibit a distinguishing phenotype based on morphology and molecular profiles from tissue microarrays. Am J Surg Pathol. 2007 Jan;31(1):121–8. PMID: 17197928. Exclusion: E317197928
Barke LD, Freivogel ME. Breast cancer risk assessment models and high-risk screening. Radiol Clin North Am. 2017;55(3):457–74. doi: 10.1016/j.rcl.2016.12.013. PMID: 28411673. Exclusion: 228411673
Barlin J, Pike M, Otegbeye E, . Does postmenopausal risk-reducing salpingo-oophorectomy reduce the risk of BRCA-associated breast cancer? Gynecol Oncol. 2013;130(1):e103–e4. doi: 10.1016/j.ygyno.2013.04.304. Exclusion: E6
Barlow-Stewart K, Taylor SD, Treloar SA, . Verification of consumers’ experiences and perceptions of genetic discrimination and its impact on utilization of genetic testing. Genet Med. 2009 Mar;11(3):193–201. PMID: 19287242. Exclusion: E519287242
Barrett-Connor E, Mosca L, Collins P, . Effects of raloxifene on cardiovascular events and breast cancer in postmenopausal women. N Engl J Med. 2006;355(2):125–37. PMID: 16837676. Exclusion: 216837676
Barry A, Merrigan A, Tormey S. Choosing the most suitable risk assessment model when establishing a Family Risk Assessment Breast Cancer Clinic. Ir J Med Sci. 2013;182:S73. doi: 10.1007/s11845-013-0908-z. Exclusion: E6
Barton M, CN W, IL L, . Complications following bilateral prophylactic mastectomy. J Natl Cancer Inst Monogr. 2005;35:61–6. PMID: 16287887. Exclusion: E316287887
Barton MK. Rates of testing for BRCA mutations in young women are on the rise. CA Cancer J Clin. 2016;66(4):269–70. doi: 10.3322/caac.21306. PMID: 27149306. Exclusion: E627149306
Basham VM, Lipscombe JM, Ward JM, . BRCA1 and BRCA2 mutations in a population-based study of male breast cancer. Breast Cancer Res. 2002;4(1) PMID: 11879560. Exclusion: E311879560
Basu NN, Ingham S, Hodson J, . Risk of contralateral breast cancer in BRCA1 and BRCA2 mutation carriers: a 30-year semi-prospective analysis. Fam Cancer. 2015 Dec;14(4):531–8. doi: 10.1007/s10689-015-9825-9. PMID: 26239694. Exclusion: E3b26239694
Basu NN, Littlechild S, Barr L, . Attitudes to contralateral risk reducing mastectomy among breast and plastic surgeons in England. Ann R Coll Surg Engl. 2016 Feb;98(2):121–7. doi: 10.1308/rcsann.2016.0039. PMID: 26741657. Exclusion: E526741657
Basu NN, Littlechild S, Evans G, . Contralateral risk reducing mastectomy e A national survey of surgeons’ practices and perceptions. Eur J Surg Oncol. 2013;39(11):S64. doi: 10.1016/j.ejso.2013.07.190. Exclusion: E3
Batista LI, Lu KH, Beahm EK, . Coordinated prophylactic surgical management for women with hereditary breast-ovarian cancer syndrome. BMC Cancer. 2008;8:101. PMID: 18410690. Exclusion: E318410690
Baty BJ, Dudley WN, Musters A, . Uncertainty in BRCA1 cancer susceptibility testing. Am J Med Genet C Semin Med Genet. 2006 Nov 15;142C(4):241–50. PMID: 17068806. Exclusion: E317068806
Baumann SL. Family Systems genetic Illness Model-breast cancer. Clin J Oncol Nurs. 2006 Jun;10(3):377–81. PMID: 16789582. Exclusion: E616789582
Bayraktar S, Arun B. BRCA mutation genetic testing implications in the United States. Breast. 2017 Feb;31:224–32. doi: 10.1016/j.breast.2016.11.021. PMID: 27931006. Exclusion: E927931006
Bayraktar S, Elsayegh N, Gutierrez Barrera AM, . Predictive factors for BRCA1/BRCA2 mutations in women with ductal carcinoma in situ. Cancer. 2012 Mar 15;118(6):1515–22. doi: 10.1002/cncr.26428. PMID: 22009639. Exclusion: E522009639
Bayraktar S, Gutierrez-Barrera AM, Liu D, . Outcome of triple-negative breast cancer in patients with or without deleterious BRCA mutations. Breast Cancer Res Treat. 2011 Nov;130(1):145–53. PMID: 21830012. Exclusion: E321830012
Bayraktar S, Jackson M, Gutierrez-Barrera AM, . Genotype-Phenotype Correlations by Ethnicity and Mutation Location in BRCA Mutation Carriers. Breast J. 2015 May–Jun;21(3):260–7. doi: 10.1111/tbj.12392. PMID: 25789811. Exclusion: E525789811
Beattie MS, Copeland K, Fehniger J, . Genetic counseling, cancer screening, breast cancer characteristics, and general health among a diverse population of BRCA genetic testers. J Health Care Poor Underserved. 2013 Aug;24(3):1150–66. doi: 10.1353/hpu.2013.0151. PMID: 23974388. Exclusion: E523974388
Beattie MS, Crawford B, Lin F, . Uptake, time course, and predictors of risk-reducing surgeries in BRCA carriers. Genet Test Mol Biomarkers. 2009 Feb;13(1):51–6. PMID: 19309274. Exclusion: E519309274
Beattie MS, Ganschow P, Gabram-Mendola S, . The consortium of underserved BRCA testers (CUB): A clinical and research database. Current Oncology. 2012;19(2):e100. doi: 10.3747/co.19.1076. Exclusion: E6
Beattie MS, Ganschow P, Gabram-Mendola S, . Comparative assessment of 636 women at risk for hereditary breast cancer within 3 public hospitals: The consortium of underserved BRCA testers. Cancer Res. 2011;71(24)doi: 10.1158/0008-5472.SABCS11-P2-13-03. Exclusion: E5
Becker M. Women’s descriptions six months post notification of positive BRCA 1/2 genetic mutations. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2018;79(2-B(E)):No Pagination Specified. Exclusion: E9
Bednar E, Oakley HD, Sun CCL, . Achieving universal BRCA1 and BRCA2 genetic testing with a novel care delivery model. Gynecol Oncol. 2016;141:80. doi: 10.1016/j.ygyno.2016.04.227. Exclusion: E626748214
Bednar EM, Oakley HD, Sun CC, . A universal genetic testing initiative for patients with high-grade, non-mucinous epithelial ovarian cancer and the implications for cancer treatment. Gynecol Oncol. 2017 Aug;146(2):399–404. doi: 10.1016/j.ygyno.2017.05.037. PMID: 28610746. Exclusion: E328610746
Beery TA, Williams JK. Risk reduction and health promotion behaviors following genetic testing for adult-onset disorders. Genetic Testing. 2007;11(2):111–23. PMID: 17627380. Exclusion: E517627380
Beetstra S, Salisbury C, Turner J, . Lymphocytes of BRCA1 and BRCA2 germ-line mutation carriers, with or without breast cancer, are not abnormally sensitive to the chromosome damaging effect of moderate folate deficiency. Carcinogenesis. 2006 Mar;27(3):517–24. PMID: 16162645. Exclusion: E516162645
Begg CB, Haile RW, Borg A, . Variation of breast cancer risk among BRCA1/2 carriers. JAMA. 2008 Jan 9;299(2):194–201. PMID: 18182601. Exclusion: E518182601
Beiner ME, Finch A, Rosen B, . The risk of endometrial cancer in women with BRCA1 and BRCA2 mutations. A prospective study. Gynecol Oncol. 2007 Jan;104(1):7–10. PMID: 16962648. Exclusion: E416962648
Beitsch PD, Whitworth PW. Can breast surgeons provide breast cancer genetic testing? An American Society of Breast Surgeons survey. Ann Surg Oncol. 2014 Dec;21(13):4104–8. doi: 10.1245/s10434-014-3711-9. PMID: 24756810. Exclusion: E424756810
Bell DW, Kim SH, Godwin AK, . Genetic and functional analysis of CHEK2 (CHK2) variants in multiethnic cohorts. Int J Cancer. 2007 Dec 15;121(12):2661–7. PMID: 17721994. Exclusion: E517721994
Bell K, Learn L, Parpia S, . Exploring family communication of BRCA mutation results and uptake of predictive genetic testing in a clinical setting. Curr Oncol. 2012;19(2):e109. doi: 10.3747/co.19.1076. Exclusion: E6
Bell RA, McDermott H, Fancher TL, . Impact of a randomized controlled educational trial to improve physician practice behaviors around screening for inherited breast cancer. J Gen Intern Med. 2015 Mar;30(3):334–41. doi: 10.1007/s11606-014-3113-5. PMID: 25451990. Exclusion: E325451990
Bellcross C. Further development and evaluation of a breast/ovarian cancer genetics referral screening tool. Genet Med. 2010 Apr;12(4):240. doi: 10.1097/GIM.0b013e3181d4bc3a. PMID: 20395744. Exclusion: E620395744
Bellcross C, Hermstad A, Tallo CL, . Identification and referral of women at risk for BRCA mutations. J Clin Oncol. 2018;36(15)doi: 10.1200/JCO.2018.36.15_suppl.1514. Exclusion: E6
Bellcross CA, Kolor K, Goddard KA, . Awareness and utilization of BRCA1/2 testing among U.S. primary care physicians. Am J Prev Med. 2011 Jan;40(1):61–6. doi: 10.1016/j.amepre.2010.09.027. PMID: 21146769. Exclusion: E521146769
Bellcross CA, Leadbetter S, Alford SH, . Prevalence and healthcare actions of women in a large health system with a family history meeting the 2005 USPSTF recommendation for BRCA genetic counseling referral. Cancer Epidemiol Biomarkers Prev. 2013 Apr;22(4):728–35. doi: 10.1158/1055-9965.EPI-12-1280. PMID: 23371291. Exclusion: E523371291
Bellcross CA, Peipins LA, McCarty FA, . Characteristics associated with genetic counseling referral and BRCA1/2 testing among women in a large integrated health system. Genet Med. 2015 Jan;17(1):43–50. doi: 10.1038/gim.2014.68. PMID: 24946155. Exclusion: E524946155
Beller U. Preconception counseling for the couple at risk preventing the hereditary breast and ovarian cancer syndrome. Int J Gynecol Cancer. 2010 Oct;20(11 Suppl 2):S29–30. PMID: 20975358. Exclusion: E420975358
Benjamin, Caroline M, Thomas, . Interventions to improve patient access to and utilisation of genetic and genomic counselling services. [Protocol]. Cochrane Database Syst Rev. 2015(11) PMID: 26989348. Exclusion: E526989348
Bennett J, Chitty L, Lewis C. Non-invasive prenatal diagnosis for BRCA mutations - a qualitative pilot study of health professionals’ views. J Genet Couns. 2016 Feb;25(1):198–207. doi: 10.1007/s10897-015-9858-0. PMID: 26174937. Exclusion: E526174937
Bennett P, Parsons E, Brain K, . Long-term cohort study of women at intermediate risk of familial breast cancer: experiences of living at risk. Psychooncology. 2010 Apr;19(4):390–8. PMID: 19514016. Exclusion: E519514016
Bennett P, Phelps C, Brain K, . A randomized controlled trial of a brief self-help coping intervention designed to reduce distress when awaiting genetic risk information. J Psychosom Res. 2007 Jul;63(1):59–64. PMID: 17586338. Exclusion: E417586338
Benusiglio PR, Di Maria M, Dorling L, . Hereditary breast and ovarian cancer: successful systematic implementation of a group approach to genetic counselling. Fam Cancer. 2017;16(1):51–6. doi: 10.1007/s10689-016-9929-x. PMID: 27624814. Exclusion: E427624814
Beran TM, Stanton AL, Kwan L, . The trajectory of psychological impact in BRCA1/2 genetic testing: does time heal? Ann Behav Med. 2008 Oct;36(2):107–16. PMID: 18787910. Exclusion: E3a18787910
Bergin C. Take off your genes and let the doctor have a look: why the Mayo and Myriad decisions have invalidated method claims for genetic diagnostic testing. Am Univ Law Rev. 2013;63(1):173–217. PMID: 25335200. Exclusion: E925335200
Bergman A, Flodin A, Engwall Y, . A high frequency of germline BRCA1/2 mutations in western Sweden detected with complementary screening techniques. Fam Cancer. 2005;4(2):89–96. PMID: 15951958. Exclusion: E515951958
Berliner JL, Fay AM, Cummings SA, . NSGC practice guideline: risk assessment and genetic counseling for hereditary breast and ovarian cancer. J Genet Couns. 2013 Apr;22(2):155–63. doi: 10.1007/s10897-012-9547-1. PMID: 23188549. Exclusion: E623188549
Bernholtz S, Jakobson-Setton A, Korach J, . Appendectomy and cancer risk in Jewish BRCA1 and BRCA2 mutation carriers. Breast Cancer Res Treat. 2012 Feb;131(3):981–5. PMID: 21984204. Exclusion: E521984204
Bernier G, Mandell J, Walsh T, . Next generation sequencing to identify inherited mutations in all breast cancer genes in three breast cancer cohorts. J Am Coll Surg. 2013;217(3):S31–S2. doi: 10.1016/j.jamcollsurg.2013.07.058. Exclusion: E5
Berry DA, Parmigiani G, Sanchez J, . Probability of carrying a mutation of breast-ovarian cancer gene BRCA1 based on family history. J Natl Cancer Inst. 1997 Feb 05;89(3):227–38. PMID: 9017003. Exclusion: 29017003
Besic N, Cernivc B, De Grève J, . BRCA2 gene mutations in Slovenian male breast cancer patients. Genetic Testing. 2008;12(2):203–9. PMID: 18439106. Exclusion: E318439106
Bhai P, Gupta D, Saxena R, . Next generation sequencing for diagnosis of patients with hereditary breast and ovarian cancer. Eur J Cancer. 2015;51:S134. Exclusion: E5
Biglia N, D’Alonzo M, Sgro LG, . Breast cancer treatment in mutation carriers: surgical treatment. Minerva Ginecol. 2016 Oct;68(5):548–56. PMID: 26822896. Exclusion: E626822896
Bish A, Sutton S, Jacobs C, . No news is (not necessarily) good news: Impact of preliminary results for BRCA1 mutation searches. Genet Med. 2002;4(5):353–8. PMID: 12394348. Exclusion: E3a12394348
Biswas S, Atienza P, Chipman J, . Simplifying clinical use of the genetic risk prediction model BRCAPRO. Breast Cancer Res Treat. 2013 Jun;139(2):571–9. doi: 10.1007/s10549-013-2564-4. PMID: 23690142. Exclusion: E423690142
Bjorge T, Lie AK, Hovig E, . BRCA1 mutations in ovarian cancer and borderline tumours in Norway: a nested case-control study. Br J Cancer. 2004 Nov 15;91(10):1829–34. PMID: 15477862. Exclusion: E315477862
Bjornslett M, Dahl AA, Sorebo O, . Psychological distress related to BRCA testing in ovarian cancer patients. Fam Cancer. 2015 Dec;14(4):495–504. doi: 10.1007/s10689-015-9811-2. PMID: 25980896. Exclusion: E325980896
Bjorvatn C, Eide GE, Hanestad BR, . Risk perception, worry and satisfaction related to genetic counseling for hereditary cancer. J Genet Couns. 2007 Apr;16(2):211–22. PMID: 17279329. Exclusion: E317279329
Black L, Knoppers BM, Avard D, . Legal liability and the uncertain nature of risk prediction: the case of breast cancer risk prediction models. Public Health Genomics. 2012;15(6):335–40. doi: 10.1159/000342138. PMID: 22987123. Exclusion: E622987123
Bober SL, Hoke LA, Duda RB, . Recommendation recall and satisfaction after attending breast/ovarian cancer risk counseling. J Genet Couns. 2007 Dec;16(6):755–62. PMID: 17674165. Exclusion: E417674165
Bober SL, Recklitis CJ, Bakan J, . Addressing sexual dysfunction after risk-reducing salpingo-oophorectomy: effects of a brief, psychosexual intervention. J Sex Med. 2015 Jan;12(1):189–97. doi: 10.1111/jsm.12713. PMID: 25311333. Exclusion: E425311333
Boccardo F, Rubagotti A, Amoroso D, . Sequential tamoxifen and aminoglutethimide versus tamoxifen alone in the adjuvant treatment of postmenopausal breast cancer patients: results of an Italian cooperative study. J Clin Oncol. 2001 Nov;19(22):4209–15. PMID: 11709564. Exclusion: E311709564
Bodmer D, Ligtenberg MJL, van der Hout AH, . Optimal selection for BRCA1 and BRCA2 mutation testing using a combination of ‘easy to apply’ probability models. Br J Cancer. 2006 Sep 18;95(6):757–62. PMID: 16909138. Exclusion: 216909138
Bodurtha J, Quillin JM, Tracy KA, . Mammography screening after risk-tailored messages: the women improving screening through education and risk assessment (WISER) randomized, controlled trial. J Womens Health. 2009 Jan;18(1):41–7. doi: 10.1089/jwh.2007.0703. PMID: 19105686. Exclusion: E519105686
Boetes C. Update on screening breast MRI in high-risk women. Obstet Gynecol Clin North Am. 2011 Mar;38(1):149–58, viii–ix. PMID: 21419331. Exclusion: E921419331
Bogani G, Tagliabue E, Signorelli M, . Assessing the Risk of Occult Cancer and 30-day Morbidity in Women Undergoing Risk-reducing Surgery: A Prospective Experience. J Minim Invasive Gynecol. 2017 Jul – Aug;24(5):837–42. doi: 10.1016/j.jmig.2017.04.017. PMID: 28479170. Exclusion: E3a28479170
Bolton KL, Chenevix-Trench G, Goh C, . Association between BRCA1 and BRCA2 mutations and survival in women with invasive epithelial ovarian cancer. JAMA. 2012 Jan 25;307(4):382–90. doi: 10.1001/jama.2012.20. PMID: 22274685. Exclusion: 222274685
Bonadies DC, Matloff ET, Brierley KL, . What would the experts do? Genetic testing, surveillance, and risk-reduction preferences for BRCA and Lynch syndrome. J Clin Oncol. 2013;31(15). Exclusion: E6
Bonadona V, Sinilnikova OM, Chopin S, . Contribution of BRCA1 and BRCA2 germ-line mutations to the incidence of breast cancer in young women: results from a prospective population-based study in France. Genes Chromosomes Cancer. 2005 Aug;43(4):404–13. PMID: 15887246. Exclusion: E315887246
Bonanni B, Lazzeroni M. Acceptability of chemoprevention trials in high-risk subjects. Ann Oncol. 2013 Nov;24: Suppl 8:viii42–viii6. doi: 10.1093/annonc/mdt328. PMID: 24131969. Exclusion: E624131969
Bondy ML, Vogel VG, Halabi S, . Identification of women at increased risk for breast cancer in a population-based screening program. Cancer Epidemiol Biomarkers Prev. 1992 Jan–Feb;1(2):143–7. PMID: 1306097. Exclusion: E51306097
Bordeleau L, Lipscombe L, Lubinski J, . Diabetes and breast cancer among women with BRCA1 and BRCA2 mutations. Cancer. 2011 May 1;117(9):1812–8. doi: 10.1002/cncr.25595. PMID: 21509758. Exclusion: E521509758
Bordeleau L, Panchal S, Goodwin P. Prognosis of BRCA-associated breast cancer: a summary of evidence. Breast Cancer Res Treat. 2010 Jan;119(1):13–24. PMID: 19789974. Exclusion: E519789974
Borry P, Fryns JP, Schotsmans P, . Attitudes towards carrier testing in minors: A systematic review. Genet Couns. 2005;16(4):341–52. PMID: 16440876. Exclusion: E516440876
Borry P, Stultiens L, Nys H, . Attitudes towards predictive genetic testing in minors for familial breast cancer: a systematic review. Crit Rev Oncol Hematol. 2007 Dec;64(3):173–81. PMID: 17553690. Exclusion: 217553690
Bosch N, Junyent N, Gadea N, . What factors may influence psychological well being at three months and one year post BRCA genetic result disclosure? Breast. 2012 Dec;21(6):755–60. doi: 10.1016/j.breast.2012.02.004. PMID: 22381151. Exclusion: E322381151
Bosch N, Junyent N, Gadea N, . Long term psychological impact of BRCA1/2 genetic testing in a Spanish population a. Curr Oncol. 2012;19(2):e102. doi: 10.3747/co.19.1076. Exclusion: E6
Bosetti C, Negri E, Trichopoulos D, . Long-term effects of oral contraceptives on ovarian cancer risk. Int J Cancer. 2002;102(3):262–5. PMID: 12397647. Exclusion: E312397647
Bosse K, Rhiem K, Wappenschmidt B, . Screening for ovarian cancer by transvaginal ultrasound and serum CA125 measurement in women with a familial predisposition: a prospective cohort study. Gynecol Oncol. 2006 Dec;103(3):1077–82. PMID: 16904167. Exclusion: E316904167
Bouhnik AD, N’Diaye K, Evans DG, . Validation of a scale for assessing attitudes towards outcomes of genetic cancer testing among primary care providers and breast specialists. PLoS ONE [Electronic Resource]. 2017;12(6):e0178447. doi: 10.1371/journal.pone.0178447. PMID: 28570656. Exclusion: E428570656
Bourret P. BRCA patients and clinical collectives: new configurations of action in cancer genetics practices. Social Studies of Science. 2005 Feb;35(1):41–68. PMID: 15991445. Exclusion: E615991445
Bowen DJ, Powers D. Effects of a mail and telephone intervention on breast health behaviors. Health Educ Behav. 2010 Aug;37(4):479–89. PMID: 20157016. Exclusion: E520157016
Bradbury AR, Ibe CN, Dignam JJ, . Uptake and timing of bilateral prophylactic salpingo-oophorectomy among BRCA1 and BRCA2 mutation carriers. Genet Med. 2008 Mar;10(3):161–6. PMID: 18344704. Exclusion: E3a18344704
Bradbury AR, Patrick-Miller L, Egleston BL, . Knowledge and perceptions of familial and genetic risks for breast cancer risk in adolescent girls. Breast Cancer Res Treat. 2012 Dec;136(3):749–57. doi: 10.1007/s10549-012-2254-7. PMID: 23065030. Exclusion: E523065030
Bradbury AR, Patrick-Miller LJ, Egleston B, . A randomized trial of telephone versus in-person disclosure of BRCA 1/2 results. J Clin Oncol. 2013;31(15). Exclusion: E4
Bradbury AR, Patrick-Miller LJ, Egleston BL, . Patient feedback and early outcome data with a novel tiered-binned model for multiplex breast cancer susceptibility testing. Genet Med. 2016 Jan;18(1):25–33. doi: 10.1038/gim.2015.19. PMID: 25834950. Exclusion: E3a25834950
Brain KE, Lifford KJ, Fraser L, . Psychological outcomes of familial ovarian cancer screening: no evidence of long-term harm. Gynecol Oncol. 2012 Dec;127(3):556–63. doi: 10.1016/j.ygyno.2012.08.034. PMID: 22943881. Exclusion: 222943881
Braithwaite RS, Chlebowski RT, Lau J, . Meta-analysis of vascular and neoplastic events associated with tamoxifen. J Gen Intern Med. 2003 Nov;18(11):937–47. PMID: 14687281. Exclusion: 214687281
Brandenburg DL, Matthews AK, Johnson TP, . Breast cancer risk and screening: a comparison of lesbian and heterosexual women. Women Health. 2007;45(4):109–30. PMID: 18032170. Exclusion: E518032170
Brandt R, Polinsky C, Katz J, . Factors influencing risk reduction surgery among BRCA mutation carriers: A qualitative analysis. J Clin Oncol. 2012;30(27). Exclusion: E5
Brandt-Rauf SI, Raveis VH, Drummond NF, . Ashkenazi Jews and breast cancer: the consequences of linking ethnic identity to genetic disease. Am J Public Health. 2006 Nov;96(11):1979–88. PMID: 17018815. Exclusion: E617018815
Brannon Traxler L, Martin ML, Kerber AS, . Implementing a screening tool for identifying patients at risk for hereditary breast and ovarian cancer: a statewide initiative. Ann Surg Oncol. 2014 Oct;21(10):3342–7. doi: 10.1245/s10434-014-3921-1. PMID: 25047474. Exclusion: E525047474
Breast Cancer Family Registry, Kathleen Cuningham Consortium for Research into Familial Breast Cancer, Ontario Cancer Genetics Network. Smoking and risk of breast cancer in carriers of mutations in BRCA1 or BRCA2 aged less than 50 years. Breast Cancer Res Treat. 2008 May;109(1):67–75. PMID: 17972172. Exclusion: E517972172
Bredart A, Kop JL, De Pauw A, . Effect on perceived control and psychological distress of genetic knowledge in women with breast cancer receiving a BRCA1/2 test result. Breast. 2017 Feb;31:121–7. doi: 10.1016/j.breast.2016.10.024. PMID: 27837705. Exclusion: E327837705
Bredart A, Kop JL, Depauw A, . Short-term psychological impact of the BRCA1/2 test result in women with breast cancer according to their perceived probability of genetic predisposition to cancer. Br J Cancer. 2013 Mar 19;108(5):1012–20. doi: 10.1038/bjc.2012.599. PMID: 23462725. Exclusion: E323462725
Brekelmans CTM, Tilanus-Linthorst MMA, Seynaeve C, . Tumour characteristics, survival and prognostic factors of hereditary breast cancer from BRCA2-, BRCA1- and non-BRCA1/2 families as compared to sporadic breast cancer cases. Eur J Cancer. 2007 Mar;43(5):867–76. PMID: 17307353. Exclusion: E517307353
Brenner RJ. Computer-assisted detection in clinical practice: medical legal considerations. Semin Roentgenol. 2007 Oct;42(4):280–6. PMID: 17919530. Exclusion: E917919530
Bresser PJC, Seynaeve C, Van Gool AR, . Satisfaction with prophylactic mastectomy and breast reconstruction in genetically predisposed women. Plast Reconstr Surg. 2006 May;117(6):1675–82; discussion 83-4. PMID: 16651934. Exclusion: E3a16651934
Bresser PJC, Van Gool AR, Seynaeve C, . Who is prone to high levels of distress after prophylactic mastectomy and/or salpingo-ovariectomy? Ann Oncol. 2007 Oct;18(10):1641–5. PMID: 17660493. Exclusion: E517660493
Bressler T, Popp B. Orthodox jewish thought leaders’ insights regarding BRCA mutations: A descriptive study. J Oncol Pract. 2017;13(4):e303–e9. doi: 10.1200/JOP.2016.015503. PMID: 27875073. Exclusion: E327875073
Brewer HR, Jones ME, Schoemaker MJ, . Family history and risk of breast cancer: an analysis accounting for family structure. Breast Cancer Res Treat. 2017 Aug;165(1):193–200. doi: 10.1007/s10549-017-4325-2. PMID: 28578505. Exclusion: E528578505
Brewer NT, Richman AR, DeFrank JT, . Improving communication of breast cancer recurrence risk. Breast Cancer Res Treat. 2012 Jun;133(2):553–61. PMID: 21964579. Exclusion: E321964579
Brody LC, Biesecker BB. Breast cancer susceptibility genes. BRCA1 and BRCA2. Medicine (Baltimore). 1998 May;77(3):208–26. PMID: 9653432. Exclusion: 29653432
Brooks GA, Stopfer JE, Erlichman J, . Childhood cancer in families with and without BRCA1 or BRCA2 mutations ascertained at a high-risk breast cancer clinic. Cancer Biol Ther. 2006 Sep;5(9):1098–102. PMID: 16931905. Exclusion: 216931905
Brown SM, Culver JO, Osann KE, . Health literacy, numeracy, and interpretation of graphical breast cancer risk estimates. Patient Educ Couns. 2011 Apr;83(1):92–8. doi: 10.1016/j.pec.2010.04.027. PMID: 20554149. Exclusion: E520554149
Brownrigg A. Mother still knows best: cancer-related gene mutations, familial privacy, and a physician’s duty to warn. Fordham Urban Law J. 1999 Jan;26(2):247–79. PMID: 16437785. Exclusion: E516437785
Brownson RC, Dodson EA, Stamatakis KA, . Communicating evidence-based information on cancer prevention to state-level policy makers. J Natl Cancer Inst. 2011 Feb 16;103(4):306–16. PMID: 21212381. Exclusion: E421212381
Bruchim I, Amichay K, Kidron D, . BRCA1/2 germline mutations in Jewish patients with uterine serous carcinoma. Int J Gynecol Cancer. 2010 Oct;20(7):1148–53. PMID: 21206239. Exclusion: E521206239
Brunstrom K, Murray A, McAllister M. Experiences of women who underwent predictive BRCA 1/2 mutation testing before the age of 30. J Genet Couns. 2016 Feb;25(1):90–100. doi: 10.1007/s10897-015-9845-5. PMID: 25983051. Exclusion: E525983051
Buchanan AH, Datta SK, Skinner CS, . Randomized trial of telegenetics vs. In-person cancer genetic counseling: Cost, patient satisfaction and attendance. J Genet Couns. 2015 Dec;24(6):961–70. doi: 10.1007/s10897-015-9836-6. PMID: 2015-52093-002. Exclusion: E3a25833335
Buchanan AH, Skinner CS, Rawl SM, . Patients’ interest in discussing cancer risk and risk management with primary care physicians. Patient Educ Couns. 2005 Apr;57(1):77–87. doi: 10.1016/j.pec.2004.04.003. PMID: 15797155. Exclusion: E515797155
Buchanan AH, Voils CI, Schildkraut JM, . Adherence to recommended risk management among unaffected women with a BRCA mutation. J Genet Couns. 2017 Feb;26(1):79–92. doi: 10.1007/s10897-016-9981-6. PMID: 27265406. Exclusion: E527265406
Bucheit L, Johansen Taber K, Ready K. Validation of a digital identification tool for individuals at risk for hereditary cancer syndromes. Hered Cancer Clin Pract. 2019;17(1)doi: 10.1186/s13053-018-0099-8. Exclusion: E4
Budroni M, Cesaraccio R, Coviello V, . Role of BRCA2 mutation status on overall survival among breast cancer patients from Sardinia. BMC Cancer. 2009;9:62. PMID: 19232099. Exclusion: E319232099
Buffone A, Capalbo C, Ricevuto E, . Prevalence of BRCA1 and BRCA2 genomic rearrangements in a cohort of consecutive Italian breast and/or ovarian cancer families. Breast Cancer Res Treat. 2007 Dec;106(2):289–96. PMID: 17333342. Exclusion: E517333342
Bunnik EM, Janssens AC, Schermer MH. Personal utility in genomic testing: is there such a thing? J Med Ethics. 2015 Apr;41(4):322–6. doi: 10.1136/medethics-2013-101887. PMID: 24872596. Exclusion: E524872596
Burga LN, Tung NM, Troyan SL, . Altered proliferation and differentiation properties of primary mammary epithelial cells from BRCA1 mutation carriers. Cancer Res. 2009 Feb 15;69(4):1273–8. PMID: 19190334. Exclusion: E519190334
Burkadze G, Khardzeishvili O, Gudadze M, . Immunohistochemical expression of BRCA1 protein in invasive ductal carcinoma of the breast. Georgian Med News. 2010 Jul–Aug(184–185):51–60. PMID: 20834076. Exclusion: E520834076
Burwinkel B, Wirtenberger M, Klaes R, . Association of NCOA3 polymorphisms with breast cancer risk. Clin Cancer Res. 2005;11(6):2169–74. PMID: 15788663. Exclusion: E515788663
Butrick M, Kelly S, Peshkin BN, . Disparities in uptake of BRCA1/2 genetic testing in a randomized trial of telephone counseling. Genet Med. 2015 Jun;17(6):467–75. doi: 10.1038/gim.2014.125. PMID: 25232856. Exclusion: E525232856
Buys SS, Partridge E, Black A, . Effect of screening on ovarian cancer mortality: The Prostate, Lung, Colorectal and Ovarian (PLCO) cancer screening randomized controlled trial. JAMA. 2011;305(22):2295–302. PMID: 21642681. Exclusion: E321642681
Buzolin AL, Moreira CM, Sacramento PR, . Development and validation of a variant detection workflow for BRCA1 and BRCA2 genes and its clinical application based on the Ion Torrent technology. Human Genomics. 2017 Jun 26;11(1):14. doi: 10.1186/s40246-017-0110-x. PMID: 28651617. Exclusion: E528651617
Byram SJ, Schwartz LM, Woloshin S, . Women’s beliefs about breast cancer risk factors: A mental models approach. Rationality and social responsibility: Essays in honor of Robyn Mason Dawes. New York, NY: Psychology Press; US; 2008:245–74. Exclusion: E5
Byrd LM, Shenton A, Maher ER, . Better life expectancy in women with BRCA2 compared with BRCA1 mutations is attributable to lower frequency and later onset of ovarian cancer. Cancer Epidemiol Biomarkers Prev. 2008 Jun;17(6):1535–42. PMID: 18559571. Exclusion: E318559571
Byrnes GB, Southey MC, Hopper JL. Are the so-called low penetrance breast cancer genes, ATM, BRIP1, PALB2 and CHEK2, high risk for women with strong family histories? Breast Cancer Res. 2008;10(3):208. PMID: 18557994. Exclusion: E518557994
Byrski T, Gronwald J, Huzarski T, . Response to neo-adjuvant chemotherapy in women with BRCA1-positive breast cancers. Breast Cancer Res Treat. 2008 Mar;108(2):289–96. PMID: 17492376. Exclusion: E317492376
Cabrera E, Blanco I, Yague C, . The impact of genetic counseling on knowledge and emotional responses in Spanish population with family history of breast cancer. Patient Educ Couns. 2010 Mar;78(3):382–8. PMID: 19948386. Exclusion: E319948386
Caiata-Zufferey M. Genetically at-risk status and individual agency. A qualitative study on asymptomatic women living with genetic risk of breast/ovarian cancer. Soc Sci Med. 2015 May;132:141–8. doi: 10.1016/j.socscimed.2015.03.037. PMID: 25813728. Exclusion: E425813728
Caiata-Zufferey M, Pagani O, Cina V, . Challenges in managing genetic cancer risk: a long-term qualitative study of unaffected women carrying BRCA1/BRCA2 mutations. Genet Med. 2015 Sep;17(9):726–32. doi: 10.1038/gim.2014.183. PMID: 25503500. Exclusion: E525503500
Callahan MJ, Crum CP, Medeiros F, . Primary fallopian tube malignancies in BRCA-positive women undergoing surgery for ovarian cancer risk reduction. J Clin Oncol. 2007 Sep 1;25(25):3985–90. PMID: 17761984. Exclusion: E517761984
Calzone KA, Prindiville SA, Jourkiv O, . Randomized comparison of group versus individual genetic education and counseling for familial breast and/or ovarian cancer. J Clin Oncol. 2005;23(15):3455–64. doi: 10.1200/JCO.2005.04.050. PMID: 15908654. Exclusion: E315908654
Cameron LD, Reeve J. Risk perceptions, worry, and attitudes about genetic testing for breast cancer susceptibility. Psychol Health. 2006;21(2):211–30. doi: 10.1080/14768320500230318. PMID: 21985118. Exclusion: E421985118
Campfield Bonadies D, Moyer A, Matloff ET. What I wish I’d known before surgery: BRCA carriers’ perspectives after bilateral salipingo-oophorectomy. Fam Cancer. 2011 Mar;10(1):79–85. PMID: 20852945. Exclusion: E520852945
Cao A, Huang L, Shao Z. The Preventive Intervention of Hereditary Breast Cancer. Adv Exp Med Biol. 2017;1026:41–57. doi: 10.1007/978-981-10-6020-5_3. PMID: 29282679. Exclusion: E929282679
Cao MZ. Analysis of BRCA1 mutations among familial and/or breast cancer praecox patients in the east of Shandong in China. Prog Mod Biomed. 2009;9:1028–30. Exclusion: E8
Cao W, Wang X, Li J-C. Hereditary breast cancer in the Han Chinese population. J Epidemiol. 2013;23(2):75–84. PMID: 23318652. Exclusion: E623318652
Capanu M, Concannon P, Haile RW, . Assessment of rare BRCA1 and BRCA2 variants of unknown significance using hierarchical modeling. Genet Epidemiol. 2011 Jul;35(5):389–97. doi: 10.1002/gepi.20587. PMID: 21520273. Exclusion: E521520273
Cappelli M, Verma S, Korneluk Y, . Psychological and genetic counseling implications for adolescent daughters of mothers with breast cancer. Clin Genet. 2005 Jun;67(6):481–91. PMID: 15857415. Exclusion: E515857415
Carlsson AH, Bjorvatn C, Engebretsen LF, . Psychosocial factors associated with quality of life among individuals attending genetic counseling for hereditary cancer. J Genet Couns. 2004 Oct;13(5):425–45. PMID: 15604640. Exclusion: E515604640
Carmichael H, Matsen C, Freer P, . Breast cancer screening of pregnant and breastfeeding women with BRCA mutations. Breast Cancer Res Treat. 2017 04;162(2):225–30. doi: 10.1007/s10549-017-4122-y. PMID: 28138892. Exclusion: E728138892
Carney ME, Basiliere MS, Mates K, . Detection of BRCA1 and BRCA2 mutations in a selected Hawaii population. Hawaii Med J. 2010 Nov;69(11):268–71. PMID: 21218378. Exclusion: E521218378
Carroll JC, Wilson BJ, Allanson J, . GenetiKit: a randomized controlled trial to enhance delivery of genetics services by family physicians. Fam Pract. 2011 Dec;28(6):615–23. doi: 10.1093/fampra/cmr040. PMID: 21746696. Exclusion: E321746696
Carser JE, Quinn JE, Michie CO, . BRCA1 is both a prognostic and predictive biomarker of response to chemotherapy in sporadic epithelial ovarian cancer. Gynecol Oncol. 2011 Dec;123(3):492–8. PMID: 21920589. Exclusion: E321920589
Caruso A, Vigna C, Maggi G, . The withdrawal from oncogenetic counselling and testing for hereditary and familial breast and ovarian cancer. A descriptive study of an Italian sample. J Exp Clin Cancer Res. 2008;27:75. PMID: 19025627. Exclusion: E519025627
Caruso A, Vigna C, Marozzo B, . Subjective versus objective risk in genetic counseling for hereditary breast and/or ovarian cancers. J Exp Clin Cancer Res. 2009;28:157. PMID: 20025726. Exclusion: E320025726
Caruso A, Vigna C, Sega FM, . BRCA1/2 genes - Psychological side effects of unknown mutation result. Eur J Cancer. 2011;47:S185. doi: 10.1016/S0959-8049(11)70946-7. Exclusion: E6
Casey MJ, Synder C, Bewtra C, . Intra-abdominal carcinomatosis after prophylactic oophorectomy in women of hereditary breast ovarian cancer syndrome kindreds associated with BRCA1 and BRCA2 mutations. Gynecol Oncol. 2005 May;97(2):457–67. PMID: 15863145. Exclusion: E3a15863145
Casey WJ, 3rd, Rebecca AM, Andres LA, . Safety and efficacy of perforator flap breast reconstruction with combined intraabdominal procedures. Ann Plast Surg. 2010 Feb;64(2):144–50. PMID: 20098096. Exclusion: E320098096
Catania C, Feroce I, Barile M, . Improved health perception after genetic counselling for women at high risk of breast and/or ovarian cancer: construction of new questionnaires-an Italian exploratory study. J Cancer Res Clin Oncol. 2016 Mar;142(3):633–48. doi: 10.1007/s00432-015-2062-7. PMID: 26577826. Exclusion: E526577826
Cavallone L, Arcand SL, Maugard CM, . Comprehensive BRCA1 and BRCA2 mutation analyses and review of French Canadian families with at least three cases of breast cancer. Fam Cancer. 2010 Dec;9(4):507–17. PMID: 20694749. Exclusion: E520694749
Ceber E, Soyer MT, Ciceklioglu M, . Breast cancer risk assessment and risk perception on nurses and midwives in Bornova Health District in Turkey. Cancer Nurs. 2006 May–Jun;29(3):244–9. PMID: 16783126. Exclusion: E416783126
Centre for Reviews and Dissemination. The psychological impact of mammographic screening on women with a family history of breast cancer: a systematic review (Provisional abstract). Database of Abstracts of Reviews of Effects. 2012(1). Exclusion: E5
Centre for Reviews and Dissemination. Ovarian cancer and oral contraceptives: collaborative reanalysis of data from 45 epidemiological studies including 23257 women with ovarian cancer and 87303 controls (Structured abstract). Database of Abstracts of Reviews of Effects. 2012(1). Exclusion: E5
Centre for Reviews and Dissemination. MRI and mammography surveillance of women at increased risk for breast cancer: recommendations using an evidence-based approach (Structured abstract). Database of Abstracts of Reviews of Effects. 2012(1). Exclusion: E6
Centre for Reviews and Dissemination. Does this patient have a family history of cancer: an evidence-based analysis of the accuracy of family cancer history (Structured abstract). Database of Abstracts of Reviews of Effects. 2012(1). Exclusion: E5
Centre for Reviews and Dissemination. Collection and use of cancer family history in primary care (Structured abstract). Database of Abstracts of Reviews of Effects. 2012(1). Exclusion: 2
Centre for Reviews and Dissemination. Breast cancer and hormonal contraceptives: collaborative reanalysis of individual data on 53 297 women with breast cancer and 100 239 women without breast cancer from 54 epidemiological studies (Structured abstract). Database of Abstracts of Reviews of Effects. 2012(1). Exclusion: E5
Centre for Reviews and Dissemination. Expanding the criteria for BRCA mutation testing in breast cancer survivors (provisional abstract). NHS Economic Evaluation Database. 2012(1)doi: 10.1002/14651858. Exclusion: E6
Centre for Reviews and Dissemination. Preventing future cancers by testing women with ovarian cancer for BRCA mutations (structured abstract). NHS Economic Evaluation Database. 2012(1)doi: 10.1002/14651858. Exclusion: E5
Centre for Reviews and Dissemination. Cost-effectiveness of population-based BRCA1/2 testing and ovarian cancer prevention for Ashkenazi Jews: a call for dialogue (Provisional abstract). NHS Economic Evaluation Database. 2012(1)doi: 10.1002/14651858. Exclusion: E5
Centre for Reviews and Dissemination. Cost-effectiveness of testing for breast cancer susceptibility genes (Structured abstract). NHS Economic Evaluation Database. 2012(1)doi: 10.1002/14651858. Exclusion: E5
Centre for Reviews and Dissemination. The cost-utility of magnetic resonance imaging for breast cancer in BRCA1 mutation carriers aged 30-49 (Structured abstract). NHS Economic Evaluation Database. 2012(1)doi: 10.1002/14651858. Exclusion: E5
Centre for Reviews and Dissemination. Cost-effectiveness of screening BRCA1/2 mutation carriers with breast magnetic resonance imaging (Structured abstract). NHS Economic Evaluation Database. 2012(1)doi: 10.1002/14651858. Exclusion: E5
Centre for Reviews and Dissemination. Cost-effectiveness of preventive strategies for women with a BRCA1 or a BRCA2 mutation (Structured abstract). NHS Economic Evaluation Database. 2012(1)doi: 10.1002/14651858. Exclusion: E5
Centre for Reviews and Dissemination. Cost-effectiveness of screening with contrast enhanced magnetic resonance imaging vs X-ray mammography of women at a high familial risk of breast cancer (structured abstract). NHS Economic Evaluation Database. 2012(1)doi: 10.1002/14651858. Exclusion: E5
Centre for Reviews and Dissemination. Breast cancer screening, outside the population-screening program, of women from breast cancer families without proven BRCA1/BRCA2 mutations: a simulation study (Structured abstract). NHS Economic Evaluation Database. 2012(1)doi: 10.1002/14651858. Exclusion: E5
Centre for Reviews and Dissemination. Gene expression profiling and breast cancer care: what are the potential benefits and policy implications? (Structured abstract). NHS Economic Evaluation Database. 2012(1)doi: 10.1002/14651858. Exclusion: E3
Centre for Reviews and Dissemination. BRCA1 mutations in Southern England (Structured abstract). NHS Economic Evaluation Database. 2012(1)doi: 10.1002/14651858. Exclusion: E5
Centre for Reviews and Dissemination. Decision analysis of prophylactic mastectomy and oophorectomy in BRCA1-positive or BRCA2-positive patients (Structured abstract). NHS Economic Evaluation Database. 2012(1)doi: 10.1002/14651858. Exclusion: E6
Centre for Reviews and Dissemination. Systematic review: comparative effectiveness of medications to reduce risk for primary breast cancer (Structured abstract). Database of Abstracts of Reviews of Effects. 2012(1). Exclusion: E5
Centre for Reviews and Dissemination. Chemoprevention of breast cancer: a joint guideline from the Canadian Task Force on Preventive Health Care and the Canadian Breast Cancer Initiative’s Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer (Structured abstract). Database of Abstracts of Reviews of Effects. 2012(1). Exclusion: E9
Centre for Reviews and Dissemination. Genetic risk assessment and BRCA mutation testing for breast and ovarian cancer susceptibility: evidence synthethis (Structured abstract). Database of Abstracts of Reviews of Effects. 2012(1). Exclusion: E6
Centre for Reviews and Dissemination. Prophylactic laparoscopic ovarian ablation for premenopausal breast cancer: medical and economic efficacy (Structured abstract). NHS Economic Evaluation Database. 2012(1)doi: 10.1002/14651858. Exclusion: E3
Centre for Reviews and Dissemination. Costs and benefits of diagnosing familial breast cancer (Structured abstract). NHS Economic Evaluation Database. 2012(1)doi: 10.1002/14651858. Exclusion: E5
Centre for Reviews and Dissemination. Meta-analysis of risk reduction estimates associated with risk-reducing salpingo-oophorectomy in BRCA1 or BRCA2 mutation carriers (Provisional abstract). Database of Abstracts of Reviews of Effects; 2012. Exclusion: 2
Centre for Reviews and Dissemination. Nonpharmacologic strategies for managing common chemotherapy adverse effects: a systematic review (Structured abstract). Database of Abstracts of Reviews of Effects; 2012. Exclusion: 2
Centre Oscar Lambret. Radical Fimbriectomy for Young BRCA Mutation Carriers (Fimbriectomy). 2011. https://clinicaltrials.gov/ct2/show/NCT01608074. Accessed May 16 2019. Exclusion: E6
Chadwell SE, He H, Knapke S, . Factors influencing clinical follow-up for individuals with a personal history of breast and/or ovarian cancer and previous uninformative brca1 and brca2 testing. J Genet Couns. 2018 Mar:No Pagination Specified. doi: 10.1007/s10897-018-0241-9. PMID: 29550970. Exclusion: E329550970
Chai X, Domchek S, Kauff N, . RE: Breast cancer risk after salpingo-oophorectomy in healthy BRCA1/2 mutation carriers: revisiting the evidence for risk reduction. J Natl Cancer Inst. 2015 Sep;107(9)doi: 10.1093/jnci/djv217. PMID: 26264690. Exclusion: E626264690
Chai X, Friebel TM, Singer CF, . Use of risk-reducing surgeries in a prospective cohort of 1,499 BRCA1 and BRCA2 mutation carriers. Breast Cancer Res Treat. 2014 Nov;148(2):397–406. doi: 10.1007/s10549-014-3134-0. PMID: 25311111. Exclusion: E525311111
Challberg J, Ashcroft L, Lalloo F, . Menopausal symptoms and bone health in women undertaking risk reducing bilateral salpingo-oophorectomy: significant bone health issues in those not taking HRT. Br J Cancer. 2011 Jun 28;105(1):22–7. doi: 10.1038/bjc.2011.202. PMID: 21654687. Exclusion: E521654687
Chambers K, Armstrong Iii EJ, Flippo-Morton T, . Treatment decisions in individuals with deleterious mutations of BRCA-1 and/or BRCA-2. Ann Surg Oncol. 2012;19(2):32–3. doi: 10.1245/s10434-012-2344-06p. Exclusion: E5
Chambers K, Carpenter K, Flippo-Morton T, . BRCA-positive patients without cancer at the time of diagnosis and the plan of care chosen. Ann Surg Oncol. 2013;20(2):29. doi: 10.1245/s10434-013-2964-z. Exclusion: E6
Chambers KM, Armstrong EJ, Flippo T, . The follow-up sought after diagnosis of a BRCA-1 or BRCA-2 mutation. J Clin Oncol. 2012;30(27). Exclusion: E5
Chan JL, Johnson LNC, Sammel MD, . Reproductive Decision-Making in Women with BRCA1/2 Mutations. J Genet Couns. 2017 Jun;26(3):594–603. doi: 10.1007/s10897-016-0035-x. PMID: 27796678. Exclusion: E527796678
Chan K, Morris GJ. Chemoprevention of breast cancer for women at high risk. Semin Oncol. 2006 Dec;33(6):642–6. PMID: 17145342. Exclusion: E917145342
Chang M, Lee SC, Min JW, . Validation study of a breast cancer risk assessment programme for Korean women. Eur J Cancer. 2014;50:S83. doi: 10.1016/S0959-8049(14)70078-4. Exclusion: E5
Chang-Claude J, Andrieu N, Rookus M, . Age at menarche and menopause and breast cancer risk in the International BRCA1/2 Carrier Cohort Study. Cancer Epidemiol Biomarkers Prev. 2007 Apr;16(4):740–6. PMID: 17416765. Exclusion: E517416765
Chapman JS, Jacoby V, Chen LM. Managing symptoms and maximizing quality of life after preventive interventions for cancer risk reduction. Curr Opin Obstet Gynecol. 2015 Feb;27(1):40–4. doi: 10.1097/GCO.0000000000000146. PMID: 25502430. Exclusion: E625502430
Chart PL, Franssen E. Management of women at increased risk for breast cancer: Preliminary results from a new program. Can Med Assoc J. 1997;157:1235–42. PMID: 9361645. Exclusion: E59361645
Chavarri-Guerra Y, Blazer KR, Weitzel JN. Genetic cancer risk assessment for breast cancer in Latin America. Rev Invest Clin. 2017 Mar–Apr;69(2):94–102. PMID: 28453507. Exclusion: E928453507
Chen F-M, Hou M-F, Chang M-Y, . High frequency of somatic missense mutation of BRCA2 in female breast cancer from Taiwan. Cancer Lett. 2005 Apr 8;220(2):177–84. PMID: 15766593. Exclusion: E315766593
Chen S, Parmigiani G. Meta-analysis of BRCA1 and BRCA2 penetrance. J Clin Oncol. 2007 Apr 10;25(11):1329–33. doi: 10.1200/JCO.2006.09.1066. PMID: 17416853. Exclusion: 217416853
Chen Y, Toland AE, McLennan J, . Lack of germ-line promoter methylation in BRCA1-negative families with familial breast cancer. Genetic Testing. 2006;10(4):281–4. PMID: 17253935. Exclusion: E517253935
Chern JY, Lee SS, Frey MK, . The influence of BRCA variants of uncertain significance in cancer risk management decision-making. J Clin Oncol. 2015;33(15). Exclusion: E5
Cherry C, Ropka M, Lyle J, . Understanding the needs of women considering risk-reducing salpingo-oophorectomy. Cancer Nurs. 2013 May–Jun;36(3):E33–8. doi: 10.1097/NCC.0b013e3182642cb5. PMID: 22964868. Exclusion: E422964868
Chetrit A, Hirsh-Yechezkel G, Ben-David Y, . Effect of BRCA1/2 mutations on long-term survival of patients with invasive ovarian cancer: the national Israeli study of ovarian cancer. J Clin Oncol. 2008 Jan 1;26(1):20–5. PMID: 18165636. Exclusion: E318165636
Chiaffarino F, Parazzini F, Decarli A, . Hysterectomy with or without unilateral oophorectomy and risk of ovarian cancer. Gynecol Oncol. 2005 May;97(2):318–22. PMID: 15863124. Exclusion: E315863124
Chin T-M, Tan S-H, Lim S-E, . Acceptance, motivators, and barriers in attending breast cancer genetic counseling in Asians. Cancer Detect Prev. 2005;29(5):412–8. PMID: 16185817. Exclusion: E516185817
Chlebowski RT, Prentice RL. Menopausal hormone therapy in BRCA1 mutation carriers: uncertainty and caution. J Natl Cancer Inst. 2008 Oct 1;100(19):1341–3. PMID: 18812547. Exclusion: E418812547
Chopra I, Kelly KM. Cancer Risk Information Sharing: The Experience of Individuals Receiving Genetic Counseling for BRCA1/2 Mutations. J Health Commun. 2017 Feb;22(2):143–52. doi: 10.1080/10810730.2016.1258743. PMID: 28112991. Exclusion: E3a28112991
Chowdhury S, Dent T, Pashayan N, . Incorporating genomics into breast and prostate cancer screening: assessing the implications. Genet Med. 2013 Jun;15(6):423–32. doi: 10.1038/gim.2012.167. PMID: 23412607. Exclusion: E623412607
Christie J, Quinn GP, Malo T, . Cognitive and psychological impact of BRCA genetic counseling in before and after definitive surgery breast cancer patients. Ann Surg Oncol. 2012 Dec;19(13):4003–11. doi: 10.1245/s10434-012-2460-x. PMID: 22766984. Exclusion: E322766984
Chun DS, Berse B, Venne VL, . BRCA testing within the Department of Veterans Affairs: concordance with clinical practice guidelines. Fam Cancer. 2017;16(1):41–9. doi: 10.1007/s10689-016-9921-5. PMID: 27589855. Exclusion: E527589855
Cibula D, Zikan M, Dusek L, . Oral contraceptives and risk of ovarian and breast cancers in BRCA mutation carriers: a meta-analysis. Expert Rev Anticancer Ther. 2011 Aug;11(8):1197–207. PMID: 21916573. Exclusion: E421916573
Cicchetti A, Ruggeri M, Di Brino E. Cost-effectiveness of a preventive testing strategy in relatives of patients with BRCA mutated ovarian cancer versus a no test strategy. Value Health. 2016;19(7):A696. Exclusion: E6
Cicero G, De Luca R, Dorangricchia P, . Risk perception and psychological distress in genetic counselling for hereditary breast and/or ovarian cancer. J Genet Couns. 2017 Oct;26(5):999–1007. doi: 10.1007/s10897-017-0072-0. PMID: 28283917. Exclusion: E3a28283917
Ciernikova S, Tomka M, Kovac M, . Ashkenazi founder BRCA1/BRCA2 mutations in Slovak hereditary breast and/or ovarian cancer families. Neoplasma. 2006;53(2):97–102. PMID: 16575464. Exclusion: E516575464
Cini G, Mezzavilla M, Della Puppa L, . Tracking of the origin of recurrent mutations of the BRCA1 and BRCA2 genes in the North-East of Italy and improved mutation analysis strategy. BMC Med Genet. 2016;17:11. doi: 10.1186/s12881-016-0274-6. PMID: 26852130. Exclusion: E526852130
Claes E, Evers-Kiebooms G, Boogaerts A, . Diagnostic genetic testing for hereditary breast and ovarian cancer in cancer patients: women’s looking back on the pre-test period and a psychological evaluation. Genetic Testing. 2004;8(1):13–21. PMID: 15140370. Exclusion: E315140370
Clague J, Villarreal-Garza C, Navarro AD, . Evaluation of the BOADICEA model for predicting BRCA1 and BRCA2 mutation carrier probabilities in high-risk US Hispanic and Mexican families: A report from the clinical cancer genetics community research network. Cancer Res. 2015;75(15)doi: 10.1158/1538-7445.AM2015-2761. Exclusion: E4
Clementino LS, Suzuki EH, de Oliveira KB. Risk assessment for breast cancer and BRCA mutations in women with personal and familial history. Acta Scientiarum - Health Sciences. 2013;35(2):263–71. doi: 10.4025/actascihealthsci.v35i2.12134. Exclusion: E5
Clements A, Henderson BJ, Tyndel S, . Diagnosed with breast cancer while on a family history screening programme: an exploratory qualitative study. Eur J Cancer Care (Engl). 2008 May;17(3):245–52. PMID: 18419627. Exclusion: E518419627
Cock-Rada AM, Ossa CA, Garcia HI, . A multi-gene panel study in hereditary breast and ovarian cancer in Colombia. Fam Cancer. 2018 01;17(1):23–30. doi: 10.1007/s10689-017-0004-z. PMID: 28528518. Exclusion: E528528518
Cody N, Green A, McDevitt T, . Cascade screening in BRCA1/2 mutation carriers. Ir Med J. 2008 May;101(5):140–2. PMID: 18624259. Exclusion: E518624259
Coelho JJ, Arnold A, Nayler J, . An assessment of the efficacy of cancer genetic counselling using real-time videoconferencing technology (telemedicine) compared to face-to-face consultations. Eur J Cancer. 2005 Oct;41(15):2257–61. doi: 10.1016/j.ejca.2005.06.020. PMID: 16176873. Exclusion: E416176873
Cohen SA, Nixon DM. A collaborative approach to cancer risk assessment services using genetic counselor extenders in a multi-system community hospital. Breast Cancer Res Treat. 2016;159(3):527–34. doi: 10.1007/s10549-016-3964-z. PMID: 27581128. Exclusion: E527581128
Colditz GA, Willett WC, Hunter DJ, . Family history, age, and risk of breast cancer. Prospective data from the Nurses’ Health Study. JAMA. 1993 Jul 21;270(3):338–43. PMID: 8123079. Exclusion: 28123079
Collins IM, Milne RL, Weideman PC, . Preventing breast and ovarian cancers in high-risk BRCA1 and BRCA2 mutation carriers. Med J Aust. 2013 Nov 18;199(10):680–3. PMID: 24237098. Exclusion: E524237098
Collins LC, Baer HJ, Tamimi RM, . The influence of family history on breast cancer risk in women with biopsy-confirmed benign breast disease: results from the Nurses’ Health Study. Cancer. 2006 Sep 15;107(6):1240–7. PMID: 16902983. Exclusion: E516902983
Conner JR, Meserve E, Pizer E, . Outcome of unexpected adnexal neoplasia discovered during risk reduction salpingo-oophorectomy in women with germ-line BRCA1 or BRCA2 mutations. Gynecol Oncol. 2014 Feb;132(2):280–6. doi: 10.1016/j.ygyno.2013.12.009. PMID: 24333842. Exclusion: E724333842
Contant C, van Wersch A, Menke-Pluymers M, . Satisfaction and prosthesis related complaints in women with immediate breast reconstruction following prophylactic and oncological mastectomy. Psychol Health Med. 2004 Feb;9(1):71–84. doi: 10.1080/13548500310001637760. Exclusion: E3
Contant CM, Menke-Pluijmers MB, Seynaeve C, . Clinical experience of prophylactic mastectomy followed by immediate breast reconstruction in women at hereditary risk of breast cancer (HB(O)C) or a proven BRCA1 and BRCA2 germ-line mutation. Eur J Surg Oncol. 2002 Original Search 6-20-03 Reference Search 3-17-04;28(6):627–32. PMID: 12359199 Exclusion: E312359199
Contegiacomo A, Pensabene M, Capuano I, . An oncologist-based model of cancer genetic counselling for hereditary breast and ovarian cancer. Ann Oncol. 2004 May;15(5):726–32. PMID: 15111339. Exclusion: E315111339
Cook LS, Neilson HK, Lorenzetti DL, . A systematic literature review of vitamin D and ovarian cancer. Am J Obstet Gynecol. 2010;203(1):70. e1-. e8. PMID: 20227054. Exclusion: E520227054
Coopey SB, Acar A, Griffin M, . The impact of patient age on breast cancer risk prediction models. Breast J. 2018;24(4):592–8. doi: 10.1111/tbj.12976. Exclusion: E429316072
Copur MS, Percich S, Jordan A, . Cancer genetic counseling services (GCS) in a community-based cancer center (CBCC) in rural Nebraska: Effect of National Community Cancer Centers Program (NCCCP). J Clin Oncol. 2011;29(15). Exclusion: E4
Cortesi L, Masini C, Cirilli C, . Favourable ten-year overall survival in a Caucasian population with high probability of hereditary breast cancer. BMC Cancer. 2010;10:90. PMID: 20219108. Exclusion: E320219108
Costa S, Sacchetti M, Batista R, . Evaluation of the program BRCAPRO in a breast cancer centre. Eur J Cancer. 2012;48:S52. Exclusion: E6
Cott Chubiz JE, Lee JM, Gilmore ME, . Cost-effectiveness of alternating magnetic resonance imaging and digital mammography screening in BRCA1 and BRCA2 gene mutation carriers. Cancer. 2013 Mar 15;119(6):1266–76. doi: 10.1002/cncr.27864. PMID: 23184400. Exclusion: E723184400
Couch FJ, Sinilnikova O, Vierkant RA, . AURKA F31I polymorphism and breast cancer risk in BRCA1 and BRCA2 mutation carriers: a consortium of investigators of modifiers of BRCA1/2 study. Cancer Epidemiol Biomarkers Prev. 2007 Jul;16(7):1416–21. PMID: 17627006. Exclusion: E517627006
Couzin J. Breast cancer. Dissecting a hidden breast cancer risk. Science. 2005 Sep 9;309(5741):1664–6. PMID: 16150987. Exclusion: E616150987
Cox DG, Hankinson SE, Hunter DJ. No association between BRCA2 N372H and breast cancer risk. Cancer Epidemiol Biomarkers Prev. 2005 May;14(5):1353–4. PMID: 15894703. Exclusion: E515894703
Cox DG, Kraft P, Hankinson SE, . Haplotype analysis of common variants in the BRCA1 gene and risk of sporadic breast cancer. Breast Cancer Res. 2005;7(2):R171–5. PMID: 15743496. Exclusion: E515743496
Cragun D, Weidner A, Lewis C, . Racial disparities in BRCA testing and cancer risk management across a population-based sample of young breast cancer survivors. Cancer. 2017 doi: 10.1002/cncr.30621. PMID: 28182268. Exclusion: E528182268
Crepeau AZ, Willoughby L, Pinsky B, . Accuracy of personal breast cancer risk estimation in cancer-free women during primary care visits. Women Health. 2008;47(2):113–30. PMID: 18681103. Exclusion: E518681103
Crispo A, D’Aiuto G, De Marco M, . Gail model risk factors: impact of adding an extended family history for breast cancer. Breast J. 2008 May–Jun;14(3):221–7. PMID: 18373641. Exclusion: E318373641
Crotser CB, Dickerson SS. Women receiving news of a family BRCA1/2 mutation: messages of fear and empowerment. J Nurs Scholarsh. 2010;42(4):367–78. doi: 10.1111/j.1547-5069.2010.01366.x. PMID: 21091619. Exclusion: 221091619
Crum CP, Drapkin R, Kindelberger D, . Lessons from BRCA: the tubal fimbria emerges as an origin for pelvic serous cancer. Clin Med Res. 2007 Mar;5(1):35–44. doi: 10.3121/cmr.2007.702. PMID: 17456833. Exclusion: 217456833
Cruzado JA. Decision making of participants in cancer genetic counseling. Psicooncologia. 2010;7(2–3):341–62. Exclusion: E4
Cukier YR, Thompson HS, Sussner K, . Factors associated with psychological distress among women of African descent at high risk for BRCA mutations. J Genet Couns. 2013 Feb;22(1):101–7. doi: 10.1007/s10897-012-9510-1. PMID: 22736212. Exclusion: E322736212
Cullinane CA, Lubinski J, Neuhausen SL, . Effect of pregnancy as a risk factor for breast cancer in BRCA1/BRCA2 mutation carriers. Int J Cancer. 2005 Dec 20;117(6):988–91. PMID: 15986445. Exclusion: E515986445
Culver JO, Bowen DJ, Reynolds SE, . Breast cancer risk communication: assessment of primary care physicians by standardized patients. Genet Med. 2009 Oct;11(10):735–41. PMID: 19661809. Exclusion: E519661809
Culver JO, Brinkerhoff CD, Clague J, . Variants of uncertain significance in BRCA testing: evaluation of surgical decisions, risk perception, and cancer distress. Clin Genet. 2013 Nov;84(5):464–72. doi: 10.1111/cge.12097. PMID: 23323793. Exclusion: E523323793
Cummings SR, Eckert S, Krueger KA, . The effect of raloxifene on risk of breast cancer in postmenopausal women: results from the MORE randomized trial. Multiple Outcomes of Raloxifene Evaluation. JAMA. 1999 Jun 16;281(23):2189–97. PMID: 10376571. Exclusion: 210376571
Cunningham LL, Andrykowski MA, Wilson JF, . Physical symptoms, distress, and breast cancer risk perceptions in women with benign breast problems. Health Psychol. 1998 Jul;17(4):371–5. PMID: 9697947. Exclusion: E39697947
Curtis MG. Comparative tolerability of first-generation selective estrogen receptor modulators in breast cancer treatment and prevention. Drug Saf. 2001;24(14):1039–53. PMID: 11735660. Exclusion: 211735660
Cusido M, Baulies S, Alsina A, . Counseling high-risk patients for breast/ovarian cancer. Int J Gynecol Cancer. 2011;21(12):S507. doi: 10.1097/IGC.0b013e318235bd21. Exclusion: E6
Cuzick J, Forbes J, Edwards R, . First results from the International Breast Cancer Intervention Study (IBIS-I): a randomised prevention trial. Lancet. 2002 Sep 14;360(9336):817–24. PMID: 12243915. Exclusion: 212243915
Cuzick J, Forbes JF, Sestak I, . Long-term results of tamoxifen prophylaxis for breast cancer—96-month follow-up of the randomized IBIS-I trial. J Natl Cancer Inst. 2007 February 21, 2007;99(4):272–82. doi: 10.1093/jnci/djk049. PMID: 17312304. Exclusion: E317312304
Cuzick J, Sestak I, Cawthorn S, . Tamoxifen for prevention of breast cancer: extended long-term follow-up of the IBIS-I breast cancer prevention trial. Lancet Oncol. 2015 Jan;16(1):67–75. doi: 10.1016/S1470-2045(14)71171-4. PMID: 25497694. Exclusion: E325497694
Cuzick J, Sestak I, Forbes JF, . Anastrozole for prevention of breast cancer in high-risk postmenopausal women (IBIS-II): an international, double-blind, randomised placebo-controlled trial. Lancet. 2014 Mar 22;383(9922):1041–8. doi: 10.1016/S0140-6736(13)62292-8. PMID: 24333009. Exclusion: 224333009
Cvelbar M, Ursic-Vrscaj M, Rakar S. Risk factors and prognostic factors in patients with double primary cancer: epithelial ovarian cancer and breast cancer. Eur J Gynaecol Oncol. 2005;26(1):59–63. PMID: 15755003. Exclusion: E315755003
Cybulski C, Huzarski T, Byrski T, . Estrogen receptor status in CHEK2-positive breast cancers: implications for chemoprevention. Clin Genet. 2009 Jan;75(1):72–8. PMID: 19021634. Exclusion: E519021634
Cypowyj C, Eisinger F, Huiart L, . Subjective interpretation of inconclusive BRCA1/2 cancer genetic test results and transmission of information to the relatives. Psychooncology. 2009 Feb;18(2):209–15. PMID: 19061202. Exclusion: E319061202
Dagan E, Gershoni-Baruch R, Kurolap A, . Early onset breast cancer in Ashkenazi women carriers of founder BRCA1/2 mutations: beyond 10 years of follow-up. Eur J Cancer Care (Engl). 2017 Nov;26(6)doi: 10.1111/ecc.12594. PMID: 27726213. Exclusion: E427726213
Dagan E, Gil S, Gershoni-Baruch R. Socio-demographic and clinical profile of BRCA1/2 mutation carriers opting for prophylactic oophorectomy. Prev Med. 2008 May;46(5):470–2. PMID: 18255133. Exclusion: E618255133
Dagan E, Goldblatt H. The twilight zone between health and sickness: a qualitative exploration with asymptomatic BRCA1 and 2 mutation carriers. Women Health. 2009 Jun;49(4):263–79. PMID: 19753503. Exclusion: E519753503
d’Agincourt-Canning L. Genetic testing for hereditary breast and ovarian cancer: Responsibility and choice. Qual Health Res. 2006;16(1):97–118. PMID: 16317179. Exclusion: E916317179
Dai J, Hu Z, Jiang Y, . Breast cancer risk assessment with five independent genetic variants and two risk factors in Chinese women. Breast Cancer Res. 2012;14(1):R17. PMID: 22269215. Exclusion: E322269215
Daib S, Sedlacek S, Hamlington B, . The performance of next generation panel testing in individuals assessed by a community-based genetics program. Cancer Res. 2016;76(4)doi: 10.1158/1538-7445.SABCS15-P2-09-19. Exclusion: E5
Daly MB, Montgomery S, Bingler R, . Communicating genetic test results within the family: Is it lost in translation? A survey of relatives in the randomized six-step study. Fam Cancer. 2016 10;15(4):697–706. doi: 10.1007/s10689-016-9889-1. PMID: 26897130. Exclusion: E526897130
Daly MB, Pilarski R, Axilbund JE, . Genetic/Familial High-Risk Assessment: Breast and Ovarian, Version 2.2015. J Natl Compr Canc Netw. 2016 Feb;14(2):153–62. PMID: 26850485. Exclusion: 226850485
Daly MB, Pilarski R, Berry M, . NCCN guidelines insights: genetic/familial high-risk assessment: breast and ovarian, Version 2.2017. J Natl Compr Canc Netw. 2017 Jan;15(1):9–20. PMID: 28040716. Exclusion: 228040716
Dancyger C, Smith JA, Jacobs C, . Comparing family members’ motivations and attitudes towards genetic testing for hereditary breast and ovarian cancer: a qualitative analysis. Eur J Hum Genet. 2010 Dec;18(12):1289–95. PMID: 20648056. Exclusion: E3a20648056
Daniels MS, Lu KH. Genetic predisposition in gynecologic cancers. Semin Oncol. 2016;43(5):543–7. doi: 10.1053/j.seminoncol.2016.08.005. PMID: 27899185 Exclusion: E927899185
Daniels MS, Urbauer DL, Stanley JL, . Timing of BRCA1/BRCA2 genetic testing in women with ovarian cancer. Genet Med. 2009 Sep;11(9):624–8. PMID: 19606053. Exclusion: E319606053
Darabi H, Czene K, Zhao W, . Breast cancer risk prediction and individualised screening based on common genetic variation and breast density measurement. Breast Cancer Res. 2012;14(1):R25. PMID: 22314178. Exclusion: E322314178
Davies KR, Cantor SB, Brewster AM. Better contralateral breast cancer risk estimation and alternative options to contralateral prophylactic mastectomy. Int J Womens Health. 2015;7:181–7. doi: 10.2147/IJWH.S52380. PMID: 25678823. Exclusion: E525678823
Dawson S-J, Price MA, Jenkins MA, . Cancer risk management practices of noncarriers within BRCA1/2 mutation positive families in the Kathleen Cuningham Foundation Consortium for Research into Familial Breast Cancer. J Clin Oncol. 2008 Jan 10;26(2):225–32. PMID: 18040054. Exclusion: E518040054
De Bock GH, Mourits MJE, Oosterwijk JC. One risk fits all? J Clin Oncol. 2007 Aug 1;25(22):3383–4; author reply 4. PMID: 17664491. Exclusion: E617664491
de Bock GH, Vliet Vlieland TP, Hageman GC, . The assessment of genetic risk of breast cancer: a set of GP guidelines. Fam Pract. 1999 Feb;16(1):71–7. PMID: 10321400. Exclusion: 210321400
De Bruin MA, Ford JM, Kurian AW. Genetic polymorphisms as predictors of breast cancer risk. Curr Breast Cancer Rep. 2012;4(4):232–9. doi: 10.1007/s12609-012-0091-7. Exclusion: E9
de Bruin MA, Kwong A, Goldstein BA, . Breast cancer risk factors differ between Asian and white women with BRCA1/2 mutations. Fam Cancer. 2012 Sep;11(3):429–39. doi: 10.1007/s10689-012-9531-9. PMID: 22638769. Exclusion: E522638769
De Felice F, Marchetti C, Musella A, . Bilateral risk-reduction mastectomy in BRCA1 and BRCA2 mutation carriers: a meta-analysis. Ann Surg Oncol. 2015 Sep;22(9):2876–80. doi: 10.1245/s10434-015-4532-1. PMID: 25808098. Exclusion: E525808098
De Greve J, Sermijn E, De Brakeleer S, . Hereditary breast cancer: from bench to bedside. Curr Opin Oncol. 2008 Nov;20(6):605–13. PMID: 18841041. Exclusion: E618841041
de la Hoya M, Meijers-Heijboer H, Fernandez JM, . Mutant BRCA1 alleles transmission: different approaches and different biases. Int J Cancer. 2005 Jan 1;113(1):166–7. PMID: 15386425. Exclusion: E515386425
de la Noval BD. Potential implications on female fertility and reproductive lifespan in BRCA germline mutation women. Arch Gynecol Obstet. 2016;294(5):1099–103. doi: 10.1007/s00404-016-4187-6. PMID: 27561295. Exclusion: E527561295
De Luca R, Dorangricchia P, Calò V, . Psychological distress and risk perception in the genetic counseling for hereditary breast and/or ovarian cancer. Psychooncology. 2014;23:309. doi: 10.1111/j.1099-1611.2014.3696. Exclusion: E6
De Palo G, Mariani L, Camerini T, . Effect of fenretinide on ovarian carcinoma occurrence. Gynecol Oncol. 2002;86(1):24–7. PMID: CN-00389758. Exclusion: E312079295
de Silva D, Gilbert F, Needham G, . Identification of women at high genetic risk of breast cancer through the National Health Service Breast Screening Programme (NHSBSP). J Med Genet. 1995 Nov;32(11):862–6. PMID: 8592328. Exclusion: 28592328
Dean M, Davidson LG. Previvors’ uncertainty management strategies for hereditary breast and ovarian cancer. Health Communication. 2018 Feb;33(2):122–30. doi: 10.1080/10410236.2016.1250187. PMID: 27976925. Exclusion: E527976925
Dean M, Scherr CL, Clements M, . “When information is not enough”: A model for understanding BRCA-positive previvors’ information needs regarding hereditary breast and ovarian cancer risk. Patient Educ Couns. 2017 Sep;100(9):1738–43. doi: 10.1016/j.pec.2017.03.013. PMID: 28385363. Exclusion: E528385363
Decarli A, Calza S, Masala G, . Gail model for prediction of absolute risk of invasive breast cancer: independent evaluation in the Florence-European Prospective Investigation Into Cancer and Nutrition cohort. J Natl Cancer Inst. 2006 Dec 6;98(23):1686–93. PMID: 17148770. Exclusion: E317148770
Decensi A, Maisonneuve P, Rotmensz N, . Effect of tamoxifen on venous thromboembolic events in a breast cancer prevention trial. Circulation. 2005 Feb 8;111(5):650–6. PMID: 15699284. Exclusion: E315699284
Dekker N, van Dorst EB, van der Luijt RB, . Acceptance of genetic counseling and testing in a hospital-based series of patients with gynecological cancer. J Genet Couns. 2013 Jun;22(3):345–57. doi: 10.1007/s10897-012-9553-3. PMID: 23192360. Exclusion: E323192360
Del Sole A, Cinquetti S, Fedato C, . Management of women at high risk of hereditary breast cancer in the Veneto Regional Program for Prevention. Epidemiol Prev. 2015 Jul–Aug;39(4 Suppl 1):99–101. PMID: 26499424. Exclusion: E626499424
Demarco TA, Nusbaum RH, Peshkin BN, . Prevalence and correlates of mothers and fathers attending pretest cancer genetic counseling together. Patient Educ Couns. 2010 Jan;78(1):29–33. PMID: 19545972. Exclusion: E519545972
Demsky R, McCuaig J, Maganti M, . Keeping it simple: genetics referrals for all invasive serous ovarian cancers. Gynecol Oncol. 2013 Aug;130(2):329–33. doi: 10.1016/j.ygyno.2013.05.003. PMID: 23707676. Exclusion: E323707676
den Heijer M, Seynaeve C, Vanheusden K, . The contribution of self-esteem and self-concept in psychological distress in women at risk of hereditary breast cancer. Psychooncology. 2011 Nov;20(11):1170–5. doi: 10.1002/pon.1824. PMID: 20690113. Exclusion: E420690113
Denayer L, Boogaerts A, Philippe K, . BRCA1/2 predictive testing and gender: uptake, motivation and psychological characteristics. Genet Couns. 2009;20(4):293–305. PMID: 20162864. Exclusion: E520162864
Dennis J, Ghadirian P, Little J, . Alcohol consumption and the risk of breast cancer among BRCA1 and BRCA2 mutation carriers. Breast. 2010 Dec;19(6):479–83. PMID: 20541936. Exclusion: E520541936
Derks-Smeets IA, Gietel-Habets JJ, Tibben A, . Decision-making on preimplantation genetic diagnosis and prenatal diagnosis: a challenge for couples with hereditary breast and ovarian cancer. Hum Reprod. 2014 May;29(5):1103–12. doi: 10.1093/humrep/deu034. PMID: 24603131. Exclusion: E524603131
Desai S, Jena AB. Do celebrity endorsements matter? Observational study of BRCA gene testing and mastectomy rates after Angelina Jolie’s New York Times editorial. BMJ. 2016 Dec 14;355:i6357. doi: 10.1136/bmj.i6357. PMID: 27974323. Exclusion: E527974323
Desjardins S, Belleau P, Labrie Y, . Genetic variants and haplotype analyses of the ZBRK1/ZNF350 gene in high-risk non BRCA1/2 French Canadian breast and ovarian cancer families. Int J Cancer. 2008 Jan 1;122(1):108–16. PMID: 17764113. Exclusion: E517764113
Desmond A, Kurian AW, Gabree M, . Clinical actionability of multigene panel testing for hereditary breast and ovarian cancer risk assessment. JAMA Oncology. 2015 Oct;1(7):943–51. doi: 10.1001/jamaoncol.2015.2690. PMID: 26270727. Exclusion: E526270727
Dhawan MS, Aggarwal R, Bartelink I, . Carboplatin and talazoparib combination therapy results in differential efficacy and hematologic toxicity in BRCA-mutated patients. Cancer Res. 2016;76(14)doi: 10.1158/1538-7445.AM2016-CT051. Exclusion: E3
Dhawan MS, Aggarwal RR, Bartelink I, . Efficacy and hematologic toxicity of carboplatin and talazoparib combination therapy in BRCA mutated patients. J Clin Oncol. 2016;34. Exclusion: E3
Dhingra K. Antiestrogens-tamoxifen, SERMs and beyond. Invest New Drugs. 1999;17(3):285–311. PMID: 10665480. Exclusion: 210665480
Di Mattei VE, Duchini E, Zucchi P, . [Cancer genetic counseling and quality of life: the effect of coping strategies and psychopathological symptoms during pre-test genetic counseling]. Recenti Prog Med. 2015 Aug;106(8):380–4. doi: 10.1701/1960.21304. PMID: 26228860. Exclusion: E326228860
Di Prospero LS, Seminsky M, Honeyford J, . Psychosocial issues following a positive result of genetic testing for BRCA1 and BRCA2 mutations: findings from a focus group and a needs-assessment survey. CMAJ. 2001 Apr 3;164(7):1005–9. PMID: 11314429. Exclusion: E3a11314429
DiCastro M, Frydman M, Friedman I, . Genetic counseling in hereditary breast/ovarian cancer in Israel: Psychosocial impact and retention of genetic information. Am J Med Genet. 2002;111(2):147–51. PMID: 12210341. Exclusion: E312210341
Didraga MA, van Beers EH, Joosse SA, . A non-BRCA1/2 hereditary breast cancer sub-group defined by aCGH profiling of genetically related patients. Breast Cancer Res Treat. 2011 Nov;130(2):425–36. PMID: 21286804. Exclusion: E321286804
Dieng M, Watts CG, Kasparian NA, . Improving subjective perception of personal cancer risk: systematic review and meta-analysis of educational interventions for people with cancer or at high risk of cancer. Psychooncology. 2014 Jun;23(6):613–25. doi: 10.1002/pon.3476. PMID: 24420128. Exclusion: E324420128
Digianni LM, Rue M, Emmons K, . Complementary medicine use before and 1 year following genetic testing for BRCA1/2 mutations. Cancer Epidemiol Biomarkers Prev. 2006 Jan;15(1):70–5. PMID: 16434589. Exclusion: E416434589
Dijkstra H, Albada A, Klockner Cronauer C, . Nonverbal communication and conversational contribution in breast cancer genetic counseling: are counselors’ nonverbal communication and conversational contribution associated with counselees’ satisfaction, needs fulfillment and state anxiety in breast cancer genetic counseling? Patient Educ Couns. 2013 Nov;93(2):216–23. doi: 10.1016/j.pec.2013.05.014. PMID: 23786807. Exclusion: E3a23786807
Dillard AJ, McCaul KD, Kelso PD, . Resisting good news: reactions to breast cancer risk communication. J Health Commun. 2006;19(2):115–23. doi: 10.1207/s15327027hc1902_3. PMID: 16548702. Exclusion: E416548702
Disis ML. Adjuvant oophorectomy in the treatment of early-stage BRCA mutation-positive breast cancer. JAMA Oncology. 2015 Jun;1(3):313. doi: 10.1001/jamaoncol.2015.0708. PMID: 26181176. Exclusion: E626181176
Dite GS, MacInnis RJ, Bickerstaffe A, . Breast cancer risk prediction using clinical models and 77 independent risk-associated SNPs for women aged under 50 years: Australian Breast Cancer Family Registry. Cancer Epidemiol Biomarkers Prev. 2016 Feb;25(2):359–65. doi: 10.1158/1055-9965.EPI-15-0838. PMID: 26677205. Exclusion: E426677205
Dite GS, Whittemore AS, Knight JA, . Increased cancer risks for relatives of very early-onset breast cancer cases with and without BRCA1 and BRCA2 mutations. Br J Cancer. 2010 Sep 28;103(7):1103–8. PMID: 20877337. Exclusion: E320877337
Dohany L, Zakalik D. Genetic testing for BRCA1/2 in Arabic American women. Curr Oncol. 2012;19(2):e100. doi: 10.3747/co.19.1076. Exclusion: E6
Doherty J, Bonadies DC, Matloff ET. Testing for hereditary breast cancer: Panel or targeted testing? Experience from a clinical cancer genetics practice. J Genet Couns. 2015 Aug;24(4):683–7. doi: 10.1007/s10897-014-9796-2. PMID: 25475920. Exclusion: E725475920
Doll KM, Weldon CB, Trosman JR, . BRCA+ test result impact and timing on surgical treatment decisions for patients with breast cancer. J Clin Oncol. 2011;29(15). Exclusion: E3
Domagala P, Wokolorczyk D, Cybulski C, . Different CHEK2 germline mutations are associated with distinct immunophenotypic molecular subtypes of breast cancer. Breast Cancer Res Treat. 2012 Apr;132(3):937–45. PMID: 21701879. Exclusion: E521701879
Domchek SM, Friebel TM, Garber JE, . Occult ovarian cancers identified at risk-reducing salpingo-oophorectomy in a prospective cohort of BRCA1/2 mutation carriers. Breast Cancer Res Treat. 2010 Nov;124(1):195–203. PMID: 20180014. Exclusion: E720180014
Domchek SM, Friebel TM, Neuhausen SL, . Mortality after bilateral salpingo-oophorectomy in BRCA1 and BRCA2 mutation carriers: a prospective cohort study. Lancet Oncol. 2006 Mar;7(3):223–9. doi: 10.1016/s1470-2045(06)70585-x. PMID: 16510331. Exclusion: E1016510331
Domchek SM, Jhaveri K, Patil S, . Risk of metachronous breast cancer after BRCA mutation-associated ovarian cancer. Cancer. 2013 Apr 1;119(7):1344–8. doi: 10.1002/cncr.27842. PMID: 23165893. Exclusion: 223165893
Dominguez FJ, Jones JL, Zabicki K, . Prevalence of hereditary breast/ovarian carcinoma risk in patients with a personal history of breast or ovarian carcinoma in a mammography population. Cancer. 2005 Nov 1;104(9):1849–53. PMID: 16136597. Exclusion: E516136597
Donelle L, Hoffman-Goetz L, Clarke J. Ethnicity, genetics, and breast cancer: Media portrayal of disease identities. Ethn Health. 2005 Aug;10(3):185–97. doi: 10.1080/13557850500120751. PMID: 16087452. Exclusion: E416087452
Donelle L, Hoffman-Goetz L, Clarke JN. Portrayal of genetic risk for breast cancer in ethnic and non-ethnic newspapers. Women Health. 2004;40(4):93–111. PMID: 15911512. Exclusion: E715911512
Dong L, Wu N, Wang S, . Detection of novel germline mutations in six breast cancer predisposition genes by targeted next-generation sequencing. Hum Mutat. 2018;39(10):1442–55. doi: 10.1002/humu.23597. Exclusion: E530039884
Donnelly L, Watson M, Moynihan C, . Attitudes towards reproductive options for childless individuals following a breast/ovarian cancer gene mutation test. Psychooncology. 2013;22:24. doi: 10.10002/pon.3239. Exclusion: E5
Donnelly LS, Watson M, Moynihan C, . Reproductive decision-making in young female carriers of a BRCA mutation. Hum Reprod. 2013 Apr;28(4):1006–12. doi: 10.1093/humrep/des441. PMID: 23293217. Exclusion: E523293217
Dorairaj JJ, Irwin R, Wall D, . Clinicopathological variables of BRCA 1 and 2 gene mutations in the west of Ireland population. Ir J Med Sci. 2011;180:S111–S2. doi: 10.1007/s11845-011-0693-5. Exclusion: E6
Dørum A, Heimdal K, Løvslett K, . Prospectively detected cancer in familial breast/ovarian cancer screening. Acta Obstet Gynecol Scand. 1999;78(10):906–11. PMID: 10577622. Exclusion: E710577622
Dorval M, Bouchard K, Chiquette J, . A focus group study on breast cancer risk presentation: one format does not fit all. Eur J Hum Genet. 2013 Jul;21(7):719–24. doi: 10.1038/ejhg.2012.248. PMID: 23169493. Exclusion: E423169493
Dorval M, Drolet M, LeBlanc M, . Using the Impact of Event Scale to evaluate distress in the context of genetic testing for breast cancer susceptibility. Psychol Rep. 2006 Jun;98(3):873–81. doi: 10.2466/PR0.98.3.873-881. PMID: 16933689. Exclusion: E516933689
Dorval M, Gauthier G, Maunsell E, . No evidence of false reassurance among women with an inconclusive BRCA1/2 genetic test result. Cancer Epidemiol Biomarkers Prev. 2005 Dec;14(12):2862–7. PMID: 16365001. Exclusion: E3a16365001
Dos Santos Vidal R, Hawrysh A, Walia JS, . Eligibility criteria and genetic testing results from a high-risk cohort for hereditary breast and ovarian cancer syndrome in Southeastern Ontario. J Mol Diagn. 2016;18(3):362–9. doi: 10.1016/j.jmoldx.2015.11.007. PMID: 26941049. Exclusion: E426941049
Dougall AL, Smith AW, Somers TJ, . Coping with genetic testing for breast cancer susceptibility. Psychosom Med. 2009 Jan;71(1):98–105. PMID: 19124622. Exclusion: E319124622
Doughty Rice C, Ruschman JG, Martin LJ, . Retrospective comparison of patient outcomes after in-person and telephone results disclosure counseling for BRCA1/2 genetic testing. Fam Cancer. 2010 Jun;9(2):203–12. PMID: 20473602. Exclusion: E3a20473602
Douglas HA, Hamilton RJ, Grubs RE. The effect of BRCA gene testing on family relationships: A thematic analysis of qualitative interviews. J Genet Couns. 2009 Oct;18(5):418–35. PMID: 19479365. Exclusion: E3a19479365
Dowdy SC, Stefanek M, Hartmann LC. Surgical risk reduction: prophylactic salpingo-oophorectomy and prophylactic mastectomy. Am J Obstet Gynecol. 2004;191(4):1113–23. PMID: 15507929. Exclusion: E915507929
Dreyfuss H, Dohany L, Fulbright J, . Non-founder mutations in Ashkenazi Jewish individuals undergoing testing for BRCA1/2. Curr Oncol. 2014;21(2):e368. doi: 10.3747/co.21.2077. Exclusion: E6
Duquette D, Lewis K, McLosky J, . Using core public health functions to promote BRCA best practices among health plans. Public Health Genomics. 2012;15(2):92–7. PMID: 22189434. Exclusion: E422189434
Dutil J, Colon-Colon JL, Matta JL, . Identification of the prevalent BRCA1 and BRCA2 mutations in the female population of Puerto Rico. Cancer Genet. 2012 May;205(5):242–8. PMID: 22682623. Exclusion: E522682623
Easton DF, Pharoah PD, Antoniou AC, . Gene-panel sequencing and the prediction of breast-cancer risk. N Engl J Med. 2015 Jun 04;372(23):2243–57. doi: 10.1056/NEJMsr1501341. PMID: 26014596. Exclusion: 226014596
Eccles DM. How to treat and follow-up BRCA mutation carriers. Eur J Cancer. 2014;50:S107. doi: 10.1016/S0959-8049(14)70089-9. Exclusion: E6
Edwards, Adrian GK, Naik, . Personalised risk communication for informed decision making about taking screening tests [Systematic Review]. Cochrane Database Syst Rev. 2013(2) PMID: 17054144. Exclusion: E317054144
Edwards AGK, Naik G, Ahmed H, . Personalised risk communication for informed decision making about taking screening tests. Cochrane Database Syst Rev. 2013;2:CD001865. doi: 10.1002/14651858.CD001865.pub3. PMID: 23450534. Exclusion: E523450534
Edwards QT, Maradiegue A, Seibert D, . Breast cancer risk elements and nurse practitioners’ knowledge, use, and perceived comfort level of breast cancer risk assessment. J Am Acad Nurse Pract. 2009 May;21(5):270–7. PMID: 19432911. Exclusion: E519432911
Edwards TA, Thompson HS, Kwate NOA, . Association between temporal orientation and attitudes about BRCA1/2 testing among women of African descent with family histories of breast cancer. Patient Educ Couns. 2008 Aug;72(2):276–82. PMID: 18479882. Exclusion: E3a18479882
Eerola H, Heikkila P, Tamminen A, . Histopathological features of breast tumours in BRCA1, BRCA2 and mutation-negative breast cancer families. Breast Cancer Res. 2005;7(1):R93–100. PMID: 15642173. Exclusion: E315642173
Einarsdottir K, Humphreys K, Bonnard C, . Linkage disequilibrium mapping of CHEK2: common variation and breast cancer risk. PLoS Medicine / Public Library of Science. 2006 Jun;3(6):e168. PMID: 16671833. Exclusion: E416671833
Einbeigi Z, Bergman A, Kindblom LG, . A founder mutation of the BRCA1 gene in Western Sweden associated with a high incidence of breast and ovarian cancer. Eur J Cancer. 2001 Oct;37(15):1904–9. PMID: 11576847. Exclusion: 211576847
Einbeigi Z, Enerback C, Wallgren A, . BRCA1 gene mutations may explain more than 80% of excess number of ovarian cancer cases after breast cancer - a population based study from the Western Sweden Health Care region. Acta Oncol. 2010 Apr;49(3):361–7. PMID: 20151938. Exclusion: E320151938
Eisen A, Lubinski J, Gronwald J, . Hormone therapy and the risk of breast cancer in BRCA1 mutation carriers. J Natl Cancer Inst. 2008 Oct 1;100(19):1361–7. PMID: 18812548. Exclusion: E418812548
Eisen A, Lubinski J, Klijn J, . Breast cancer risk following bilateral oophorectomy in BRCA1 and BRCA2 mutation carriers: an international case-control study. J Clin Oncol. 2005 Oct 20;23(30):7491–6. PMID: 16234515. Exclusion: E316234515
Eisinger F, Fabre R, Lasset C, . Spontaneous disclosure of BRCA1/2 genetic test results to employers: a French prospective study. Eur J Hum Genet. 2012 Sep;20(9):981–3. doi: 10.1038/ejhg.2012.37. PMID: 22378286. Exclusion: E522378286
Eisinger F, Reynier CJ, Chabal F, . Acceptable strategies for dealing with hereditary breast/ovarian cancer risk. J Natl Cancer Inst. 1997 Reference Search 3-17-04;89(10):731. PMID: 9168189. Exclusion: E59168189
El Saghir N, Uhrhammer N, Assi H, . BRCA1 and BRCA2 mutations in ethnic Lebanese Arab high risk women for hereditary breast cancer. Cancer Res. 2015;75(9)doi: 10.1158/1538-7445.SABCS14-P1-03-06. PMID: 25777348. Exclusion: E325777348
Eliade M, Skrypski J, Baurand A, . The power of next generation sequencing in the detection of breast and ovarian cancer susceptibility genes other than BRCA. Cancer Res. 2016;76(4)doi: 10.1158/1538-7445.SABCS15-P2-06-04. Exclusion: E5
Eliade M, Skrzypski J, Baurand A, . The transfer of multigene panel testing for hereditary breast and ovarian cancer to healthcare: What are the implications for the management of patients and families? Oncotarget. 2017;8(2):1957–71. doi: 10.18632/oncotarget.12699. Exclusion: E527779110
Elit L, Esplen MJ, Butler K, . Quality of life and psychosexual adjustment after prophylactic oophorectomy for a family history of ovarian cancer. Fam Cancer. 2001;1(3–4):149–56. PMID: 14574171. Exclusion: E314574171
Eljuga LJ, Musani V, Sucac I, . Treatment options in patients with BRCA1 and BRCA2 germline mutation. The value of testing unaffected members in families with breast/ovarian cancer. Eur J Cancer. 2014;50:S112–S3. doi: 10.1016/S0959-8049(14)70092-9. Exclusion: E5
Ellberg C, Jernstrom H, Broberg P, . Impact of a paternal origin of germline BRCA1/2 mutations on the age at breast and ovarian cancer diagnosis in a Southern Swedish cohort. Genes Chromosomes Cancer. 2015 Jan;54(1):39–50. doi: 10.1002/gcc.22217. PMID: 25251729. Exclusion: E325251729
Ellberg C, Jonsson G, Olsson H. Can a phenotype for recessive inheritance in breast cancer be defined? Fam Cancer. 2010 Dec;9(4):525–30. PMID: 20549370. Exclusion: E320549370
Ellisen LW, Kurian AW, Desmond AJ, . Clinical impact of multi-gene panel testing for hereditary breast and ovarian cancer risk assessment. J Clin Oncol. 2015;33(15). Exclusion: E5
Elmore L, Margenthaler JA. Use of breast MRI surveillance in women at high risk for breast cancer: a single-institutional experience. Ann Surg Oncol. 2010 Oct;17:(Suppl 3):263–7. PMID: 20853044. Exclusion: 220853044
Elrick A, Ashida S, Ivanovich J, . Psychosocial and clinical factors associated with family communication of cancer genetic test results among women diagnosed with breast cancer at a young age. J Genet Couns. 2017 Feb;26(1):173–81. doi: 10.1007/s10897-016-9995-0. PMID: 27422778. Exclusion: E327422778
Elsayegh N, Angelica MGB, Muse KI, . Predictors of contralateral prophylactic mastectomy among patients with ductal carcinoma in situ (DCIS) who underwent evaluation for BRCA genetic testing. J Clin Oncol. 2012;30(15). Exclusion: E5
Elsayegh N, Gutierrez Barrera AM, Muse KI, . Evaluation of BRCAPRO risk assessment model in patients with ductal carcinoma in situ who underwent clinical BRCA genetic testing. Frontiers in Genetics. 2016;7(APR)doi: 10.3389/fgene.2016.00071. PMID: 27200080. Exclusion: E427200080
Emborgo T, Muse KI, Bednar E, . Universal BRCA testing and family outreach for women with triple negative breast cancer. Cancer Res. 2016;76(4)doi: 10.1158/1538-7445.SABCS15-P2-09-08. Exclusion: E3
Emery J. The GRAIDS Trial: the development and evaluation of computer decision support for cancer genetic risk assessment in primary care. Ann Hum Biol. 2005 Mar–Apr;32(2):218–27. doi: 10.1080/03014460500074921. PMID: 16096220. Exclusion: E616096220
Emery J, Morris H, Goodchild R, . The GRAIDS Trial: a cluster randomised controlled trial of computer decision support for the management of familial cancer risk in primary care. Br J Cancer. 2007 Aug;97(4):486–93. PMID: 17700548. Exclusion: 217700548
Emery J, Walton R, Murphy M, . Computer support for interpreting family histories of breast and ovarian cancer in primary care: comparative study with simulated cases. BMJ. 2000 Jul 01;321(7252):28–32. PMID: 10875832. Exclusion: E310875832
Erblich J, Bovbjerg DH, Valdimarsdottir HB. Looking forward and back: distress among women at familial risk for breast cancer. Ann Behav Med. 2000 Winter;22(1):53–9. doi: 10.1007/bf02895167. PMID: 10892528. Exclusion: E410892528
Escobar PF, Starks DC, Fader AN, . Single-port risk-reducing salpingo-oophorectomy with and without hysterectomy: surgical outcomes and learning curve analysis. Gynecol Oncol. 2010 Oct;119(1):43–7. PMID: 20579712. Exclusion: E320579712
Esplen MJ, Hunter J, Leszcz M, . A multicenter study of supportive-expressive group therapy for women with BRCA1/BRCA2 mutations. Cancer. 2004 Nov 15;101(10):2327–40. PMID: 15478194. Exclusion: E415478194
Esteban Cardenosa E, Bolufer Gilabert P, Palanca Suela S, . Twenty-three novel BRCA1 and BRCA2 sequence alterations in breast and/or ovarian cancer families of Eastern Spain. Breast Cancer Res Treat. 2008 Nov;112(1):69–73. PMID: 18060494. Exclusion: E518060494
Esteban Cardenosa E, de Juan Jimenez I, Palanca Suela S, . Low penetrance alleles as risk modifiers in familial and sporadic breast cancer. Fam Cancer. 2012 Dec;11(4):629–36. doi: 10.1007/s10689-012-9563-1. PMID: 22926736. Exclusion: E422926736
Esteves V, Thuler L, Amendola L, . Prevalence of BRCA1 and BRCA2 gene mutations in families with medium and high risk of breast and ovarian cancer in Brazil. Braz J Med Biol Res. 2009 May;42(5):453–7. doi: 10.1590/S0100-879X2009000500009. PMID: 19377795. Exclusion: E519377795
Euhus DM. Risk-reducing mastectomy for BRCA gene mutation carriers. Ann Surg Oncol. 2015 Sep;22(9):2807–9. doi: 10.1245/s10434-015-4537-9. PMID: 25821000. Exclusion: E625821000
Evans D, Gareth R, Lennard F, . Eligibility for magnetic resonance imaging screening in the United Kingdom: effect of strict selection criteria and anonymous DNA testing on breast cancer incidence in the MARIBS Study. Cancer Epidemiol Biomarkers Prev. 2009 Jul;18(7):2123–31. PMID: 19567506. Exclusion: 219567506
Evans DG, Barwell J, Eccles DM, . The Angelina Jolie effect: how high celebrity profile can have a major impact on provision of cancer related services. Breast Cancer Res. 2014;16(5):442. doi: 10.1186/s13058-014-0442-6. PMID: 25510853. Exclusion: 225510853
Evans DG, Gaarenstroom KN, Stirling D, . Screening for familial ovarian cancer: poor survival of BRCA1/2 related cancers. J Med Genet. 2009;46(9):593–7. PMID: 18413372. Exclusion: E518413372
Evans DG, Harkness E, Lalloo F, . Long-term prospective clinical follow-up after BRCA1/2 presymptomatic testing: BRCA2 risks higher than in adjusted retrospective studies. J Med Genet. 2014 Sep;51(9):573–80. doi: 10.1136/jmedgenet-2014-102336. PMID: 25053764. Exclusion: E525053764
Evans DG, Howell A. Are we ready for online tools in decision making for BRCA1/2 mutation carriers? J Clin Oncol. 2012 Feb 10;30(5):471–3. PMID: 22231044. Exclusion: E622231044
Evans DG, Howell A. Can the breast screening appointment be used to provide risk assessment and prevention advice? Breast Cancer Res. 2015;17:84. doi: 10.1186/s13058-015-0595-y. PMID: 26155950. Exclusion: E426155950
Evans DG, Howell A, Ingham SL, . Contralateral breast cancer risk in BRCA1/2-positive families needs to be adjusted for phenocopy rates particularly in second-degree untested relatives. Breast Cancer Res. 2013;15(1):401. doi: 10.1186/bcr3382. PMID: 23448362. Exclusion: E623448362
Evans DG, Ingham S, Dawe S, . Breast cancer risk assessment in 8,824 women attending a family history evaluation and screening programme. Fam Cancer. 2014 Jun;13(2):189–96. doi: 10.1007/s10689-013-9694-z. PMID: 24276527. Exclusion: E424276527
Evans DG, Ingham SL, Baildam A, . Contralateral mastectomy improves survival in women with BRCA1/2-associated breast cancer. Breast Cancer Res Treat. 2013 Jul;140(1):135–42. doi: 10.1007/s10549-013-2583-1. PMID: 23784379. Exclusion: E3b23784379
Evans DG, Kesavan N, Lim Y, . MRI breast screening in high-risk women: cancer detection and survival analysis. Breast Cancer Res Treat. 2014 Jun;145(3):663–72. doi: 10.1007/s10549-014-2931-9. PMID: 24687378. Exclusion: E724687378
Evans DG, Woodward ER, Howell SJ, . Risk algorithms that include pathology adjustment for HER2 amplification need to make further downward adjustments in likelihood scores. Fam Cancer. 2017 04;16(2):173–9. doi: 10.1007/s10689-016-9942-0. PMID: 27796713. Exclusion: E327796713
Evans DG, Young K, Bulman M, . Probability of BRCA1/2 mutation varies with ovarian histology: results from screening 442 ovarian cancer families. Clin Genet. 2008 Apr;73(4):338–45. doi: 10.1111/j.1399-0004.2008.00974.x. PMID: 18312450. Exclusion: 218312450
Evans DGR, Binchy A, Shenton A, . Comparison of proactive and usual approaches to offering predictive testing for BRCA1/2 mutations in unaffected relatives. Clin Genet. 2009 Feb;75(2):124–32. PMID: 19215246. Exclusion: E519215246
Evans DGR, Lalloo F, Ashcroft L, . Uptake of risk-reducing surgery in unaffected women at high risk of breast and ovarian cancer is risk, age, and time dependent. Cancer Epidemiol Biomarkers Prev. 2009 Aug;18(8):2318–24. PMID: 19661091. Exclusion: E519661091
Evans JP, Skrzynia C, Susswein L, . Genetics and the young woman with breast cancer. Breast Dis. 2005;23:17–29. PMID: 16823163. Exclusion: E916823163
Fackenthal JD, Zhang J, Zhang B, . High prevalence of BRCA1 and BRCA2 mutations in unselected Nigerian breast cancer patients. Int J Cancer. 2012 Sep 1;131(5):1114–23. doi: 10.1002/ijc.27326. PMID: 22034289. Exclusion: E322034289
Fakkert IE, Jansen L, Meijer K, . Breast cancer screening in BRCA1 and BRCA2 mutation carriers after risk reducing salpingo-oophorectomy. Breast Cancer Res Treat. 2011 Aug;129(1):157–64. PMID: 21373873. Exclusion: E521373873
Fakkert IE, Mourits MJE, Jansen L, . Breast cancer incidence after risk-reducing salpingo-oophorectomy in BRCA1 and BRCA2 mutation carriers. Cancer Prev Res (Phila). 2012 Nov;5(11):1291–7. doi: 10.1158/1940-6207.CAPR-12-0190. PMID: 23009828. Exclusion: H223009828
Falconer H, Yin L, Grönberg H, . Ovarian cancer risk after salpingectomy: a nationwide population-based study. J Natl Cancer Inst. 2015;107(2):dju410. PMID: 25628372. Exclusion: E325628372
Fanale D, Amodeo V, Corsini LR, . Breast cancer genome-wide association studies: there is strength in numbers. Oncogene. 2012 Apr 26;31(17):2121–8. doi: 10.1038/onc.2011.408. PMID: 21996731. Exclusion: 221996731
Fang CY, Cherry C, Devarajan K, . A prospective study of quality of life among women undergoing risk-reducing salpingo-oophorectomy versus gynecologic screening for ovarian cancer. Gynecol Oncol. 2009 Mar;112(3):594–600. PMID: 19141360. Exclusion: H219141360
Fang CY, Miller SM, Malick J, . Psychosocial correlates of intention to undergo prophylactic oophorectomy among women with a family history of ovarian cancer. Prev Med. 2003 Nov;37(5):424–31. PMID: 14572427. Exclusion: E514572427
Farooq A, Naveed AK, Azeem Z, . Breast and ovarian cancer risk due to prevalence of BRCA1 and BRCA2 variants in pakistani population: A Pakistani database report. J Oncol. 2011 PMID: 21559243. Exclusion: E521559243
Farr DE. The impact of false positive mammography results on breast cancer screening intention among Black women. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2018;79(11-B(E)):No Pagination Specified. PMID: 2018-40527-027. Exclusion: E6
Farr DE, Brandt HM, Friedman DB, . False-positive mammography and mammography screening intentions among black women: the influence of emotions and coping strategies(). Ethn Health. 2019 Jan 24:1–18. doi: 10.1080/13557858.2019.1571563. PMID: 30676782. Exclusion: E330676782
Farrell C, Lyman M, Freitag K, . The role of hereditary nonpolyposis colorectal cancer in the management of familial ovarian cancer. Genet Med. 2006 Oct;8(10):653–7. PMID: 17079882. Exclusion: E517079882
Farrelly A, White V, Meiser B, . Unmet support needs and distress among women with a BRCA1/2 mutation. Fam Cancer. 2013 Sep;12(3):509–18. doi: 10.1007/s10689-012-9596-5. PMID: 23264090. Exclusion: E423264090
Farshid G, Balleine RL, Cummings M, . Morphology of breast cancer as a means of triage of patients for BRCA1 genetic testing. Am J Surg Pathol. 2006 Nov;30(11):1357–66. PMID: 17063074. Exclusion: E317063074
Fehniger J, Lin F, Beattie M. Family communication of genetic test results and uptake of genetic testing in a diverse population of BRCA1 and BRCA2 (BRCA1/2) carriers. Gynecol Oncol. 2012;127(1):S22–S3. doi: 10.1016/j.ygyno.2012.07.062. Exclusion: E5
Fehniger J, Lin F, Beattie MS, . Family communication of BRCA1/2 results and family uptake of BRCA1/2 testing in a diverse population of BRCA1/2 carriers. J Genet Couns. 2013 Oct;22(5):603–12. doi: 10.1007/s10897-013-9592-4. PMID: 23666114. Exclusion: E523666114
Fejerman L, John EM, Huntsman S, . Genetic ancestry and risk of breast cancer among U.S. Latinas. Cancer Res. 2008 Dec 1;68(23):9723–8. PMID: 19047150. Exclusion: E419047150
Feki A, Irminger-Finger I. Mutational spectrum of p53 mutations in primary breast and ovarian tumors. Crit Rev Oncol Hematol. 2004 Nov;52(2):103–16. PMID: 15501075. Exclusion: E915501075
Ferla R, Calo V, Cascio S, . Founder mutations in BRCA1 and BRCA2 genes. Ann Oncol. 2007 Jun;18: Suppl 6:vi93–8. PMID: 17591843. Exclusion: E617591843
Field KM, Jenkins MA, Friedlander ML, . Predictors of the use of complementary and alternative medicine (CAM) by women at high risk for breast cancer. Eur J Cancer. 2009 Mar;45(4):551–60. PMID: 18996690. Exclusion: E518996690
Figueiredo JC, Haile RW, Bernstein L, . Oral contraceptives and postmenopausal hormones and risk of contralateral breast cancer among BRCA1 and BRCA2 mutation carriers and noncarriers: the WECARE Study. Breast Cancer Res Treat. 2010 Feb;120(1):175–83. PMID: 19597986. Exclusion: E519597986
Finch A, Beiner M, Lubinski J, . Salpingo-oophorectomy and the risk of ovarian, fallopian tube, and peritoneal cancers in women with a BRCA1 or BRCA2 Mutation. JAMA. 2006 Jul 12;296(2):185–92. PMID: 16835424. Exclusion: E3a16835424
Finch A, Evans G, Narod SA. BRCA carriers, prophylactic salpingo-oophorectomy and menopause: clinical management considerations and recommendations. Womens Health. 2012 Sep;8(5):543–55. doi: 10.2217/whe.12.41. PMID: 22934728. Exclusion: E922934728
Finch A, Metcalfe K, Lui J, . Breast and ovarian cancer risk perception after prophylactic salpingo-oophorectomy due to an inherited mutation in the BRCA1 or BRCA2 gene. Clin Genet. 2009 Mar;75(3):220–4. PMID: 19263514. Exclusion: E519263514
Finch A, Metcalfe KA, Chiang J, . The impact of prophylactic salpingo-oophorectomy on quality of life and psychological distress in women with a BRCA mutation. Psychooncology. 2013 Jan;22(1):212–9. doi: 10.1002/pon.2041. PMID: 21913283. Exclusion: E3a21913283
Finch A, Narod SA. Quality of life and health status after prophylactic salpingo-oophorectomy in women who carry a BRCA mutation: A review. Maturitas. 2011 Nov;70(3):261–5. PMID: 21893388. Exclusion: E921893388
Finch A, Shaw P, Rosen B, . Clinical and pathologic findings of prophylactic salpingo-oophorectomies in 159 BRCA1 and BRCA2 carriers. Gynecol Oncol. 2006 Jan;100(1):58–64. PMID: 16137750. Exclusion: E516137750
Finch AP, Lubinski J, Moller P, . Impact of oophorectomy on cancer incidence and mortality in women with a BRCA1 or BRCA2 mutation. J Clin Oncol. 2014 May 20;32(15):1547–53. doi: 10.1200/JCO.2013.53.2820. PMID: 24567435. Exclusion: E3a24567435
Fisher B, Costantino JP, Wickerham DL, . Tamoxifen for the prevention of breast cancer: current status of the National Surgical Adjuvant Breast and Bowel Project P-1 study. J Natl Cancer Inst. 2005;97(22):1652–62. PMID: 16288118. Exclusion: E316288118
Fisher B, Costantino JP, Wickerham DL, . Tamoxifen for prevention of breast cancer: report of the National Surgical Adjuvant Breast and Bowel Project P-1 Study. J Natl Cancer Inst. 1998 Sep 16;90(18):1371–88. PMID: 9747868. Exclusion: 29747868
Fisher C, Bylund C, Rising C, . Managing women’s uncertainty during genetic counseling sessions for BRCA testing. Psychooncology. 2015;24:51–2. doi: 10.1002/pon.3873. Exclusion: E5
Fisher CL, Maloney E, Glogowski E, . Talking about familial breast cancer risk: topics and strategies to enhance mother-daughter interactions. Qual Health Res. 2014 Apr;24(4):517–35. doi: 10.1177/1049732314524638. PMID: 24633365. Exclusion: E524633365
Fisher CL, Roccotagliata T, Rising CJ, . “I don’t want to be an ostrich”: Managing mothers’ uncertainty during BRCA1/2 genetic counseling. J Genet Couns. 2017 Jun;26(3):455–68. doi: 10.1007/s10897-016-9998-x. PMID: 27473644. Exclusion: E527473644
Fishman A. The effects of parity, breastfeeding, and infertility treatment on the risk of hereditary breast and ovarian cancer: a review. Int J Gynecol Cancer. 2010 Oct;20(11 Suppl 2):S31–3. PMID: 20975359. Exclusion: E920975359
Fishman DA, Cohen L, Blank SV, . The role of ultrasound evaluation in the detection of early-stage epithelial ovarian cancer. Am J Obstet Gynecol. 2005;192(4):1214–22. PMID: 15846205. Exclusion: E515846205
Fleeman N, Martin Saborido C, Payne K, . The clinical effectiveness and cost-effectiveness of genotyping for CYP2D6 for the management of women with breast cancer treated with tamoxifen: a systematic review (Structured abstract). Health Technol Assess; 2011. Exclusion: E3
Fleming PJ, Vadaparampil ST, Bonner D, . BRCA mutations and surgical decision making in a sample of young black women with invasive breast cancer. Cancer Epidemiology Biomarkers and Prevention. 2011;20(10)doi: 10.1158/1055-9965.DISP-11-A71. Exclusion: E3
Fletcher O, Johnson N, Dos Santos Silva I, . Family history, genetic testing, and clinical risk prediction: pooled analysis of CHEK2 1100delC in 1,828 bilateral breast cancers and 7,030 controls. Cancer Epidemiol Biomarkers Prev. 2009 Jan;18(1):230–4. PMID: 19124502. Exclusion: E519124502
Flores KG, Steffen LE, McLouth CJ, . Factors associated with interest in gene-panel testing and risk communication preferences in women from BRCA1/2 negative families. J Genet Couns. 2017 Jun;26(3):480–90. doi: 10.1007/s10897-016-0001-7. PMID: 27496122. Exclusion: E327496122
Forbes Shepherd R, Browne TK, Warwick L. A Relational Approach to Genetic Counseling for Hereditary Breast and Ovarian Cancer. J Genet Couns. 2017 Apr;26(2):283–99. doi: 10.1007/s10897-016-0022-2. PMID: 27761849. Exclusion: E527761849
Fortuny D, Balmana J, Grana B, . Opinion about reproductive decision making among individuals undergoing BRCA1/2 genetic testing in a multicentre Spanish cohort.[Erratum appears in Hum Reprod. 2009 Jul;24(7):1772]. Hum Reprod. 2009 Apr;24(4):1000–6. PMID: 19112076. Exclusion: E419112076
Foulkes WD. BRCA1 and BRCA2 - update and implications on the genetics of breast cancer: a clinical perspective. Clin Genet. 2014 Jan;85(1):1–4. doi: 10.1111/cge.12291. PMID: 24116874. Exclusion: E624116874
Foulkes WD, Knoppers BM, Turnbull C. Population genetic testing for cancer susceptibility: founder mutations to genomes. Nature Reviews Clinical Oncology. 2016 Jan;13(1):41–54. doi: 10.1038/nrclinonc.2015.173. PMID: 26483301. Exclusion: 226483301
Fourquet A, Stoppa-Lyonnet D, Kirova YM, . Familial breast cancer: clinical response to induction chemotherapy or radiotherapy related to BRCA1/2 mutations status. Am J Clin Oncol. 2009 Apr;32(2):127–31. PMID: 19307946. Exclusion: E319307946
Francken AB, Schouten PC, Bleiker EM, . Breast cancer in women at high risk: the role of rapid genetic testing for BRCA1 and -2 mutations and the consequences for treatment strategies. Breast. 2013 Oct;22(5):561–8. doi: 10.1016/j.breast.2013.07.045. PMID: 23972475. Exclusion: E323972475
Frank B, Hemminki K, Meindl A, . BRIP1 (BACH1) variants and familial breast cancer risk: a case-control study. BMC Cancer. 2007;7:83. PMID: 17504528. Exclusion: E517504528
Freedman AN, Wideroff L, Olson L, . US physicians’ attitudes toward genetic testing for cancer susceptibility. Am J Med Genet. 2003;120 A(1):63–71. PMID: 12794694. Exclusion: E512794694
Freedman ML, Penney KL, Stram DO, . Common variation in BRCA2 and breast cancer risk: a haplotype-based analysis in the Multiethnic Cohort. Hum Mol Genet. 2004 Oct 15;13(20):2431–41. PMID: 15317758. Exclusion: E515317758
Freedman ML, Penney KL, Stram DO, . A haplotype-based case-control study of BRCA1 and sporadic breast cancer risk. Cancer Res. 2005 Aug 15;65(16):7516–22. PMID: 16103107. Exclusion: E516103107
Freisinger F, Domchek SM. Clinical implications of low-penetrance breast cancer susceptibility alleles. Curr Oncol Rep. 2009 Jan;11(1):8–14. PMID: 19080736. Exclusion: E919080736
Frey MK, Kim SH, Bassett RY, . Rescreening for genetic mutations using multi-gene panel testing in patients who previously underwent non-informative genetic screening. Gynecol Oncol. 2015 Nov;139(2):211–5. doi: 10.1016/j.ygyno.2015.08.006. PMID: 26296696. Exclusion: E526296696
Freysteinson WM, Deutsch AS, Lewis C, . The experience of viewing oneself in the mirror after a mastectomy. Oncol Nurs Forum. 2012 Jul;39(4):361–9. doi: 10.1188/12.ONF.361-369. PMID: 22750894. Exclusion: E322750894
Frezzo TM, Rubinstein WS, Dunham D, . The genetic family history as a risk assessment tool in internal medicine. Genet Med. 2003;5(2):84–91. PMID: CN-00558460. Exclusion: E512644777
Friedenson B. BRCA1 and BRCA2 pathways and the risk of cancers other than breast or ovarian. MedGenMed. 2005;7(2):60. PMID: 16369438. Exclusion: E916369438
Friedenson B. The BRCA1/2 pathway prevents hematologic cancers in addition to breast and ovarian cancers. BMC Cancer. 2007;7:152. PMID: 17683622. Exclusion: E517683622
Friedman E, Kotsopoulos J, Lubinski J, . Spontaneous and therapeutic abortions and the risk of breast cancer among BRCA mutation carriers. Breast Cancer Res. 2006;8(2):R15. PMID: 16563180. Exclusion: E416563180
Friedman LC. Psychological impact of receiving negative BRCA1 mutation test results in Ashkenazim. Genet Med. 1999;1(3):74–9. PMID: 11336456. Exclusion: H211336456
Friedman LC, Kalidas M, Elledge R, . Optimism, social support and psychosocial functioning among women with breast cancer. Psycho Oncology. 2006 Jul;15(7):595–603. doi: 10.1002/pon.992. PMID: 16287209. Exclusion: E316287209
Friedrichsen DM, Malone KE, Doody DR, . Frequency of CHEK2 mutations in a population based, case-control study of breast cancer in young women. Breast Cancer Res. 2004;6(6):R629–35. PMID: 15535844. Exclusion: E415535844
Frost MH, Hoskin TL, Hartmann LC, . Contralateral prophylactic mastectomy: long-term consistency of satisfaction and adverse effects and the significance of informed decision-making, quality of life, and personality traits. Ann Surg Oncol. 2011 Oct;18(11):3110–6. PMID: 21947589. Exclusion: E321947589
Frost MH, Slezak JM, Tran NV, . Satisfaction after contralateral prophylactic mastectomy: the significance of mastectomy type, reconstructive complications, and body appearance. J Clin Oncol. 2005 Nov 1;23(31):7849–56. PMID: 16204003. Exclusion: E3a16204003
Fumagalli D, Sotiriou C. Treatment of pT1N0 breast cancer: multigene predictors to assess risk of relapse. Ann Oncol. 2010 Oct;21: Suppl 7:vii103–6. PMID: 20943601. Exclusion: E920943601
Gaba FM, Manchanda R, Gaba FM, . Genetic testing for gynaecological cancer. Obstetrics, Gynaecology and Reproductive Medicine. 2017;27(1):29–31. doi: 10.1016/j.ogrm.2016.11.001. Exclusion: E3
Gabai-Kapara E, Lahad A, Kaufman B, . Population-based screening for breast and ovarian cancer risk due to BRCA1 and BRCA2. Proc Natl Acad Sci U S A. 2014 Sep 30;111(39):14205–10. doi: 10.1073/pnas.1415979111. PMID: 25192939. Exclusion: E325192939
Gabaldó Barrios X, Sánchez Bermúdez A, Sarabia Meseguer A, . Prevalence of BRCA mutation carriers with breast cancer without family history of cancer. Are physician recommendations for brca1/2 testing appropriate? Clin Chem Lab Med. 2014;52:S836. doi: 10.1515/cclm-2014-4027. Exclusion: E4
Gabaldó Barrios X, Sánchez Bermúdez AI, Sánchez P, . Clinical characteristics of gynecological cancer in BRCA mutation carriers and noncarriers. Clin Chem Lab Med. 2014;52:S819. doi: 10.1515/cclm-2014-4027. Exclusion: E4
Gaber RS, Thekkekara RJ, Gil DN, . Uptake of genetic testing for BRCA mutations in a medically underserved population. Cancer Res. 2016;76(4)doi: 10.1158/1538-7445.SABCS15-P6-12-09. Exclusion: E5
Gabos Z, Thoms J, Ghosh S, . The association between biological subtype and locoregional recurrence in newly diagnosed breast cancer. Breast Cancer Res Treat. 2010 Nov;124(1):187–94. PMID: 20814819. Exclusion: E320814819
Gabriel CA, Tigges-Cardwell J, Stopfer J, . Use of total abdominal hysterectomy and hormone replacement therapy in BRCA1 and BRCA2 mutation carriers undergoing risk-reducing salpingo-oophorectomy. Fam Cancer. 2009;8(1):23–8. PMID: 18758995. Exclusion: E518758995
Gabrovska PN, Smith RA, O’Leary G, . Investigation of the 1758G>C and 2880A>G variants within the NCOA3 gene in a breast cancer affected Australian population. Gene. 2011;482(1–2):68–72. PMID: 21601620. Exclusion: E321601620
Gadducci A, Biglia N, Cosio S, . Gynaecologic challenging issues in the management of BRCA mutation carriers: oral contraceptives, prophylactic salpingo-oophorectomy and hormone replacement therapy. Gynecol Endocrinol. 2010 Aug;26(8):568–77. PMID: 20632911. Exclusion: E520632911
Gadducci A, Sergiampietri C, Tana R. Alternatives to risk-reducing surgery for ovarian cancer. Ann Oncol. 2013;24(suppl_8):viii47–viii53. PMID: 24131970. Exclusion: E924131970
Gadzicki D, Schubert A, Fischer C, . Histopathological criteria and selection algorithms for BRCA1 genetic testing. Cancer Genet Cytogenet. 2009 Mar;189(2):105–11. PMID: 19215791. Exclusion: E319215791
Gail MH, Costantino JP, Pee D, . Projecting individualized absolute invasive breast cancer risk in African American women. J Natl Cancer Inst. 2007 Dec 5;99(23):1782–92. PMID: 18042936. Exclusion: E318042936
Gaj P, Kluska A, Nowakowska D, . High frequency of BRCA1 founder mutations in Polish women with nonfamilial breast cancer. Fam Cancer. 2012 Dec;11(4):623–8. doi: 10.1007/s10689-012-9560-4. PMID: 22864640. Exclusion: 222864640
Gal I, Kimmel G, Gershoni-Baruch R, . A specific RAD51 haplotype increases breast cancer risk in Jewish non-Ashkenazi high-risk women. Eur J Cancer. 2006 May;42(8):1129–34. PMID: 16624550. Exclusion: E516624550
Galizia E, Giorgetti G, Piccinini G, . BRCA1 expression in triple negative sporadic breast cancers. Anal Quant Cytol Histol. 2010 Feb;32(1):24–9. PMID: 20701084. Exclusion: E520701084
Gallion H, Kryscio RJ, Clarke Pearson DL, . The prognostic significance of germline BRCA1 mutations in epithelial ovarian cancer: a Gynecologic Oncology Group study [abstract]. Gynecol Oncol. 2003 4, 2003;88(2):157–8. Exclusion: E5
Gammon AD, Rothwell E, Simmons R, . Awareness and preferences regarding BRCA1/2 genetic counseling and testing among Latinas and non-Latina White women at increased risk for hereditary breast and ovarian cancer. J Genet Couns. 2011 Dec;20(6):625–38. doi: 10.1007/s10897-011-9376-7. PMID: 21691939. Exclusion: E421691939
Gangi A, Cass I, Paik D, . Breast cancer following ovarian cancer in BRCA mutation carriers.[Erratum appears in JAMA Surg. 2015 Feb;150(2):183; PMID: 25692820]. JAMA Surgery. 2014 Dec;149(12):1306–13. doi: 10.1001/jamasurg.2014.1081. PMID: 25372568. Exclusion: E3b25372568
Ganz PA. Breast cancer, menopause, and long-term survivorship: critical issues for the 21st century. Am J Med. 2005 Dec 19;118 Suppl 12B:136–41. PMID: 16414339. Exclusion: E916414339
Gao B, Xie X-J, Huang C, . RASSF1A polymorphism A133S is associated with early onset breast cancer in BRCA1/2 mutation carriers. Cancer Res. 2008 Jan 1;68(1):22–5. PMID: 18172292. Exclusion: E418172292
Gao J, Ke Q, Ma H-X, . Functional polymorphisms in the cyclooxygenase 2 (COX-2) gene and risk of breast cancer in a Chinese population. J Toxicol Environ Health A. 2007 Jun;70(11):908–15. PMID: 17479405. Exclusion: E517479405
Garber J. Using germline genetics in the management of breast cancer patients and their families. Breast. 2015;24:S10–S1. doi: 10.1016/S0960-9776(15)70023-8. Exclusion: E6
Garcia C, Lyon L, Conell C, . Osteoporosis risk and management in BRCA1 and BRCA2 carriers who undergo risk-reducing salpingo-oophorectomy. Gynecol Oncol. 2015 Sep;138(3):723–6. doi: 10.1016/j.ygyno.2015.06.020. PMID: 26086567. Exclusion: E3a26086567
Garcia C, Powell CB. A comprehensive approach to the identification and management of the BRCA patient. Obstet Gynecol Surv. 2015 Feb;70(2):131–43. doi: 10.1097/OGX.0000000000000156. PMID: 25671374. Exclusion: E625671374
Garcia C, Wendt J, Lyon L, . Risk management options elected by women after testing positive for a BRCA mutation. Gynecol Oncol. 2014 Feb;132(2):428–33. doi: 10.1016/j.ygyno.2013.12.014. PMID: 24355485. Exclusion: E524355485
Garcia-Closas M, Egan KM, Newcomb PA, . Polymorphisms in DNA double-strand break repair genes and risk of breast cancer: two population-based studies in USA and Poland, and meta-analyses. Hum Genet. 2006 May;119(4):376–88. PMID: 16485136. Exclusion: E416485136
Garcia-Etienne CA, Barile M, Gentilini OD, . Breast-conserving surgery in BRCA1/2 mutation carriers: are we approaching an answer? Ann Surg Oncol. 2009 Dec;16(12):3380–7. PMID: 19649554. Exclusion: E319649554
Gaudet MM, Chanock S, Dunning A, . HSD17B1 genetic variants and hormone receptor-defined breast cancer. Cancer Epidemiol Biomarkers Prev. 2008 Oct;17(10):2766–72. PMID: 18843021. Exclusion: E518843021
Gavaruzzi T, Tasso A, Franiuk M, . A Psychological Perspective on Factors Predicting Prophylactic Salpingo-Oophorectomy in a Sample of Italian Women from the General Population. Results from a Hypothetical Study in the Context of BRCA Mutations. J Genet Couns. 2017 Oct;26(5):1144–52. doi: 10.1007/s10897-017-0093-8. PMID: 28337671. Exclusion: E428337671
Geiger AM, Yu O, Herrinton LJ, . A population-based study of bilateral prophylactic mastectomy efficacy in women at elevated risk for breast cancer in community practices. Arch Intern Med. 2005 Mar 14;165(5):516–20. PMID: 15767526. Exclusion: E315767526
Ghadirian P, Robidoux A, Nassif E, . Screening for BRCA1 and BRCA2 mutations among French-Canadian breast cancer cases attending an outpatient clinic in Montreal. Clin Genet. 2014;85:31–5. PMID: 23621881. Exclusion: 223621881
Ghadirian P, Robidoux A, Zhang P, . The contribution of founder mutations to early-onset breast cancer in French-Canadian women. Clin Genet. 2009;76:421–6. PMID: 19863560. Exclusion: 219863560
Ghoussaini M, Fletcher O, Michailidou K, . Genome-wide association analysis identifies three new breast cancer susceptibility loci. Nat Genet. 2012 Mar;44(3):312–8. doi: 10.1038/ng.1049. PMID: 22267197. Exclusion: E322267197
Giannakeas V, Lubinski J, Gronwald J, . Mammography screening and the risk of breast cancer in BRCA1 and BRCA2 mutation carriers: a prospective study. Breast Cancer Res Treat. 2014 Aug;147(1):113–8. doi: 10.1007/s10549-014-3063-y. PMID: 25082516. Exclusion: E425082516
Giannakeas V, Narod S. A cancer risk assessment tool for BRCA1 and BRCA2 carriers. Current Oncology. 2014;21(2):e386. doi: 10.3747/co.21.2077. Exclusion: E6
Gierach GL, Loud JT, Chow CK, . Mammographic density does not differ between unaffected BRCA1/2 mutation carriers and women at low-to-average risk of breast cancer. Breast Cancer Res Treat. 2010 Aug;123(1):245–55. doi: 10.1007/s10549-010-0749-7. PMID: 20130984. Exclusion: 220130984
Gil F, Mendez I, Sirgo A, . Perception of breast cancer risk and surveillance behaviours of women with family history of breast cancer: a brief report on a Spanish cohort. Psychooncology. 2003 Dec;12(8):821–7. doi: 10.1002/pon.704. PMID: 14681955. Exclusion: E414681955
Gilbar R, Shalev S, Spiegel R, . Patients’ attitudes towards disclosure of genetic test results to family members: The impact of patients’ sociodemographic background and counseling experience. J Genet Couns. 2016 Apr;25(2):314–24. doi: 10.1007/s10897-015-9873-1. PMID: 26371363. Exclusion: E426371363
Gilbert FJ, Warren RML, Kwan-Lim G, . Cancers in BRCA1 and BRCA2 carriers and in women at high risk for breast cancer: MR imaging and mammographic features. Radiology. 2009 Aug;252(2):358–68. PMID: 19703879. Exclusion: E319703879
Ginsburg O, Ghadirian P, Lubinski J, . Smoking and the risk of breast cancer in BRCA1 and BRCA2 carriers: an update. Breast Cancer Res Treat. 2009 Mar;114(1):127–35. PMID: 18483851. Exclusion: E418483851
Glassey R, Ives A, Saunders C, . Decision making, psychological wellbeing and psychosocial outcomes for high risk women who choose to undergo bilateral prophylactic mastectomy - A review of the literature. Breast. 2016 Aug;28:130–5. doi: 10.1016/j.breast.2016.05.012. PMID: 27318167. Exclusion: E927318167
Glasspool DW, Oettinger A, Braithwaite D, . Interactive decision support for risk management: a qualitative evaluation in cancer genetic counselling sessions. J Cancer Educ. 2010 Sep;25(3):312–6. PMID: 20162470. Exclusion: E520162470
Glendon G, Frost CJ, Andrulis IL, . A qualitative study evaluating parental attitudes towards the creation of a female youth cohort (LEGACY) in the Breast Cancer Family Registry. Psychooncology. 2010 Jan;19(1):93–101. PMID: 19415783. Exclusion: E519415783
Gochhait S, Bukhari SIA, Bairwa N, . Implication of BRCA2 -26G>A 5’ untranslated region polymorphism in susceptibility to sporadic breast cancer and its modulation by p53 codon 72 Arg>Pro polymorphism. Breast Cancer Res. 2007;9(5):R71. PMID: 17945002. Exclusion: E517945002
Godino L, Razzaboni E, Bianconi M, . Impact of genetic counseling in women with a family history of breast cancer in Italy. J Genet Couns. 2016 Apr;25(2):405–11. doi: 10.1007/s10897-015-9884-y. PMID: 26354337. Exclusion: E326354337
Goel MS. Breast cancer risk assessment in a primary care, federally qualified community health center population. J Gen Intern Med. 2017;32(2):S131. Exclusion: E6
Goffin JR, Chappuis PO, Bégin LR, . Impact of germline BRCA1 mutations and overexpression of p53 on prognosis and response to treatment following breast carcinoma: 10-Year follow-up data. Cancer. 2003;97(3):527–36. PMID: 12548593. Exclusion: E312548593
Goldgar C. GINA: What PAs need to know to protect patients and their families. JAAPA. 2010 Jul;23(7):56–9. PMID: 20690446. Exclusion: E620690446
Golshan M, Miron A, Nixon AJ, . The prevalence of germline BRCA1 and BRCA2 mutations in young women with breast cancer undergoing breast-conservation therapy. Am J Surg. 2006 Jul;192(1):58–62. PMID: 16769276. Exclusion: E316769276
Gómez Garcia E, Eccles D, Balmaña J, . Evidence around criteria for selecting ovarian cancer patients for BRCA mutation testing-findings from the literature and guidelines review. Int J Gynecol Cancer. 2014;24(9):282–3. doi: 10.1097/01.IGC.0000457075.08973.89. Exclusion: E3
Gonzalez BD, Hoogland AI, Kasting ML, . Psychosocial impact of BRCA testing in young Black breast cancer survivors. Psychooncology. 2018;27(12):2778–85. doi: 10.1002/pon.4887. Exclusion: E3b30207419
Gonzalez-Angulo AM, Timms KM, Liu S, . Incidence and outcome of BRCA mutations in unselected patients with triple receptor-negative breast cancer. Clin Cancer Res. 2011 Mar 1;17(5):1082–9. PMID: 21233401. Exclusion: E321233401
Gonzalez-Hormazabal P, Reyes JM, Blanco R, . The BARD1 Cys557Ser variant and risk of familial breast cancer in a South-American population. Mol Biol Rep. 2012 Aug;39(8):8091–8. doi: 10.1007/s11033-012-1656-2. PMID: 22544576. Exclusion: E522544576
Gooding HC, Organista K, Burack J, . Genetic susceptibility testing from a stress and coping perspective. Soc Sci Med. 2006 Apr;62(8):1880–90. PMID: 16198036. Exclusion: E916198036
Goodnight JE, Jr., Quagliana JM, Morton DL. Failure of subcutaneous mastectomy to prevent the development of breast cancer. J Surg Oncol. 1984 Jul;26(3):198–201. PMID: 6330460. Exclusion: 26330460
Gordon E. What PAs should know before they refer patients to a genetic counselor. JAAPA. 2009 Sep;22(9):61–3. PMID: 19827402. Exclusion: E619827402
Gorringe KL, Choong DYH, Lindeman GJ, . Breast cancer risk and the BRCA1 interacting protein CTIP. Breast Cancer Res Treat. 2008 Nov;112(2):351–2. PMID: 18095152. Exclusion: E518095152
Gorski B, Narod SA, Lubinski J. A common missense variant in BRCA2 predisposes to early onset breast cancer. Breast Cancer Res. 2005;7(6):R1023–7. PMID: 16280055. Exclusion: E516280055
Goss PE, Ingle JN, Ales-Martinez JE, . Exemestane for breast-cancer prevention in postmenopausal women. N Engl J Med. 2011 Jun 23;364(25):2381–91. doi: 10.1056/NEJMoa1103507. PMID: 21639806. Exclusion: 221639806
Gotimer KF, Jimenez EA, Villella JA, . Impact of universal screening recommendation on genetic testing in ovarian, fallopian tube, and peritoneal cancers. Obstet Gynecol. 2016;127:134S. doi: 10.1097/01.AOG.0000483540.79207.b3. Exclusion: E5
Gotlieb WH, Barchana M, Ben-Baruch G, . Malignancies following bilateral salpingo-oophorectomy (BSO). Eur J Surg Oncol. 2006 Dec;32(10):1231–4. PMID: 16626923. Exclusion: E316626923
Grady D, Cauley JA, Geiger MJ, . Reduced incidence of invasive breast cancer with raloxifene among women at increased coronary risk. J Natl Cancer Inst. 2008 Jun 18;100(12):854–61. doi: 10.1093/jnci/djn153. PMID: 18544744. Exclusion: E318544744
Grady D, Cauley JA, Stock JL, . Effect of Raloxifene on all-cause mortality. Am J Med. 2010 May;123(5):469.e1–7. doi: 10.1016/j.amjmed.2009.12.018. PMID: 20399327. Exclusion: E5 - descriptive20399327
Graeser M, Bosse K, Brosig M, . Association of hormone receptor status with grading, age of onset, and tumor size in BRCA1-associated breast cancer. Virchows Arch. 2009 May;454(5):519–24. PMID: 19381686. Exclusion: E319381686
Graham T, Eisen A, Richter S, . Variants of uncertain significance in BRCA testing: Impact on risk perception, worry, prevention, and counseling. J Clin Oncol. 2012;30(15). Exclusion: E5
Gramling R, Anthony D, Frierson G, . The cancer worry chart: a single-item screening measure of worry about developing breast cancer. Psychooncology. 2007 Jun;16(6):593–7. PMID: 17096453. Exclusion: E417096453
Gramling R, Duffy C, David S. Does providing hereditary breast cancer risk assessment support to practicing physicians decrease the likelihood of them discussing such risk with their patients? Genet Med. 2004 Nov–Dec;6(6):542. PMID: 15545753. Exclusion: E415545753
Granader EJ, Dwamena B, Carlos RC. MRI and mammography surveillance of women at increased risk for breast cancer: recommendations using an evidence-based approach. Acad Radiol. 2008 Dec;15(12):1590–5. doi: 10.1016/j.acra.2008.06.006. PMID: 19000876. Exclusion: E919000876
Grann VR, Panageas KS, Whang W, . Decision analysis of prophylactic mastectomy and oophorectomy in BRCA1-positive or BRCA2-positive patients. J Clin Oncol. 1998 Mar;16(3):979–85. doi: 10.1200/jco.1998.16.3.979. PMID: 9508180. Exclusion: E79508180
Graves KD, Peshkin BN, Halbert CH, . Predictors and outcomes of contralateral prophylactic mastectomy among breast cancer survivors. Breast Cancer Res Treat. 2007 Sep;104(3):321–9. PMID: 17066320. Exclusion: E517066320
Green L, Meric-Bernstam F. Risk of ipsilateral and contralateral cancer in BRCA mutation carriers with breast cancer. Curr Breast Cancer Rep. 2011;3(3):151–5. doi: 10.1007/s12609-011-0047-3. PMID: 24587872. Exclusion: E324587872
Green MJ, Peterson SK, Baker MW, . Use of an educational computer program before genetic counseling for breast cancer susceptibility: effects on duration and content of counseling sessions. Genet Med. 2005 Apr;7(4):221–9. PMID: 15834239. Exclusion: H215834239
Green MJ, Peterson SK, Baker MW, . Effect of a computer-based decision aid on knowledge, perceptions, and intentions about genetic testing for breast cancer susceptibility: a randomized controlled trial. JAMA. 2004 Jul;292(4):442–52. PMID: 15280342. Exclusion: H215280342
Greenberg RA. BRCA mutations and childhood cancer. Cancer Biol Ther. 2006 Sep;5(9):1103–4. PMID: 17012842. Exclusion: E617012842
Greene MH, Mai PL, Schwartz PE. Does bilateral salpingectomy with ovarian retention warrant consideration as a temporary bridge to risk-reducing bilateral oophorectomy in BRCA1/2 mutation carriers? Am J Obstet Gynecol. 2011;204(1):19. e1-. e6. PMID: 20619389. Exclusion: E520619389
Greene MH, Piedmonte M, Alberts D, . A prospective study of risk-reducing salpingo-oophorectomy and longitudinal CA-125 screening among women at increased genetic risk of ovarian cancer: design and baseline characteristics: a Gynecologic Oncology Group study. Cancer Epidemiology and Prevention Biomarkers. 2008;17(3):594–604. PMID: 18349277. Exclusion: E618349277
Grenader T, Peretz T, Lifchitz M, . BRCA1 and BRCA2 germ-line mutations and oral contraceptives: to use or not to use. Breast. 2005 Aug;14(4):264–8. PMID: 16085232. Exclusion: E516085232
Grimmett C, Brooks C, Reciosaucedo A, . Information requirements of young women with breast cancer; developing a decision aid around genetic testing-the YoDA BRCA study. Psychooncology. 2016;25:43. doi: 10.1002/pon.4272. PMID: 29955974. Exclusion: E625808921
Grimmett C, Brooks C, Recio-Saucedo A, . Developing a decision aid around genetic testing for young women with breast cancer-the YoDA BRCA Study. Breast Cancer Res Treat. 2016;159(1):183–4. doi: 10.1007/s10549-016-3898-5. Exclusion: E6
Grimmett C, Pickett K, Shepherd J, . Systematic review of the empirical investigation of resources to support decision-making regarding brca1 and brca2 genetic testing in women with breast cancer. Patient Educ Couns. 2017 Nov:No Pagination Specified. doi: 10.1016/j.pec.2017.11.016. PMID: 2017-55349-001. Exclusion: E3
Grindedal EM, Renkonen-Sinisalo L, Vasen H, . Survival in women with MMR mutations and ovarian cancer: a multicentre study in Lynch syndrome kindreds. J Med Genet. 2010 Feb;47(2):99–102. PMID: 19635727. Exclusion: E319635727
Gronwald J, Elsakov P, Gorski B, . High incidence of 4153delA BRCA1 gene mutations in Lithuanian breast- and breast-ovarian cancer families. Breast Cancer Res Treat. 2005 Nov;94(2):111–3. PMID: 16261409. Exclusion: E516261409
Gronwald J, Huzarski T, Byrski B, . Cancer risks in first degree relatives of BRCA1 mutation carriers: effects of mutation and proband disease status. J Med Genet. 2006 May;43(5):424–8. PMID: 16227521. Exclusion: E316227521
Gronwald J, Robidoux A, Kim-Sing C, . Duration of tamoxifen use and the risk of contralateral breast cancer in BRCA1 and BRCA2 mutation carriers. Breast Cancer Res Treat. 2014 Jul;146(2):421–7. doi: 10.1007/s10549-014-3026-3. PMID: 24951267. Exclusion: E324951267
Gronwald J, Tung N, Foulkes WD, . Tamoxifen and contralateral breast cancer in BRCA1 and BRCA2 carriers: an update. Int J Cancer. 2006 May 1;118(9):2281–4. PMID: 16331614. Exclusion: E316331614
Grunda JM, Steg AD, He Q, . Differential expression of breast cancer-associated genes between stage- and age-matched tumor specimens from African- and Caucasian-American Women diagnosed with breast cancer. BMC Res Notes. 2012;5:248. doi: 10.1186/1756-0500-5-248. PMID: 22616718. Exclusion: E322616718
Guenard F, Labrie Y, Ouellette G, . Genetic sequence variations of BRCA1-interacting genes AURKA, BAP1, BARD1 and DHX9 in French Canadian families with high risk of breast cancer. J Hum Genet. 2009 Mar;54(3):152–61. PMID: 19197335. Exclusion: E319197335
Guenard F, Labrie Y, Ouellette G, . Mutational analysis of the breast cancer susceptibility gene BRIP1 /BACH1/FANCJ in high-risk non-BRCA1/BRCA2 breast cancer families. J Hum Genet. 2008;53(7):579–91. PMID: 18414782. Exclusion: E318414782
Guinan EM, McGarrigle SA, Hussey J, . An investigation into the presence of modifiable breast cancer risk factors in BRCA mutation carriers. Current Oncology. 2014;21(2):e387. doi: 10.3747/co.21.2077. Exclusion: E5
Guindalini RS, Song A, Fackenthal JD, . Genetic anticipation in BRCA1/BRCA2 families after controlling for ascertainment bias and cohort effect. Cancer. 2016 06 15;122(12):1913–20. doi: 10.1002/cncr.29972. PMID: 26992017. Exclusion: E326992017
Guo F, Hirth JM, Lin YL, . Use of BRCA Mutation Test in the U.S., 2004-2014. Am J Prev Med. 2017 Jun;52(6):702–9. doi: 10.1016/j.amepre.2017.01.027. PMID: 28342662. Exclusion: 228342662
Gutierrez-Enriquez S, de la Hoya M, Martinez-Bouzas C, . Screening for large rearrangements of the BRCA2 gene in Spanish families with breast/ovarian cancer. Breast Cancer Res Treat. 2007 May;103(1):103–7. PMID: 17063271. Exclusion: E517063271
Haas JS, Kaplan CP, Des Jarlais G, . Perceived risk of breast cancer among women at average and increased risk. J Womens Health. 2005 Nov;14(9):845–51. doi: 10.1089/jwh.2005.14.845. PMID: 16313212. Exclusion: E416313212
Haas JS, Liang S-Y, Hassett MJ, . Gene expression profile testing for breast cancer and the use of chemotherapy, serious adverse effects, and costs of care. Breast Cancer Res Treat. 2011 Nov;130(2):619–26. PMID: 21681446. Exclusion: E321681446
Habel LA, Shak S, Jacobs MK, . A population-based study of tumor gene expression and risk of breast cancer death among lymph node-negative patients. Breast Cancer Res. 2006;8(3):R25. PMID: 16737553. Exclusion: 216737553
Hadley DW, Ashida S, Jenkins JF, . Generation after generation: exploring the psychological impact of providing genetic services through a cascading approach. Genet Med. 2010 Dec;12(12):808–15. PMID: 20921894. Exclusion: E320921894
Hadley DW, Jenkins JF, Steinberg SM, . Perceptions of cancer risks and predictors of colon and endometrial cancer screening in women undergoing genetic testing for Lynch syndrome. J Clin Oncol. 2008 Feb 20;26(6):948–54. PMID: 18281669. Exclusion: E318281669
Hafertepen L, Pastorino A, Morman N, . Barriers to genetic testing in newly diagnosed breast cancer patients: Do surgeons limit testing? Am J Surg. 2017 Jul;214(1):105–10. doi: 10.1016/j.amjsurg.2016.08.012. PMID: 27773374. Exclusion: E327773374
Haffty BG, Choi DH, Goyal S, . Breast cancer in young women (YBC): prevalence of BRCA1/2 mutations and risk of secondary malignancies across diverse racial groups. Ann Oncol. 2009 Oct;20(10):1653–9. PMID: 19491284. Exclusion: E519491284
Haffty BG, Silber A, Matloff E, . Racial differences in the incidence of BRCA1 and BRCA2 mutations in a cohort of early onset breast cancer patients: African American compared to white women. J Med Genet. 2006 Feb;43(2):133–7. PMID: 15983021. Exclusion: E315983021
Hagag E, Shwaireb M, Coffa J, . Screening for BRCA1 large genomic rearrangements in female Egyptian hereditary breast cancer patients. East Mediterr Health J. 2013;19(3):255–62. PMID: 23879077. Exclusion: E523879077
Hagen AI, Kvistad KA, Maehle L, . Sensitivity of MRI versus conventional screening in the diagnosis of BRCA-associated breast cancer in a national prospective series. Breast (Edinburgh, Scotland). 2007 Aug;16(4):367–74. PMID: 17317184. Exclusion: E717317184
Hagen AI, Maehle L, Veda N, . Risk reducing mastectomy, breast reconstruction and patient satisfaction in Norwegian BRCA1/2 mutation carriers. Breast. 2014 Feb;23(1):38–43. doi: 10.1016/j.breast.2013.10.002. PMID: 24210736. Exclusion: E3a24210736
Hagoel L, Neter E, Dishon S, . BRCA1/2 mutation carriers: living with susceptibility. Community Genet. 2003;6(4):242–8. PMID: 15331870. Exclusion: E515331870
Haile RW, Thomas DC, McGuire V, . BRCA1 and BRCA2 mutation carriers, oral contraceptive use, and breast cancer before age 50. Cancer Epidemiol Biomarkers Prev. 2006 Oct;15(10):1863–70. PMID: 17021353. Exclusion: E517021353
Hain JZ, Mange S, Bach J, . Assessment of cancer screening practices after BRCA testing in Michigan. J Clin Oncol. 2013;31(15). Exclusion: E5
Halapy E, Chiarelli AM, Klar N, . Accuracy of breast screening among women with and without a family history of breast and/or ovarian cancer. Breast Cancer Res Treat. 2005;90(3):299–305. PMID: 15830144. Exclusion: E415830144
Halbert C, Kessler L, Collier A, . Psychological functioning in African American women at an increased risk of hereditary breast and ovarian cancer. Clin Genet. 2005 Sep;68(3):222–7. PMID: 16098010. Exclusion: E416098010
Halbert CH, Kessler L, Troxel AB, . Effect of genetic counseling and testing for BRCA1 and BRCA2 mutations in African American women: a randomized trial. Public Health Genomics. 2010;13(7–8):440–8. PMID: 20234119. Exclusion: E3a20234119
Halbert CH, Schwartz MD, Wenzel L, . Predictors of cognitive appraisals following genetic testing for BRCA1 and BRCA2 mutations. J Behav Med. 2004 Aug;27(4):373–92. PMID: 15559734. Exclusion: E315559734
Halbert CH, Stopfer JE, McDonald J, . Long-term reactions to genetic testing for BRCA1 and BRCA2 mutations: does time heal women’s concerns? J Clin Oncol. 2011 November 10, 2011;29(32):4302–6. doi: 10.1200/jco.2010.33.1561. PMID: 21990416. Exclusion: E3a21990416
Hall AE, Chowdhury S, Hallowell N, . Implementing risk-stratified screening for common cancers: a review of potential ethical, legal and social issues. J Public Health (Oxf). 2014 Jun;36(2):285–91. doi: 10.1093/pubmed/fdt078. PMID: 23986542. Exclusion: 223986542
Hall MJ. Genetic services have value beyond BRCA1/2 testing. Cancer Epidemiol Biomarkers Prev. 2009 Feb;18(2):686. PMID: 19208665. Exclusion: E619208665
Hallam S, Govindarajulu S, Huckett B, . BRCA1/2 mutation-associated breast cancer, wide local excision and radiotherapy or unilateral mastectomy: a systematic review. Clin Oncol (R Coll Radiol). 2015 Sep;27(9):527–35. doi: 10.1016/j.clon.2015.06.001. PMID: 26113392. Exclusion: E326113392
Hallowell N, Ardern-Jones A, Eeles R, . Communication about genetic testing in families of male BRCA1/2 carriers and non-carriers: patterns, priorities and problems. Clin Genet. 2005 Jun;67(6):492–502. PMID: 15857416. Exclusion: E315857416
Hallowell N, Ardern-Jones A, Eeles R, . Men’s decision-making about predictive BRCA1/2 testing: the role of family. J Genet Couns. 2005 Jun;14(3):207–17. PMID: 15959652. Exclusion: E315959652
Hallowell N, Foster C, Eeles R, . Accommodating risk: Responses to BRCA1/2 genetic testing of women who have had cancer. Soc Sci Med. 2004 Aug;59(3):553–65. doi: 10.1016/j.socscimed.2003.11.025. PMID: 15144764. Exclusion: E3b15144764
Hallowell N, Mackay J, Richards M, . High-risk premenopausal women’s experiences of undergoing prophylactic oophorectomy: a descriptive study. Genetic Testing. 2004;8(2):148–56. PMID: 15345112. Exclusion: E315345112
Hamann HA, Smith TW, Smith KR, . Interpersonal responses among sibling dyads tested for BRCA1/BRCA2 gene mutations. Health Psychol. 2008 Jan;27(1):100–9. PMID: 18230020. Exclusion: H218230020
Hamann HA, Somers TJ, Smith AW, . Posttraumatic stress associated with cancer history and BRCA1/2 genetic testing. Psychosom Med. 2005 Sep–Oct;67(5):766–72. PMID: 16204436. Exclusion: E3a16204436
Hamann HA, Tiro JA, Sanders JM, . Validity of self-reported genetic counseling and genetic testing use among breast cancer survivors. J Cancer Surviv. 2013 Dec;7(4):624–9. doi: 10.1007/s11764-013-0301-y. PMID: 23975610. Exclusion: E523975610
Hamilton JG. Psychosocial aspects of risk perceptions for cardiovascular disease, breast cancer, and lung cancer in younger and older women: Hamilton, Jada Gabrielle: State U New York at Stony Brook, US; 2010. Exclusion: E4
Hamilton JG, Lobel M, Moyer A. Emotional distress following genetic testing for hereditary breast and ovarian cancer: a meta-analytic review. Health Psychol. 2009 Jul;28(4):510–8. PMID: 19594276. Exclusion: E519594276
Hamilton LJ, Evans AJ, Wilson ARM, . Breast imaging findings in women with BRCA1- and BRCA2-associated breast carcinoma. Clin Radiol. 2004 Oct;59(10):895–902. PMID: 15451348. Exclusion: E315451348
Hamilton R. Genetics: breast cancer as an exemplar. Nurs Clin North Am. 2009 Sep;44(3):327–38. PMID: 19683094. Exclusion: E619683094
Hamilton R, William JK, Bowers BJ, . Life trajectories, genetic testing, and risk reduction decisions in 18-39 year old women at risk for hereditary breast and ovarian cancer. J Genet Couns. 2009 Apr;18(2):147–59. doi: 10.1007/s10897-008-9200-1. PMID: 18979190. Exclusion: E518979190
Hampel H, Bennett RL, Buchanan A, . A practice guideline from the American College of Medical Genetics and Genomics and the National Society of Genetic Counselors: referral indications for cancer predisposition assessment. Genet Med. 2015 Jan;17(1):70–87. doi: 10.1038/gim.2014.147. PMID: 25394175. Exclusion: 225394175
Hampel H SK, Westman JA, . Referral for cancer genetics consultation: a review and compilation of risk assessment criteria. J Med Genet. 2004;41:81–91. PMID: 14757853. Exclusion: 214757853
Han X, Jemal A. Recent patterns in genetic testing for breast and ovarian cancer risk in the U.S. Am J Prev Med. 2017 Oct;53(4):504–7. doi: 10.1016/j.amepre.2017.04.014. PMID: 28669566. Exclusion: 228669566
Hannemann M, Fox R, James M. Ovarian cancer death reduction for women at high risk: workload implications for gynaecology services. J Obstet Gynaecol. 2006 Jan;26(1):42–4. PMID: 16390709. Exclusion: E416390709
Hanoch Y, Miron-Shatz T, Rolison JJ, . Understanding of BRCA1/2 genetic tests results: the importance of objective and subjective numeracy. Psychooncology. 2014 Oct;23(10):1142–8. doi: 10.1002/pon.3537. PMID: 24733657. Exclusion: E424733657
Hansa J, Kannan R, Ghosh SK. Screening of 185DelAG, 1014DelGT and 3889DelAG BRCA1 mutations in breast cancer patients from North-East India. Asian Pac J Cancer Prev. 2012;13(11):5871–4. PMID: 23317271. Exclusion: E323317271
Haque R, Alvarado M, Ahmed SA, . Implementation of next generation cancer gene panel testing in a large HMO. Cancer Res. 2016;76(4)doi: 10.1158/1538-7445.SABCS15-P2-09-04. Exclusion: E5
Haque R, Alvarado M, Ahmed SA, . Triple negative breast cancer and BRCA status: implications for genetic counseling. Cancer Res. 2012;72(24)doi: 10.1158/0008-5472.SABCS12-P3-08-06. Exclusion: E3
Harmsen MG, Arts-de Jong M, Hoogerbrugge N, . Early salpingectomy (TUbectomy) with delayed oophorectomy to improve quality of life as alternative for risk-reducing salpingo-oophorectomy in BRCA1/2 mutation carriers (TUBA study): a prospective non-randomised multicentre study. BMC Cancer. 2015;15:593. doi: 10.1186/s12885-015-1597-y. PMID: 26286255. Exclusion: E626286255
Harmsen MG, Arts-de Jong M, Horstik K, . Very high uptake of risk-reducing salpingo-oophorectomy in BRCA1/2 mutation carriers: A single-center experience. Gynecol Oncol. 2016 Oct;143(1):113–9. doi: 10.1016/j.ygyno.2016.07.104. PMID: 27430397. Exclusion: E527430397
Harmsen MG, IntHout J, Arts-de Jong M, . Salpingectomy with delayed oophorectomy in BRCA1/2 mutation carriers: estimating ovarian cancer risk. Obstet Gynecol. 2016 Jun;127(6):1054–63. doi: 10.1097/AOG.0000000000001448. PMID: 27159752. Exclusion: E727159752
Haroun I, Graham T, Poll A, . Reasons for risk-reducing mastectomy versus MRI-screening in a cohort of women at high hereditary risk of breast cancer. Breast. 2011 Jun;20(3):254–8. PMID: 21306899. Exclusion: E521306899
Harris J, Ward S. A UK collaborative 1-day pilot information and support forum facilitated by a national breast cancer charity and NHS cancer genetic counsellors, for women at high risk, BRCA 1/2 gene carriers and hereditary breast cancer. Eur J Cancer Care (Engl). 2011 Nov;20(6):818–24. doi: 10.1111/j.1365-2354.2011.01273.x. PMID: 21838724. Exclusion: E421838724
Hart SL, Torbit LA, Crangle CJ, . Moderators of cancer-related distress and worry after a pancreatic cancer genetic counseling and screening intervention. Psycho Oncology. 2012 Dec;21(12):1324–30. doi: 10.1002/pon.2026. PMID: 21774034. Exclusion: E321774034
Hartman AR, Daniel BL, Kurian AW, . Breast magnetic resonance image screening and ductal lavage in women at high genetic risk for breast carcinoma. Cancer. 2004;100(3):479–89. PMID: 14745863. Exclusion: E514745863
Hartmann LC, Lindor NM. The role of risk-reducing surgery in hereditary breast and ovarian cancer. N Engl J Med. 2016 Feb 04;374(5):454–68. doi: 10.1056/NEJMra1503523. PMID: 26840135. Exclusion: 226840135
Hashemian AH, Hajizadeh E, Kazemnejad A, . Penetrance of BRCA1/BRCA2 specific gene mutations in Iranian women with breast cancer. Saudi Med J. 2009 Jan;30(1):41–4. PMID: 19139771. Exclusion: E519139771
Hasmad HN, Lai KN, Wen WX, . Evaluation of germline BRCA1 and BRCA2 mutations in a multi-ethnic Asian cohort of ovarian cancer patients. Gynecol Oncol. 2016;141(2):318–22. doi: 10.1016/j.ygyno.2015.11.001. PMID: 26541979. Exclusion: E326541979
Hassan N, Yee YS, Mohd Taib NA, . Evaluating the performance of BOADICEA and Manchester Scoring System for predicting the risk of having a BRCA mutation in an Asian breast cancer cohort. Curr Oncol. 2014;21(2):e389. doi: 10.3747/co.21.2077. Exclusion: E4
Hatcher MB, Fallowfield L, A’Hern R. The psychosocial impact of bilateral prophylactic mastectomy: prospective study using questionnaires and semistructured interviews. BMJ. 2001 Jan 13;322(7278):76. PMID: 11154619. Exclusion: E311154619
Hayden S, Mange S, Duquette D, . Large, Prospective Analysis of the Reasons Patients Do Not Pursue BRCA Genetic Testing Following Genetic Counseling. J Genet Couns. 2017 Aug;26(4):859–65. doi: 10.1007/s10897-016-0064-5. PMID: 28093663. Exclusion: E328093663
HAYES, Inc. Oncotype DX for prognosis of breast cancer recurrence (structured abstract). Health Technol Assess. 2012(1)doi: 10.1002/14651858. Exclusion: E6
He Q-Y, Zhou Y, Wong E, . Proteomic analysis of a preneoplastic phenotype in ovarian surface epithelial cells derived from prophylactic oophorectomies. Gynecol Oncol. 2005 Jul;98(1):68–76. PMID: 15913737. Exclusion: E415913737
Heemskerk-Gerritsen BA, Rookus MA, Aalfs CM, . Improved overall survival after contralateral risk-reducing mastectomy in BRCA1/2 mutation carriers with a history of unilateral breast cancer: a prospective analysis. Int J Cancer. 2015 Feb 1;136(3):668–77. doi: 10.1002/ijc.29032. PMID: 24947112. Exclusion: E3b24947112
Heemskerk-Gerritsen BAM, Kriege M, Seynaeve C. Association of risk-reducing surgery with cancer risks and mortality in BRCA mutation carriers. JAMA. 2010 Dec 22;304(24):2695; author reply -6. PMID: 21177502. Exclusion: E621177502
Heerma van Voss MR, van der Groep P, Bart J, . Lympho-vascular invasion in BRCA related breast cancer compared to sporadic controls. BMC Cancer. 2010;10:145. PMID: 20398395. Exclusion: E320398395
Heerma van Voss MR, van der Groep P, Bart J, . Expression of the stem cell marker ALDH1 in BRCA1 related breast cancer. Cell Oncol. 2011 Feb;34(1):3–10. PMID: 21336637. Exclusion: E321336637
Heiniger L, Butow PN, Coll J, . Long-term outcomes of risk-reducing surgery in unaffected women at increased familial risk of breast and/or ovarian cancer. Fam Cancer. 2015 Mar;14(1):105–15. doi: 10.1007/s10689-014-9759-7. PMID: 25283514. Exclusion: E325283514
Hendrix A, Robinson L, Pritzlaff M, . Identification of BRCA gene mutation carriers through systematic family history screening in mammography populations. Ann Surg Oncol. 2014;21(1):S54. doi: 10.1245/s10434-013-3474-8. Exclusion: E6
Henneman L, Oosterwijk JC, van Asperen CJ, . The effectiveness of a graphical presentation in addition to a frequency format in the context of familial breast cancer risk communication: a multicenter controlled trial. BMC Med Inform Decis Mak. 2013;13:55. doi: 10.1186/1472-6947-13-55. PMID: 23627498. Exclusion: E423627498
Henneman L, Timmermans DR, Bouwman CM, . ‘A low risk is still a risk’: exploring women’s attitudes towards genetic testing for breast cancer susceptibility in order to target disease prevention. Public Health Genomics. 2011;14(4–5):238–47. PMID: 20090298. Exclusion: E420090298
Henriksson K, Olsson H, Kristoffersson U. The need for oncogenetic counselling. Ten years’ experience of a regional oncogenetic clinic. Acta Oncol. 2004;43(7):637–49. PMID: 15545184. Exclusion: E515545184
Herman JD, Appelbaum H. Hereditary breast and ovarian cancer syndrome and issues in pediatric and adolescent practice. J Pediatr Adolesc Gynecol. 2010 Aug;23(4):253–8. PMID: 20632459. Exclusion: E920632459
Hermsen BBJ, van Diest PJ, Berkhof J, . Low prevalence of (pre) malignant lesions in the breast and high prevalence in the ovary and Fallopian tube in women at hereditary high risk of breast and ovarian cancer. Int J Cancer. 2006 Sep 15;119(6):1412–8. PMID: 16615107. Exclusion: E416615107
Hermsen BBJ, von Mensdorff-Pouilly S, Berkhof J, . Serum CA-125 in relation to adnexal dysplasia and cancer in women at hereditary high risk of ovarian cancer. J Clin Oncol. 2007 Apr 10;25(11):1383–9. PMID: 17416858. Exclusion: E517416858
Herrinton LJ, Barlow WE, Yu O, . Efficacy of prophylactic mastectomy in women with unilateral breast cancer: A cancer research network project. J Clin Oncol. 2005;23(19):4275–86. PMID: 15795415. Exclusion: E315795415
Higgins SA, Matloff ET, Rimm DL, . Patterns of reduced nipple aspirate fluid production and ductal lavage cellularity in women at high risk for breast cancer. Breast Cancer Res. 2005;7(6):R1017–22. PMID: 16280052. Exclusion: E516280052
Hilgart, Jennifer S, Coles, . Cancer genetic risk assessment for individuals at risk of familial breast cancer [Systematic Review]. Cochrane Database Syst Rev. 2012(2) PMID: 22336791. Exclusion: E922336791
Hirasawa A, Masuda K, Akahane T, . Experience of risk-reducing salpingo-oophorectomy for a BRCA1 mutation carrier and establishment of a system performing a preventive surgery for hereditary breast and ovarian cancer syndrome in Japan: our challenges for the future. Jpn J Clin Oncol. 2013 May;43(5):515–9. doi: 10.1093/jjco/hyt036. PMID: 23487443. Exclusion: E723487443
Hirst JE, Gard GB, McIllroy K, . High rates of occult fallopian tube cancer diagnosed at prophylactic bilateral salpingo-oophorectomy. Int J Gynecol Cancer. 2009 Jul;19(5):826–9. PMID: 19574767. Exclusion: E519574767
Ho L, Fivecoat H, Wang J, . Alzheimer’s disease biomarker discovery in symptomatic and asymptomatic patients: Experimental approaches and future clinical applications. Exp Gerontol. 2010;45(1):15–22. PMID: 19796674. Exclusion: E319796674
Hofvind S, Ursin G, Tretli S, . Breast cancer mortality in participants of the Norwegian Breast Cancer Screening Program. Cancer. 2013 Sep 1;119(17):3106–12. doi: 10.1002/cncr.28174. PMID: 23720226. Exclusion: E423720226
Holbert JM. The relationship of involvement in a support group, communication patterns, and marital satisfaction in couples with a genetic mutation for breast and ovarian cancer (BRCA): Holbert, Joanne M: U Akron, US; 2012. Exclusion: E4
Holland ML, Huston A, Noyes K. Cost-effectiveness of testing for breast cancer susceptibility genes. Value Health. 2009 Mar–Apr;12(2):207–16. PMID: 18647256. Exclusion: E718647256
Hollander D. Pill use is associated with reductions in overall risk of cancer and in risk of main gynecologic cancers. Perspectives on Sexual and Reproductive Health. 2008 Mar;40(1):52–3. doi: 10.1363/4005208. Exclusion: E6
Holm J, Li J, Darabi H, . Associations of breast cancer risk prediction tools with tumor characteristics and metastasis. J Clin Oncol. 2016 Jan 20;34(3):251–8. doi: 10.1200/JCO.2015.63.0624. PMID: 26628467. Exclusion: E326628467
Hoogerbrugge N, Kamm YJL, Bult P, . The impact of a false-positive MRI on the choice for mastectomy in BRCA mutation carriers is limited. Ann Oncol. 2008 Apr;19(4):655–9. PMID: 18096566. Exclusion: E318096566
Hooker GW, Leventhal K-G, DeMarco T, . Longitudinal changes in patient distress following interactive decision aid use among BRCA1/2 carriers: a randomized trial. Med Decis Making. 2011 May–Jun;31(3):412–21. PMID: 20876346. Exclusion: E420876346
Hoover DJ, Paragi PR, Santoro E, . Prophylactic mastectomy in high risk patients: a practice-based review of the indications. Do we follow guidelines? Breast Dis. 2010 Jan 1;31(1):19–27. PMID: 20519802. Exclusion: E320519802
Hopper JL, Jenkins MA, Dowty JG, . Using tumour pathology to identify people at high genetic risk of breast and colorectal cancers. Pathology. 2012 Feb;44(2):89–98. PMID: 22198256. Exclusion: E622198256
Hopwood P. Psychological care of women with a family history of breast cancer. Psicooncologia. 2005;2(2–3):293–302. Exclusion: E9
Hoskins LM, Greene MH. Anticipatory loss and early mastectomy for young female BRCA1/2 mutation carriers. Qual Health Res. 2012 Dec;22(12):1633–46. doi: 10.1177/1049732312458182. PMID: 22927701. Exclusion: E522927701
Hosmer DW, Lemeshow S. Applied Logistic Regression. 2nd ed. Hoboken, NJ: John Wiley & Sons, Inc.; 2000. Exclusion: 2
Howard AF, Balneaves LG, Bottorff JL, . Preserving the self: the process of decision making about hereditary breast cancer and ovarian cancer risk reduction. Qual Health Res. 2011 Apr;21(4):502–19. PMID: 20980697. Exclusion: E520980697
Howard AF, Bottorff JL, Balneaves LG, . Women’s constructions of the ‘right time’ to consider decisions about risk-reducing mastectomy and risk-reducing oophorectomy. BMC Womens Health. 2010;10:24. PMID: 20687957. Exclusion: E520687957
Howard-McNatt M, Schroll RW, Hurt GJ, . Contralateral prophylactic mastectomy in breast cancer patients who test negative for BRCA mutations. Am J Surg. 2011 Sep;202(3):298–302. PMID: 21871984. Exclusion: E321871984
Howarth DR, Lum SS, Esquivel P, . Initial results of multigene panel testing for hereditary breast and ovarian cancer and Lynch Syndrome. Am Surg. 2015 Oct;81(10):941–4. PMID: 26463285. Exclusion: E526463285
Howell A, Bundred NJ, Cuzick J, . Response and resistance to the endocrine prevention of breast cancer. Adv Exp Med Biol. 2008;617:201–11. PMID: 18497044. Exclusion: E618497044
Hu Y, Ghosh S, Amleh A, . Modulation of aromatase expression by BRCA1: a possible link to tissue-specific tumor suppression. Oncogene. 2005 Dec 15;24(56):8343–8. PMID: 16170371. Exclusion: E516170371
Hulbert-Williams N, Neal R, Morrison V, . Anxiety, depression and quality of life after cancer diagnosis: What psychosocial variables best predict how patients adjust? Psychooncology. 2012 Aug;21(8):857–67. doi: 10.1002/pon.1980. PMID: 21695744. Exclusion: E321695744
Huo D, Senie RT, Daly M, . Prediction of BRCA mutations using the BRCAPRO model in clinic-based African American, Hispanic, and other minority families in the United States. J Clin Oncol. 2009 Mar 10;27(8):1184–90. PMID: 19188678. Exclusion: E419188678
Hurley R. Angelina Jolie’s double mastectomy and the question of who owns our genes. BMJ. 2013;346:f3340. doi: 10.1136/bmj.f3340. PMID: 23697674. Exclusion: 223697674
Hurtado-de-Mendoza A, Jackson MC, Anderson L, . The role of knowledge on genetic counseling and testing in black cancer survivors at increased risk of carrying a BRCA1/2 mutation. J Genet Couns. 2017 Feb;26(1):113–21. doi: 10.1007/s10897-016-9986-1. PMID: 27402168. Exclusion: E3a27402168
Huzarski T, Byrski T, Gronwald J, . The impact of oophorectomy on survival after breast cancer in BRCA1-positive breast cancer patients. Breast Cancer Res Treat. 2016 Apr;156(2):371–8. doi: 10.1007/s10549-016-3749-4. PMID: 26983446. Exclusion: E326983446
Hwang ES, McLennan JL, Moore DH, . Ductal carcinoma in situ in BRCA mutation carriers. J Clin Oncol. 2007 Feb 20;25(6):642–7. PMID: 17210933. Exclusion: E517210933
Hyland F, Kinmonth AL, Marteau TM, . Raising concerns about family history of breast cancer in primary care consultations: prospective, population based study. Women’s Concerns Study Group. BMJ. 2001 Jan 06;322(7277):27–8. PMID: 11141150. Exclusion: E411141150
Iatrakis G, Iavazzo C, Zervoudis S, . The role of oral contraception use in the occurrence of breast cancer. A retrospective study of 405 patients. Clin Exp Obstet Gynecol. 2011;38(3):225–7. PMID: 21995151. Exclusion: E521995151
Ibrahim SS, Hafez EE, Hashishe MM. Presymptomatic breast cancer in Egypt: role of BRCA1 and BRCA2 tumor suppressor genes mutations detection. J Exp Clin Cancer Res. 2010;29:82. PMID: 20579331. Exclusion: E520579331
Improvement IfCS. Magnetic resonance imaging (MRI) for the detection of breast abnormalities (structured abstract). Health Technol Assess. 2012(1)doi: 10.1002/14651858. Exclusion: E6
Infante M, Duran M, Lasa A, . Two founder BRCA2 mutations predispose to breast cancer in young women. Breast Cancer Res Treat. 2010 Jul;122(2):567–71. PMID: 19949853. Exclusion: E519949853
Ingham SL, Sperrin M, Baildam A, . Risk-reducing surgery increases survival in BRCA1/2 mutation carriers unaffected at time of family referral. Breast Cancer Res Treat. 2013 Dec;142(3):611–8. doi: 10.1007/s10549-013-2765-x. PMID: 24249359. Exclusion: H224249359
Ingham SL, Warwick J, Byers H, . Is multiple SNP testing in BRCA2 and BRCA1 female carriers ready for use in clinical practice? Results from a large genetic centre in the UK. Clin Genet. 2013 Jul;84(1):37–42. doi: 10.1111/cge.12035. PMID: 23050611. Exclusion: E423050611
Iodice S, Barile M, Rotmensz N, . Oral contraceptive use and breast or ovarian cancer risk in BRCA1/2 carriers: a meta-analysis. Eur J Cancer. 2010;46(12):2275–84. PMID: 20537530. Exclusion: E520537530
Iorio MV, Casalini P, Piovan C, . Breast cancer and microRNAs: therapeutic impact. Breast. 2011 Oct;20: Suppl 3:S63–70. PMID: 22015296. Exclusion: E922015296
Isern AE, Loman N, Malina J, . Histopathological findings and follow-up after prophylactic mastectomy and immediate breast reconstruction in 100 women from families with hereditary breast cancer. Eur J Surg Oncol. 2008 Oct;34(10):1148–54. PMID: 18434071. Exclusion: E3b18434071
Issa AM, Chaudhari VS, Marchant GE. The value of multigene predictors of clinical outcome in breast cancer: an analysis of the evidence. Expert Rev Mol Diagn. 2015 Feb;15(2):277–86. doi: 10.1586/14737159.2015.983476. PMID: 25479414. Exclusion: E325479414
Issa J-PJ, Garber JE. Time to think outside the (genetic) box. Cancer Prevention Research. 2011 Jan;4(1):6–8. PMID: 21205738. Exclusion: E521205738
Iwamoto T, Lee J-S, Bianchini G, . First generation prognostic gene signatures for breast cancer predict both survival and chemotherapy sensitivity and identify overlapping patient populations. Breast Cancer Res Treat. 2011 Nov;130(1):155–64. PMID: 21833625. Exclusion: E321833625
Jacobi CE, van Ierland Y, van Asperen CJ, . Prediction of BRCA1/2 mutation status in patients with ovarian cancer from a hospital-based cohort. Genet Med. 2007 Mar;9(3):173–9. PMID: 17413421. Exclusion: E317413421
Jacobs AS, Schwartz MD, Valdimarsdottir H, . Patient and genetic counselor perceptions of in-person versus telephone genetic counseling for hereditary breast/ovarian cancer. Fam Cancer. 2016 10;15(4):529–39. doi: 10.1007/s10689-016-9900-x. PMID: 26969308. Exclusion: E526969308
Jacobs IJ, Menon U, Ryan A, . Ovarian cancer screening and mortality in the UK Collaborative Trial of Ovarian Cancer Screening (UKCTOCS): a randomised controlled trial. Lancet (london, england). 2016;387(10022):945–56. PMID: 26707054. Exclusion: E326707054
Jacoby VL, Grady D, Wactawski-Wende J, . Oophorectomy vs ovarian conservation with hysterectomy: cardiovascular disease, hip fracture, and cancer in the Women’s Health Initiative Observational Study. Arch Intern Med. 2011 Apr 25;171(8):760–8. PMID: 21518944. Exclusion: E321518944
Jakubowska A, Jaworska K, Cybulski C, . Do BRCA1 modifiers also affect the risk of breast cancer in non-carriers? Eur J Cancer. 2009 Mar;45(5):837–42. PMID: 19071013. Exclusion: E519071013
Jara L, Ampuero S, Santibanez E, . BRCA1 and BRCA2 mutations in a South American population. Cancer Genet Cytogenet. 2006 Apr 1;166(1):36–45. PMID: 16616110. Exclusion: E516616110
Jatoi I, Benson JR. Management of women with a hereditary predisposition for breast cancer. Future Oncology. 2016;12(19):2277–88. doi: 10.2217/fon-2016-0186. Exclusion: E627384952
Jernstrom H, Sandberg T, Bageman E, . Insulin-like growth factor-1 genotype predicts breast volume after pregnancy and hormonal contraception and is associated with circulating insulin-like growth factor-1 levels: implications for risk of early-onset breast cancer in young women from hereditary breast cancer families. Int J Gynecol Cancer. 2006;16: Suppl 2:497. PMID: 17010055. Exclusion: E517010055
Jervis S, Song H, Lee A, . A risk prediction algorithm for ovarian cancer incorporating BRCA1, BRCA2, common alleles and other familial effects. J Med Genet. 2015 Jul;52(7):465–75. doi: 10.1136/jmedgenet-2015-103077. PMID: 26025000. Exclusion: E526025000
Jhaveri KL, Patil S, Khasraw M, . Risk of breast cancer (BC) after BRCA-mutation associated ovarian cancer (BRCA-OC): Memorial Sloan-Kettering Cancer Center (MSKCC) experience. J Clin Oncol. 2011;29(15). Exclusion: E4
Johansen N, Liavaag AH, Tanbo TG, . Sexual activity and functioning after risk-reducing salpingo-oophorectomy: impact of hormone replacement therapy. Gynecol Oncol. 2016 Jan;140(1):101–6. doi: 10.1016/j.ygyno.2015.11.016. PMID: 26597462. Exclusion: E326597462
Johnatty SE, Beesley J, Chen X, . The BARD1 Cys557Ser polymorphism and breast cancer risk: an Australian case-control and family analysis. Breast Cancer Res Treat. 2009 May;115(1):145–50. PMID: 18481171. Exclusion: E518481171
Johnson N, Lancaster T, Fuller A, . The prevalence of a family history of cancer in general practice. Fam Pract. 1995 Sep;12(3):287–9. PMID: 8536831. Exclusion: 28536831
Jones A. Feasibility of tamoxifen in chemoprevention of breast cancer (meeting abstract). Br J Cancer. 1990;62:(Suppl 12):3. Exclusion: E6
Jones T, Lockhart JS, Mendelsohn-Victor KE, . Use of cancer genetics services in African-American young breast cancer survivors. Am J Prev Med. 2016 Oct;51(4):427–36. doi: 10.1016/j.amepre.2016.03.016. PMID: 27117712. Exclusion: E527117712
Joosse SA, van Beers EH, Tielen IHG, . Prediction of BRCA1-association in hereditary non-BRCA1/2 breast carcinomas with array-CGH. Breast Cancer Res Treat. 2009 Aug;116(3):479–89. PMID: 18704682. Exclusion: E318704682
Joseph G, Kaplan C, Luce J, . Efficient identification and referral of low-income women at high risk for hereditary breast cancer: a practice-based approach. Public Health Genomics. 2012;15(3–4):172–80. PMID: 22488460. Exclusion: E522488460
Joseph M, Rab F, Panabaker K, . Anger, frustration, and regret among women with a strong family history of breast/ovarian carcinoma who subsequent to their breast cancer diagnosis tested BRCA-positive. Curr Oncol. 2014;21(2):e374. doi: 10.3747/co.21.2077. Exclusion: E3
Joseph M, Rab F, Panabaker K, . Feelings of women with strong family histories who subsequent to their breast cancer diagnosis tested BRCA positive. Int J Gynecol Cancer. 2015 May;25(4):584–92. doi: 10.1097/IGC.0000000000000403. PMID: 25675043. Exclusion: E325675043
Juan AS, Wakefield CE, Kasparian NA, . Development and pilot testing of a decision aid for men considering genetic testing for breast and/or ovarian cancer-related mutations (BRCA1/2). Genetic Testing. 2008 Dec;12(4):523–32. PMID: 19072564. Exclusion: E319072564
Judkins T, Rosenthal E, Arnell C, . Clinical significance of large rearrangements in BRCA1 and BRCA2. Cancer. 2012 Nov 1;118(21):5210–6. doi: 10.1002/cncr.27556. PMID: 22544547. Exclusion: 222544547
Kaas R, Verhoef S, Wesseling J, . Prophylactic mastectomy in BRCA1 and BRCA2 mutation carriers: very low risk for subsequent breast cancer. Ann Surg. 2010 Mar;251(3):488–92. PMID: 20134318. Exclusion: E720134318
Kadouri L, Hubert A, Rotenberg Y, . Cancer risks in carriers of the BRCA1/2 Ashkenazi founder mutations. J Med Genet. 2007 Jul;44(7):467–71. PMID: 17307836. Exclusion: E317307836
Kamal AH, Loprinzi CL, Reynolds C, . Breast medical oncologists’ use of standard prognostic factors to predict a 21-gene recurrence score. Oncologist. 2011;16(10):1359–66. PMID: 21934103. Exclusion: E321934103
Kamara D, Weil J, Youngblom J, . Cancer counseling of low-income limited english proficient latina women using medical interpreters: Implications for shared decision-making. J Genet Couns. 2017 Aug:No Pagination Specified. doi: 10.1007/s10897-017-0132-5. PMID: 28791541. Exclusion: E528791541
Kandel MJ, Stadler Z, Masciari S, . Prevalence of BRCA1 mutations in triple negative breast cancer (BC). J Clin Oncol; 2006. 24. p. 508. Exclusion: E6
Kang E, Park SK, Lee JW, . KOHBRA BRCA risk calculator (KOHCal): a model for predicting BRCA1 and BRCA2 mutations in Korean breast cancer patients. J Hum Genet. 2016 May;61(5):365–71. doi: 10.1038/jhg.2015.164. PMID: 26763880. Exclusion: E426763880
Kang E, Park SK, Yang JJ, . Accuracy of BRCA1/2 mutation prediction models in Korean breast cancer patients. Breast Cancer Res Treat. 2012 Aug;134(3):1189–97. doi: 10.1007/s10549-012-2022-8. PMID: 22438049. Exclusion: E422438049
Kang HH, Williams R, Leary J, . Evaluation of models to predict BRCA germline mutations. Br J Cancer. 2006 Oct 9;95(7):914–20. PMID: 17016486. Exclusion: E3a17016486
Kang HP, Maguire JR, Chu CS, . Design and validation of a next generation sequencing assay for hereditary BRCA1 and BRCA2 mutation testing. PeerJ. 2016;2016(6)doi: 10.7717/peerj.2162. PMID: 27375968. Exclusion: E527375968
Kang P, Mariapun S, Phuah SY, . Large BRCA1 and BRCA2 genomic rearrangements in Malaysian high risk breast-ovarian cancer families. Breast Cancer Res Treat. 2010 Nov;124(2):579–84. PMID: 20617377. Exclusion: E520617377
Kaplan CP, Haas JS, Perez-Stable EJ, . Factors affecting breast cancer risk reduction practices among California physicians. Prev Med. 2005 Jul;41(1):7–15. PMID: 15916987. Exclusion: E315916987
Kapoor NS, Curcio LD, Banks K, . Multi-gene panel testing detects equal rates of pathogenic BRCA1/2 mutations and has a higher diagnostic yield compared to limited BRCA1/2 analysis alone in patients at risk for hereditary breast cancer. Ann Surg Oncol. 2015;22(2):12–3. doi: 10.1245/s10434-015-4561-9. PMID: 26219241. Exclusion: E626219241
Kapoor NS, Curcio LD, Blakemore CA, . Multigene panel testing detects equal rates of pathogenic BRCA1/2 mutations and has a higher diagnostic yield compared to limited BRCA1/2 analysis alone in patients at risk for hereditary breast cancer. Ann Surg Oncol. 2015 Oct;22(10):3282–8. doi: 10.1245/s10434-015-4754-2. PMID: 26219241. Exclusion: E3a26219241
Kapoor NS, Curcio LD, Blakemore CA, . Benefits and safety of multigene panel testing in patients at risk for hereditary breast cancer. J Clin Oncol. 2015;33(28). Exclusion: E6
Kapoor NS, Curcio LD, Patrick M, . Multi-gene panel testing and the cancers identified in patients at risk for hereditary breast cancer. Cancer Res. 2016;76(4)doi: 10.1158/1538-7445.SABCS15-PD7-05. Exclusion: E6
Karlan BY, Baldwin RL, Lopez-Luevanos E, . Peritoneal serous papillary carcinoma, a phenotypic variant of familial ovarian cancer: implications for ovarian cancer screening. Am J Obstet Gynecol. 1999;180(4):917–28. PMID: 10203660. Exclusion: E310203660
Katapodi MC, Munro ML, Pierce PF, . Psychometric testing of the decisional conflict scale: genetic testing hereditary breast and ovarian cancer. Nurs Res. 2011 Nov–Dec;60(6):368–77. doi: 10.1097/NNR.0b013e3182337dad. PMID: 22048556. Exclusion: E422048556
Katapodi MC, Northouse LL, Milliron KJ, . Individual and family characteristics associated with BRCA1/2 genetic testing in high-risk families. Psychooncology. 2013 Jun;22(6):1336–43. doi: 10.1002/pon.3139. PMID: 22826208. Exclusion: E522826208
Katki HA. Effect of misreported family history on Mendelian mutation prediction models. Biometrics. 2006 Jun;62(2):478–87. PMID: 16918912. Exclusion: E416918912
Katki HA. Incorporating medical interventions into carrier probability estimation for genetic counseling. BMC Med Genet. 2007;8:13. PMID: 17378937. Exclusion: E417378937
Kauff ND, Domchek SM, Friebel TM, . Risk-reducing salpingo-oophorectomy for the prevention of BRCA1- and BRCA2-associated breast and gynecologic cancer: a multicenter, prospective study. J Clin Oncol. 2008 Mar 10;26(8):1331–7. PMID: 18268356. Exclusion: E3a18268356
Kauff ND, Satagopan JM, Robson ME, . Risk-reducing salpingo-oophorectomy in women with a BRCA1 or BRCA2 mutation. N Engl J Med. 2002;346(21):1609–15. PMID: 12023992. Exclusion: E3a12023992
Keating NL, Stoeckert KA, Regan MM, . Physicians’ experiences with BRCA1/2 testing in community settings. J Clin Oncol. 2008 Dec 10;26(35):5789–96. PMID: 19001322. Exclusion: E519001322
Keenan KF, Simpson SA, Wilson BJ, . ‘It’s their blood not mine’: who’s responsible for (not) telling relatives about genetic risk? Health Risk Soc. 2005 Sep;7(3):209–26. doi: 10.1080/13698570500229606. Exclusion: E4
Kelly K, Leventhal H, Andrykowski M, . The decision to test in women receiving genetic counseling for BRCA1 and BRCA2 mutations. J Genet Couns. 2004 Jun;13(3):237–57. PMID: 15604634. Exclusion: E3a15604634
Kelly K, Leventhal H, Andrykowski M, . Using the common sense model to understand perceived cancer risk in individuals testing for BRCA1/2 mutations. Psychooncology. 2005 Jan;14(1):34–48. PMID: 15386791. Exclusion: E315386791
Kelly K, Leventhal H, Marvin M, . Cancer genetics knowledge and beliefs and receipt of results in Ashkenazi Jewish individuals receiving counseling for BRCA1/2 mutations. Cancer Control. 2004 Jul–Aug;11(4):236–44. PMID: 15284715. Exclusion: E3a15284715
Kelly KM, Ellington L, Schoenberg N, . Linking genetic counseling content to short-term outcomes in individuals at elevated breast cancer risk. J Genet Couns. 2014 Oct;23(5):838–48. doi: 10.1007/s10897-014-9705-8. PMID: 24671341. Exclusion: E324671341
Kelly KM, Ellington L, Schoenberg N, . Genetic counseling content: how does it impact health behavior? J Behav Med. 2015 Oct;38(5):766–76. doi: 10.1007/s10865-014-9613-2. PMID: 25533642. Exclusion: E525533642
Kelly KM, Love MM, Pearce KA, . Cancer risk assessment by rural and Appalachian family medicine physicians. J Rural Health. 2009 Fal;25(4):372–7. doi: 10.1111/j.1748-0361.2009.00246.x. PMID: 19780917. Exclusion: E319780917
Kenen R, Ardern-Jones A, Eeles R. We are talking, but are they listening? Communication patterns in families with a History of Breast/Ovarian Cancer (HBOC). Psycho Oncology. 2004 May;13(5):335–45. doi: 10.1002/pon.745. PMID: 15133774. Exclusion: E415133774
Kenen R, Ardern-Jones A, Eeles R. “Social separation” among women under 40 years of age diagnosed with breast cancer and carrying a BRCA1 or BRCA2 mutation. J Genet Couns. 2006 Jun;15(3):149–62. PMID: 16724273. Exclusion: E3a16724273
Kenen R, Ardern-Jones A, Lynch E, . Ownership of uncertainty: healthcare professionals counseling and treating women from hereditary breast and ovarian cancer families who receive an inconclusive BRCA1/2 genetic test result. Genet Test Mol Biomarkers. 2011 Apr;15(4):243–50. PMID: 21254913. Exclusion: E521254913
Kenen RH, Shapiro PJ, Friedman S, . Peer-support in coping with medical uncertainty: Discussion of oophorectomy and hormone replacement therapy on a web-based message board. Psycho Oncology. 2007 Aug;16(8):763–71. doi: 10.1002/pon.1152. PMID: 17230435. Exclusion: E517230435
Kenen RH, Shapiro PJ, Hantsoo L, . Women with BRCA1 or BRCA2 mutations renegotiating a post-prophylactic mastectomy identity: self-image and self-disclosure. J Genet Couns. 2007 Dec;16(6):789–98. PMID: 17917796. Exclusion: E517917796
Kentwell M, Dow E, Antill Y, . Mainstreaming cancer genetics: A model integrating germline BRCA testing into routine ovarian cancer clinics. Gynecol Oncol. 2017;145(1):130–6. doi: 10.1016/j.ygyno.2017.01.030. PMID: 28162234. Exclusion: E328162234
Keogh LA, Hopper JL, Rosenthal D, . Australian clinicians and chemoprevention for women at high familial risk for breast cancer. Hered Cancer Clin Pract. 2009;7(1) PMID: 19409108. Exclusion: E519409108
Kerber RA, Slattery ML. Comparison of self-reported and database-linked family history of cancer data in a case-control study. Am J Epidemiol. 1997 Aug 1;146(3):244–8. PMID: 9247008. Exclusion: 29247008
Kershberg HB, Alvarado M, Natoli JL, . Use of the electronic medical record (EMR) to identify women at increased risk for hereditary breast and ovarian cancer (HBOC). J Clin Oncol. 2013;31(31). Exclusion: E4
Keshavarzi F, Javadi GR, Zeinali S. BRCA1 and BRCA2 germline mutations in 85 Iranian breast cancer patients. Fam Cancer. 2012 Mar;11(1):57–67. PMID: 21918854. Exclusion: E521918854
Kessenich CR, Bacher K, Moore PA. Genetic testing for BRCA1 and BRCA2 genes. Nurse Pract. 2014 Jun 15;39(6):8–10. doi: 10.1097/01.NPR.0000446876.99650.eb. PMID: 24841458. Exclusion: E924841458
Kessler L, Collier A, Brewster K, . Attitudes about genetic testing and genetic testing intentions in African American women at increased risk for hereditary breast cancer. Genet Med. 2005 Apr;7(4):230–8. PMID: 15834240. Exclusion: E515834240
Kessler L, Domchek S, Stopfer J, . BRCA1 and BRCA2 risk perceptions among African American women at increased risk for hereditary breast-ovarian cancer. Community Genet. 2008;11(4):193–200. PMID: 18417966. Exclusion: E518417966
Khansa I, Wang D, Coriddi M, . Timing of prophylactic hysterectomy-oophorectomy, mastectomy, and microsurgical breast reconstruction in BRCA1 and BRCA2 carriers. Microsurgery. 2014 May;34(4):271–6. doi: 10.1002/micr.22195. PMID: 24123194. Exclusion: E324123194
Khatcheressian JL, Wolff AC, Smith TJ, . American Society of Clinical Oncology 2006 update of the breast cancer follow-up and management guidelines in the adjuvant setting. J Clin Oncol. 2006 Nov 1;24(31):5091–7. PMID: 17033037. Exclusion: E317033037
Kiely BE, Hossack LK, Shadbolt CL, . Practicalities of developing a breast magnetic resonance imaging screening service for women at high risk for breast cancer. ANZ J Surg. 2011 Oct;81(10):688–93. PMID: 22295308. Exclusion: E322295308
Kiely BE, Jenkins MA, McKinley JM, . Contralateral risk-reducing mastectomy in BRCA1 and BRCA2 mutation carriers and other high-risk women in the Kathleen Cuningham Foundation Consortium for Research into Familial Breast Cancer (kConFab). Breast Cancer Res Treat. 2010 Apr;120(3):715–23. PMID: 19669874. Exclusion: E3b19669874
Kieran S, Loescher LJ, Lim KH. The role of financial factors in acceptance of clinical BRCA genetic testing. Genetic Testing. 2007;11(1):101–10. PMID: 17394399. Exclusion: E517394399
Kim J, Skrzynia C, Mersereau JE. A pilot study of BRCA mutation carriers’ knowledge about the clinical impact of prophylactic-oophorectomy and views on fertility consultation: a single-center pilot study. J Genet Couns. 2015 Feb;24(1):149–57. doi: 10.1007/s10897-014-9747-y. PMID: 25120035. Exclusion: E525120035
Kim SH, Kim MK. Clinical significance of BRCA gene testing among ovarian carcinoma: Can advanced staging be an obstacle for acceptance of counseling? Ann Oncol. 2015;26:ix81. doi: 10.1093/annonc/mdv525.05. Exclusion: E6
King MC, Wieand S, Hale K, . Tamoxifen and breast cancer incidence among women with inherited mutations in BRCA1 and BRCA2: National Surgical Adjuvant Breast and Bowel Project (NSABP-P1) Breast Cancer Prevention Trial. JAMA. 2001 Nov 14;286(18):2251–6. PMID: 11710890. Exclusion: E611710890
King TA, Sakr R, Patil S, . Clinical management factors contribute to the decision for contralateral prophylactic mastectomy. J Clin Oncol. 2011 Jun 1;29(16):2158–64. PMID: 21464413. Exclusion: E321464413
Kinney AY, Butler KM, Schwartz MD, . Expanding access to BRCA1/2 genetic counseling with telephone delivery: a cluster randomized trial. J Natl Cancer Inst. 2014 Dec;106(12)doi: 10.1093/jnci/dju328. PMID: 25376862. Exclusion: E3a25376862
Kinney AY, Gammon A, Coxworth J, . Exploring attitudes, beliefs, and communication preferences of Latino community members regarding BRCA1/2 mutation testing and preventive strategies. Genet Med. 2010 Feb;12(2):105–15. PMID: 20061960. Exclusion: E520061960
Kinney AY, Steffen LE, Brumbach BH, . Randomized noninferiority trial of telephone delivery of BRCA1/2 genetic counseling compared with in-person counseling: 1-Year follow-up. J Clin Oncol. 2016 Aug 20;34(24):2914–24. doi: 10.1200/JCO.2015.65.9557. PMID: 27325848. Exclusion: E3a27325848
Kinsinger L, Harris R, Lewis C, . Chemoprevention of breast cancer (structured abstract). Health Technol Assess. 2012(1)doi: 10.1002/14651858. Exclusion: E6
Kirchhoff T, Gaudet MM, Antoniou AC, . Breast cancer risk and 6q22.33: combined results from Breast Cancer Association Consortium and Consortium of Investigators on Modifiers of BRCA1/2. PLoS ONE [Electronic Resource]. 2012;7(6):e35706. doi: 10.1371/journal.pone.0035706. PMID: 22768030. Exclusion: E522768030
Klitzman R. “Am I my genes?”: Questions of identity among individuals confronting genetic disease. Genet Med. 2009 Dec;11(12):880–9. PMID: 20010365. Exclusion: 220010365
Klitzman RL. Am I my genes? Confronting fate and family secrets in the age of genetic testing. New York, NY: Oxford University Press; US; 2012. Exclusion: E3
Klitzman RL, Sweeney MM. “In sickness and in health”? Disclosures of genetic risks in dating. J Genet Couns. 2011 Feb;20(1):98–112. doi: 10.1007/s10897-010-9331-z. PMID: 20890722. Exclusion: E320890722
Koehly LM, Peters JA, Kenen R, . Characteristics of health information gatherers, disseminators, and blockers within families at risk of hereditary cancer: implications for family health communication interventions. Am J Public Health. 2009 Dec;99(12):2203–9. doi: 10.2105/AJPH.2008.154096. PMID: 19833996. Exclusion: E519833996
Koehly LM, Peters JA, Kuhn N, . Sisters in hereditary breast and ovarian cancer families: communal coping, social integration, and psychological well-being. Psychooncology. 2008 Aug;17(8):812–21. PMID: 18688790. Exclusion: E418688790
Kohut K, D’Mello L, Bancroft EK, . Implications for cancer genetics practice of pro-actively assessing family history in a General Practice cohort in North West London. Fam Cancer. 2012 Mar;11(1):107–13. PMID: 22016143. Exclusion: E522016143
Kolone V. Understanding intention to test for genetic breast and ovarian cancer risk: A path model: Kolone, Valerie: Alliant International U, Los Angeles, US; 2004. Exclusion: E5
Kolor K, Chen Z, Grosse SD, . BRCA genetic testing and receipt of preventive interventions among women aged 18-64 years with employer sponsored health insurance in nonmetropolitan and metropolitan areas - United States, 2009-2014. MMWR Surveill Summ. 2017 Sep 8;66(15):1–11. doi: 10.15585/mmwr.ss6615a1. PMID: 28880857. Exclusion: E528880857
Kong SY, Cho E, Lee J, . Next generation sequencing-based analysis of BRCA1 and BRCA2 genes: applicability for fast diagnostics of large samples. Cancer Res. 2015;75(9)doi: 10.1158/1538-7445.SABCS14-P4-12-12. Exclusion: E5
Konstantopoulou I, Pertesi M, Fostira F, . Hereditary cancer predisposition syndromes and preimplantation genetic diagnosis: where are we now? J BUON. 2009 Sep;14: Suppl 1:S187–92. PMID: 19785065. Exclusion: E919785065
Konstantopoulou I, Rampias T, Ladopoulou A, . Greek BRCA1 and BRCA2 mutation spectrum: Two BRCA1 mutations account for half the carriers found among high-risk breast/ovarian cancer patients. Breast Cancer Res Treat. 2008;107(3):431–41. PMID: 17453335. Exclusion: E517453335
Koslow S, Pharmer LA, Scott AM, . Long-term patient-reported satisfaction after contralateral prophylactic mastectomy and implant reconstruction. Ann Surg Oncol. 2013 Oct;20(11):3422–9. doi: 10.1245/s10434-013-3026-2. PMID: 23720070. Exclusion: E323720070
Kossman DA, Williams NI, Domchek SM, . Exercise lowers estrogen and progesterone levels in premenopausal women at high risk of breast cancer. J Appl Physiol. 2011 Dec;111(6):1687–93. PMID: 21903887. Exclusion: E421903887
Kotsopoulos J, Ghadirian P, El-Sohemy A, . The CYP1A2 genotype modifies the association between coffee consumption and breast cancer risk among BRCA1 mutation carriers. Cancer Epidemiol Biomarkers Prev. 2007 May;16(5):912–6. PMID: 17507615. Exclusion: E517507615
Kotsopoulos J, Huzarski T, Gronwald J, . Hormone replacement therapy after menopause and risk of breast cancer in BRCA1 mutation carriers: a case-control study. Breast Cancer Res Treat. 2016 Jan;155(2):365–73. doi: 10.1007/s10549-016-3685-3. PMID: 26780555. Exclusion: E526780555
Kotsopoulos J, Kim Y-I, Narod SA. Folate and breast cancer: what about high-risk women? Cancer Causes Control. 2012 Sep;23(9):1405–20. doi: 10.1007/s10552-012-0022-y. PMID: 22767328. Exclusion: E522767328
Kotsopoulos J, Lubinski J, Moller P, . Timing of oral contraceptive use and the risk of breast cancer in BRCA1 mutation carriers. Breast Cancer Res Treat. 2014 Feb;143(3):579–86. doi: 10.1007/s10549-013-2823-4. PMID: 24458845. Exclusion: E524458845
Kotsopoulos J, Lubinski J, Neuhausen SL, . Hormone replacement therapy and the risk of ovarian cancer in BRCA1 and BRCA2 mutation carriers. Gynecol Oncol. 2006 Jan;100(1):83–8. PMID: 16137751. Exclusion: E516137751
Kotsopoulos J, Metcalfe K, Alston J, . Prospective study of high-risk, BRCA1/2-mutation negative women: the ‘negative study’. BMC Cancer. 2014;14:221. doi: 10.1186/1471-2407-14-221. PMID: 24667084. Exclusion: E624667084
Kotsopoulos J, Narod SA. Towards a dietary prevention of hereditary breast cancer. Cancer Causes Control. 2005 Mar;16(2):125–38. PMID: 15868454. Exclusion: E915868454
Kotsopoulos J, Olopado OI, Ghadirian P, . Changes in body weight and the risk of breast cancer in BRCA1 and BRCA2 mutation carriers. Breast Cancer Res. 2005;7(5):R833–43. PMID: 16168130. Exclusion: E516168130
Kotsopoulos J, Sukiennicki G, Muszynska M, . Plasma micronutrients, trace elements, and breast cancer in BRCA1 mutation carriers: an exploratory study. Cancer Causes Control. 2012 Jul;23(7):1065–74. doi: 10.1007/s10552-012-9975-0. PMID: 22576580. Exclusion: E522576580
Kraus C, Hoyer J, Vasileiou G, . Gene panel sequencing in familial breast/ovarian cancer patients identifies multiple novel mutations also in genes others than BRCA1/2. Int J Cancer. 2017;140(1):95–102. doi: 10.1002/ijc.30428. PMID: 27616075. Exclusion: E527616075
Kriege M, Brekelmans CTM, Obdeijn IM, . Factors affecting sensitivity and specificity of screening mammography and MRI in women with an inherited risk for breast cancer. Breast Cancer Res Treat. 2006 Nov;100(1):109–19. PMID: 16791481. Exclusion: E516791481
Kriege M, Jager A, Hooning MJ, . The efficacy of taxane chemotherapy for metastatic breast cancer in BRCA1 and BRCA2 mutation carriers. Cancer. 2012 Feb 15;118(4):899–907. doi: 10.1002/cncr.26351. PMID: 21761396. Exclusion: E321761396
Kringen P, Wang Y, Dumeaux V, . TP53 mutations in ovarian carcinomas from sporadic cases and carriers of two distinct BRCA1 founder mutations; relation to age at diagnosis and survival. BMC Cancer. 2005;5:134. PMID: 16229746. Exclusion: E316229746
Kuchenbaecker KB, McGuffog L, Barrowdale D, . Evaluation of polygenic risk scores for breast and ovarian cancer risk prediction in BRCA1 and BRCA2 mutation carriers. J Natl Cancer Inst. 2017 Jul 01;109(7):01. doi: 10.1093/jnci/djw302. PMID: 28376175. Exclusion: E528376175
Kuderer NM, Lyman GH. Gene expression profile assays as predictors of distant recurrence-free survival in early-stage breast cancer. Cancer Invest. 2009 Nov;27(9):885–90. PMID: 19832034. Exclusion: E319832034
Kuhl CK. MR imaging for surveillance of women at high familial risk for breast cancer. Magn Reson Imaging Clin N Am. 2006 Aug;14(3):391–402, vii. PMID: 17098180. Exclusion: E617098180
Kuhl CK, Schrading S, Leutner CC, . Mammography, breast ultrasound, and magnetic resonance imaging for surveillance of women at high familial risk for breast cancer. J Clin Oncol. 2005;23(33):8469–76. PMID: 16293877. Exclusion: E316293877
Kuijper TM, Ruigrok-Ritstier K, Verhoef-Post M, . LH receptor gene expression is essentially absent in breast tumor tissue: Implications for treatment. Mol Cell Endocrinol. 2009;302(1):58–64. PMID: 19356624. Exclusion: E319356624
Kurian AW, Gong GD, Chun NM, . Performance of BRCA1/2 mutation prediction models in Asian Americans. J Clin Oncol. 2008 Oct 10;26(29):4752–8. PMID: 18779604. Exclusion: 218779604
Kurian AW, Gong GD, John EM, . Performance of prediction models for BRCA mutation carriage in three racial/ethnic groups: findings from the Northern California Breast Cancer Family Registry. Cancer Epidemiol Biomarkers Prev. 2009 Apr;18(4):1084–91. PMID: 19336551. Exclusion: E419336551
Kurian AW, Hartman A-R, Mills MA, . Opinions of women with high inherited breast cancer risk about prophylactic mastectomy: an initial evaluation from a screening trial including magnetic resonance imaging and ductal lavage. Health Expect. 2005 Sep;8(3):221–33. PMID: 16098152. Exclusion: E316098152
Kurian AW, Idos G, McDonnell K, . The patient experience in a prospective trial of multiplex gene panel testing for cancer risk. Cancer Res. 2016;76(4)doi: 10.1158/1538-7445.SABCS15-P2-09-07. Exclusion: E6
Kurian AW, Kingham KE, Ford JM. Next-generation sequencing for hereditary breast and gynecologic cancer risk assessment. Curr Opin Obstet Gynecol. 2015 Feb;27(1):23–33. doi: 10.1097/GCO.0000000000000141. PMID: 25502425. Exclusion: 225502425
Kushnir A, Laitman Y, Shimon SP, . Germline mutations in RAD51C in Jewish high cancer risk families. Breast Cancer Res Treat. 2012 Dec;136(3):869–74. doi: 10.1007/s10549-012-2317-9. PMID: 23117857. Exclusion: 223117857
Kuusisto KM, Bebel A, Vihinen M, . Screening for BRCA1, BRCA2, CHEK2, PALB2, BRIP1, RAD50, and CDH1 mutations in high-risk Finnish BRCA1/2-founder mutation-negative breast and/or ovarian cancer individuals. Breast Cancer Res. 2011;13(1) PMID: 21356067. Exclusion: E521356067
Kwiatkowski F, Dessenne P, Laquet C, . Permanence of the information given during oncogenetic counseling to persons at familial risk of breast/ovarian and/or colon cancer. Eur J Hum Genet. 2012 Feb;20(2):141–7. doi: 10.1038/ejhg.2011.169. PMID: 21934710. Exclusion: E321934710
Kwon JS, Daniels MS, Sun CC, . Preventing future cancers by testing women with ovarian cancer for BRCA mutations. J Clin Oncol. 2010 Feb 1;28(4):675–82. PMID: 19841329. Exclusion: E719841329
Kwon JS, Gutierrez-Barrera AM, Young D, . Expanding the criteria for BRCA mutation testing in breast cancer survivors. J Clin Oncol. 2010 Sep 20;28(27):4214–20. PMID: 20733129. Exclusion: E720733129
Kwon JS, Lenehan J, Carey M, . Prolonged survival among women with BRCA germline mutations and advanced endometrial cancer: a case series. Int J Gynecol Cancer. 2008 May–Jun;18(3):546–9. PMID: 17645508. Exclusion: E317645508
Kwon JS, Tinker A, Pansegrau G, . Prophylactic salpingectomy and delayed oophorectomy as an alternative for BRCA mutation carriers. Obstet Gynecol. 2013;121(1):14–24. PMID: 23232752. Exclusion: E723232752
Kwong A, Chen J, Shin V, . Identification of BRCA1/2 germline mutations by integrated approach. Breast. 2015;24:S73. doi: 10.1016/S0960-9776(15)70182-7. Exclusion: E526387601
Kwong A, Chen JW, Shin VY. A new paradigm of genetic testing for hereditary breast/ovarian cancers. Hong Kong Med J. 2016 Apr;22(2):171–7. doi: 10.12809/hkmj154634. PMID: 26980575. Exclusion: 226980575
Kwong A, Chu ATW. What made her give up her breasts: a qualitative study on decisional considerations for contralateral prophylactic mastectomy among breast cancer survivors undergoing BRCA1/2 genetic testing. Asian Pac J Cancer Prev. 2012;13(5):2241–7. PMID: 22901201. Exclusion: E522901201
Kwong A, Ng EKO, Wong CLP, . Identification of BRCA1/2 founder mutations in Southern Chinese breast cancer patients using gene sequencing and high resolution DNA melting analysis. PLoS ONE [Electronic Resource]. 2012;7(9):e43994. doi: 10.1371/journal.pone.0043994. PMID: 22970155. Exclusion: E522970155
Kwong A, Wong CH, Suen DT, . Accuracy of BRCA1/2 mutation prediction models for different ethnicities and genders: experience in a southern Chinese cohort. World J Surg. 2012 Apr;36(4):702–13. doi: 10.1007/s00268-011-1406-y. PMID: 22290208. Exclusion: E322290208
La Verde N, Corsi F, Moretti A, . A targeted approach to genetic counseling in breast cancer patients: the experience of an Italian local project. Tumori. 2016 Jan–Feb;102(1):45–50. doi: 10.5301/tj.5000407. PMID: 26357973. Exclusion: E526357973
Lacour RA, Daniels MS, Westin SN, . What women with ovarian cancer think and know about genetic testing. Gynecol Oncol. 2008 Oct;111(1):132–6. PMID: 18684498. Exclusion: E318684498
Lacour RA, Westin SN, Meyer LA, . Improved survival in non-Ashkenazi Jewish ovarian cancer patients with BRCA1 and BRCA2 gene mutations. Gynecol Oncol. 2011 May 1;121(2):358–63. PMID: 21276604. Exclusion: E321276604
Lagos VI, Perez MA, Ricker CN, . Social-cognitive aspects of underserved Latinas preparing to undergo genetic cancer risk assessment for hereditary breast and ovarian cancer. Psychooncology. 2008 Aug;17(8):774–82. PMID: 18646245. Exclusion: E418646245
Laitman Y, Kaufman B, Lahad EL, . Germline CHEK2 mutations in Jewish Ashkenazi women at high risk for breast cancer. Isr Med Assoc J. 2007 Nov;9(11):791–6. PMID: 18085035. Exclusion: E518085035
Laitman Y, Kuchenbaecker KB, Rantala J, . The KL-VS sequence variant of Klotho and cancer risk in BRCA1 and BRCA2 mutation carriers. Breast Cancer Res Treat. 2012 Apr;132(3):1119–26. PMID: 22212556. Exclusion: E522212556
Lakhani SR, Manek S, Penault-Llorca F, . Pathology of ovarian cancers in BRCA1 and BRCA2 carriers. Clin Cancer Res. 2004 Apr 01;10(7):2473–81. PMID: 15073127. Exclusion: 215073127
Laki F, Kirova YM, This P, . Prophylactic salpingo-oophorectomy in a series of 89 women carrying a BRCA1 or a BRCA2 mutation. Cancer. 2007 May 1;109(9):1784–90. PMID: 17351952. Exclusion: E3a17351952
Lamb JD, Garcia RL, Goff BA, . Predictors of occult neoplasia in women undergoing risk-reducing salpingo-oophorectomy. Am J Obstet Gynecol. 2006 Jun;194(6):1702–9. PMID: 16731090. Exclusion: E3a16731090
Lancaster DR. Development and psychometric testing of the coping with breast cancer threat instrument. J Nurs Meas. 2004 Spr–Sum;12(1):33–46. doi: 10.1891/jnum.12.1.33.66319. PMID: 15916318. Exclusion: E415916318
Land SR, Wickerham D, Constantino JP, . “Patient-reported symptoms and quality of life during treatment with tamoxifen or raloxifene for breast cancer prevention: The NSABP Study of Tamoxifen and Raloxifene (STAR) P-2 Trial”: Erratum. JAMA. 2007 Sep;298(9):973. doi: 10.1001/jama.298.9.973-a. PMID: 16754728. Exclusion: E316754728
Land SR, Wickerham D, Costantino JP, . Patient-reported symptoms and quality of life during treatment with tamoxifen or raloxifene for breast cancer prevention: the NSABP Study of Tamoxifen and Raloxifene (STAR) P-2 Trial. JAMA. 2006 Jun;295(23):2742–51. doi: 10.1001/jama.295.23.joc60075. PMID: 16754728. Exclusion: E316754728
Lane G. Prophylactic oophorectomy: why and when? J Br Menopause Soc. 2003 Dec;9(4):156–60. PMID: 15107258. Exclusion: E615107258
Lapointe J, Abdous B, Camden S, . Influence of the family cluster effect on psychosocial variables in families undergoing BRCA1/2 genetic testing for cancer susceptibility. Psychooncology. 2012 May;21(5):515–23. doi: 10.1002/pon.1936. PMID: 21370312. Exclusion: E321370312
Lapointe J, Bouchard K, Patenaude AF, . Incidence and predictors of positive and negative effects of BRCA1/2 genetic testing on familial relationships: A 3-year follow-up study. Genet Med. 2012;14(1):60–8. PMID: 22237432. Exclusion: E322237432
Lebel S, Jakubovits G, Rosberger Z, . Waiting for a breast biopsy. Psychosocial consequences and coping strategies. J Psychosom Res. 2003 Nov;55(5):437–43. PMID: 14581098. Exclusion: E414581098
Leblanc E, Narducci F, Farre I, . Radical fimbriectomy: a reasonable temporary risk-reducing surgery for selected women with a germ line mutation of BRCA 1 or 2 genes? Rationale and preliminary development. Gynecol Oncol. 2011 Jun 1;121(3):472–6. PMID: 21411127. Exclusion: E421411127
Leblond D, Bredart A, Dolbeault S, . [Perception accuracy of BRCA1/2 mutation predisposition in breast cancer women and associated factors]. Bull Cancer. 2012 Jun;99(6):673–84. PMID: 22641341. Exclusion: E822641341
Lecarpentier J, Nogues C, Mouret-Fourme E, . Variation in breast cancer risk with mutation position, smoking, alcohol, and chest X-ray history, in the French National BRCA1/2 carrier cohort (GENEPSO). Breast Cancer Res Treat. 2011 Dec;130(3):927–38. PMID: 21761160. Exclusion: E521761160
Lee DSC, Yoon S-Y, Looi LM, . Comparable frequency of BRCA1, BRCA2 and TP53 germline mutations in a multi-ethnic Asian cohort suggests TP53 screening should be offered together with BRCA1/2 screening to early-onset breast cancer patients. Breast Cancer Res. 2012;14(2):R66. PMID: 22507745. Exclusion: E522507745
Lee E, Ma H, McKean-Cowdin R, . Effect of reproductive factors and oral contraceptives on breast cancer risk in BRCA1/2 mutation carriers and noncarriers: results from a population-based study. Cancer Epidemiol Biomarkers Prev. 2008 Nov;17(11):3170–8. PMID: 18990759. Exclusion: E518990759
Lee E-H, Park SK, Park B, . Effect of BRCA1/2 mutation on short-term and long-term breast cancer survival: a systematic review and meta-analysis. Breast Cancer Res Treat. 2010 Jul;122(1):11–25. PMID: 20376556. Exclusion: E320376556
Lee JS, John EM, McGuire V, . Breast and ovarian cancer in relatives of cancer patients, with and without BRCA mutations. Cancer Epidemiol Biomarkers Prev. 2006 Feb;15(2):359–63. PMID: 16492929. Exclusion: E516492929
Lee YJ, Lee SW, Kim KR, . Pathologic findings at risk-reducing salpingo-oophorectomy (RRSO) in germline BRCA mutation carriers with breast cancer: significance of bilateral RRSO at the optimal age in germline BRCA mutation carriers. J Gynecol Oncol. 2017 Jan;28(1):e3. doi: 10.3802/jgo.2017.28.e3. PMID: 27670257. Exclusion: 227670257
LeGrazie B. Counseling high-risk women about breast cancer. Oncology (Williston Park). 2011 Feb;25(2 Suppl Nurse Ed):30–5. PMID: 25373281. Exclusion: E625373281
Lehman CD, Isaacs C, Schnall MD, . Cancer yield of mammography, MR, and US in high-risk women: prospective multi-institution breast cancer screening study. Radiology. 2007 Aug;244(2):381–8. PMID: 17641362. Exclusion: E317641362
Lerman C, Hughes C, Lemon SJ, . What you don’t know can hurt you: Adverse psychologic effects in members of BRCA1-linked and BRCA2-linked families who decline genetic testing. J Clin Oncol. 1998;16(5):1650–4. PMID: 9586874. Exclusion: E39586874
Lerman C, Kash K, Stefanek M. Younger women at increased risk for breast cancer: perceived risk, psychological well-being, and surveillance behavior. J Natl Cancer Inst Monogr. 1994(16):171–6. PMID: 7999461. Exclusion: E57999461
Lerman C, Lustbader E, Rimer B, . Effects of individualized breast cancer risk counseling: a randomized trial. J Natl Cancer Inst. 1995;87(4):286–92. PMID: 7707420. Exclusion: 27707420
Lerman C, Narod S, Schulman K, . BRCA1 testing in families with hereditary breast-ovarian cancer. A prospective study of patient decision making and outcomes. JAMA. 1996 Jun 26;275(24):1885–92. PMID: 8648868. Exclusion: 28648868
Lerner-Ellis J, Khalouei S, Sopik V, . Genetic risk assessment and prevention: the role of genetic testing panels in breast cancer. Expert Rev Anticancer Ther. 2015;15(11):1315–26. doi: 10.1586/14737140.2015.1090879. PMID: 26523341. Exclusion: 226523341
Leunen K, Legius E, Moerman P, . Prophylactic salpingo-oophorectomy in 51 women with familial breast-ovarian cancer: importance of fallopian tube dysplasia. Int J Gynecol Cancer. 2006 Jan–Feb;16(1):183–8. PMID: 16445631. Exclusion: E516445631
Levine DA, Argenta PA, Yee CJ, . Fallopian tube and primary peritoneal carcinomas associated with BRCA mutations. J Clin Oncol. 2003 Nov 15;21(22):4222–7. doi: 10.1200/JCO.2003.04.131. PMID: 14615451. Exclusion: 214615451
Levy D, Garber J, Shields A. Guidelines for genetic risk assessment of hereditary breast and ovarian cancer: early disagreements and low utilization. J Gen Intern Med. 2009;24(7):822–8. doi: 10.1007/s11606-009-1009-6. PMID: 19455369. Exclusion: E519455369
Levy DE, Byfield SD, Comstock CB, . Underutilization of BRCA1/2 testing to guide breast cancer treatment: black and Hispanic women particularly at risk. Genet Med. 2011 Apr;13(4):349–55. PMID: 21358336. Exclusion: E521358336
Li CI, Uribe DJ, Daling JR. Clinical characteristics of different histologic types of breast cancer. Br J Cancer. 2005 Oct 31;93(9):1046–52. doi: 10.1038/sj.bjc.6602787. PMID: 16175185. Exclusion: 216175185
Li H, Feng B, Miron A, . Breast cancer risk prediction using a polygenic risk score in the familial setting: a prospective study from the Breast Cancer Family Registry and kConFab. Genet Med. 2017;19(1):30–5. doi: 10.1038/gim.2016.43. PMID: 27171545. Exclusion: E327171545
Li L, Mao X, Qin X, . Aspirin inhibits growth of ovarian cancer by upregulating caspase-3 and downregulating bcl-2. Oncol Lett. 2016;12(1):93–6. PMID: 27347106. Exclusion: E327347106
Li W-F, Hu Z, Rao N-Y, . The prevalence of BRCA1 and BRCA2 germline mutations in high-risk breast cancer patients of Chinese Han nationality: two recurrent mutations were identified. Breast Cancer Res Treat. 2008 Jul;110(1):99–109. PMID: 17851763. Exclusion: E517851763
Li X, You R, Wang X, . Effectiveness of prophylactic surgeries in BRCA1 or BRCA2 mutation carriers: A meta-analysis and systematic review. Clin Cancer Res. 2016;22(15):3971–81. doi: 10.1158/1078-0432.CCR-15-1465. PMID: 26979395. Exclusion: 226979395
Li Y, Arellano AR, Bare LA, . A multigene test could cost-effectively help extend life expectancy for women at risk of hereditary breast cancer. Value Health. 2017 Apr;20(4):547–55. doi: 10.1016/j.jval.2017.01.006. PMID: 28407996. Exclusion: E528407996
Lieberman S, Lahad A, Tomer A, . Population screening for BRCA1/BRCA2 mutations: lessons from qualitative analysis of the screening experience. Genet Med. 2017 Jun;19(6):628–34. doi: 10.1038/gim.2016.175. PMID: 27906198. Exclusion: E527906198
Lieberman S, Tomer A, Raz A, . Population screening for BRCA mutations: What is the optimal screening program? Current Oncology. 2014;21(2):e388. doi: 10.3747/co.21.2077. Exclusion: E5
Lin CJ, Block B, Nowalk MP, . Breast cancer risk assessment in socioeconomically disadvantaged urban communities. J Natl Med Assoc. 2007 Jul;99(7):752–6. PMID: 17668640. Exclusion: 217668640
Lin PH, Kuo WH, Huang AC, . Multiple gene sequencing for risk assessment in patients with early-onset or familial breast cancer. Oncotarget. 2016 Feb 16;7(7):8310–20. doi: 10.18632/oncotarget.7027. PMID: 26824983. Exclusion: E526824983
Lindor NM, Greene MH. The concise handbook of family cancer syndromes. Mayo Familial Cancer Program. J Natl Cancer Inst. 1998 Jul 15;90(14):1039–71. PMID: 9672254. Exclusion: 29672254
Lindor NM, Johnson KJ, Harvey H, . Predicting BRCA1 and BRCA2 gene mutation carriers: comparison of PENN II model to previous study. Fam Cancer. 2010 Dec;9(4):495–502. PMID: 20512419. Exclusion: E3a20512419
Lindstrom LS, Hall P, Hartman M, . Familial concordance in cancer survival: a Swedish population-based study. Lancet Oncol. 2007 Nov;8(11):1001–6. PMID: 17921068. Exclusion: E317921068
Lipkus IM, Vadaparampil ST, Jacobsen PB, . Knowledge about genomic recurrence risk testing among breast cancer survivors. J Cancer Educ. 2011 Dec;26(4):664–9. PMID: 21688183. Exclusion: E521688183
Lippman ME, Cummings SR, Disch DP, . Effect of raloxifene on the incidence of invasive breast cancer in postmenopausal women with osteoporosis categorized by breast cancer risk. Clin Cancer Res. 2006;12(17):5242–7. PMID: 16951244. Exclusion: E316951244
Lippuner K, Buchard PA, De Geyter C, . Recommendations for raloxifene use in daily clinical practice in the Swiss setting. Eur Spine J. 2012 Dec;21(12):2407–17. doi: 10.1007/s00586-012-2404-y. PMID: 22739699. Exclusion: E322739699
Listøl W, Høberg-Vetti H, Eide GE, . Anxiety and depression symptoms among women attending group-based patient education courses for hereditary breast and ovarian cancer. Hered Cancer Clin Pract. 2017;15(1)doi: 10.1186/s13053-016-0062-5. PMID: 28096903. Exclusion: H228096903
Litton JK, Etzel CJ, Jackson MA, . Breast cancer, BRCA mutations and attitudes regarding pregnancy and preimplantation genetic diagnosis. Cancer Res. 2011;71(24)doi: 10.1158/0008-5472.SABCS11-P2-13-05. Exclusion: E5
Litton JK, Westin SN, Ready K, . Perception of screening and risk reduction surgeries in patients tested for a BRCA deleterious mutation. Cancer. 2009 Apr 15;115(8):1598–604. PMID: 19280625. Exclusion: E519280625
Liu G-Y, Zhang W. Will Chinese ovarian cancer patients benefit from knowing the BRCA2 mutation status? Chin J Cancer. 2012 Jan;31(1):1–4. doi: 10.5732/cjc.011.10432. PMID: 22176776. Exclusion: E622176776
Liu J, Li S, Dunker AK, . Molecular profiling: an essential technology enabling personalized medicine in breast cancer. Curr Drug Targets. 2012 Apr;13(4):541–54. PMID: 22250651. Exclusion: E522250651
Livaudais-Toman J, Karliner LS, Tice JA, . Impact of a primary care based intervention on breast cancer knowledge, risk perception and concern: a randomized, controlled trial. Breast. 2015 Dec;24(6):758–66. doi: 10.1016/j.breast.2015.09.009. PMID: 26476466. Exclusion: E426476466
Lizard S, Eliade M, Skrzypski J, . The transfer of multigene panel testing for hereditary breast and ovarian cancer to healthcare: What are the implications for the management of patients and families? J Clin Oncol. 2016;34. Exclusion: E5
Llort G, Peris M, Blanco I. [Hereditary breast and ovarian cancer: primary and secondary prevention for BRCA1 and BRCA2 mutation carriers]. Med Clin (Barc). 2007 Mar 31;128(12):468–76. PMID: 17408542. Exclusion: E917408542
Lo SS, Mumby PB, Norton J, . Prospective multicenter study of the impact of the 21-gene recurrence score assay on medical oncologist and patient adjuvant breast cancer treatment selection. J Clin Oncol. 2010 Apr 1;28(10):1671–6. PMID: 20065191. Exclusion: E320065191
Lobb E, Butow P, Meiser B, . The use of audiotapes in consultations with women from high risk breast cancer families: a randomised trial. J Med Genet. 2002;39(9):697–703. PMID: 12205117. Exclusion: E312205117
Lobb EA, Butow PN, Moore A, . Development of a communication aid to facilitate risk communication in consultations with unaffected women from high risk breast cancer families: a pilot study. J Genet Couns. 2006 Oct;15(5):393–405. PMID: 16967332. Exclusion: E416967332
Lobo M, Lopez-Tarruella S, Luque S, . Evaluation of breast cancer patients with genetic risk: before and after a multidisciplinary heredo familiar cancer unit implementation. Ann Oncol. 2016;27 doi: 10.1093/annonc/mdw385.13. Exclusion: E3
Loizidou M, Marcou Y, Anastasiadou V, . Contribution of BRCA1 and BRCA2 germline mutations to the incidence of early-onset breast cancer in Cyprus. Clin Genet. 2007 Feb;71(2):165–70. PMID: 17250666. Exclusion: E517250666
Long KC, Pike MC, Otegbeye E, . Impact of bilateral oophorectomy on contralateral breast cancer risk in BRCA negative women from site-specific hereditary breast cancer kindreds. J Clin Oncol. 2013;31(15). Exclusion: E3
Lonning PE. The role of aromatase inactivators in the treatment of breast cancer. Int J Clin Oncol. 2002;7(4):265–70. PMID: 12202980. Exclusion: E612202980
Lonning PE, Geisler J, Krag LE, . Effects of exemestane administered for 2 years versus placebo on bone mineral density, bone biomarkers, and plasma lipids in patients with surgically resected early breast cancer. J Clin Oncol. 2005 Aug;23(22):5126–37. PMID: 15983390. Exclusion: E315983390
Lorenzo Bermejo J, Hemminki K. A population-based assessment of the clustering of breast cancer in families eligible for testing of BRCA1 and BRCA2 mutations. Ann Oncol. 2005 Feb;16(2):322–9. PMID: 15668291. Exclusion: E515668291
Lorusso D, Cirillo F, Mancini M, . The different impact of BRCA mutations on the survival of epithelial ovarian cancer patients: a retrospective single-center experience. Oncology. 2013;85(2):122–7. doi: 10.1159/000353786. PMID: 23941904. Exclusion: E3a23941904
Lose F, Duffy DL, Kay GF, . Skewed X chromosome inactivation and breast and ovarian cancer status: evidence for X-linked modifiers of BRCA1. J Natl Cancer Inst. 2008 Nov 5;100(21):1519–29. PMID: 18957670. Exclusion: E518957670
Lostumbo L, Carbine NE, Wallace J. Prophylactic mastectomy for the prevention of breast cancer. Cochrane Database Syst Rev. 2010;11:CD002748. PMID: 21069671. Exclusion: E321069671
Lostumbo L, Carbine NE, Wallace J. Prophylactic mastectomy for the prevention of breast cancer. Cochrane Database Syst Rev. 2011(1) PMID: 15495033. Exclusion: E915495033
Lotfi-Jam K, Carey M, Jefford M, . Nonpharmacologic strategies for managing common chemotherapy adverse effects: a systematic review. J Clin Oncol. 2008 Dec 1;26(34):5618–29. doi: 10.1200/jco.2007.15.9053. PMID: 18981466. Exclusion: E318981466
Loud JT, Beckjord EB, Nichols K, . Tolerability of breast ductal lavage in women from families at high genetic risk of breast cancer. BMC Womens Health. 2009;9:20. PMID: 19602282. Exclusion: E419602282
Loud JT, Thiebaut AC, Abati AD, . Ductal lavage in women from BRCA1/2 families: is there a future for ductal lavage in women at increased genetic risk of breast cancer? Cancer Epidemiol Biomarkers Prev. 2009 Apr;18(4):1243–51. doi: 10.1158/1055-9965.epi-08-0795. PMID: 19336560. Exclusion: 219336560
Love RR. Luteal v. follicular phase surgical oophorectomy & tamoxifen in premenopausal women with metastatic hormone receptor + Br. CA. Physician Data Query. 2006. Exclusion: E3
Low CA, Stanton AL, Thompson N, . Contextual life stress and coping strategies as predictors of adjustment to breast cancer survivorship. Ann Behav Med. 2006 Oct;32(3):235–44. doi: 10.1207/s15324796abm3203_10. PMID: 17107297. Exclusion: E317107297
Low Y-L, Wedren S, Liu J. High-throughput genomic technology in research and clinical management of breast cancer. Evolving landscape of genetic epidemiological studies. Breast Cancer Res. 2006;8(3):209. PMID: 16834767. Exclusion: E616834767
Lu KH. Hereditary gynecologic cancers: differential diagnosis, surveillance, management and surgical prophylaxis. Fam Cancer. 2008;7(1):53–8. PMID: 17636427. Exclusion: E617636427
Lu P-H, Yang J, Li C, . Association between mitogen-activated protein kinase kinase kinase 1 rs889312 polymorphism and breast cancer risk: evidence from 59,977 subjects. Breast Cancer Res Treat. 2011 Apr;126(3):663–70. PMID: 20809358. Exclusion: 220809358
Ludwig KK, Neuner J, Butler A, . Risk reduction and survival benefit of prophylactic surgery in BRCA mutation carriers, a systematic review. Am J Surg. 2016 Oct;212(4):660–9. doi: 10.1016/j.amjsurg.2016.06.010. PMID: 27649974. Exclusion: 227649974
Lund MJ, Mosunjac M, Davis KM, . 21-Gene recurrence scores: racial differences in testing, scores, treatment, and outcome. Cancer. 2012 Feb 1;118(3):788–96. doi: 10.1002/cncr.26180. PMID: 21720988. Exclusion: E321720988
Lux MP, Ackermann S, Nestle-Kramling C, . Use of intensified early cancer detection in high-risk patients with familial breast and ovarian cancer. Eur J Cancer Prev. 2005 Aug;14(4):399–411. PMID: 16030432. Exclusion: E516030432
Lynch HT, Snyder C, Lynch JF, . Patient responses to the disclosure of BRCA mutation tests in hereditary breast-ovarian cancer families. Cancer Genet Cytogenet. 2006 Mar;165(2):91–7. PMID: 16527602. Exclusion: E316527602
Lynch HT, Snyder CL, Lynch JF. Genetic counseling and the advanced practice oncology nursing role in a hereditary cancer prevention clinic: hereditary breast cancer focus (part II). Breast J. 2009 Sep–Oct;15 Suppl 1:S11–9. PMID: 19775324. Exclusion: E719775324
Lynch JA, Venne V, Berse B. Genetic tests to identify risk for breast cancer. Semin Oncol Nurs. 2015 May;31(2):100–7. doi: 10.1016/j.soncn.2015.02.007. PMID: 25951739. Exclusion: E625951739
M.D. Anderson Cancer Center. Prophylactic salpingectomy with delayed oophorectomy. 2013. https://clinicaltrials.gov/ct2/show/NCT01907789?term=NCT01907789. Accessed May 16 2019. Exclusion: E6
Macdonald DJ, Deri J, Ricker C, . Closing the loop: an interactive action-research conference format for delivering updated medical information while eliciting Latina patient/family experiences and psychosocial needs post-genetic cancer risk assessment. Fam Cancer. 2012 Sep;11(3):449–58. doi: 10.1007/s10689-012-9535-5. PMID: 22678665. Exclusion: E422678665
MacDonald DJ, Hurley K, Garcia N, . Enhancing psychosocial well-being in ethnically diverse reproductive age BRCA+ women. Curr Oncol. 2012;19(2):e87. doi: 10.3747/co.19.1076. Exclusion: E6
MacDonald DJ, Sarna L, Uman GC, . Health beliefs of women with and without breast cancer seeking genetic cancer risk assessment. Cancer Nurs. 2005 Sep–Oct;28(5):372–9; quiz 80-1. PMID: 16192828. Exclusion: E416192828
MacDonald DJ, Sarna L, Uman GC, . Cancer screening and risk-reducing behaviors of women seeking genetic cancer risk assessment for breast and ovarian cancers. Oncol Nurs Forum. 2006 Mar;33(2):E27–35. PMID: 16518435. Exclusion: E516518435
Machackova E, Foretova L, Lukesova M, . Spectrum and characterisation of BRCA1 and BRCA2 deleterious mutations in high-risk Czech patients with breast and/or ovarian cancer. BMC Cancer. 2008;8:140. PMID: 18489799. Exclusion: E518489799
MacInnis RJ, Bickerstaffe A, Apicella C, . Prospective validation of the breast cancer risk prediction model BOADICEA and a batch-mode version BOADICEACentre. Br J Cancer. 2013 Sep 3;109(5):1296–301. doi: 10.1038/bjc.2013.382. PMID: 23942072. Exclusion: E423942072
Mackay J, Taylor A. Moving genetics into clinical cancer care: examples from BRCA gene testing and telemedicine.[Erratum appears in Breast. 2008 Apr;17(2):213]. Breast. 2006 Dec;15: Suppl 2:S65–70. PMID: 17382866. Exclusion: E417382866
MacNew HG, Rudolph R, Brower ST, . Assessing the knowledge and attitudes regarding genetic testing for breast cancer risk in our region of southeastern Georgia. Breast J. 2010 Mar–Apr;16(2):189–92. PMID: 20030654. Exclusion: E420030654
Madalinska JB, Hollenstein J, Bleiker E, . Quality-of-life effects of prophylactic salpingo-oophorectomy versus gynecologic screening among women at increased risk of hereditary ovarian cancer. J Clin Oncol. 2005 Oct 1;23(28):6890–8. PMID: 16129845. Exclusion: E3a16129845
Madalinska JB, van Beurden M, Bleiker EMA, . The impact of hormone replacement therapy on menopausal symptoms in younger high-risk women after prophylactic salpingo-oophorectomy. J Clin Oncol. 2006 Aug 1;24(22):3576–82. PMID: 16877724. Exclusion: E416877724
Madalinska JB, van Beurden M, Bleiker EMA, . Predictors of prophylactic bilateral salpingo-oophorectomy compared with gynecologic screening use in BRCA1/2 mutation carriers. J Clin Oncol. 2007 Jan 20;25(3):301–7. PMID: 17235045. Exclusion: E517235045
Madhusudhana S. Hereditary breast-ovarian cancer knowledge and interest in genetic testing among African American women. J Clin Oncol. 2015;33(15). Exclusion: E4
Maehle L, Apold J, Paulsen T, . High risk for ovarian cancer in a prospective series is restricted to BRCA1/2 mutation carriers. Clin Cancer Res. 2008 Nov 15;14(22):7569–73. PMID: 19010876. Exclusion: E719010876
Maganini R, Maganini R, Maganini A, . Genetic counseling in a comprehensive community cancer center: Identification and analysis of individuals with breast and ovarian cancer for brca I/II genetic testing. Ann Surg Oncol. 2013;20(2):76–7. doi: 10.1245/s10434-013-2964-z. Exclusion: E6
Mahajan NN. Prophylactic salpingo-oophorectomy in a series of 89 women carrying a BRCA1 or a BRCA2 mutation. Cancer. 2007 Dec 15;110(12):2819; author reply -20. PMID: 17969078. Exclusion: E617969078
Mahdi H, Gockley A, Esselen K, . Outcome of neoadjuvant chemotherapy in BRCA1/2 mutation positive women with advanced-stage Mullerian cancer. Gynecol Oncol. 2015 Dec;139(3):407–12. doi: 10.1016/j.ygyno.2015.07.101. PMID: 26210778. Exclusion: E326210778
Maheu C, Apostolidis T, Petri-Cal A, . French women’s breast self-examination practices with time after undergoing BRCA1/2 genetic testing. Fam Cancer. 2012 Jun;11(2):269–78. doi: 10.1007/s10689-012-9512-z. PMID: 22350503. Exclusion: E522350503
Maheu C, Bouhnik AD, Nogues C, . Which factors predict proposal and uptake of psychological counselling after BRCA1/2 test result disclosure? Psychooncology. 2014 Apr;23(4):420–7. doi: 10.1002/pon.3435. PMID: 24127257. Exclusion: E424127257
Maheu C, Thorne S. Receiving inconclusive genetic test results: an interpretive description of the BRCA1/2 experience. Res Nurs Health. 2008 Dec;31(6):553–62. PMID: 18449940. Exclusion: E518449940
Mai PL, Garceau AO, Graubard BI, . Confirmation of family cancer history reported in a population-based survey. J Natl Cancer Inst. 2011 May 18;103(10):788–97. doi: 10.1093/jnci/djr114. PMID: 21562245. Exclusion: 221562245
Mai PL, Lagos VI, Palomares MR, . Contralateral risk-reducing mastectomy in young breast cancer patients with and without genetic cancer risk assessment. Ann Surg Oncol. 2008 Dec;15(12):3415–21. PMID: 18836779. Exclusion: E3b18836779
Mai PL, Piedmonte M, Han PK, . Factors associated with deciding between risk-reducing salpingo-oophorectomy and ovarian cancer screening among high-risk women enrolled in GOG-0199: An NRG Oncology/Gynecologic Oncology Group study. Gynecol Oncol. 2017 Apr;145(1):122–9. doi: 10.1016/j.ygyno.2017.02.008. PMID: 28190649. Exclusion: E528190649
Majdak EJ, Debniak J, Milczek T, . Prognostic impact of BRCA1 pathogenic and BRCA1/BRCA2 unclassified variant mutations in patients with ovarian carcinoma. Cancer. 2005 Sep 1;104(5):1004–12. PMID: 16047333. Exclusion: E516047333
Makin JC, Anderson EK, Cunningham MJ, . Quality of BRCA counseling by gynecologic oncologists: A patient survey based analysis. Gynecol Oncol. 2015;137:172. doi: 10.1016/j.ygyno.2015.01.431. Exclusion: E6
Malacrida S, Agata S, Callegaro M, . BRCA1 p.Val1688del is a deleterious mutation that recurs in breast and ovarian cancer families from Northeast Italy. J Clin Oncol. 2008 Jan 1;26(1):26–31. PMID: 18165637. Exclusion: E518165637
Malinowski MJ, Blatt RJR. Commercialization of genetic testing services: the FDA, market forces, and biological tarot cards. Tulane Law Review. 1997 Mar;71(4):1211–312. PMID: 15744901. Exclusion: E915744901
Malone KE, Begg CB, Haile RW, . Population-based study of the risk of second primary contralateral breast cancer associated with carrying a mutation in BRCA1 or BRCA2. J Clin Oncol. 2010 May 10;28(14):2404–10. PMID: 20368571. Exclusion: E520368571
Maloney E, Edgerson S, Robson M, . What women with breast cancer discuss with clinicians about risk for their adolescent daughters. J Psychosoc Oncol. 2012;30(4):484–502. PMID: 22747109. Exclusion: E522747109
Manchanda R. Brca testing in high-risk populations. Clin Cancer Res. 2015;21(16)doi: 10.1158/1557-3265.OVCASYMP14-IS01. Exclusion: E6
Manchanda R, Abdelraheim A, Johnson M, . Outcome of risk-reducing salpingo-oophorectomy in BRCA carriers and women of unknown mutation status. BJOG. 2011 Jun;118(7):814–24. doi: 10.1111/j.1471-0528.2011.02920.x. PMID: 21392246. Exclusion: E521392246
Manchanda R, Burnell M, Loggenberg K, . Cluster-randomised non-inferiority trial comparing DVD-assisted and traditional genetic counselling in systematic population testing for BRCA1/2 mutations. J Med Genet. 2016 Jul;53(7):472–80. doi: 10.1136/jmedgenet-2015-103740. PMID: 26993268. Exclusion: E426993268
Manchanda R, Drapkin R, Jacobs I, . The role of peritoneal cytology at risk-reducing salpingo-oophorectomy (RRSO) in women at increased risk of familial ovarian/tubal cancer. Gynecol Oncol. 2012 Feb;124(2):185–91. PMID: 22019526. Exclusion: E422019526
Manchanda R, Gaba F. Population based testing for primary prevention: A systematic review. Cancers (Basel). 2018;10(11)doi: 10.3390/cancers10110424. Exclusion: E5
Manchanda R, Gessler S, Loggenberg K, . Population testing for inherited, cancer predisposing brca 1 and brca2 founder mutations in the ashkenazi jewish community in london: The psychological impact on participants of a randomised controlled trial. Psychooncology. 2014;23:120–1. doi: 10.1111/j.1099-1611.2014.3694. Exclusion: E6
Manchanda R, Loggenberg K, Burnell M, . Dvd-based genetic counselling is as effective and more cost-efficient than standard-counselling for BRCA testing: Results from a randomised trial. Int J Gynecol Cancer. 2012;22:E413. doi: 10.1097/01.IGC.0000422085.58592.d3. Exclusion: E6
Manchanda R, Loggenberg K, Burnell M, . Population-based testing for BRCA1/2 mutations does not cause short term psychological harm: Results from a randomised trial (GCAPPS). Int J Gynecol Cancer. 2012;22:E153. doi: 10.1097/01.IGC.0000422085.58592.d3. Exclusion: E6
Mancini J, Resseguier N, Pellegrini I, . 5-year parenthood rates after BRCA1/2 genetic testing in the GENEPSO-Psy cohort. Fam Cancer. 2013;12:S22. doi: 10.1007/s10689-013-9605-3. Exclusion: E6
Mancini J, Santin G, Chabal F, . Cross-cultural validation of the Decisional Conflict Scale in a sample of French patients. Qual Life Res. 2006 Aug;15(6):1063–8. PMID: 16900286. Exclusion: E416900286
Manguoglu E, Guran S, Yamac D, . Germline mutations of BRCA1 and BRCA2 genes in Turkish breast, ovarian, and prostate cancer patients. Cancer Genet Cytogenet. 2010 Dec;203(2):230–7. PMID: 21156238. Exclusion: E521156238
Manguoglu E, Guran S, Yamac D, . Genomic large rearrangement screening of BRCA1 and BRCA2 genes in high-risk Turkish breast/ovarian cancer patients by using multiplex ligation-dependent probe amplification assay. Cancer Invest. 2011 Jan;29(1):73–7. PMID: 20919953. Exclusion: E520919953
Mannan AU, Singh J, Lakshmikeshava R, . Detection of high frequency of mutations in a breast and/or ovarian cancer cohort: implications of embracing a multi-gene panel in molecular diagnosis in India. J Hum Genet. 2016 Jun;61(6):515–22. doi: 10.1038/jhg.2016.4. PMID: 26911350. Exclusion: E526911350
Marchbanks PA, McDonald JA, Wilson HG, . The NICHD Women’s Contraceptive and Reproductive Experiences Study: methods and operational results. Ann Epidemiol. 2002;12(4):213–21. PMID: 11988408. Exclusion: E511988408
Marchetti C, De Felice F, Palaia I, . Risk-reducing salpingo-oophorectomy: a meta-analysis on impact on ovarian cancer risk and all cause mortality in BRCA 1 and BRCA 2 mutation carriers. BMC Womens Health. 2014 Dec 12;14:150. doi: 10.1186/s12905-014-0150-5. PMID: 25494812. Exclusion: 225494812
Marchina E, Fontana MG, Speziani M, . BRCA1 and BRCA2 genetic test in high risk patients and families: counselling and management. Oncol Rep. 2010 Dec;24(6):1661–7. PMID: 21042765. Exclusion: E521042765
Margolin S, Werelius B, Fornander T, . BRCA1 mutations in a population-based study of breast cancer in Stockholm County. Genetic Testing. 2004;8(2):127–32. PMID: 15345109. Exclusion: E315345109
Marini H, Bitto A, Altavilla D, . Breast safety and efficacy of genistein aglycone for postmenopausal bone loss: a follow-up study. J Clin Endocrinol Metab. 2008 Dec;93(12):4787–96. PMID: 18796517. Exclusion: E518796517
Markopoulos C, Tsaroucha AK, Kouskos E, . Impact of breast cancer surgery on the self-esteem and sexual life of female patients. J Int Med Res. 2009;37(1):182–8. PMID: 19215689. Exclusion: E319215689
Marshall E. Lawsuit challenges legal basis for patenting human genes. Science. 2009 May;324(5930):1000–1. doi: 10.1126/science.324_1000a. PMID: 19460975. Exclusion: E619460975
Marshall T. Informed consent for mammography screening: modelling the risks and benefits for American women. Health Expect. 2005 Dec;8(4):295–305. doi: 10.1111/j.1369-7625.2005.00345.x. PMID: 16266417. Exclusion: E316266417
Marteau TM, French DP, Griffin SJ, . Effects of communicating DNA-based disease risk estimates on risk-reducing behaviours. Cochrane Database Syst Rev. 2010(10) PMID: 20927756. Exclusion: E320927756
Martinez-Delgado B, Yanowsky K, Inglada-Perez L, . Shorter telomere length is associated with increased ovarian cancer risk in both familial and sporadic cases. J Med Genet. 2012 May;49(5):341–4. doi: 10.1136/jmedgenet-2012-100807. PMID: 22493152. Exclusion: E522493152
Masciari S, Garber JE. Quality or quantity in the management of hereditary ovarian cancer risk: Is it really a trade-off? J Clin Oncol. 2005 Oct 1;23(28):6817–9. PMID: 16157931. Exclusion: E616157931
Masi CM, Blackman DJ, Peek ME. Interventions to enhance breast cancer screening, diagnosis, and treatment among racial and ethnic minority women. Med Care Res Rev. 2007 Oct;64(5, Suppl):195S–242S. doi: 10.1177/1077558707305410. PMID: 17881627. Exclusion: E317881627
Massimino K, Dorsey PB, Glissmeyer M, . Impact of inappropriate genetic testing on patients with breast cancer. Ann Surg Oncol. 2012;19:S83. doi: 10.1245/s10434-012-2244-3. Exclusion: E3
Matloff ET, Barnett RE, Bober SL. Unraveling the next chapter: sexual development, body image, and sexual functioning in female BRCA carriers. Cancer J. 2009 Jan–Feb;15(1):15–8. PMID: 19197168. Exclusion: E419197168
Matloff ET, Shannon KM, Moyer A, . Should menopausal women at increased risk for breast cancer use tamoxifen, raloxifene, or hormone therapy?: a framework for personalized risk assessment and counseling. J Cancer Educ. 2007;22(1):10–4. PMID: 17570802. Exclusion: E617570802
Maunsell E, Goss PE, Chlebowski RT, . Quality of life in MAP.3 (Mammary Prevention 3): a randomized, placebo-controlled trial evaluating exemestane for prevention of breast cancer. J Clin Oncol. 2014 May 10;32(14):1427–36. doi: 10.1200/JCO.2013.51.2483. PMID: 24711552. Exclusion: E324711552
Maurice A, Evans DGR, Shenton A, . Screening younger women with a family history of breast cancer-does early detection improve outcome? Eur J Cancer. 2006 Jul;42(10):1385–90. PMID: 16750910. Exclusion: E316750910
Mavaddat N, Barrowdale D, Andrulis IL, . Pathology of breast and ovarian cancers among BRCA1 and BRCA2 mutation carriers: results from the Consortium of Investigators of Modifiers of BRCA1/2 (CIMBA). Cancer Epidemiol Biomarkers Prev. 2012 Jan;21(1):134–47. doi: 10.1158/1055-9965.EPI-11-0775. PMID: 22144499. Exclusion: 222144499
Mays D, DeMarco TA, Luta G, . Distress and the parenting dynamic among BRCA1/2 tested mothers and their partners. Health Psychol. 2014 Aug;33(8):765–73. doi: 10.1037/a0033418. PMID: 23795707. Exclusion: E423795707
Mays D, Sharff ME, DeMarco TA, . Outcomes of a systems-level intervention offering breast cancer risk assessments to low-income underserved women. Fam Cancer. 2012 Sep;11(3):493–502. doi: 10.1007/s10689-012-9541-7. PMID: 22711611. Exclusion: 222711611
Mazzola E, Blackford A, Parmigiani G, . Recent enhancements to the genetic risk prediction model BRCAPRO. Cancer Inform. 2015;14:147–57. doi: 10.4137/CIN.S17292. PMID: 25983549. Exclusion: E425983549
McCarthy AM, Bristol M, Domchek SM, . Health care segregation, physician recommendation, and racial disparities in BRCA1/2 testing among women with breast cancer. J Clin Oncol. 2016 Aug 01;34(22):2610–8. doi: 10.1200/JCO.2015.66.0019. PMID: 27161971. Exclusion: E3a27161971
McCuaig JM, Armel SR, Novokmet A, . Routine TP53 testing for breast cancer under age 30: ready for prime time? Fam Cancer. 2012 Dec;11(4):607–13. doi: 10.1007/s10689-012-9557-z. PMID: 22851211. Exclusion: E522851211
McGee J, Giannakeas V, Karlan B, . Risk of breast cancer after a diagnosis of ovarian cancer in BRCA mutation carriers: Is preventive mastectomy warranted? Gynecol Oncol. 2017 May;145(2):346–51. doi: 10.1016/j.ygyno.2017.02.032. PMID: 28314588. Exclusion: 228314588
McInerney-Leo A, Biesecker BB, Hadley DW, . BRCA1/2 testing in hereditary breast and ovarian cancer families: effectiveness of problem-solving training as a counseling intervention. Am J Med Genet A. 2004 Oct 15;130A(3):221–7. PMID: 15378542. Exclusion: E315378542
McMartin C. Molecular sieving, receptor processing and peptidolysis as major determinants of peptide pharmacokinetics in vivo. Biochem Soc Trans. 1989 Oct;17(5):931–4. PMID: 2559863. Exclusion: 22559863
McQuirter M, Castiglia LL, Loiselle CG, . Decision-making process of women carrying a BRCA1 or BRCA2 mutation who have chosen prophylactic mastectomy. Oncol Nurs Forum. 2010 May;37(3):313–20. PMID: 20439215. Exclusion: E520439215
McTiernan A, Kuniyuki A, Yasui Y, . Comparisons of two breast cancer risk estimates in women with a family history of breast cancer. Cancer Epidemiol Biomarkers Prev. 2001 Apr;10(4):333–8. PMID: 11319173. Exclusion: E411319173
Mealiffe ME, Stokowski RP, Rhees BK, . Assessment of clinical validity of a breast cancer risk model combining genetic and clinical information. J Natl Cancer Inst. 2010 Nov 3;102(21):1618–27. PMID: 20956782. Exclusion: E420956782
Meeuwissen PAM, Seynaeve C, Brekelmans CTM, . Outcome of surveillance and prophylactic salpingo-oophorectomy in asymptomatic women at high risk for ovarian cancer. Gynecol Oncol. 2005 May;97(2):476–82. PMID: 15863147. Exclusion: E315863147
Mefford HC, Baumbach L, Panguluri RC, . Evidence for a BRCA1 founder mutation in families of West African ancestry. Am J Hum Genet. 1999 Aug;65(2):575–8. doi: 10.1086/302511. PMID: 10417303. Exclusion: 210417303
Meijers-Heijboer H, van Geel B, van Putten WLJ, . Breast cancer after prophylactic bilateral mastectomy in women with a BRCA1 or BRCA2 mutation. N Engl J Med. 2001;345(3):159–64. PMID: 1463009. Exclusion: H211463009
Meindl A, Ditsch N, Kast K, . Hereditary breast and ovarian cancer: new genes, new treatments, new concepts. Deutsches Arzteblatt International. 2011 May;108(19):323–30. PMID: 21637635. Exclusion: E721637635
Meisel SF, Side L, Fraser L, . Population-based, risk-stratified genetic testing for ovarian cancer risk: a focus group study. Public Health Genomics. 2013;16(4):184–91. doi: 10.1159/000352028. PMID: 23838408. Exclusion: E423838408
Meiser B, Price MA, Butow PN, . Psychosocial factors and uptake of risk-reducing salpingo-oophorectomy in women at high risk for ovarian cancer. Fam Cancer. 2013 Mar;12(1):101–9. doi: 10.1007/s10689-012-9585-8. PMID: 23203849. Exclusion: E523203849
Meiser B, Price MA, Butow PN, . Misperceptions of ovarian cancer risk in women at increased risk for hereditary ovarian cancer. Fam Cancer. 2014 Jun;13(2):153–62. doi: 10.1007/s10689-013-9687-y. PMID: 24081834. Exclusion: E424081834
Mellon S, Berry-Bobovski L, Gold R, . Communication and decision-making about seeking inherited cancer risk information: findings from female survivor-relative focus groups. Psychooncology. 2006 Mar;15(3):193–208. PMID: 16100704. Exclusion: E316100704
Mellon S, Gauthier J, Cichon M, . Knowledge, attitudes, and beliefs of Arab-American women regarding inherited cancer risk. J Genet Couns. 2013 Apr;22(2):268–76. doi: 10.1007/s10897-012-9546-2. PMID: 23054337. Exclusion: 223054337
Mellon S, Gold R, Janisse J, . Risk perception and cancer worries in families at increased risk of familial breast/ovarian cancer. Psychooncology. 2008 Aug;17(8):756–66. PMID: 18613300. Exclusion: E418613300
Mendes Á, Chiquelho R, Santos TA, . Family matters: Examining a multi-family group intervention for women with BRCA mutations in the scope of genetic counselling. J Community Genet. 2010;1(4):161–8. doi: 10.1007/s12687-010-0022-0. PMID: 22460298. Exclusion: E322460298
Menes TS, Terry MB, Goldgar D, . Second primary breast cancer in BRCA1 and BRCA2 mutation carriers: 10-year cumulative incidence in the Breast Cancer Family Registry. Breast Cancer Res Treat. 2015 Jun;151(3):653–60. doi: 10.1007/s10549-015-3419-y. PMID: 25975955. Exclusion: E525975955
Menkiszak J, Chudecka-Glaz A, Gronwald J, . [Characteristics of selected clinical features in BRCA1 mutation carriers affected with breast cancer undergoing preventive female genital tract surgeries]. Ginekol Pol. 2013 Sep;84(9):758–64. PMID: 24191513. Exclusion: E824191513
Menkiszak J, Chudecka-Glaz A, Gronwald J, . Prophylactic salpingo-oophorectomy in BRCA1 mutation carriers and postoperative incidence of peritoneal and breast cancers. J Ovarian Res. 2016 Feb 29;9:11. doi: 10.1186/s13048-016-0220-4. PMID: 26928677. Exclusion: E3a26928677
Menon U, Skates SJ, Lewis S, . Prospective study using the risk of ovarian cancer algorithm to screen for ovarian cancer. J Clin Oncol. 2005 Nov;23(31):7919–26. PMID: 16258091. Exclusion: E316258091
Merck B. Contralateral risk-reducing mastectomy in young women. Breast Cancer Res Treat. 2010 Sep;123: Suppl 1:29–32. PMID: 20711671. Exclusion: E620711671
Meric-Bernstam F, Gutierrez-Barrera AM, Litton J, . Genotype in BRCA-associated breast cancers. Breast J. 2012 Jan–Feb;19(1):87–91. doi: 10.1111/tbj.12056. PMID: 23231005. Exclusion: E523231005
Meropol NJ, Daly MB, Vig HS, . Delivery of Internet-based cancer genetic counselling services to patients’ homes: a feasibility study. J Telemed Telecare. 2011;17(1):36–40. PMID: 21097566. Exclusion: E321097566
Mersch J, Jackson MA, Park M, . Cancers associated with BRCA1 and BRCA2 mutations other than breast and ovarian. Cancer. 2015 Jan 15;121(2):269–75. doi: 10.1002/cncr.29041. PMID: 25224030. Exclusion: 225224030
Metcalfe K, Gershman S, Ghadirian P, . Contralateral mastectomy and survival after breast cancer in carriers of BRCA1 and BRCA2 mutations: retrospective analysis. BMJ. 2014;348:g226. doi: 10.1136/bmj.g226. PMID: 24519767. Exclusion: E3b24519767
Metcalfe K, Gershman S, Lynch HT, . Predictors of contralateral breast cancer in BRCA1 and BRCA2 mutation carriers. Br J Cancer. 2011 Apr 26;104(9):1384–92. PMID: 21487411. Exclusion: E521487411
Metcalfe K, Lynch HT, Foulkes WD, . Effect of oophorectomy on survival after breast cancer in BRCA1 and BRCA2 mutation carriers. JAMA Oncology. 2015 Jun;1(3):306–13. doi: 10.1001/jamaoncol.2015.0658. PMID: 26181175. Exclusion: E3b26181175
Metcalfe K, Lynch HT, Ghadirian P, . Risk of ipsilateral breast cancer in BRCA1 and BRCA2 mutation carriers. Breast Cancer Res Treat. 2011 May;127(1):287–96. PMID: 21221768. Exclusion: E321221768
Metcalfe K, Lynch HT, Ghadirian P, . Contralateral breast cancer in BRCA1 and BRCA2 mutation carriers. J Clin Oncol. 2004;22(12):2328–35. PMID: 15197194. Exclusion: E515197194
Metcalfe KA. Prophylactic bilateral mastectomy for breast cancer prevention. J Womens Health. 2004 Sep;13(7):822–9. PMID: 15385076. Exclusion: E915385076
Metcalfe KA. Oophorectomy for breast cancer prevention in women with BRCA1 or BRCA2 mutations. Womens Health. 2009 Jan;5(1):63–8. PMID: 19102642. Exclusion: E919102642
Metcalfe KA, Dennis CL, Poll A, . Effect of decision aid for breast cancer prevention on decisional conflict in women with a BRCA1 or BRCA2 mutation: A multisite, randomized, controlled trial. Genet Med. 2017;19(3):330–6. doi: 10.1038/gim.2016.108. PMID: 27584910. Exclusion: E427584910
Metcalfe KA, Esplen MJ, Goel V, . Predictors of quality of life in women with a bilateral prophylactic mastectomy. Breast J. 2005 Jan–Feb;11(1):65–9. PMID: 15647082. Exclusion: E315647082
Metcalfe KA, Kim-Sing C, Ghadirian P, . Health care provider recommendations for reducing cancer risks among women with a BRCA1 or BRCA2 mutation. Clin Genet. 2014 Jan;85(1):21–30. doi: 10.1111/cge.12233. PMID: 23859469. Exclusion: E523859469
Metcalfe KA, Lubinski J, Ghadirian P, . Predictors of contralateral prophylactic mastectomy in women with a BRCA1 or BRCA2 mutation: the Hereditary Breast Cancer Clinical Study Group. J Clin Oncol. 2008 Mar 1;26(7):1093–7. PMID: 18195327. Exclusion: E518195327
Metcalfe KA, Lynch HT, Ghadirian P, . The risk of ovarian cancer after breast cancer in BRCA1 and BRCA2 carriers. Gynecol Oncol. 2005 Jan;96(1):222–6. PMID: 15589605. Exclusion: E415589605
Metcalfe KA, Poll A, Llacuachaqui M, . Patient satisfaction and cancer-related distress among unselected Jewish women undergoing genetic testing for BRCA1 and BRCA2. Clin Genet. 2010 Nov;78(5):411–7. doi: 10.1111/j.1399-0004.2010.01499.x. PMID: 20653694. Exclusion: H220653694
Metcalfe KA, Poll A, Llacuachaqui M, . Patient-reported outcomes associated with population-based Jewish genetic testing for BRCA1 and BRCA2. J Clin Oncol. 2015;33(15). Exclusion: E6
Metcalfe KA, Semple JL, Narod SA. Time to reconsider subcutaneous mastectomy for breast-cancer prevention? Lancet Oncol. 2005 Jun;6(6):431–4. PMID: 15925821. Exclusion: E915925821
Metcalfe KA, Snyder C, Seidel J, . The use of preventive measures among healthy women who carry a BRCA1 or BRCA2 mutation. Fam Cancer. 2005;4(2):97–103. PMID: 15951959. Exclusion: E515951959
Meyer F, Farrell E, Yuppa D. When ethical dilemmas split teams: Case studies of fertility preservation in the context of metastatic cancer. Psychooncology. 2015;24:64–5. doi: 10.1002/pon.3873. Exclusion: E6
Meyer LA, Anderson ME, Lacour RA, . Evaluating women with ovarian cancer for BRCA1 and BRCA2 mutations: missed opportunities. Obstet Gynecol. 2010 May;115(5):945–52. PMID: 20410767. Exclusion: E320410767
Michelsen TM, Dorum A, Dahl AA. A controlled study of mental distress and somatic complaints after risk-reducing salpingo-oophorectomy in women at risk for hereditary breast ovarian cancer. Gynecol Oncol. 2009 Apr;113(1):128–33. PMID: 19178933. Exclusion: E319178933
Michelsen TM, Pripp AH, Tonstad S, . Metabolic syndrome after risk-reducing salpingo-oophorectomy in women at high risk for hereditary breast ovarian cancer: a controlled observational study. Eur J Cancer. 2009 Jan;45(1):82–9. PMID: 19008092. Exclusion: E319008092
Michelsen TM, Tonstad S, Pripp AH, . Coronary heart disease risk profile in women who underwent salpingo-oophorectomy to prevent hereditary breast ovarian cancer. Int J Gynecol Cancer. 2010 Feb;20(2):233–9. PMID: 20169665. Exclusion: E320169665
Miki Y, Swensen J, Shattuck-Eidens D, . A strong candidate for the breast and ovarian cancer susceptibility gene BRCA1. Science. 1994 Oct 07;266(5182):66–71. PMID: 7545954. Exclusion: 27545954
Mikkelsen EM, Sunde L, Johansen C, . Psychosocial conditions of women awaiting genetic counseling: a population-based study. J Genet Couns. 2008 Jun;17(3):242–51. PMID: 18256912. Exclusion: E418256912
Milewski B, McKenna D, Parker M, . Risk models accuracy at predicting BRCA1 and BRCA2 mutation status. Curr Oncol. 2012;19(2):e108. doi: 10.3747/co.19.1076. Exclusion: E9
Milhabet I, Duprez C, Krzeminski A, . Cancer risk comparative perception and overscreening behaviours of non-carriers from BRCA1/2 families. Eur J Cancer Care (Engl). 2013 Jul;22(4):540–8. doi: 10.1111/ecc.12060 PMID: 23731020. Exclusion: E323731020
Miller DM, McAlpine JN, Gilks CB, . Opportunistic salpingectomy: the way forward-response to Steven Narod. Curr Oncol. 2013;20(3):143–4. doi: 10.3747/co.20.1492. PMID: 23737680. Exclusion: E623737680
Miller FA, Giacomini M, Ahern C. Contending visions in the evolution of genetic medicine: The case of cancer genetic services in Ontario, Canada. Soc Sci Med. 2008 Jul;67(1):152–60. doi: 10.1016/j.socscimed.2008.03.035. PMID: 18436360. Exclusion: E318436360
Miller H, Pipkin LS, Tung C, . The role of routine peritoneal and omental biopsies at risk-reducing salpingo-oophorectomy. J Minim Invasive Gynecol. 2017 Jul – Aug;24(5):772–6. doi: 10.1016/j.jmig.2017.03.001. PMID: 28285055. Exclusion: E3a28285055
Miller SM, Fleisher L, Roussi P, . Facilitating informed decision making about breast cancer risk and genetic counseling among women calling the NCI’s Cancer Information Service. J Health Commun. 2005;10: Suppl 1:119–36. PMID: 16377604. Exclusion: H216377604
Miller SM, Roussi P, Daly MB, . Enhanced counseling for women undergoing BRCA1/2 testing: impact on subsequent decision making about risk reduction behaviors. Health Educ Behav. 2005 Oct;32(5):654–67. PMID: 16148211. Exclusion: E3a16148211
Miller SM, Roussi P, Daly MB, . New strategies in ovarian cancer: uptake and experience of women at high risk of ovarian cancer who are considering risk-reducing salpingo-oophorectomy. Clin Cancer Res. 2010 Nov 1;16(21):5094–106. PMID: 20829330. Exclusion: E520829330
Miller-Samuel S, Rosenberg A, Berger A, . BRCA1 and BRCA2 variants of uncertain significance. Part two: medical management. Semin Oncol. 2011 Oct;38(5):605–11. doi: 10.1053/j.seminoncol.2011.04.009. PMID: 21943665. Exclusion: E621943665
Milne RL, Knight JA, John EM, . Oral contraceptive use and risk of early-onset breast cancer in carriers and noncarriers of BRCA1 and BRCA2 mutations. Cancer Epidemiol Biomarkers Prev. 2005 Feb;14(2):350–6. PMID: 15734957. Exclusion: E515734957
Mireskandari S, Meiser B, Sherman K, . Evaluation of the needs and concerns of partners of women at high risk of developing breast/ovarian cancer. Psycho Oncology. 2006 Feb;15(2):96–108. doi: 10.1002/pon.925. PMID: 15880639. Exclusion: E315880639
Mireskandari S, Sherman KA, Meiser B, . Psychological adjustment among partners of women at high risk of developing breast/ovarian cancer. Genet Med. 2007 May;9(5):311–20. PMID: 17505209. Exclusion: E317505209
Missana MC, Chompret A. [Prophylactic mastectomies and immediate breast reconstruction in patients at very high genetic risk: our experience with 14 cases]. Ann Chir Plast Esthet. 2008 Aug;53(4):325–33. PMID: 18055089. Exclusion: E818055089
Mitchell G. Clinical management of women in BRCAX families: Issues and controversies. Hered Cancer Clin Pract. 2012;10. Exclusion: E6
Moatter T, Aban M, Khan S, . BRCA1 status in Pakistani breast cancer patients with moderate family history. J Coll Physicians Surg Pak. 2011 Nov;21(11):680–4. PMID: 22078348. Exclusion: E522078348
Moberg IO, Schou Bredal I, Schneider MR, . Complications, risk factors, and patients-reported outcomes after skin-sparing mastectomy followed by breast reconstruction in women with BRCA mutations. J Plast Surg Hand Surg. 2018 Aug;52(4):234–9. doi: 10.1080/2000656X.2018.1470093. PMID: 29741462. Exclusion: H229741462
Mohamad HB, Apffelstaedt JP. Counseling for male BRCA mutation carriers: a review. Breast. 2008 Oct;17(5):441–50. PMID: 18657973. Exclusion: E318657973
Mokbel K. Risk-reducing strategies for breast cancer-a review of recent literature. Int J Fertil Womens Med. 2003 Nov–Dec;48(6):274–7. PMID: 15646397. Exclusion: E915646397
Molina Y, Ceballos RM, Dolan ED, . Perceived breast cancer risk and breast cancer worry among women with a family history of breast cancer: a new perspective on coping as a mediator. Psychooncology. 2015 Jan;24(1):113–6. doi: 10.1002/pon.3587. PMID: 24986795. Exclusion: E324986795
Moller P. Costs and benefits of diagnosing familial breast cancer. Ann Oncol. 2004;15: Suppl 1:I55–I9. PMID: 15280189. Exclusion: E615280189
Moller P, Evans DG, Reis MM, . Surveillance for familial breast cancer: Differences in outcome according to BRCA mutation status. Int J Cancer. 2007 Sep 1;121(5):1017–20. PMID: 17471561. Exclusion: E317471561
Møller P, Hagen AI, Apold J, . Genetic epidemiology of BRCA mutations - family history detects less than 50% of the mutation carriers. Eur J Cancer. 2007;43(11):1713–7. PMID: 17574839. Exclusion: 217574839
Moller P, Maehle L, Apold J. [Hereditary breast cancer]. Tidsskr Nor Laegeforen. 2005 Nov 17;125(22):3136–8. PMID: 16299574. Exclusion: E816299574
Montgomery KG, Chang J-H, Gertig DM, . The AIB1 glutamine repeat polymorphism is not associated with risk of breast cancer before age 40 years in Australian women. Breast Cancer Res. 2005;7(3):R353–6. PMID: 15987430. Exclusion: E515987430
Montgomery SV, Barsevick AM, Egleston BL, . Preparing individuals to communicate genetic test results to their relatives: report of a randomized control trial. Fam Cancer. 2013 Sep;12(3):537–46. doi: 10.1007/s10689-013-9609-z. PMID: 23420550. Exclusion: E3a23420550
Mook J, Hamann HA, Robinson L, . BRCA gene mutation testing and uptake of risk management recommendations in a minority underinsured population. Ann Surg Oncol. 2011;18:S176. doi: 10.1245/s10434-011-1680-9. Exclusion: E6
Moorman PG, Havrilesky LJ, Gierisch JM, . Oral contraceptives and risk of ovarian cancer and breast cancer among high-risk women: a systematic review and meta-analysis. J Clin Oncol. 2013;31(33):4188–98. PMID: 24145348. Exclusion: E524145348
Moran O, Nikitina D, Royer R, . Revisiting breast cancer patients who previously tested negative for BRCA mutations using a 12-gene panel. Breast Cancer Res Treat. 2017;161(1):135–42. doi: 10.1007/s10549-016-4038-y. PMID: 27798748. Exclusion: E727798748
Morelli M, Venturella R, Mocciaro R, . Prophylactic salpingectomy in premenopausal low-risk women for ovarian cancer: primum non nocere. Gynecol Oncol. 2013 Jun;129(3):448–51. doi: 10.1016/j.ygyno.2013.03.023. PMID: 23558052. Exclusion: E323558052
Morgan D, Sylvester H, Lucas FL, . Hereditary breast and ovarian cancer: referral source for genetic assessment and communication regarding assessment with nongenetic clinicians in the community setting. Genet Med. 2010 Jan;12(1):25–31. PMID: 20027114. Exclusion: E520027114
Morgan R, Brown A, Hamman KJ, . Risk management decisions in women with BRCA1 and BRCA2 mutations. Am J Surg. 2018;215(5):899–903. doi: 10.1016/j.amjsurg.2018.02.010. PMID: 29499861. Exclusion: E3a29499861
Morrison PJ. Insurance, unfair discrimination, and genetic testing. Lancet. 2005 Sep;366(9489):877–80. doi: 10.1016/S0140-6736%2805%2967298-4. PMID: 16154000. Exclusion: E616154000
Morrow M, Waters J, Morris E. MRI for breast cancer screening, diagnosis, and treatment. Lancet. 2011 Nov 19;378(9805):1804–11. PMID: 22098853. Exclusion: E922098853
Moss HA, Samimi G, Havrilesky LJ, . Estimating the number of potential family members eligible for BRCA1 and BRCA2 mutation testing in a "Traceback" approach. Genet Epidemiol. 2018 02;42(1):117–22. doi: 10.1002/gepi.22095. PMID: 29193313. Exclusion: E3a29193313
Mouchawar J, Valentine Goins K, Somkin C, . Guidelines for breast and ovarian cancer genetic counseling referral: adoption and implementation in HMOs. Genet Med. 2003 Nov–Dec;5(6):444–50. doi: 10.1097/01.gim.0000093979.08524.86. PMID: 14614396. Exclusion: 214614396
Mourits MJ, de Bock GH. Managing hereditary ovarian cancer. Maturitas. 2009 Nov 20;64(3):172–6. PMID: 19811881. Exclusion: E919811881
Moyer VA, U. S. Preventive Services Task Force. Risk assessment, genetic counseling, and genetic testing for BRCA-related cancer in women: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2014 Feb 18;160(4):271–81. doi: 10.7326/M13-2747. PMID: 24366376. Exclusion: 224366376
Mozersky J. Who’s to blame? Accounts of genetic responsibility and blame among Ashkenazi Jewish women at risk of BRCA breast cancer. Sociol Health Illn. 2012 Jun;34(5):776–90. doi: 10.1111/j.1467-9566.2011.01427.x. PMID: 22257279. Exclusion: E722257279
Muggia F, Smaldone V, Paradiso A. Conclusions: fruits of the convergence of laboratory, clinic and public. Ann Oncol. 2011 Jan;22: Suppl 1:i67–8. PMID: 21285155. Exclusion: E621285155
Muir A, Meiser B, Tucker M, . The feasibility of women at high risk for breast cancer participating in chemoprevention trials: An attitudinal study. J Psychosoc Oncol. 2004;22(4):31–45. doi: 10.1300/J077v22n04_02. Exclusion: E3
Murphy RX, Jr., Adkinson JM, Namey T, . Surgical and financial implications of genetic counseling and requests for concurrent prophylactic mastectomy.[Erratum appears in Ann Plast Surg. 2010 Jul;65(1):116 Note: Adkinson, Joshua M [added]]. Ann Plast Surg. 2010 May;64(5):684–7. PMID: 20395792. Exclusion: E320395792
Murray ML, Cerrato F, Bennett RL, . Follow-up of carriers of BRCA1 and BRCA2 variants of unknown significance: variant reclassification and surgical decisions. Genet Med. 2011 Dec;13(12):998–1005. doi: 10.1097/GIM.0b013e318226fc15. PMID: 21811163. Exclusion: E521811163
Murthy RK, Chen H, Wei C, . Genetic testing referral patterns and clinical outcomes among high-risk breast cancer survivors. J Clin Oncol. 2014;32(15). Exclusion: E4
Myers ER, Havrilesky LJ, Kulasingam SL, . Genomic tests for ovarian cancer detection and management. Evidence Report/Technology Assessment. 2006 Oct(145):1–100. PMID: 17764207. Exclusion: E317764207
Mykitiuk R. Caveat emptor: direct-to-consumer supply and advertising of genetic testing. Clin Invest Med. 2004 Feb;27(1):23–32. PMID: 15061583. Exclusion: E615061583
Myriad. Myriad PRO BRCA1 and BRCA2 prevalence tables. Salt Lake City, Utah; 2012. http://d1izdzz43r5o67.cloudfront.net/brac/brca-prevalence-tables.pdf. Accessed May 16 2019. Exclusion: 2
Nakagomi H, Sakamoto I, Hirotsu Y, . Willingness of Japanese patients with breast cancer to have genetic testing of BRCA without burden of expenses. Breast Cancer. 2016;23(4):649–53. doi: 10.1007/s12282-015-0618-7. PMID: 26025266. Exclusion: E326025266
Narod SA. Testing for CHEK2 in the cancer genetics clinic: ready for prime time? Clin Genet. 2010 Jul;78(1):1–7. PMID: 20597917. Exclusion: E320597917
Narod SA. The impact of contralateral mastectomy on mortality in BRCA1 and BRCA2 mutation carriers with breast cancer. Breast Cancer Res Treat. 2011 Jul;128(2):581–3. PMID: 21455666. Exclusion: E621455666
Narod SA, Brunet JS, Ghadirian P, . Tamoxifen and risk of contralateral breast cancer in BRCA1 and BRCA2 mutation carriers: A case-control study. Lancet. 2000;356(9245):1876–81. PMID: 11130383. Exclusion: E3b11130383
Narod SA, Moody JR, Rosen B, . Estimating survival rates after ovarian cancer among women tested for BRCA1 and BRCA2 mutations. Clin Genet. 2013 Mar;83(3):232–7. doi: 10.1111/j.1399-0004.2012.01906.x. PMID: 22680617. Exclusion: E622680617
Narod SA, Rodriguez AA. [Genetic predisposition for breast cancer: BRCA1 and BRCA2 genes]. Salud Publica Mex. 2011 Sep–Oct;53(5):420–9. PMID: 22218796. Exclusion: E822218796
Narod SA, Salmena L. BRCA1 and BRCA2 mutations and breast cancer. Discov Med. 2011 Nov;12(66):445–53. PMID: 22127115. Exclusion: E922127115
Narod SA, Sun P, Ghadirian P, . Tubal ligation and risk of ovarian cancer in carriers of BRCA1 or BRCA2 mutations: a case-control study. The Lancet. 2001;357(9267):1467–70. PMID: 11377596. Exclusion: E711377596
Nasir A, Shackelford RE, Anwar F, . Genetic risk of breast cancer. Minerva Endocrinol. 2009 Dec;34(4):295–309. PMID: 20046159. Exclusion: E920046159
Nathanson KL, Domchek SM. Therapeutic approaches for women predisposed to breast cancer. Annu Rev Med. 2011 Feb 18;62:295–306. PMID: 21034216. Exclusion: E621034216
Nathorst-Böös J, von Schoultz B, Carlström K. Elective ovarian removal and estrogen replacement therapy-effects on sexual life, psychological well-being and androgen status. J Psychosom Obstet Gynaecol. 1993;14(4):283. PMID: 8142982. Exclusion: E38142982
National Breast Cancer Center. Advice about familial aspects of breast cancer and ovarian cancer - A guide for health professionals. Sydney: National Breast Cancer Center; 2000. Exclusion:
National Cancer Institute. PDQ® Breast Cancer Treatment. 2013. http://www.cancer.gov/cancertopics/pdq/treatment/breast/healthprofessional. Accessed May 1 2019. Exclusion: 2
National Cancer Institute. Breast cancer. 2012. http://www.cancer.gov/cancertopics/types/breast. Accessed May 16 2019. Exclusion: 2
National Cancer Institute. SEER Stat Fact Sheets: Female breast cancer. Bethesda, MD: National Cancer Institute 2016. https://seer.cancer.gov/statfacts/html/breast.html. Accessed May 16 2019. Exclusion: 2
National Cancer Institute. SEER Cancer Statistics Factsheets: Ovarian cancer. Bethesda, MD: National Cancer Institute; 2016. http://seer.cancer.gov/statfacts/html/ovary.html. Accessed July 2 2018. Exclusion: 2
National Cancer Institute. Genetics of Breast and Gynecologic Cancers (PDQ®)–Health Professional Version. U.S. Department of Health and Human Services 2017. http://www.cancer.gov/cancertopics/pdq/treatment/breast/healthprofessional. Accessed May 16 2019. Exclusion: 2
National Cancer Institute. Cancer Stat Facts: Female breast cancer. National Institute of Health; 2018. https://seer.cancer.gov/statfacts/html/breast.html. Accessed May 16 2019. Exclusion: 2
National Comprehensive Cancer N. Breast cancer risk reduction clinical practice guidelines in oncology. J Natl Compr Canc Netw. 2003 Apr;1(2):280–96. PMID: 19768886. Exclusion: E619768886
National Comprehensive Cancer Network. NCCN Clinical Practice Guidelines in Oncology: Breast cancer screening and diagnosis. 2018. https://www.nccn.org/professionals/physician_gls/pdf/breast-screening.pdf. Accessed May 1 2019. Exclusion: 2
National Comprehensive Cancer Network. Genetic/Familial High-Risk Assessment: Breast and Ovarian. 2019. http://www.nccn.org/professionals/physician_gls/pdf/genetics_screening.pdf. Accessed May 16 2019. Exclusion: 2
Navarro de Souza A, Groleau D, Loiselle CG, . Cultural aspects of healthy BRCA carriers from two ethnocultural groups. Qual Health Res. 2014 May;24(5):665–81. doi: 10.1177/1049732314528756. PMID: 24692182. Exclusion: E424692182
Nease RFJ, Ross JM. The decision to enter a randomized trial of tamoxifen for the prevention of breast cancer in healthy women: an analysis of the tradeoffs [see comments]. Am J Med. 1995;99(2):180–9. PMID: 7625423. Exclusion: E77625423
Nebgen DR, Hurteau J, Holman LL, . Bilateral salpingectomy with delayed oophorectomy for ovarian cancer risk reduction: a pilot study in women with BRCA1/2 mutations. Gynecol Oncol. 2018 PMID: 29735278. Exclusion: E3a29735278
Negura L, Uhrhammer N, Negura A, . Complete BRCA mutation screening in breast and ovarian cancer predisposition families from a North-Eastern Romanian population. Fam Cancer. 2010 Dec;9(4):519–23. PMID: 20567915. Exclusion: E520567915
Nelson HD, Fu R, Goddard K, . Risk assessment, genetic counseling, and genetic testing for BRCA-related cancer: Systematic review to update the U.S. Preventive Services Task Force recommendation Agency for Healthcare Research and Quality. Rockville (MD): 2013. https://www.ncbi.nlm.nih.gov/pubmed/24432435 PMID: 2443243524432435. Exclusion: 2
Nelson HD, Fu R, Griffin JC, . Systematic review: comparative effectiveness of medications to reduce risk for primary breast cancer. Ann Intern Med. 2009 Nov 17;151(10):703–15, w-226-35. doi: 10.7326/0003-4819-151-10-200911170-00147. PMID: 19920271. Exclusion: 219920271
Nelson HD, Fu R, McDonagh M, . Medication Use for the Risk Reduction of Primary Breast Cancer in Women: A Systematic Review for the U.S. Preventive Services Task Force [in press]. Rockville, MD: Agency for Healthcare Research and Quality: 2019. Exclusion: 2
Nelson HD, Pappas M, Zakher B, . Risk assessment, genetic counseling, and genetic testing for BRCA-related cancer in women: a systematic review to update the U.S. Preventive Services Task Force recommendation. Ann Intern Med. 2014 Feb 18;160(4):255–66. doi: 10.7326/M13-1684. PMID: 24366442. Exclusion: 224366442
Nelson HD, Smith ME, Griffin JC, . Use of medications to reduce risk for primary breast cancer: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2013 Apr 16;158(8):604–14. doi: 10.7326/0003-4819-158-8-201304160-00005. PMID: 23588749. Exclusion: 223588749
Neuhausen S, Gilewski T, Norton L, . Recurrent BRCA2 6174delT mutations in Ashkenazi Jewish women affected by breast cancer. Nat Genet. 1996 May;13(1):126–8. doi: 10.1038/ng0596-126. PMID: 8673092. Exclusion: 28673092
Neuhausen SL, Brummel S, Ding YC, . Genetic variation in IGF2 and HTRA1 and breast cancer risk among BRCA1 and BRCA2 carriers. Cancer Epidemiol Biomarkers Prev. 2011 Aug;20(8):1690–702. PMID: 21708937. Exclusion: E521708937
Newman LA. Risk-reducing mastectomy: Who is a candidate and what are the outcomes? Curr Breast Cancer Rep. 2013;5(2):73–85. doi: 10.1007/s12609-013-0110-3. Exclusion: E9
Ngoi N, Lee S-C, Hartman M, . Interest and attitudes of patients, cancer physicians, medical students and cancer researchers towards a spectrum of genetic tests relevant to breast cancer patients. Breast. 2013 Feb;22(1):47–52. doi: 10.1016/j.breast.2012.04.003. PMID: 22560561. Exclusion: E522560561
Ni X, Ma J, Zhao Y, . Meta‐analysis on the association between non‐steroidal anti‐inflammatory drug use and ovarian cancer. Br J Clin Pharmacol. 2013;75(1):26–35. PMID: 22471948. Exclusion: E522471948
Nilsson MP, Hartman L, Kristoffersson U, . High risk of in-breast tumor recurrence after BRCA1/2-associated breast cancer. Breast Cancer Res Treat. 2014 Oct;147(3):571–8. doi: 10.1007/s10549-014-3115-3. PMID: 25187270. Exclusion: E325187270
Nisman B, Kadouri L, Allweis T, . Increased proliferative background in healthy women with BRCA1/2 haploinsufficiency is associated with high risk for breast cancer. Cancer Epidemiol Biomarkers Prev. 2013 Nov;22(11):2110–5. doi: 10.1158/1055-9965.EPI-13-0193. PMID: 23966579. Exclusion: E523966579
Noah-Vanhoucke J, Green LE, Dinh TA, . Cost-effectiveness of chemoprevention of breast cancer using tamoxifen in a postmenopausal US population. Cancer. 2011 Aug;117(15):3322–31. doi: 10.1002/cncr.25926. PMID: 21404271. Exclusion: E521404271
Nobbenhuis M, Brockbank E, Ind TEJ, . Serous intraepithelial carcinoma (STIC) and p53 signatures in women who have had risk reducing bilateral salpingo-oophorectomy: Our experience. Int J Gynecol Cancer. 2013;23(8):955. Exclusion: E6
Noble R, Bahadur G, Iqbal M, . Pandora’s box: ethics of PGD for inherited risk of late-onset disorders. Reproductive Biomedicine Online. 2008;17: Suppl 3:55–60. PMID: 18983739. Exclusion: E618983739
Nordin K, Roshanai A, Bjorvatn C, . Is genetic counseling a stressful event? Acta Oncol. 2011 Oct;50(7):1089–97. PMID: 21864049. Exclusion: E321864049
Norman P, Brain K. Does dispositional optimism predict psychological responses to counseling for familial breast cancer? J Psychosom Res. 2007 Sep;63(3):247–54. PMID: 17719361. Exclusion: 217719361
Norman SA, Potashnik SL, Galantino ML, . Modifiable risk factors for breast cancer recurrence: What can we tell survivors? J Womens Health. 2007 Mar;16(2):177–90. doi: 10.1089/jwh.2006.0047. PMID: 17388734. Exclusion: E317388734
Norquist BM, Garcia RL, Allison KH, . The molecular pathogenesis of hereditary ovarian carcinoma: alterations in the tubal epithelium of women with BRCA1 and BRCA2 mutations. Cancer. 2010 Nov 15;116(22):5261–71. doi: 10.1002/cncr.25439. PMID: 20665887. Exclusion: 220665887
Norquist BM, Pennington KP, Agnew KJ, . Characteristics of women with ovarian carcinoma who have BRCA1 and BRCA2 mutations not identified by clinical testing. Gynecol Oncol. 2013 Mar;128(3):483–7. doi: 10.1016/j.ygyno.2012.12.015. PMID: 23262210. Exclusion: E323262210
Norum J, Hagen AI, Maehle L, . Prophylactic bilateral salpingo-oophorectomy (PBSO) with or without prophylactic bilateral mastectomy (PBM) or no intervention in BRCA1 mutation carriers: a cost-effectiveness analysis. Eur J Cancer. 2008 May;44(7):963–71. PMID: 18362067. Exclusion: E718362067
Noruzinia M, Coupier I, Pujol P. Is BRCA1/BRCA2-related breast carcinogenesis estrogen dependent? Cancer. 2005 Oct 15;104(8):1567–74. PMID: 16155942. Exclusion: E416155942
Nurudeen S, Chun Y, Guo H, . Patient experience with breast reconstruction following bilateral mastectomy in BRCA mutation carriers. Ann Surg Oncol. 2016;23(1):S72–S3. doi: 10.1245/s10434-015-5010-5. PMID: 28683895. Exclusion: E728683895
Obdeijn IM, Winter-Warnars GA, Mann RM, . Should we screen BRCA1 mutation carriers only with MRI? A multicenter study. Breast Cancer Res Treat. 2014 Apr;144(3):577–82. doi: 10.1007/s10549-014-2888-8. PMID: 24567197. Exclusion: E324567197
Oberguggenberger A, Sztankay M, Morscher RJ, . Psychosocial outcomes and counselee satisfaction following genetic counseling for hereditary breast and ovarian cancer: A patient-reported outcome study. J Psychosom Res. 2016 10;89:39–45. doi: 10.1016/j.jpsychores.2016.08.005. PMID: 27663109. Exclusion: E3b27663109
Obermair A, Youlden DR, Baade PD, . The impact of risk-reducing hysterectomy and bilateral salpingo-oophorectomy on survival in patients with a history of breast cancer-a population-based data linkage study. Int J Cancer. 2014 May 1;134(9):2211–22. doi: 10.1002/ijc.28537. PMID: 24127248. Exclusion: E3a24127248
Oei AL, Massuger LF, Bulten J, . Surveillance of women at high risk for hereditary ovarian cancer is inefficient. Br J Cancer. 2006;94(6):814–9. PMID: 16495917. Exclusion: E416495917
Oestreicher N, Ramsey SD, Linden HM, . Gene expression profiling and breast cancer care: what are the potential benefits and policy implications? Genet Med. 2005 Jul–Aug;7(6):380–9. doi: 10.1097/01.gim.0000170776.31248.75. PMID: 16024969. Exclusion: E716024969
Offit K, Kohut K, Clagett B, . Cancer genetic testing and assisted reproduction. J Clin Oncol. 2006 Oct 10;24(29):4775–82. PMID: 16840542. Exclusion: E516840542
Oguntola AS, Olaitan PB, Omotoso O, . Knowledge, attitude and practice of prophylactic mastectomy among patients and relations attending a surgical outpatient clinic. Pan Afr Med J. 2012;13:20. PMID: 23308325. Exclusion: E323308325
Olawaiye A, Caesar L, Walsh D, . Analysis of the time interval between diagnoses in women with double primary breast and ovarian or primary peritoneal cancers. Gynecol Oncol. 2004 Sep;94(3):796–802. PMID: 15350375. Exclusion: 215350375
Oliver Perez MR, Magrina J, Garcia AT, . Prophylactic salpingectomy and prophylactic salpingoophorectomy for adnexal high-grade serous epithelial carcinoma: A reappraisal. Surg Oncol. 2015 Dec;24(4):335–44. doi: 10.1016/j.suronc.2015.09.008. PMID: 26690823. Exclusion: E926690823
Olivier RI, Lubsen-Brandsma LAC, van Boven H, . Additional salpingectomy after previous prophylactic oophorectomy in high-risk women: sense or nonsense? Gynecol Oncol. 2005 Feb;96(2):439–43. PMID: 15661233. Exclusion: E415661233
Olivier RI, van Beurden M. Re: “Intra-abdominal carcinomatosis after prophylactic oophorectomy in women of hereditary breast ovarian cancer syndrome kindreds associated with BRCA1 and BRCA2 mutations”. Gynecol Oncol. 2005 Nov;99(2):520–1. PMID: 16188301. Exclusion: E616188301
Olivier RI, Van Beurden M, Lubsen MAC, . Clinical outcome of prophylactic oophorectomy in BRCA1/BRCA2 mutation carriers and events during follow-up. Br J Cancer. 2004;90(8):1492–7. PMID: 15083174. Exclusion: E3a15083174
Olopade OI, Grushko TA, Nanda R, . Advances in breast cancer: pathways to personalized medicine. Clin Cancer Res. 2008 Dec 15;14(24):7988–99. PMID: 19088015. Exclusion: E419088015
Onay VU, Briollais L, Knight JA, . SNP-SNP interactions in breast cancer susceptibility. BMC Cancer. 2006;6:114. PMID: 16672066. Exclusion: E516672066
O’Neill SC, Brewer NT, Lillie SE, . Women’s interest in gene expression analysis for breast cancer recurrence risk. J Clin Oncol. 2007 Oct 10;25(29):4628–34. PMID: 17925559. Exclusion: E317925559
O’Neill SC, DeMarco T, Peshkin BN, . Tolerance for uncertainty and perceived risk among women receiving uninformative BRCA1/2 test results. Am J Med Genet C Semin Med Genet. 2006;142(4):251–9. PMID: 17024668. Exclusion: E3b17024668
O’Neill SC, Kaufman E, DeMarco T, . Changes in diet and physical activity following BRCA1/2 testing. J Psychosoc Oncol. 2008 Jun;26(3):63–80. doi: 10.1080/07347330802116051. PMID: 19042265. Exclusion: 219042265
O’Neill SC, Rini C, Goldsmith RE, . Distress among women receiving uninformative BRCA1/2 results: 12-month outcomes. Psychooncology. 2009 Oct;18(10):1088–96. PMID: 19214961. Exclusion: E3b19214961
Ong J-S, Cuellar-Partida G, Lu Y, . Association of vitamin D levels and risk of ovarian cancer: a Mendelian randomization study. Int J Epidemiol. 2016;45(5):1619–30. PMID: 27594614. Exclusion: E527594614
Ong KR, Sims AH, Harvie M, . Biomarkers of dietary energy restriction in women at increased risk of breast cancer. Cancer Prev Res (Phila). 2009 Aug;2(8):720–31. PMID: 19656771. Exclusion: E419656771
Orlando LA, Wu RR, Beadles C, . Implementing family health history risk stratification in primary care: impact of guideline criteria on populations and resource demand. Am J Med Genet C Semin Med Genet. 2014 Mar;166C(1):24–33. doi: 10.1002/ajmg.c.31388. PMID: 24616329. Exclusion: E424616329
Ormondroyd E, Donnelly L, Moynihan C, . Attitudes to reproductive genetic testing in women who had a positive BRCA test before having children: a qualitative analysis. Eur J Hum Genet. 2012 Jan;20(1):4–10. doi: 10.1038/ejhg.2011.146. PMID: 21811309. Exclusion: E521811309
Ormsby EL, Pavlik EJ, van Nagell JR. Ultrasound follow up of an adnexal mass has the potential to save lives. Am J Obstet Gynecol. 2015 Nov;213(5):657–61, .e1. doi: 10.1016/j.ajog.2015.06.041. PMID: 26116103. Exclusion: E626116103
Ow SG, Yong YF, Chieng WS, . Inadequate family history assessment by oncologists is an important physician barrier to referral for hereditary breast cancer evaluation. Clin Oncol (R Coll Radiol). 2014 Mar;26(3):174–5. doi: 10.1016/j.clon.2013.11.029. PMID: 24393786. Exclusion: E524393786
Ozanne E, Esserman L. Decision making in breast cancer prevention. Psicooncologia. 2010;7(2–3):299–311. Exclusion: E6
Ozanne EM, Wittenberg E, Garber JE, . Breast cancer prevention: patient decision making and risk communication in the high risk setting. Breast J. 2010 Jan–Feb;16(1):38–47. PMID: 19889168. Exclusion: E419889168
Paik DY, Amersi F, Bresee C, . Risk of breast cancer following ovarian cancer and the impact on overall survival. Gynecol Oncol. 2014;133:148. doi: 10.1016/j.ygyno.2014.03.388. Exclusion: E6
Pal T, Permuth-Wey J, Betts JA, . BRCA1 and BRCA2 mutations account for a large proportion of ovarian carcinoma cases. Cancer. 2005 Dec 15;104(12):2807–16. PMID: 16284991. Exclusion: E516284991
Pal T, Permuth-Wey J, Holtje T, . BRCA1 and BRCA2 mutations in a study of African American breast cancer patients. Cancer Epidemiol Biomarkers Prev. 2004 Nov;13(11 Pt 1):1794–9. PMID: 15533909. Exclusion: E515533909
Pal T, Rocchio E, Garcia A, . Recruitment of black women for a study of inherited breast cancer using a cancer registry-based approach. Genet Test Mol Biomarkers. 2011 Jan–Feb;15(1–2):69–77. PMID: 21117951. Exclusion: E521117951
Pal T, Vadaparampil S, Betts J, . BRCA1/2 in high-risk African American women with breast cancer: providing genetic testing through various recruitment strategies. Genetic Testing. 2008 Sep;12(3):401–7. PMID: 18752448. Exclusion: E518752448
Palanca Suela S, Esteban Cardenosa E, Barragan Gonzalez E, . CASP8 D302H polymorphism delays the age of onset of breast cancer in BRCA1 and BRCA2 carriers. Breast Cancer Res Treat. 2010 Jan;119(1):87–93. PMID: 19214744. Exclusion: E519214744
Paley PJ, Swisher EM, Garcia RL, . Occult cancer of the fallopian tube in BRCA-1 germline mutation carriers at prophylactic oophorectomy: a case for recommending hysterectomy at surgical prophylaxis. Gynecol Oncol. 2001;80:176–80. PMID: 11161856. Exclusion: E711161856
Palli D, Falchetti M, Masala G, . Association between the BRCA2 N372H variant and male breast cancer risk: a population-based case-control study in Tuscany, Central Italy. BMC Cancer. 2007;7:170. PMID: 17767707. Exclusion: E317767707
Palma M, Ristori E, Ricevuto E, . BRCA1 and BRCA2: the genetic testing and the current management options for mutation carriers. Crit Rev Oncol Hematol. 2006 Jan;57(1):1–23. PMID: 16337408. Exclusion: E616337408
Palma MD, Domchek SM, Stopfer J, . The relative contribution of point mutations and genomic rearrangements in BRCA1 and BRCA2 in high-risk breast cancer families. Cancer Res. 2008 Sep 1;68(17):7006–14. PMID: 18703817. Exclusion: 218703817
Palmer JR, Boggs DA, Adams-Campbell LL, . Family history of cancer and risk of breast cancer in the Black Women’s Health Study. Cancer Causes Control. 2009 Nov;20(9):1733–7. PMID: 19760028. Exclusion: E519760028
Palmer MK, Ribeiro GG. Thirty-four year follow up of patients with breast cancer in clinical trial of postoperative radiotherapy. Br Med J (Clin Res Ed). 1985 Oct;291(6502):1088–91. PMID: 3931806. Exclusion: E33931806
Palmieri G, Palomba G, Cossu A, . BRCA1 and BRCA2 germline mutations in Sardinian breast cancer families and their implications for genetic counseling. Ann Oncol. 2002;13(12):1899–907. PMID: 12453858. Exclusion: E512453858
Palomaki GE, McClain MR, Steinort K, . Screen-positive rates and agreement among six family history screening protocols for breast/ovarian cancer in a population-based cohort of 21- to 55-year-old women. Genet Med. 2006 Mar;8(3):161–8. PMID: 16540750. Exclusion: E416540750
Palomares MR, Machia JRB, Lehman CD, . Mammographic density correlation with Gail model breast cancer risk estimates and component risk factors. Cancer Epidemiol Biomarkers Prev. 2006 Jul;15(7):1324–30. PMID: 16835331. Exclusion: E516835331
Palomares MR, Paz B, Weitzel JN. Genetic cancer risk assessment in the newly diagnosed breast cancer patient is useful and possible in practice. J Clin Oncol. 2005 May 1;23(13):3165–6; author reply 6-7. PMID: 15860891. Exclusion: E615860891
Palombi L. Comment on “Myriad genetics: in the eye of the policy storm”. Genet Med. 2010 Jul;12(7):471; author reply -2. PMID: 20631548. Exclusion: E620631548
Pan H, He Z, Ling L, . Reproductive factors and breast cancer risk among BRCA1 or BRCA2 mutation carriers: results from ten studies. Cancer Epidemiol. 2014 Feb;38(1):1–8. doi: 10.1016/j.canep.2013.11.004. PMID: 24332935. Exclusion: E424332935
Panchal S, Bordeleau L, Poll A, . Does family history predict the age at onset of new breast cancers in BRCA1 and BRCA2 mutation-positive families? Clin Genet. 2010 Mar;77(3):273–9. PMID: 20002453. Exclusion: E520002453
Pankratz VS, Hartmann LC, Degnim AC, . Assessment of the accuracy of the Gail model in women with atypical hyperplasia. J Clin Oncol. 2008 Nov 20;26(33):5374–9. PMID: 18854574. Exclusion: E318854574
Pappas Y, Wei I, Car J, . Computer-assisted versus oral-and-written family history taking for identifying people with elevated risk of type 2 diabetes mellitus. Cochrane Database Syst Rev. 2011(8) PMID: 22161431. Exclusion: E522161431
Paradiso A, Muggia F. Hereditary breast and ovarian cancer: risks and challenges. 10-12 September 2009: Bari, Italy. Introduction. Ann Oncol. 2011 Jan;22: Suppl 1:i5–6. PMID: 21285151. Exclusion: E621285151
Park SM, Park CT, Park SY, . Factors related to second cancer screening practice in disease-free cervical cancer survivors. Cancer Causes Control. 2009 Nov;20(9):1697–703. doi: 10.1007/s10552-009-9421-0. PMID: 19688183. Exclusion: E519688183
Parker WH, Broder MS, Chang E, . Ovarian conservation at the time of hysterectomy and long-term health outcomes in the nurses’ health study. Obstet Gynecol. 2009;113(5):1027. PMID: 19384117. Exclusion: E319384117
Parthasarathy S. The patent is political: the consequences of patenting the BRCA genes in Britain. Community Genet. 2005;8(4):235–42. PMID: 16244478. Exclusion: 216244478
Pasacreta J. Collective fear, individualized risk: the social and cultural context of genetic testing for breast cancer. Nurs Ethics. 2001 Mar;8(2):161–2; author reply 2-3. PMID: 16010892. Exclusion: E616010892
Pasanisi P, Bruno E, Venturelli E, . Serum levels of IGF-I and BRCA penetrance: a case control study in breast cancer families. Fam Cancer. 2011 Sep;10(3):521–8. PMID: 21455766. Exclusion: E521455766
Pasick RJ, Joseph G, Stewart S, . Effective referral of low-income women at risk for hereditary breast and ovarian cancer to genetic counseling: a randomized delayed intervention control trial. Am J Public Health. 2016 Oct;106(10):1842–8. doi: 10.2105/AJPH.2016.303312. PMID: 27552275. Exclusion: E527552275
Passaperuma K, Warner E, Causer PA, . Long-term results of screening with magnetic resonance imaging in women with BRCA mutations. Br J Cancer. 2012;107(1):24–30. PMID: 22588560. Exclusion: H222588560
Passaperuma K, Warner E, Hill KA, . Is mammographic breast density a breast cancer risk factor in women with BRCA mutations? J Clin Oncol. 2010 Aug 10;28(23):3779–83. PMID: 20625126. Exclusion: E520625126
Patterson AR, Robinson LD, Naftalis EZ, . Custodianship of genetic information: clinical challenges and professional responsibility. J Clin Oncol. 2005 Mar 20;23(9):2100–4. PMID: 15774800. Exclusion: E515774800
Pavelka JC, Li AJ, Karlan BY. Hereditary ovarian cancer-assessing risk and prevention strategies. Obstet Gynecol Clin North Am. 2007 Dec;34(4):651–65, vii–viii. PMID: 18061862. Exclusion: E618061862
Pavic D, Schell MJ, Dancel RD, . Comparison of three methods to increase knowledge about breast cancer and breast cancer screening in screening mammography patients. Acad Radiol. 2007 May;14(5):553–60. PMID: 17434069. Exclusion: E417434069
Pearlman MD. Ideal risk reduction management for women with BRCA gene mutations: still not there yet. Obstet Gynecol. 2013 Jan;121(1):4–6. doi: 10.1097/AOG.0b013e31827bfc93. PMID: 23262922. Exclusion: E623262922
Peelen T, van Vliet M, Petrij-Bosch A, . A high proportion of novel mutations in BRCA1 with strong founder effects among Dutch and Belgian hereditary breast and ovarian cancer families. Am J Hum Genet. 1997 May;60(5):1041–9. PMID: 9150151. Exclusion: 29150151
Pellegrini I, Rapti M, Extra JM, . Tailored chemotherapy based on tumour gene expression analysis: breast cancer patients’ misinterpretations and positive attitudes. Eur J Cancer Care (Engl). 2012 Mar;21(2):242–50. doi: 10.1111/j.1365-2354.2011.01300.x. PMID: 22070677. Exclusion: E422070677
Peng S, Lü B, Ruan W, . Genetic polymorphisms and breast cancer risk: evidence from meta-analyses, pooled analyses, and genome-wide association studies. Breast Cancer Res Treat. 2011;127(2):309–24. doi: 10.1007/s10549-011-1459-5. PMID: 21445572. Exclusion: 221445572
Pennisi VR, Capozzi A. Subcutaneous mastectomy data: a final statistical analysis of 1500 patients. Aesthetic Plast Surg. 1989 Winter;13(1):15–21. PMID: 2728994. Exclusion: 22728994
Peshkin BN, Demarco TA, Graves KD, . Telephone genetic counseling for high-risk women undergoing BRCA1 and BRCA2 testing: rationale and development of a randomized controlled trial. Genetic Testing. 2008 Mar;12(1):37–52. PMID: 18373403. Exclusion: E518373403
Peshkin BN, Kelly S, Nusbaum RH, . Patient perceptions of telephone vs. in-person BRCA1/BRCA2 genetic counseling. J Genet Couns. 2016 Jun;25(3):472–82. doi: 10.1007/s10897-015-9897-6. PMID: 26455498. Exclusion: E3a26455498
Peters JA, Hoskins L, Prindiville S, . Evolution of the colored eco-genetic relationship map (CEGRM) for assessing social functioning in women in hereditary breast-ovarian (HBOC) families. J Genet Couns. 2006 Dec;15(6):477–89. PMID: 17111216. Exclusion: E517111216
Peters JA, Kenen R, Giusti R, . Exploratory study of the feasibility and utility of the colored eco-genetic relationship map (CEGRM) in women at high genetic risk of developing breast cancer. Am J Med Genet A. 2004 Oct 15;130A(3):258–64. PMID: 15378540. Exclusion: E515378540
Petersen RW, Quinlivan JA. Preventing anxiety and depression in gynaecological cancer: a randomised controlled trial. BJOG. 2002 Apr;109(4):386–94. PMID: 12013159. Exclusion: E412013159
Petrucelli N, Daly MB, Pal T. BRCA1- and BRCA2-Associated Hereditary Breast and Ovarian Cancer. 1998 [Updated 2016 Dec 15]. In: Adam MP, Ardinger HH, Pagon RA, Wallace SE, Bean LJH, Stephens K, ., eds. GeneReviews((R)) [Internet]. Seattle, WA: University of Washington, Seattle. GeneReviews is a registered trademark of the University of Washington, Seattle. All rights reserved. Available from: https://www.ncbi.nlm.nih.gov/books/NBK1247/. Accessed May 16 2019. Exclusion: 2
Pharoah PD, Day NE, Duffy S, . Family history and the risk of breast cancer: a systematic review and meta-analysis. Int J Cancer. 1997 May 29;71(5):800–9. PMID: 9180149. Exclusion: 29180149
Phelps C, Bennett P, Iredale R, . The development of a distraction-based coping intervention for women waiting for genetic risk information: a phase 1 qualitative study. Psychooncology. 2006 Feb;15(2):169–73. doi: 10.1002/pon.937. PMID: 15929031. Exclusion: E415929031
Phelps C, Bennett P, Jones H, . The development of a cancer genetic-specific measure of coping: the GRACE. Psychooncology. 2010 Aug;19(8):847–54. PMID: 19823974. Exclusion: E419823974
Phillips KA, Milne RL, Rookus MA, . Tamoxifen and risk of contralateral breast cancer for BRCA1 and BRCA2 mutation carriers. J Clin Oncol. 2013 Sep 1;31(25):3091–9. doi: 10.1200/JCO.2012.47.8313. PMID: 23918944. Exclusion: E323918944
Pichert G, Jacobs C, Jacobs I, . Novel one-stop multidisciplinary follow-up clinic significantly improves cancer risk management in BRCA1/2 carriers. Fam Cancer. 2010 Sep;9(3):313–9. PMID: 20300867. Exclusion: E520300867
Pichert G SR. Organizing cancer genetics programs: the Swiss model. J Clin Oncol. 2000;18:(21 Suppl):65S–9S. PMID: 11060330. Exclusion: 211060330
Pierce LJ, Phillips K-A, Griffith KA, . Local therapy in BRCA1 and BRCA2 mutation carriers with operable breast cancer: comparison of breast conservation and mastectomy. Breast Cancer Res Treat. 2010 Jun;121(2):389–98. PMID: 20411323. Exclusion: E320411323
Pieterse AH, van Dulmen AM, Beemer FA, . Cancer genetic counseling: communication and counselees’ post-visit satisfaction, cognitions, anxiety, and needs fulfillment. J Genet Couns. 2007 Feb;16(1):85–96. doi: 10.1007/s10897-006-9048-1. PMID: 17295054. Exclusion: E317295054
Pieterse AH, van Dulmen S, van Dijk S, . Risk communication in completed series of breast cancer genetic counseling visits. Genet Med. 2006 Nov;8(11):688–96. PMID: 17108760. Exclusion: E3a17108760
Pijpe A, Andrieu N, Easton DF, . Exposure to diagnostic radiation and risk of breast cancer among carriers of BRCA1/2 mutations: retrospective cohort study (GENE-RAD-RISK). BMJ. 2012 2012-09-06 23:32:21;345 doi: 10.1136/bmj.e5660. PMID: 22956590. Exclusion: E522956590
Pijpe A, Manders P, Brohet RM, . Physical activity and the risk of breast cancer in BRCA1/2 mutation carriers. Breast Cancer Res Treat. 2010 Feb;120(1):235–44. PMID: 19680614. Exclusion: E519680614
Pilarski R. Risk perception among women at risk for hereditary breast and ovarian cancer. J Genet Couns. 2009 Aug;18(4):303–12. PMID: 19360461. Exclusion: E919360461
Pinsky LE, Culver JB, Hull J, . Why should primary care physicians know about breast cancer genetics? West J Med. 2001 Sep;175(3):168–73. PMID: 11527843. Exclusion: E611527843
Pinto C, Bella MA, Capoluongo E, . Recommendations for the implementation of BRCA testing in the care and treatment pathways of ovarian cancer patients. Future Oncology. 2016;12(18):2071–5. doi: 10.2217/fon-2016-0189. PMID: 27241581. Exclusion: E727241581
Piver MS, Jishi MF, Tsukada Y, . Primary peritoneal carcinoma after prophylactic oophorectomy in women with a family history of ovarian cancer. A report of the Gilda Radner Familial Ovarian Cancer Registry. Cancer. 1993;71(9):2751–5. PMID: 8467455. Exclusion: E78467455
Plevritis SK, Kurian AW, Sigal BM, . Cost-effectiveness of screening BRCA1/2 mutation carriers with breast magnetic resonance imaging. JAMA. 2006 May 24;295(20):2374–84. PMID: 16720823. Exclusion: E516720823
Pluta RM, Golub RM. JAMA patient page. BRCA genes and breast cancer. JAMA. 2011 Jun 1;305(21):2244. PMID: 21632489. Exclusion: E621632489
Podo F, Santoro F, Di Leo G, . Triple-negative versus non-triple-negative breast cancers in high-risk women: phenotype features and survival from the HIBCRIT-1 MRI-including screening study. Clin Cancer Res. 2016 Feb 15;22(4):895–904. doi: 10.1158/1078-0432.CCR-15-0459. PMID: 26503945. Exclusion: E326503945
Ponzone R, Sismondi P. Patients with breast cancer are unlikely to benefit from prophylactic irradiation of the contralateral breast. J Clin Oncol. 2008 Feb 20;26(6):1014–5; author reply 5-6. PMID: 18281679. Exclusion: E618281679
Poon C, Hyde S, Grant P, . Incidence and Characteristics of Unsuspected Neoplasia Discovered in High-Risk Women Undergoing Risk Reductive Bilateral Salpingooophorectomy. Int J Gynecol Cancer. 2016 Oct;26(8):1415–20. doi: 10.1097/IGC.0000000000000791. PMID: 27488216. Exclusion: E727488216
Poulet A, Privat M, Ponelle F, . Improved efficiency and reliability of NGS amplicon sequencing data analysis for genetic diagnostic procedures using AGSA software. Biomed Res Int. 2016;2016 doi: 10.1155/2016/5623089. PMID: 27656653. Exclusion: E527656653
Powell CB. Occult ovarian cancer at the time of risk-reducing salpingo-oophorectomy. Gynecol Oncol. 2006 Jan;100(1):1–2. PMID: 16368438. Exclusion: 216368438
Powell CB, Chen L-m, McLennan J, . Risk-reducing salpingo-oophorectomy (RRSO) in BRCA mutation carriers: experience with a consecutive series of 111 patients using a standardized surgical-pathological protocol. Int J Gynecol Cancer. 2011 Jul;21(5):846–51. PMID: 21670699. Exclusion: E321670699
Powell CB, Littell R, Hoodfar E, . Does the diagnosis of breast or ovarian cancer trigger referral to genetic counseling? Int J Gynecol Cancer. 2013 Mar;23(3):431–6. doi: 10.1097/IGC.0b013e318280f2b4. PMID: 23354368. Exclusion: E323354368
Powell CB, Swisher EM, Cass I, . Long term follow up of BRCA1 and BRCA2 mutation carriers with unsuspected neoplasia identified at risk reducing salpingo-oophorectomy. Gynecol Oncol. 2013 May;129(2):364–71. doi: 10.1016/j.ygyno.2013.01.029. PMID: 23391663. Exclusion: E323391663
Powles T, Eeles R, Ashley S, . Interim analysis of the incidence of breast cancer in the Royal Marsden Hospital tamoxifen randomised chemoprevention trial. Lancet. 1998 Jul 11;352(9122):98–101. doi: 10.1016/S0140-6736(98)85012-5. PMID: 9672274. Exclusion: 29672274
Powles TJ, Ashley S, Tidy A, . Twenty-year follow-up of the Royal Marsden randomized, double-blinded tamoxifen breast cancer prevention trial. J Natl Cancer Inst. 2007 Feb;99(4):283–90. PMID: 17312305. Exclusion: E317312305
Prat A, Parker JS, Fan C, . Concordance among gene expression-based predictors for ER-positive breast cancer treated with adjuvant tamoxifen. Ann Oncol. 2012 Nov;23(11):2866–73. doi: 10.1093/annonc/mds080. PMID: 22532584. Exclusion: E522532584
Price EL, Creasman J, Beattie M. Recall of cancer screening and prevention recommendations from a BRCA genetic testing and counseling program. J Gen Intern Med. 2011;26:S316–S7. doi: 10.1007/s11606-011-1730-9. Exclusion: E5
Primas H, Kroiss R, Kalteis K, . Impact of lifestyle factors on preneoplastic changes in prophylactic oophorectomies of BRCA mutation carriers. Eur J Cancer Prev. 2012 Mar;21(2):199–204. PMID: 22252303. Exclusion: E522252303
Printz C. Oophorectomy can reduce ovarian cancer risk in women with BRCA mutations: patients benefit from counseling, support. Cancer. 2013 Nov 15;119(22):3897–8. doi: 10.1002/cncr.28455. PMID: 24590900. Exclusion: E624590900
Printz C. Women with BRCA mutation have better survival rates after double mastectomy. Cancer. 2014 Jul 15;120(14):2071. doi: 10.1002/cncr.28873. PMID: 24985248. Exclusion: E624985248
Printz C. BRCA 1/2-negative patients who receive counseling after genetic testing have lower anxiety. Cancer. 2016 Apr 15;122(8):1149. doi: 10.1002/cncr.30002. PMID: 27061519. Exclusion: E627061519
Profato JL, Arun BK. Genetic risk assessment for breast and gynecological malignancies. Curr Opin Obstet Gynecol. 2015 Feb;27(1):1–5. doi: 10.1097/GCO.0000000000000142. PMID: 25502427. Exclusion: E625502427
Proulx M, Beaulieu M-D, Loignon C, . Experiences and decisions that motivate women at increased risk of breast cancer to participate in an experimental screening program. J Genet Couns. 2009 Apr;18(2):160–72. PMID: 19219540. Exclusion: E719219540
Prucka SK, McIlvried DE, Korf BR. Cancer risk assessment and the genetic counseling process: using hereditary breast and ovarian cancer as an example. Med Princ Pract. 2008;17(3):173–89. PMID: 18408385. Exclusion: E618408385
Pruthi S, Heisey RE, Bevers TB. Chemoprevention for breast cancer. Ann Surg Oncol. 2015 Oct;22(10):3230–5. doi: 10.1245/s10434-015-4715-9. PMID: 26202562. Exclusion: E926202562
Pujol P, Lasset C, Berthet P, . Uptake of a randomized breast cancer prevention trial comparing letrozole to placebo in BRCA1/2 mutations carriers: the LIBER trial. Fam Cancer. 2012 Mar;11(1):77–84. PMID: 22076253. Exclusion: E522076253
Pujol P, Lyonnet DS, Frebourg T, . Lack of referral for genetic counseling and testing in BRCA1/2 and Lynch syndromes: a nationwide study based on 240,134 consultations and 134,652 genetic tests. Breast Cancer Res Treat. 2013 Aug;141(1):135–44. doi: 10.1007/s10549-013-2669-9. PMID: 23974829. Exclusion: 223974829
Pukancsik D, Kelemen P, Gulyas G, . Clinical experiences with the use of ULTRAPRO<sup></sup> mesh in single-stage direct-to-implant immediate postmastectomy breast reconstruction in 102 patients: A retrospective cohort study. Eur J Surg Oncol. 2017 Jul;43(7):1244–51. doi: 10.1016/j.ejso.2017.01.236. PMID: 28215734. Exclusion: E3a28215734
Qiu J. Psychological outcome and quality of life in Chinese breast cancer patients who underwent BRCA1/2 gene testing. Cancer Nurs. 2015;38(4):S90–S1. doi: 10.1097/NCC.0000000000000287. Exclusion: E6
Qiu J, Guan J, Yang X, . Quality of life and psychological state in Chinese breast cancer patients who received BRCA1/2 genetic testing. PLoS One. 2016;11(7)doi: 10.1371/journal.pone.0158531. PMID: 27428375. Exclusion: E527428375
Quante AS, Whittemore AS, Shriver T, . Practical problems with clinical guidelines for breast cancer prevention based on remaining lifetime risk. J Natl Cancer Inst. 2015 Jul;107(7)doi: 10.1093/jnci/djv124. PMID: 25956172. Exclusion: E425956172
Quante AS, Whittemore AS, Shriver T, . Breast cancer risk assessment across the risk continuum: genetic and nongenetic risk factors contributing to differential model performance. Breast Cancer Res. 2012;14(6):R144. doi: 10.1186/bcr3352. PMID: 23127309. Exclusion: E423127309
Quillin JM, Bodurtha JN, Smith TJ. Genetics assessment at the end of life: suggestions for implementation in clinic and future research. J Palliat Med. 2008 Apr;11(3):451–8. PMID: 18363488. Exclusion: E718363488
Quillin JM, Krist AH, Gyure M, . Patient-reported hereditary breast and ovarian cancer in a primary care practice. J Community Genet. 2014;5(2):179–83. doi: 10.1007/s12687-013-0161-1. PMID: 23872790. Exclusion: 223872790
Quillin JM, McClish DK, Jones RM, . Spiritual coping, family history, and perceived risk for breast cancer-can we make sense of it? J Genet Couns. 2006 Dec;15(6):449–60. doi: 10.1007/s10897-006-9037-4. PMID: 17013546. Exclusion: E417013546
Quinn G, Vadaparampil S, Wilson C, . Attitudes of high-risk women toward preimplantation genetic diagnosis. Fertil Steril. 2009 Jun;91(6):2361–8. PMID: 18440521. Exclusion: E518440521
Quinn GP, Pal T, Murphy D, . High-risk consumers’ perceptions of preimplantation genetic diagnosis for hereditary cancers: a systematic review and meta-analysis. Genet Med. 2012 Feb;14(2):191–200. doi: 10.1038/gim.0b013e31822ddc7e. PMID: 22261755. Exclusion: E522261755
Rabban JT, Barnes M, Chen L-M, . Ovarian pathology in risk-reducing salpingo-oophorectomies from women with BRCA mutations, emphasizing the differential diagnosis of occult primary and metastatic carcinoma. Am J Surg Pathol. 2009 Aug;33(8):1125–36. PMID: 19440148. Exclusion: E519440148
Rafnar T, Benediktsdottir KR, Eldon BJ, . BRCA2, but not BRCA1, mutations account for familial ovarian cancer in Iceland: a population-based study. Eur J Cancer. 2004 Dec;40(18):2788–93. PMID: 15571962. Exclusion: E515571962
Rahm AK, Sukhanova A, Ellis J, . Increasing utilization of cancer genetic counseling services using a patient navigator model. J Genet Couns. 2007 Apr;16(2):171–7. PMID: 17277995. Exclusion: E517277995
Rahman N, Stratton MR. The genetics of breast cancer susceptibility. Annu Rev Genet. 1998;32:95–121. doi: 10.1146/annurev.genet.32.1.95. PMID: 9928476. Exclusion: 29928476
Rajpal N, Munoz J, Peshkin BN, . Insights into BRCA1/2 Genetic Counseling from Ethnically Diverse Latina Breast Cancer Survivors. J Genet Couns. 2017 Dec;26(6):1221–37. doi: 10.1007/s10897-017-0096-5. PMID: 28374142. Exclusion: E3a28374142
Ramaswami R, Morrow M, Jagsi R. Contralateral prophylactic mastectomy. N Engl J Med. 2017 Sep 28;377(13):1288–91. doi: 10.1056/NEJMclde1708293. PMID: 28953446. Exclusion: E628953446
Ramon Y Cajal T, Torres A, Alonso C, . Risk factors associated with the occurrence of breast cancer after bilateral salpingo-oophorectomy in high-risk women. Cancer Epidemiol. 2011 Feb;35(1):78–82. PMID: 20638925. Exclusion: E320638925
Rapport F, Iredale R, Jones W, . Decision aids for familial breast cancer: exploring women’s views using focus groups. Health Expect. 2006 Sep;9(3):232–44. PMID: 16911137. Exclusion: E416911137
Rapport F, Khanom A, Doel MA, . Women’s perceptions of journeying toward an unknown future with breast cancer: The “lives at risk study”. Qual Health Res. 2018 Jan;28(1):30–46. doi: 10.1177/1049732317730569. PMID: 28938853. Exclusion: E428938853
Ratnayake P, Wakefield CE, Meiser B, . An exploration of the communication preferences regarding genetic testing in individuals from families with identified breast/ovarian cancer mutations. Fam Cancer. 2011 Mar;10(1):97–105. PMID: 20878485. Exclusion: E520878485
Rauscher EA, Dean M. “I’ve just never gotten around to doing it”: Men’s approaches to managing BRCA-related cancer risks. Patient Educ Couns. 2018 Feb;101(2):340–5. doi: 10.1016/j.pec.2017.07.015. PMID: 28757302. Exclusion: E328757302
Rauscher EA, Dean M, Campbell-Salome GM. “I am uncertain about what my uncertainty even is”: Men’s uncertainty and information management of their brca-related cancer risks. J Genet Couns. 2018 Jul:No Pagination Specified. doi: 10.1007/s10897-018-0276-y. PMID: 29971606. Exclusion: E329971606
Rawal R, Bertelsen L, Olsen JH. Cancer incidence in first-degree relatives of a population-based set of cases of early-onset breast cancer. Eur J Cancer. 2006 Nov;42(17):3034–40. PMID: 16996259. Exclusion: E516996259
Razdan SN, Patel V, Jewell S, . Quality of life among patients after bilateral prophylactic mastectomy: a systematic review of patient-reported outcomes. Qual Life Res. 2016 06;25(6):1409–21. doi: 10.1007/s11136-015-1181-6. PMID: 26577764. Exclusion: E326577764
Ready KJ, Vogel KJ, Atchley DP, . Accuracy of the BRCAPRO model among women with bilateral breast cancer. Cancer. 2009 Feb 15;115(4):725–30. PMID: 19127556. Exclusion: E419127556
Rebbeck TR, Friebel T, Lynch HT, . Bilateral prophylactic mastectomy reduces breast cancer risk in BRCA1 and BRCA2 mutation carriers: the PROSE Study Group. J Clin Oncol. 2004 Mar 15;22(6):1055–62. doi: 10.1200/JCO.2004.04.188. PMID: 14981104. Exclusion: 214981104
Rebbeck TR, Kauff ND, Domchek SM. Meta-analysis of risk reduction estimates associated with risk-reducing salpingo-oophorectomy in BRCA1 or BRCA2 mutation carriers. J Natl Cancer Inst. 2009 Jan 21;101(2):80–7. doi: 10.1093/jnci/djn442. PMID: 19141781. Exclusion: E919141781
Rebbeck TR, Levin AM, Eisen A, . Breast cancer risk after bilateral prophylactic oophorectomy in BRCA1 mutation carriers. J Natl Cancer Inst. 1999 Sep 01;91(17):1475–9. PMID: 10469748. Exclusion: 210469748
Rebbeck TR, Mitra N, Wan F, . Association of type and location of BRCA1 and BRCA2 mutations with risk of breast and ovarian cancer. JAMA. 2015 Apr 7;313(13):1347–61. doi: 10.1001/jama.2014.5985. PMID: 25849179. Exclusion: E525849179
Rees G, Young M-A, Gaff C, . A qualitative study of health professionals’ views regarding provision of information about health-protective behaviors during genetic consultation for breast cancer. J Genet Couns. 2006 Apr;15(2):95–104. doi: 10.1007/s10897-005-9009-0. PMID: 16541332. Exclusion: E516541332
Reis MM, Tavakoli M, Dewar J, . Evaluation of a surveillance programme for women with a family history of breast cancer. J Med Genet. 2009 May;46(5):319–23. PMID: 19279022. Exclusion: E319279022
Rennert G, Bisland-Naggan S, Barnett-Griness O, . Clinical outcomes of breast cancer in carriers of BRCA1 and BRCA2 mutations. N Engl J Med. 2007 Jul 12;357(2):115–23. PMID: 17625123. Exclusion: E317625123
Resta R, Drescher CW, Beatty D, . Systematic identification of high risk women for genetic counseling and surgical prevention of ovarian cancer. Clinical cancer research. Conference: 10th biennial ovarian cancer research symposium. United states. 2015;21(16 Supplement 1). Exclusion: E6
Rhiem K, Foth D, Wappenschmidt B, . Risk-reducing salpingo-oophorectomy in BRCA1 and BRCA2 mutation carriers. Arch Gynecol Obstet. 2011 Mar;283(3):623–7. PMID: 20428881. Exclusion: E3a20428881
Richards S, Aziz N, Bale S, . Standards and guidelines for the interpretation of sequence variants: a joint consensus recommendation of the American College of Medical Genetics and Genomics and the Association for Molecular Pathology. Genet Med. 2015 May;17(5):405–24. doi: 10.1038/gim.2015.30. PMID: 25741868. Exclusion: E625741868
Richter S, Graham T, Haroun I, . Variants of uncertain significance in BRCA testing: impact on risk perception, worry, prevention, and counselling [abstract]. Curr Oncol; 2012. 19. p. e84. Exclusion: E6
Richter S, Haroun I, Graham TC, . Variants of unknown significance in BRCA testing: impact on risk perception, worry, prevention and counseling. Ann Oncol. 2013 Nov;24: Suppl 8:viii69–viii74. doi: 10.1093/annonc/mdt312. PMID: 24131974. Exclusion: E424131974
Riedl CC, Ponhold L, Flöry D, . Magnetic resonance imaging of the breast improves detection of invasive cancer, preinvasive cancer, and premalignant lesions during surveillance of women at high risk for breast cancer. Clin Cancer Res. 2007;13(20):6144–52. PMID: 17947480. Exclusion: E317947480
Rimes KA, Salkovskis PM, Jones L, . Applying a cognitive-behavioral model of health anxiety in a cancer genetics service. Health Psychol. 2006;25(2):171–80. PMID: 16569108. Exclusion: E316569108
Rini C, O’Neill SC, Valdimarsdottir H, . Cognitive and emotional factors predicting decisional conflict among high-risk breast cancer survivors who receive uninformative BRCA1/2 results. Health Psychol. 2009 Sep;28(5):569–78. PMID: 19751083. Exclusion: E519751083
Ripperger T, Gadzicki D, Meindl A, . Breast cancer susceptibility: current knowledge and implications for genetic counselling. Eur J Hum Genet. 2009;17(6):722–31. doi: 10.1038/ejhg.2008.212. PMID: 19092773. Exclusion: 219092773
Robson M, Hensley M, Barakat R, . Quality of life in women at risk for ovarian cancer who have undergone risk-reducing oophorectomy. Gynecol Oncol. 2003;89(2):281–7. PMID: 12713992. Exclusion: E3a12713992
Rocca W, Bower J, Maraganore D, . Increased risk of parkinsonism in women who underwent oophorectomy before menopause. Neurology. 2008;70(3):200–9. PMID: 17761549. Exclusion: E317761549
Rocca W, Bower J, Maraganore D, . Increased risk of cognitive impairment or dementia in women who underwent oophorectomy before menopause. Neurology. 2007;69(11):1074–83. PMID: 17761551. Exclusion: E317761551
. Accelerated accumulation of multimorbidity after bilateral oophorectomy: a population-based cohort study. Mayo Clin Proc; 2016. Elsevier; 91. Exclusion: E3
Rocca WA, Grossardt BR, Geda YE, . Long-term risk of depressive and anxiety symptoms after early bilateral oophorectomy. Menopause. 2008;15(6):1050–9. PMID: 18724263. Exclusion: E318724263
Rodriguez-Balada M, Roig B, Martorell L, . In silico, in vitro and case-control analyses as an effective combination for analyzing BRCA1 and BRCA2 unclassified variants in a population-based sample. Cancer Genet. 2016 Nov;209(11):487–92. doi: 10.1016/j.cancergen.2016.09.003. PMID: 27886673. Exclusion: E427886673
Ropka ME, Wenzel J, Phillips EK, . Uptake rates for breast cancer genetic testing: a systematic review. Cancer Epidemiol Biomarkers Prev. 2006 May;15(5):840–55. PMID: 16702359. Exclusion: E516702359
Rose E, Schreiber-Agus N, Bajaj K, . Challenges of pre- and post-test counseling for Orthodox Jewish individuals in the premarital phase. J Genet Couns. 2016 Feb;25(1):18–24. doi: 10.1007/s10897-015-9880-2. PMID: 26354339. Exclusion: E726354339
Rosenthal AN, Fraser L, Manchanda R, . Results of annual screening in phase I of the United Kingdom familial ovarian cancer screening study highlight the need for strict adherence to screening schedule. J Clin Oncol. 2013;31(1):49. PMID: 23213100. Exclusion: E523213100
Rosenthal AN, Fraser LSM, Philpott S, . Evidence of stage shift in women diagnosed with ovarian cancer during Phase II of the United Kingdom Familial Ovarian Cancer Screening Study. J Clin Oncol. 2017 May 1;35(13):1411–20. doi: 10.1200/jco.2016.69.9330. PMID: 28240969. Exclusion: E528240969
Rosenthal ET, Evans B, Kidd J, . Increased identification of candidates for high-risk breast cancer screening through expanded genetic testing. J Am Coll Radiol. 2017 Apr;14(4):561–8. doi: 10.1016/j.jacr.2016.10.003. PMID: 28011157. Exclusion: E328011157
Roshanai AH, Rosenquist R, Lampic C, . Cancer genetic counselees’ self-reported psychological distress, changes in life, and adherence to recommended surveillance programs 3-7 years post counseling. J Genet Couns. 2009 Apr;18(2):185–94. doi: 10.1007/s10897-008-9203-y. PMID: 19212811. Exclusion: E3a19212811
Rothwell E, Kohlmann W, Jasperson K, . Patient outcomes associated with group and individual genetic counseling formats. Fam Cancer. 2012 Mar;11(1):97–106. PMID: 22057473. Exclusion: E3a22057473
Roussi P, Sherman KA, Miller S, . Enhanced counselling for women undergoing BRCA1/2 testing: Impact on knowledge and psychological distress-results from a randomised clinical trial. Psychol Health. 2010 Apr;25(4):401–15. PMID: 20204945. Exclusion: E3a20204945
Roussi P, Sherman KA, Miller SM, . Identification of cognitive profiles among women considering BRCA1/2 testing through the utilisation of cluster analytic techniques. Psychol Health. 2011 Oct;26(10):1327–43. PMID: 21756124. Exclusion: E421756124
Rowe JL, Montgomery GH, Duberstein PR, . Health locus of control and perceived risk for breast cancer in healthy women. Behav Med. 2005 Spring;31(1):33–40. doi: 10.3200/bmed.31.1.33-42. PMID: 16078524. Exclusion: E416078524
Rubin LR, Werner-Lin A, Sagi M, . ‘The BRCA clock is ticking!’: negotiating medical concerns and reproductive goals in preimplantation genetic diagnosis. Hum Fertil. 2014 Sep;17(3):159–64. doi: 10.3109/14647273.2014.940003. PMID: 25105219. Exclusion: E425105219
Ruddy KJ, Risendal BC, Garber JE, . Cancer survivorship care: an opportunity to revisit cancer genetics. J Clin Oncol. 2016 Feb 20;34(6):539–41. doi: 10.1200/JCO.2015.63.5375. PMID: 26712228. Exclusion: E626712228
Rummel S, Varner E, Shriver CD, . Evaluation of BRCA1 mutations in an unselected patient population with triple-negative breast cancer. Breast Cancer Res Treat. 2013 Jan;137(1):119–25. doi: 10.1007/s10549-012-2348-2. PMID: 23192404. Exclusion: 223192404
Saadatmand S, Obdeijn IM, Rutgers EJ, . Survival benefit in women with BRCA1 mutation or familial risk in the MRI screening study (MRISC). Int J Cancer. 2015 Oct 1;137(7):1729–38. doi: 10.1002/ijc.29534. PMID: 25820931. Exclusion: E325820931
Sacca RE, Koeller DR, Rana HQ, . Trans-counseling: A case series of transgender individuals at high risk for BRCA1 pathogenic variants. J Genet Couns. 2019 Jan 24 doi: 10.1002/jgc4.1046. PMID: 30680866. Exclusion: E630680866
Sahai H, Khurshid A. Confidence intervals for the mean of a Poisson Distribution: a review. Biomed J 1993;35:857–67. Exclusion: E5
Salhab M, Al Sarakbi W, Joseph A, . Skin-sparing mastectomy and immediate breast reconstruction: patient satisfaction and clinical outcome. Int J Clin Oncol. 2006 Feb;11(1):51–4. PMID: 16508729. Exclusion: E316508729
Salsman JM, Pavlik E, Boerner LM, . Clinical, demographic, and psychological characteristics of new, asymptomatic participants in a transvaginal ultrasound screening program for ovarian cancer. Prev Med. 2004 Aug;39(2):315–22. doi: 10.1016/j.ypmed.2004.04.023. PMID: 15226040. Exclusion: E515226040
Samphao S, Wheeler AJ, Rafferty E, . Diagnosis of breast cancer in women age 40 and younger: delays in diagnosis result from underuse of genetic testing and breast imaging. Am J Surg. 2009;198(4):538–43. doi: 10.1016/j.amjsurg.2009.06.010. PMID: 19800464. Exclusion: E519800464
Sandhaus LM, Singer ME, Dawson NV, . Reporting BRCA test results to primary care physicians. Genet Med. 2001 Sep–Oct;3(5):327–34. doi: 10.1097/00125817-200109000-00001. PMID: 11545685. Exclusion: E511545685
Sankar P, Wolpe PR, Jones NL, . How do women decide? Accepting or declining BRCA1/2 testing in a nationwide clinical sample in the United States. Community Genet. 2006;9(2):78–86. PMID: 16612057. Exclusion: E516612057
Santos C, Peixoto A, Rocha P, . Pathogenicity evaluation of BRCA1 and BRCA2 unclassified variants identified in Portuguese breast/ovarian cancer families. J Mol Diagn. 2014 May;16(3):324–34. doi: 10.1016/j.jmoldx.2014.01.005. PMID: 24607278. Exclusion: E524607278
Sanz J, Ramon y Cajal T, Torres A, . Uptake of predictive testing among relatives of BRCA1 and BRCA2 families: a multicenter study in northeastern Spain. Fam Cancer. 2010 Sep;9(3):297–304. PMID: 20091130. Exclusion: E520091130
Sanz R, Cruzado JA, Pérez Segura P. Aplicación del cuestionario multidimensional del impacto de la evaluación de riesgo de cáncer (MICRA), en una muestra española. PSICOONCOLOGÍA. 2005;2(2–3):347–60. Exclusion: E3
Sardanelli F, Podo F, D’Agnolo G, . Multicenter comparative multimodality surveillance of women at genetic-familial high risk for breast cancer (HIBCRIT study): interim results. Radiology. 2007 Mar;242(3):698–715. PMID: 17244718. Exclusion: E3a17244718
Sasieni PD, Duffy SW, Cuzick J. Ovarian cancer screening: UKCTOCS trial. Lancet. 2016 Jun 25;387(10038):2602. doi: 10.1016/s0140-6736(16)30847-9. PMID: 27353820. Exclusion: E627353820
Scherr CL, Christie J, Vadaparampil ST. Breast cancer survivors’ knowledge of hereditary breast and ovarian cancer following genetic counseling: An exploration of general and survivor-specific knowledge items. Public Health Genomics. 2016;19(1):1–10. doi: 10.1159/000439162. PMID: 26389838. Exclusion: E326389838
Scheuer L, Kauff N, Robson M, . Outcome of preventive surgery and screening for breast and ovarian cancer in BRCA mutation carriers. J Clin Oncol. 2002 Original Search 6-20-03;20(5):1260–8. PMID: 11870168. Exclusion: E3a11870168
Schlebusch CM, Dreyer G, Sluiter MD, . Cancer prevalence in 129 breast-ovarian cancer families tested for BRCA1 and BRCA2 mutations. S Afr Med J. 2010 Feb;100(2):113–7. PMID: 20459916. Exclusion: E520459916
Schlich-Bakker KJ, ten Kroode HFJ, Ausems MGEM. A literature review of the psychological impact of genetic testing on breast cancer patients. Patient Educ Couns. 2006 Jul;62(1):13–20. PMID: 16242293. Exclusion: E916242293
Schmutzler RK, Rhiem K, Breuer P, . Outcome of a structured surveillance programme in women with a familial predisposition for breast cancer. Eur J Cancer Prev. 2006;15(6):483–9. PMID: 17106326. Exclusion: 217106326
Schneegans SM, Rosenberger A, Engel U, . Validation of three BRCA1/2 mutation-carrier probability models Myriad, BRCAPRO and BOADICEA in a population-based series of 183 German families. Fam Cancer. 2012 Jun;11(2):181–8. doi: 10.1007/s10689-011-9498-y. PMID: 22160602. Exclusion: E722160602
Schneider KA, DiGianni LM, Patenaude AF, . Accuracy of cancer family histories: comparison of two breast cancer syndromes. Genetic Testing. 2004;8(3):222–8. PMID: 15727243. Exclusion: E415727243
Schonberg MA, Li VW, Eliassen AH, . Performance of the breast cancer risk assessment tool among women age 75 years and older. J Natl Cancer Inst. 2016 Mar;108(3)doi: 10.1093/jnci/djv348. PMID: 26625899. Exclusion: E426625899
Schott S, Vetter L, Keller M, . Women at familial risk of breast cancer electing for prophylactic mastectomy: frequencies, procedures, and decision-making characteristics. Arch Gynecol Obstet. 2017 Jun;295(6):1451–8. doi: 10.1007/s00404-017-4376-y. PMID: 28439664. Exclusion: E528439664
Schwartz MD, Lerman C, Miller SM, . Coping disposition, perceived risk, and psychological distress among women at increased risk for ovarian cancer. Health Psychol. 1995 May;14(3):232–5. PMID: 7641664. Exclusion: E47641664
Schwartz MD, Valdimarsdottir HB, DeMarco TA, . Randomized trial of a decision aid for BRCA1/BRCA2 mutation carriers: impact on measures of decision making and satisfaction. Health Psychol. 2009 Jan;28(1):11–9. PMID: 19210013. Exclusion: E419210013
Schwartz MD, Valdimarsdottir HB, Peshkin BN, . Randomized noninferiority trial of telephone versus in-person genetic counseling for hereditary breast and ovarian cancer. J Clin Oncol. 2014 Mar 1;32(7):618–26. doi: 10.1200/JCO.2013.51.3226. PMID: 24449235. Exclusion: E3b24449235
Sermijn E, Delesie L, Deschepper E, . Impact of an interventional counseling procedure in BRCA families: Efficacy and safety. J Clin Oncol. 2014;32(15). Exclusion: E6
Sermijn E, Delesie L, Deschepper E, . The impact of an interventional counselling procedure in families with a BRCA1/2 gene mutation: efficacy and safety. Fam Cancer. 2016;15(2):155–62. doi: 10.1007/s10689-015-9854-4. PMID: 26748927. Exclusion: E326748927
Sestak I, Singh S, Cuzick J, . Changes in bone mineral density at 3 years in postmenopausal women receiving anastrozole and risedronate in the IBIS-II bone substudy: an international, double-blind, randomised, placebo-controlled trial.[Erratum appears in Lancet Oncol. 2014 Dec;15(13):e587]. Lancet Oncol. 2014 Dec;15(13):1460–8. doi: 10.1016/S1470-2045(14)71035-6. PMID: 25456365. Exclusion: E325456365
Seymour IJ, Casadei S, Zampiga V, . Disease family history and modification of breast cancer risk in common BRCA2 variants. Oncol Rep. 2008 Mar;19(3):783–6. PMID: 18288416. Exclusion: E518288416
Shafaee MN, Gutierrez-Barrera AM, Lin HY, . Aromatase inhibitors and the risk of contralateral breast cancer in BRCA mutation carriers. J Clin Oncol. 2015;33(28). Exclusion: E3
Shannon KM, Muzikansky A, Chan-Smutko G, . Uptake of BRCA1 rearrangement panel testing: in individuals previously tested for BRCA1/2 mutations. Genet Med. 2006 Dec;8(12):740–5. PMID: 17172936. Exclusion: E517172936
Sharfstein J. FDA regulation of laboratory-developed diagnostic tests: protect the public, advance the science. JAMA. 2015 Feb 17;313(7):667–8. doi: 10.1001/jama.2014.18135. PMID: 25560381. Exclusion: 225560381
Shedlosky-Shoemaker R, Ngo TL, Ferketich AK, . Exploring perceptions of genetic testing: An examination of perceived accuracy over time. Patient Educ Couns. 2010 Jan;78(1):34–9. doi: 10.1016/j.pec.2009.05.010. PMID: 19553058. Exclusion: E319553058
Sheehan J, Sherman KA, Lam T, . Association of information satisfaction, psychological distress and monitoring coping style with post-decision regret following breast reconstruction. Psychooncology. 2007 Apr;16(4):342–51. doi: 10.1002/pon.1067. PMID: 16874745. Exclusion: E316874745
Sheehan J, Sherman KA, Lam T, . Regret associated with the decision for breast reconstruction: The association of negative body image, distress and surgery characteristics with decision regret. Psychol Health. 2008 Feb;23(2):207–19. doi: 10.1080/14768320601124899. PMID: 25160051. Exclusion: E325160051
Sheppard VB, Mays D, LaVeist T, . Medical mistrust influences black women’s level of engagement in BRCA 1/2 genetic counseling and testing. J Natl Med Assoc. 2013;105(1):17–22. PMID: 23862292. Exclusion: E523862292
Sherman ME, Piedmonte M, Mai PL, . Pathologic findings at risk-reducing salpingo-oophorectomy: primary results from Gynecologic Oncology Group Trial GOG-0199. J Clin Oncol. 2014 Oct 10;32(29):3275–83. doi: 10.1200/JCO.2013.54.1987. PMID: 25199754. Exclusion: 225199754
Shibata A, Hayashi Y, Imai T, . Somatic gene alteration of AIB1 gene in patients with breast cancer. Endocr J. 2001;48(2):199–204. PMID: 11456268. Exclusion: E311456268
Shieh Y, Hu D, Ma L, . Breast cancer risk prediction using a clinical risk model and polygenic risk score. Breast Cancer Res Treat. 2016 Oct;159(3):513–25. doi: 10.1007/s10549-016-3953-2. PMID: 27565998. Exclusion: E427565998
Shiloh S, Ilan S. To test or not to test? Moderators of the relationship between risk perceptions and interest in predictive genetic testing. J Behav Med. 2005 Oct;28(5):467–79. PMID: 16195820. Exclusion: E516195820
Shimelis H, LaDuca H, Hu C, . Triple-negative breast cancer risk genes identified by multigene hereditary cancer panel testing. J Natl Cancer Inst. 2018;110(8):855–62. doi: 10.1093/jnci/djy106. Exclusion: E530099541
Shkedi-Rafid S, Gabai-Kapara E, Grinshpun-Cohen J, . BRCA genetic testing of individuals from families with low prevalence of cancer: experiences of carriers and implications for population screening. Genet Med. 2012 Jul;14(7):688–94. PMID: 22481128. Exclusion: E522481128
Shu CA, Pike MC, Jotwani AR, . Uterine cancer after risk-reducing salpingo-oophorectomy without hysterectomy in women with BRCA mutations. JAMA oncology. 2016;2(11):1434–40. PMID: 27367496 Exclusion: E3a27367496
Sie AS, Spruijt L, van Zelst-Stams WA, . High Satisfaction and Low Distress in Breast Cancer Patients One Year after BRCA-Mutation Testing without Prior Face-to-Face Genetic Counseling. J Genet Couns. 2016 Jun;25(3):504–14. doi: 10.1007/s10897-015-9899-4. PMID: 26531312. Exclusion: E326531312
Sie AS, van Zelst-Stams WA, Spruijt L, . More breast cancer patients prefer BRCA-mutation testing without prior face-to-face genetic counseling. Fam Cancer. 2014 Jun;13(2):143–51. doi: 10.1007/s10689-013-9686-z. PMID: 24068317. Exclusion: E3b24068317
Sigal BM, Munoz DF, Kurian AW, . A simulation model to predict the impact of prophylactic surgery and screening on the life expectancy of BRCA1 and BRCA2 mutation carriers. Cancer Epidemiol Biomarkers Prev. 2012 Jul;21(7):1066–77. doi: 10.1158/1055-9965.EPI-12-0149. PMID: 22556274. Exclusion: E722556274
Sim LSJ, Hendriks JHCL, Fook-Chong SMC. Breast ultrasound in women with familial risk of breast cancer. Ann Acad Med Singapore. 2004 Sep;33(5):600–6. PMID: 15531956. Exclusion: E315531956
Singh K, Lester J, Karlan B, . Impact of family history on choosing risk-reducing surgery among BRCA mutation carriers. Am J Obstet Gynecol. 2013 Apr;208(4):329.e1–6. doi: 10.1016/j.ajog.2013.01.026. PMID: 23333547. Exclusion: E523333547
Slattery ML, Kerber RA. A comprehensive evaluation of family history and breast cancer risk. The Utah Population Database. JAMA. 1993 Oct 06;270(13):1563–8. PMID: 8371466. Exclusion: 28371466
Smith AW, Dougall AL, Posluszny DM, . Psychological distress and quality of life associated with genetic testing for breast cancer risk. Psychooncology. 2008 Aug;17(8):767–73. PMID: 17992698. Exclusion: E3a17992698
Smith KR, Ellington L, Chan AY, . Fertility intentions following testing for a BRCA1 gene mutation. Cancer Epidemiol Biomarkers Prev. 2004;13(5):733–40. PMID: 15159303. Exclusion: E515159303
Smith RP, Ni X, Muram D. Breast cancer risk assessment: positive predictive value of family history as a predictor of risk. Menopause. 2011 Jun;18(6):621–4. PMID: 21343830. Exclusion: E521343830
Soegaard M, Kjaer SK, Cox M, . BRCA1 and BRCA2 mutation prevalence and clinical characteristics of a population-based series of ovarian cancer cases from Denmark. Clin Cancer Res. 2008(14):3761 - 7. PMID: 18559594. Exclusion: E518559594
Son BH, Ahn SH, Kim S-W, . Prevalence of BRCA1 and BRCA2 mutations in non-familial breast cancer patients with high risks in Korea: the Korean Hereditary Breast Cancer (KOHBRA) Study. Breast Cancer Res Treat. 2012 Jun;133(3):1143–52. doi: 10.1007/s10549-012-2001-0. PMID: 22382806. Exclusion: E522382806
Song CG, Hu Z, Wu J, . The prevalence of BRCA1 and BRCA2 mutations in eastern Chinese women with breast cancer. J Cancer Res Clin Oncol. 2006;132(10):617–26. PMID: 16835750. Exclusion: E516835750
Sorscher S. Anxiety and hereditary testing results. J Genet Couns. 2017 Oct;26(5):1162–3. doi: 10.1007/s10897-017-0109-4. PMID: 2017-39025-003. Exclusion: E628540620
Spagnolo F, Sestak I, Howell A, . Anastrozole-induced carpal tunnel syndrome: Results from the international breast cancer intervention study II prevention trial. J Clin Oncol. 2016 Jan 10;34(2):139–43. doi: 10.1200/JCO.2015.63.4972. PMID: 26598748. Exclusion: E626598748
Stadler ZK, Salo-Mullen E, Patil SM, . Prevalence of BRCA1 and BRCA2 mutations in Ashkenazi Jewish families with breast and pancreatic cancer. Cancer. 2012 Jan 15;118(2):493–9. doi: 10.1002/cncr.26191. PMID: 21598239. Exclusion: E521598239
Staff Reporter. US Supreme Court strikes down gene patents but allows patenting of synthetic DNA. GenomeWeb LLC; 2013. https://www.genomeweb.com/clinical-genomics/us-supreme-court-strikes-down-gene-patents-allows-patenting-synthetic-dna. Accessed May 16 2019. Exclusion: 2
Stalmeier PF, Roosmalen MS. Concise evaluation of decision aids. Patient Educ Couns. 2009 Jan;74(1):104–9. doi: 10.1016/j.pec.2008.07.043. PMID: 18775622. Exclusion: E418775622
Stalmeier PFM, Roosmalen MS, Verhoef LCG, . The decision evaluation scales. Patient Educ Couns. 2005 Jun;57(3):286–93. PMID: 15893210. Exclusion: E515893210
Steenbeek MP, Harmsen MG, Hoogerbrugge N, . Decision making for risk-reducing surgery in BRCA1/2 mutation carriers in the prospective multicentre tuba study. Int J Gynecol Cancer. 2017;Conference: 20th international meeting of the european society of gynaecological oncology. Austria. 27(Supplement 4):2020. PMID: CN-01437672 NEW. Exclusion: E6
Stenehjem DD, Au T, Sainski AM, . Impact of a genetic counseling requirement prior to genetic testing. BMC Health Serv Res. 2018 03 07;18(1):165. doi: 10.1186/s12913-018-2957-5. PMID: 29514700. Exclusion: E3a29514700
Stewart SL, Kaplan CP, Lee R, . Validation of an Efficient Screening Tool to Identify Low-Income Women at High Risk for Hereditary Breast Cancer. Public Health Genomics. 2016;19(6):342–51. doi: 10.1159/000452095. PMID: 27788513. Exclusion: E327788513
Stirling D, Evans DGR, Pichert G, . Screening for familial ovarian cancer: Failure of current protocols to detect ovarian cancer at an early stage according to the International Federation of Gynecology and Obstetrics System. J Clin Oncol. 2005;23(24):5589–96. PMID: 16110018. Exclusion: E316110018
Stolier AJ, Corsetti RL. Newly diagnosed breast cancer patients choose bilateral mastectomy over breast-conserving surgery when testing positive for a BRCA1/2 mutation. Am Surg. 2005 Dec;71(12):1031–3. PMID: 16447474. Exclusion: E316447474
Stratton JF, Pharoah P, Smith SK, . A systematic review and meta-analysis of family history and risk of ovarian cancer. Br J Obstet Gynaecol. 1998 May;105(5):493–9. PMID: 9637117. Exclusion: 29637117
Streff H, Profato J, Ye Y, . Cancer Incidence in First- and Second-Degree Relatives of BRCA1 and BRCA2 Mutation Carriers. Oncologist. 2016 07;21(7):869–74. doi: 10.1634/theoncologist.2015-0354. PMID: 27306910. Exclusion: E527306910
Stroup AM, Smith KR. Familial effects of BRCA1 genetic mutation testing: changes in perceived family functioning. Cancer Epidemiol Biomarkers Prev. 2007 Jan;16(1):135–41. PMID: 17220342. Exclusion: E3a17220342
Stuckey AR, Onstad MA. Hereditary breast cancer: an update on risk assessment and genetic testing in 2015. Am J Obstet Gynecol. 2015 Aug;213(2):161–5. doi: 10.1016/j.ajog.2015.03.003. PMID: 25747548. Exclusion: 225747548
Sueta A, Ito H, Kawase T, . A genetic risk predictor for breast cancer using a combination of low-penetrance polymorphisms in a Japanese population. Breast Cancer Res Treat. 2012 Apr;132(2):711–21. PMID: 22160591. Exclusion: E522160591
Sussner KM, Edwards TA, Thompson HS, . Ethnic, racial and cultural identity and perceived benefits and barriers related to genetic testing for breast cancer among at-risk women of African descent in New York City. Public Health Genomics. 2011;14(6):356–70. PMID: 21540561. Exclusion: E421540561
Sussner KM, Jandorf L, Thompson HS, . Interest and beliefs about BRCA genetic counseling among at-risk Latinas in New York City. J Genet Couns. 2010 Jun;19(3):255–68. PMID: 20151317. Exclusion: E420151317
Sussner KM, Thompson HS, Jandorf L, . The influence of acculturation and breast cancer-specific distress on perceived barriers to genetic testing for breast cancer among women of African descent. Psychooncology. 2009 Sep;18(9):945–55. PMID: 19090507. Exclusion: E419090507
Swanson CL, Bakkum-Gamez JN. Options in prophylactic surgery to prevent ovarian cancer in high-risk women: how new hypotheses of fallopian tube origin influence recommendations. Curr Treat Options Oncol. 2016;17(5):20. PMID: 27032642. Exclusion: E627032642
Syamala V, Syamala VS, Sreeja L, . Hereditary breast/ovarian cancer: clinicopathological characteristics and survival of BRCA2 positive and negative cases. J Exp Ther Oncol. 2008;7(3):227–36. PMID: 19066131. Exclusion: E519066131
Szender JB, Kaur J, Clayback K, . Breadth of Genetic Testing Selected by Patients at Risk of Hereditary Breast and Ovarian Cancer. Int J Gynecol Cancer. 2018 01;28(1):26–33. doi: 10.1097/IGC.0000000000001122. PMID: 28930807. Exclusion: E528930807
Takano EA, Mitchell G, Fox SB, . Rapid detection of carriers with BRCA1 and BRCA2 mutations using high resolution melting analysis. BMC Cancer. 2008;8:59. PMID: 18298804. Exclusion: E418298804
Tassone F, Cheng S, Gardiner K. Analysis of chromosome 21 yeast artificial chromosome (YAC) clones. Am J Hum Genet. 1992 Dec;51(6):1251–64. PMID: 1463009. Exclusion: 21463009
Tea MM, Tan YY, Staudigl C, . Improving comprehension of genetic counseling for hereditary breast and ovarian cancer clients with a visual tool. PLoS ONE [Electronic Resource]. 2018;13(7):e0200559. doi: 10.1371/journal.pone.0200559. PMID: 30001421. Exclusion: E430001421
Teraoka SN, Bernstein JL, Reiner AS, . Single nucleotide polymorphisms associated with risk for contralateral breast cancer in the Women’s Environment, Cancer, and Radiation Epidemiology (WECARE) Study. Breast Cancer Res. 2011;13(6):R114. PMID: 22087758. Exclusion: E522087758
Tercyak KP, Demarco TA, Mars BD, . Women’s satisfaction with genetic counseling for hereditary breast-ovarian cancer: psychological aspects. Am J Med Genet A. 2004 Nov 15;131(1):36–41. PMID: 15389697. Exclusion: E3a15389697
Tercyak KP, Johnson SB, Roberts SF, . Psychological response to prenatal genetic counseling and amniocentesis. Patient Educ Couns. 2001;43(1):73–84. PMID: 11311841. Exclusion: E411311841
Tereschenko IV, Basham VM, Ponder BA, . BRCA1 and BRCA2 mutations in Russian familial breast cancer. Hum Mutat. 2002;19(2):184. PMID: 11793480. Exclusion: E511793480
Thombs BD, Arthurs E, El-Baalbaki G, . Risk of bias from inclusion of patients who already have diagnosis of or are undergoing treatment for depression in diagnostic accuracy studies of screening tools for depression: systematic review. Br Med J (Clin Res Ed). 2011;343 PMID: 21852353. Exclusion: E421852353
Thompson HS, Sussner K, Schwartz MD, . Receipt of genetic counseling recommendations among black women at high risk for BRCA mutations. Genet Test Mol Biomarkers. 2012 Nov;16(11):1257–62. doi: 10.1089/gtmb.2012.0114. PMID: 23057569. Exclusion: 223057569
Thorlacius S, Olafsdottir G, Tryggvadottir L, . A single BRCA2 mutation in male and female breast cancer families from Iceland with varied cancer phenotypes. Nat Genet. 1996 May;13(1):117–9. doi: 10.1038/ng0596-117. PMID: 8673089. Exclusion: 28673089
Thorlacius S, Sigurdsson S, Bjarnadottir H, . Study of a single BRCA2 mutation with high carrier frequency in a small population. Am J Hum Genet. 1997;60:1079–84. PMID: 9150155. Exclusion: 29150155
Tilanus-Linthorst MMA, Kriege M, Boetes C, . Hereditary breast cancer growth rates and its impact on screening policy. Eur J Cancer. 2005;41(11):1610–7. PMID: 15978801. Exclusion: E515978801
Tilanus-Linthorst MMA, Obdeijn IMM, Bartels KCM, . First experiences screening women at high risk for breast cancer with MR imaging. Breast Cancer Res Treat. 2000;63(1):53–60. PMID: 11079159. Exclusion: 211079159
Tilburt JC, James KM, Sinicrope PS, . Factors influencing cancer risk perception in high risk populations: A systematic review. Hered Cancer Clin Pract. 2011;9(1) PMID: 21595959. Exclusion: E321595959
Tiller K, Meiser B, Gaff C, . A randomized controlled trial of a decision aid for women at increased risk of ovarian cancer. Med Decis Making. 2006 Jul–Aug;26(4):360–72. PMID: 16855125. Exclusion: E416855125
Tiller K, Meiser B, Gould L, . Knowledge of risk management strategies, and information and risk management preferences of women at increased risk for ovarian cancer. Psychooncology. 2005 Apr;14(4):249–61. PMID: 15386771. Exclusion: E415386771
Tobacman JK, Tucker MA, Kase RG, M. H., . Intra-abdominal carcinomatosis after prophylactic oophorectomy in ovarian-cancer-prone families. Lancet. 1982;2(8302):795–7. PMID: 6126666. Exclusion: E76126666
Tong A, Kelly S, Nusbaum R, . Intentions for risk-reducing surgery among high-risk women referred for BRCA1/BRCA2 genetic counseling. Psychooncology. 2015 Jan;24(1):33–9. doi: 10.1002/pon.3560. PMID: 24839250. Exclusion: E524839250
Tonin PN, Maugard CM, Perret C, . A review of histopathological subtypes of ovarian cancer in BRCA-related French Canadian cancer families. Fam Cancer. 2007;6(4):491–7. doi: 10.1007/s10689-007-9152-x. PMID: 17636423. Exclusion: 217636423
Torrance N, Mollison J, Wordsworth S, . Genetic nurse counsellors can be an acceptable and cost-effective alternative to clinical geneticists for breast cancer risk genetic counselling. Evidence from two parallel randomised controlled equivalence trials. Br J Cancer. 2006 Aug 21;95(4):435–44. PMID: 16832415. Exclusion: E3a16832415
Touboul C, Uzan C, Ichante JL, . Factors associated with altered long-term well-being after prophylactic salpingo-oophorectomy among women at increased hereditary risk for breast and ovarian cancer. Oncologist. 2011;16:1250–57. PMID: 21765195. Exclusion: E3a21765195
Trabert B, Ness RB, Lo-Ciganic W-H, . Aspirin, nonaspirin nonsteroidal anti-inflammatory drug, and acetaminophen use and risk of invasive epithelial ovarian cancer: a pooled analysis in the Ovarian Cancer Association Consortium. J Natl Cancer Inst. 2014;106(2) PMID: 24503200. Exclusion: E524503200
Treadwell JR, Singh S, Talati R, . A framework for best evidence approaches can improve the transparency of systematic reviews. J Clin Epidemiol. 2012 Nov;65(11):1159–62. doi: 10.1016/j.jclinepi.2012.06.001. PMID: 23017634. Exclusion: E623017634
Trecate G, Vergnaghi D, Manoukian S, . MRI in the early detection of breast cancer in women with high genetic risk. Tumori. 2006;92(6):517–23. PMID: 17260493. Exclusion: E317260493
Tschernichovsky R, Goodman A. Risk-reducing strategies for ovarian cancer in BRCA mutation carriers: A balancing act. Oncologist. 2017 04;22(4):450–9. doi: 10.1634/theoncologist.2016-0444. PMID: 28314837. Exclusion: 228314837
Tsoref D, Panzarella T, Oza A. Aspirin in prevention of ovarian cancer: are we at the tipping point? J Natl Cancer Inst. 2014;106(2) PMID: 24503201. Exclusion: E624503201
U.S. Food and Drug Administration. Discussion paper on laboratory developed tests (LDTs). 2017. Exclusion: 2
U.S. Preventive Services Task Force. Chemoprevention of breast cancer: recommendations and rationale. Ann Intern Med. 2002;137(1):56–8. PMID: 12093249. Exclusion: E912093249
U.S. Preventive Services Task Force. Methods and Processes. 2018. https://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes. Accessed May 1 2019. Exclusion: 2
Ugalde A, Martin P, Rees G. Psychological impact of receiving genetic risk information for breast cancer, with and without lifestyle information. Aust J Psychol. 2008 May;60(1):1–9. doi: 10.1080/00049530701449497. Exclusion: E4
Unger MA, Nathanson KL, Calzone KA, . Screening for genomic rearrangements in families with breast and ovarian cancer identifies BRCA1 mutations previously missed by conformation-sensitive gel electrophoresis or sequencing. Am J Hum Genet. 2000;67(4):841–50. PMID: 10978226. Exclusion: E510978226
University Medical Center Groningen. Psychosexual consequences of risk-reducing salpingo-oophorectomy. 2015. https://clinicaltrials.gov/ct2/show/nct02372864. Accessed May 16 2019. Exclusion: E7
Unni SK, Schauerhamer MB, Deka R, . BRCA testing, treatment patterns and survival in platinum-sensitive recurrent ovarian cancer - an observational cohort study. J Ovarian Res. 2016 Mar 22;9:18. doi: 10.1186/s13048-016-0227-x. PMID: 27004793. Exclusion: E327004793
Uyei A, Peterson SK, Erlichman J, . Association between clinical characteristics and risk-reduction interventions in women who underwent BRCA1 and BRCA2 testing: a single-institution study. Cancer. 2006 Dec 15;107(12):2745–51. PMID: 17109443. Exclusion: 217109443
Vadaparampil ST, McIntyre J, Quinn GP. Awareness, perceptions, and provider recommendation related to genetic testing for hereditary breast cancer risk among at-risk Hispanic women: similarities and variations by sub-ethnicity. J Genet Couns. 2010 Dec;19(6):618–29. PMID: 20798982. Exclusion: 220798982
van der Aa JE, Hoogendam JP, Butter ES, . The effect of personal medical history and family history of cancer on the uptake of risk-reducing salpingo-oophorectomy. Fam Cancer. 2015 Dec;14(4):539–44. doi: 10.1007/s10689-015-9827-7. PMID: 26264902. Exclusion: E526264902
van der Groep P, van der Wall E, van Diest P. Pathology of hereditary breast cancer. Cell Oncol (Dordr). 2011;34(2):71–88. PMID: 21336636. Exclusion: 221336636
van der Velde NM, Mourits MJE, Arts HJG, . Time to stop ovarian cancer screening in BRCA1/2 mutation carriers? Int J Cancer. 2009 Feb 15;124(4):919–23. PMID: 19035463. Exclusion: E3a19035463
van Dijk S, Otten W, Timmermans DRM, . What’s the message? Interpretation of an uninformative BRCA1/2 test result for women at risk of familial breast cancer. Genet Med. 2005 Apr;7(4):239–45. PMID: 15834241. Exclusion: E515834241
van Dijk S, Otten W, Tollenaar RAEM, . Putting it all behind: long-term psychological impact of an inconclusive DNA test result for breast cancer. Genet Med. 2008 Oct;10(10):745–50. PMID: 18813137. Exclusion: E3a18813137
van Dijk S, Otten W, van Asperen CJ, . Feeling at risk: how women interpret their familial breast cancer risk. Am J Med Genet A. 2004 Nov 15;131(1):42–9. PMID: 15382029. Exclusion: E3a15382029
van Dooren S, Rijnsburger AJ, Seynaeve C, . Psychological distress and breast self-examination frequency in women at increased risk for hereditary or familial breast cancer. Community Genet. 2003;6(4):235–41. PMID: 15331869. Exclusion: E515331869
van Dooren S, Seynaeve C, Rijnsburger AJ, . The impact of having relatives affected with breast cancer on psychological distress in women at increased risk for hereditary breast cancer. Breast Cancer Res Treat. 2005 Jan;89(1):75–80. PMID: 15666200. Exclusion: E415666200
van Dooren S, Seynaeve C, Rijnsburger AJ, . Exploring the course of psychological distress around two successive control visits in women at hereditary risk of breast cancer. Eur J Cancer. 2005 Jul;41(10):1416–25. PMID: 15913982. Exclusion: E415913982
van Driel CM, de Bock GH, Arts HJ, . Stopping ovarian cancer screening in BRCA1/2 mutation carriers: effects on risk management decisions & outcome of risk-reducing salpingo-oophorectomy specimens. Maturitas. 2015 Mar;80(3):318–22. doi: 10.1016/j.maturitas.2014.12.009. PMID: 25600260. Exclusion: E425600260
van Erkelens A, Sie AS, Manders P, . Online self-test identifies women at high familial breast cancer risk in population-based breast cancer screening without inducing anxiety or distress. Eur J Cancer. 2017;78:45–52. doi: 10.1016/j.ejca.2017.03.014. PMID: 28412588. Exclusion: E428412588
van Oostrom I, Meijers-Heijboer H, Duivenvoorden HJ, . The common sense model of self-regulation and psychological adjustment to predictive genetic testing: A prospective study. Psycho Oncology. 2007 Dec;16(12):1121–9. doi: 10.1002/pon.1178. PMID: 17328098. Exclusion: E517328098
van Oostrom I, Meijers-Heijboer H, Duivenvoorden HJ, . A prospective study of the impact of genetic susceptibility testing for BRCA1/2 or HNPCC on family relationships. Psychooncology. 2007;16(4):320–8. PMID: 16909428. Exclusion: H116909428
van Oostrom I, Meijers-Heijboer H, Duivenvoorden HJ, . Comparison of individuals opting for BRCA1/2 or HNPCC genetic susceptibility testing with regard to coping, illness perceptions, illness experiences, family system characteristics and hereditary cancer distress. Patient Educ Couns. 2007 Jan;65(1):58–68. PMID: 16872788. Exclusion: 216872788
van Oostrom I, Meijers-Heijboer H, Duivenvoorden HJ, . Family system characteristics and psychological adjustment to cancer susceptibility genetic testing: a prospective study. Clin Genet. 2007 Jan;71(1):35–42. PMID: 17204044. Exclusion: H117204044
van Sprundel TC, Schmidt MK, Rookus MA, . Risk reduction of contralateral breast cancer and survival after contralateral prophylactic mastectomy in BRCA1 or BRCA2 mutation carriers. Br J Cancer. 2005 Aug 8;93(3):287–92. PMID: 16052221. Exclusion: E3b16052221
van Verschuer VM, Heemskerk-Gerritsen BA, van Deurzen CH, . Lower mitotic activity in BRCA1/2-associated primary breast cancers occurring after risk-reducing salpingo-oophorectomy. Cancer Biol Ther. 2014 Apr;15(4):371–9. doi: 10.4161/cbt.27628. PMID: 24423863. Exclusion: E324423863
Vasen HFA, Tesfay E, Boonstra H, . Early detection of breast and ovarian cancer in families with BRCA mutations. Eur J Cancer. 2005;41(4):549–54. PMID: 15737559. Exclusion: E315737559
Vencken PMLH, Kriege M, Hooning M, . The risk of primary and contralateral breast cancer after ovarian cancer in BRCA1/BRCA2 mutation carriers: Implications for counseling. Cancer. 2013 Mar 1;119(5):955–62. doi: 10.1002/cncr.27839. PMID: 23165859. Exclusion: E423165859
Venne VL, Hamann HA. Successful use of peer educators for sharing genetic information. J Genet Couns. 2007 Aug;16(4):515–25. PMID: 17597387. Exclusion: E317597387
Veronesi U, Maisonneuve P, Costa A, . Prevention of breast cancer with tamoxifen: preliminary findings from the Italian randomised trial among hysterectomised women. Italian Tamoxifen Prevention Study. Lancet. 1998 Jul 11;352(9122):93–7. PMID: 9672273. Exclusion: 29672273
Veronesi U, Maisonneuve P, Rotmensz N, . Tamoxifen for the prevention of breast cancer: late results of the Italian randomized tamoxifen prevention trial among women with hysterectomy. J Natl Cancer Inst. 2007;99(9):727–37. PMID: 17470740. Exclusion: E317470740
Vicus D, Rosen B, Lubinski J, . Tamoxifen and the risk of ovarian cancer in BRCA1 mutation carriers. Gynecol Oncol. 2009 Oct;115(1):135–7. PMID: 19577280. Exclusion: E319577280
Vogel TJ, Stoops K, Bennett RL, . A self-administered family history questionnaire improves identification of women who warrant referral to genetic counseling for hereditary cancer risk. Gynecol Oncol. 2012 Jun;125(3):693–8. PMID: 22446623. Exclusion: 222446623
Vogel VG, Costantino JP, Wickerham DL, . Update of the National Surgical Adjuvant Breast and Bowel Project Study of Tamoxifen and Raloxifene (STAR) P-2 Trial: preventing breast cancer. Cancer Prev Res. 2010 Jun;3(6):696–706. PMID: 20404000. Exclusion: E320404000
Voorwinden JS, Jaspers JP. Prognostic factors for distress after genetic testing for hereditary cancer. J Genet Couns. 2016 Jun;25(3):495–503. doi: 10.1007/s10897-015-9894-9. PMID: 26475052. Exclusion: E526475052
Vorwergk J, Radosa MP, Nicolaus K, . Prophylactic bilateral salpingectomy (PBS) to reduce ovarian cancer risk incorporated in standard premenopausal hysterectomy: complications and re-operation rate. J Cancer Res Clin Oncol. 2014 May;140(5):859–65. doi: 10.1007/s00432-014-1622-6. PMID: 24573653. Exclusion: E324573653
Vos J, Gomez-Garcia E, Oosterwijk JC, . Opening the psychological black box in genetic counseling. The psychological impact of DNA testing is predicted by the counselees’ perception, the medical impact by the pathogenic or uninformative BRCA 1/2-result. Psychooncology. 2012 Jan;21(1):29–42. doi: 10.1002/pon.1864. PMID: 21072753. Exclusion: E3b21072753
Vos J, Menko F, Jansen AM, . A whisper-game perspective on the family communication of DNA-test results: a retrospective study on the communication process of BRCA1/2-test results between proband and relatives. Fam Cancer. 2011 Mar;10(1):87–96. PMID: 20852944. Exclusion: E420852944
Vos J, Menko FH, Oosterwijk JC, . Genetic counseling does not fulfill the counselees’ need for certainty in hereditary breast/ovarian cancer families: an explorative assessment. Psychooncology. 2013 May;22(5):1167–76. doi: 10.1111/j.1399-0004.2010.01581.x. PMID: 22777929. Exclusion: E522777929
Vos J, Oosterwijk JC, Gomez-Garcia E, . Exploring the short-term impact of DNA-testing in breast cancer patients: The counselees’ perception matters, but the actual BRCA1/2 result does not. Patient Educ Couns. 2012;86(2):239–51. PMID: 21684708. Exclusion: E3b21684708
Vos J, Oosterwijk JC, Gomez-Garcia E, . Perceiving cancer-risks and heredity-likelihood in genetic-counseling: how counselees recall and interpret BRCA 1/2-test results. Clin Genet. 2011 Mar;79(3):207–18. doi: 10.1111/j.1399-0004.2010.01581.x. PMID: 21114486. Exclusion: E721114486
Vos J, Otten W, van Asperen C, . The counsellees’ view of an unclassified variant in BRCA1/2: recall, interpretation, and impact on life. Psychooncology. 2008 Aug;17(8):822–30. PMID: 18157792. Exclusion: E3a18157792
Vos J, Stiggelbout AM, Oosterwijk J, . A counselee-oriented perspective on risk communication in genetic counseling: explaining the inaccuracy of the counselees’ risk perception shortly after BRCA1/2 test result disclosure. Genet Med. 2011 Sep;13(9):800–11. PMID: 21885922. Exclusion: E3b21885922
Vos J, van Asperen CJ, Oosterwijk JC, . The counselees’ self-reported request for psychological help in genetic counseling for hereditary breast/ovarian cancer: not only psychopathology matters. Psychooncology. 2013 Apr;22(4):902–10. doi: 10.1002/pon.3081. PMID: 22740372. Exclusion: E522740372
Vreemann S, Gubern-Merida A, Schlooz-Vries MS, . Influence of risk category and screening round on the performance of an MR imaging and mammography screening program in carriers of the BRCA mutation and other women at increased risk. Radiology. 2018 02;286(2):443–51. doi: 10.1148/radiol.2017170458. PMID: 29040037. Exclusion: E529040037
Wacholder S, Hartge P, Prentice R, . Performance of common genetic variants in breast-cancer risk models.[Erratum appears in N Engl J Med. 2010 Dec 2;363(23):2272]. N Engl J Med. 2010 Mar 18;362(11):986–93. PMID: 20237344. Exclusion: E520237344
Wakefield CE, Kasparian NA, Meiser B, . Attitudes toward genetic testing for cancer risk after genetic counseling and decision support: a qualitative comparison between hereditary cancer types. Genetic Testing. 2007;11(4):401–11. PMID: 18294057. Exclusion: E518294057
Wakefield CE, Meiser B, Homewood J, . Development and pilot testing of two decision aids for individuals considering genetic testing for cancer risk. J Genet Couns. 2007 Jun;16(3):325–39. PMID: 17318456. Exclusion: E517318456
Wakefield CE, Meiser B, Homewood J, . A randomized controlled trial of a decision aid for women considering genetic testing for breast and ovarian cancer risk. Breast Cancer Res Treat. 2008 Jan;107(2):289–301. PMID: 17333332. Exclusion: E617333332
Wakefield CE, Meiser B, Homewood J, . A randomized trial of a breast/ovarian cancer genetic testing decision aid used as a communication aid during genetic counseling. Psychooncology. 2008 Aug;17(8):844–54. PMID: 18613319. Exclusion: E418613319
Walter FM, Prevost AT, Birt L, . Development and evaluation of a brief self-completed family history screening tool for common chronic disease prevention in primary care. Br J Gen Pract. 2013 Jun;63(611):e393–400. doi: 10.3399/bjgp13X668186. PMID: 23735410. Exclusion: E423735410
Walters Haygood CL, Handley KF, Farmer MB, . Comprehensive genetic testing: The next generation in an ovarian cancer risk assessment clinic. Gynecol Oncol. 2015;137:102–3. doi: 10.1016/j.ygyno.2015.01.254. Exclusion: E625684217
Wang C, Gonzalez R, Janz NK, . The role of cognitive appraisal and worry in BRCA1/2 testing decisions among a clinic population. Psychol Health. 2007;22(6):719–36. Exclusion: E5
Wang C, Gonzalez R, Milliron KJ, . Genetic counseling for BRCA1/2: a randomized controlled trial of two strategies to facilitate the education and counseling process. Am J Med Genet A. 2005 Apr 1;134A(1):66–73. PMID: 15690408. Exclusion: H215690408
Wapnir IL, Rabinowitz B, Greco RS. A reappraisal of prophylactic mastectomy. Surg Gynecol Obstet. 1990 Aug;171(2):171–84. PMID: 2200150. Exclusion: 22200150
Warner E. Intensive radiologic surveillance: a focus on the psychological issues. Ann Oncol. 2004;15: Suppl 1:I43–i7. doi: 10.1093/annonc/mdh657. PMID: 15280187. Exclusion: E615280187
Warner E. The role of magnetic resonance imaging in screening women at high risk of breast cancer. Top Magn Reson Imaging. 2008 Jun;19(3):163–9. doi: 10.1097/RMR.0b013e31818bc994. PMID: 18941396. Exclusion: E318941396
Warner E, Hill K, Causer P, . Prospective study of breast cancer incidence in women with a BRCA1 or BRCA2 mutation under surveillance with and without magnetic resonance imaging. J Clin Oncol. 2011 May;29(13):1664–9. PMID: 21444874. Exclusion: E3a21444874
Warner E, Messersmith H, Causer P, . Systematic review: using magnetic resonance imaging to screen women at high risk for breast cancer. Ann Intern Med. 2008 May 6;148(9):671–9. PMID: 18458280. Exclusion: 218458280
Warner E, Plewes DB, Hill KA, . Surveillance of BRCA1 and BRCA2 mutation carriers with magnetic resonance imaging, ultrasound, mammography, and clinical breast examination. JAMA. 2004;292(11):1317–25. PMID: 15367553. Exclusion: 215367553
Warner E, Plewes DB, Shumak RS, . Comparison of breast magnetic resonance imaging, mammography, and ultrasound for surveillance of women at high risk for hereditary breast cancer. J Clin Oncol. 2001 Aug 1;19(15):3524–31. doi: 10.1200/jco.2001.19.15.3524. PMID: 11481359. Exclusion: H211481359
Watson CH, Ulm M, Tillmanns T, . The implementation of video-assisted genetic counseling for ovarian, fallopian, and peritoneal cancer patients. Gynecol Oncol. 2016;141:9–10. doi: 10.1016/j.ygyno.2016.04.053. Exclusion: E6
Watson EK, Henderson BJ, Brett J, . The psychological impact of mammographic screening on women with a family history of breast cancer-a systematic review. Psychooncology. 2005 Nov;14(11):939–48. PMID: 15744777. Exclusion: E915744777
Weitzel JN, Clague J, Martir-Negron A, . Prevalence and type of BRCA mutations in Hispanics undergoing genetic cancer risk assessment in the southwestern United States: a report from the Clinical Cancer Genetics Community Research Network. J Clin Oncol. 2013 Jan 10;31(2):210–6. doi: 10.1200/JCO.2011.41.0027. PMID: 23233716. Exclusion: 223233716
Weitzel JN, Lagos VI, Herzog JS, . Evidence for common ancestral origin of a recurring BRCA1 genomic rearrangement identified in high-risk Hispanic families. Cancer Epidemiol Biomarkers Prev. 2007 Aug;16(8):1615–20. doi: 10.1158/1055-9965.EPI-07-0198. PMID: 17646271. Exclusion: 217646271
Wellisch DK, Cohen MM. The special case of complicated grief in women at high risk for breast cancer. Palliative & Supportive Care. 2010 Mar;8(1):7–15. PMID: 20163755. Exclusion: E420163755
Wellisch DK, Gritz ER, Schain W, . Psychological functioning of daughters of breast cancer patients - Part II: Characterizing the distressed daughter of the breast cancer patient. Psychosomatics. 1992;33(2):171–9. PMID: 1557482. Exclusion: E41557482
Wellisch DK, Lindberg NM. A psychological profile of depressed and nondepressed women at high risk for breast cancer. Psychosomatics. 2001 Jul–Aug;42(4):330–6. doi: 10.1176/appi.psy.42.4.330. PMID: 11496022. Exclusion: E411496022
Welsh JL, Hoskin TL, Day CN, . Clinical Decision-Making in Patients with Variant of Uncertain Significance in BRCA1 or BRCA2 Genes. Ann Surg Oncol. 2017 Oct;24(10):3067–72. doi: 10.1245/s10434-017-5959-3. PMID: 28766224. Exclusion: E528766224
Westin SN, Sun CC, Lu KH, . Satisfaction with ovarian carcinoma risk-reduction strategies among women at high risk for breast and ovarian carcinoma. Cancer. 2011 Jun 15;117(12):2659–67. doi: 10.1002/cncr.25820. PMID: 21656744. Exclusion: E3a21656744
Wevers MR, Aaronson NK, Verhoef S, . Impact of rapid genetic counselling and testing on the decision to undergo immediate or delayed prophylactic mastectomy in newly diagnosed breast cancer patients: findings from a randomised controlled trial. Br J Cancer. 2014 Feb 18;110(4):1081–7. doi: 10.1038/bjc.2013.805. PMID: 24423928. Exclusion: E324423928
Wevers MR, Ausems MGEM, Verhoef S, . Behavioral and psychosocial effects of rapid genetic counseling and testing in newly diagnosed breast cancer patients: design of a multicenter randomized clinical trial. BMC Cancer. 2011;11:6. PMID: 21219598. Exclusion: E621219598
White VB, Walsh KK, Foss KS, . Genetic Testing for Hereditary Breast Cancer: The Decision to Decline. Am Surg. 2018 Jan 01;84(1):154–60. PMID: 29428045. Exclusion: E529428045
Whittemore AS, Balise RR, Pharoah PDP, . Oral contraceptive use and ovarian cancer risk among carriers of BRCA1 or BRCA2 mutations. Br J Cancer. 2004 Nov 29;91(11):1911–5. PMID: 15545966. Exclusion: E515545966
Whittemore AS, Gong G, Itnyre J. Prevalence and contribution of BRCA1 mutations in breast cancer and ovarian cancer: Results from three U.S. population-based case-control studies of ovarian cancer. Am J Hum Genet. 1997;60(3):496–504. PMID: 9042908. Exclusion: E59042908
Whittemore AS, Gong G, John EM, . Prevalence of BRCA1 mutation carriers among U.S. non-Hispanic Whites. Cancer Epidemiol Biomarkers Prev. 2004 Dec;13(12):2078–83. PMID: 15598764. Exclusion: 215598764
Whitworth P, Beitsch P, Arnell C, . Impact of payer constraints on access to genetic testing. J Oncol Pract. 2017;13(1):e47–e56. doi: 10.1200/JOP.2016.013581. PMID: 28084878. Exclusion: E528084878
Whitworth P, Beitsch P, Baron P, . Variation in genetic mutations in breast cancer patients meeting NCCN criteria vs those who do not. Ann Surg Oncol. 2018;25(2):264–5. doi: 10.1245/s10434-018-6534-2. Exclusion: E6
Wiering BM, Albada A, Bensing JM, . The influence of dispositional optimism on post-visit anxiety and risk perception accuracy among breast cancer genetic counselees. Psychooncology. 2013 Nov;22(11):2419–27. doi: 10.1002/pon.3292. PMID: 23630180. Exclusion: E323630180
Williams L, Jones W, Elwyn G, . Interactive patient decision aids for women facing genetic testing for familial breast cancer: a systematic web and literature review. J Eval Clin Pract. 2008 Feb;14(1):70–4. PMID: 18211647. Exclusion: E518211647
Williamson M. FDA delays lab test changes until Trump takes office. The Bureau of National Affairs; 2016. https://www.bna.com/fda-delays-lab-n73014447523/. Accessed May 16 2019. Exclusion: 2
Wilson B, Qureshi N, Little J, . Clinical utility of cancer family history collection in primary care. Evidence Report/Technology Assessment. 2009 Apr(179):1–94. PMID: 20804228. Exclusion: E420804228
Wilson BJ, Torrance N, Mollison J, . Improving the referral process for familial breast cancer genetic counselling: findings of three randomised controlled trials of two interventions. Health Technol Assess. 2005 Feb;9(3):iii–iv, 1–126. PMID: 15694064. Exclusion: E515694064
Wise J. Ovary removal is linked to lower breast cancer mortality in BRCA1 carriers. BMJ. 2015;350:h2182. doi: 10.1136/bmj.h2182. PMID: 25911348. Exclusion: E625911348
Witten M, Singletary B, Bland K, . A 13-year analysis of a preventive care program for BRCA 1/2-positive patients at a large academic institution. Ann Surg Oncol. 2018;25(2):266. doi: 10.1245/s10434-018-6534-2. Exclusion: E6
Wolfe CR, Reyna VF, Widmer CL, . Efficacy of a web-based intelligent tutoring system for communicating genetic risk of breast cancer: a fuzzy-trace theory approach. Med Decis Making. 2015 Jan;35(1):46–59. doi: 10.1177/0272989X14535983. PMID: 24829276. Exclusion: E424829276
Wood ME, Stockdale A, Flynn BS. Interviews with primary care physicians regarding taking and interpreting the cancer family history. Fam Pract. 2008;25(5):334–40. PMID: 18765407. Exclusion: E318765407
Woods JE. Breast reconstruction: current state of the art. Mayo Clin Proc. 1986 Jul;61(7):579–85. PMID: 3713262. Exclusion: 23713262
Woodson AH, Muse KI, Jackson M, . Impact of breast cancer and BRCA mutations on thoughts and feelings of future pregnancies. J Clin Oncol. 2012;30(27). Exclusion: E5
Wooster R, Weber BL. Breast and ovarian cancer. N Engl J Med. 2003 Jun 05;348(23):2339–47. doi: 10.1056/NEJMra012284. PMID: 12788999. Exclusion: 212788999
Wright S, Porteous M, Stirling D, . Patients’ views of treatment-focused genetic testing (tfgt): Some lessons for the mainstreaming of brca1 and brca2 testing. J Genet Couns. 2018 May:No Pagination Specified. doi: 10.1007/s10897-018-0261-5. PMID: 2018-23052-001. Exclusion: E3
Wu H, Zhu K, Jatoi I, . Factors associated with the incompliance with mammogram screening among individuals with a family history of breast cancer or ovarian cancer. Breast Cancer Res Treat. 2007 Mar;101(3):317–24. PMID: 16821080. Exclusion: E316821080
Wuttke M, Phillips KA. Clinical management of women at high risk of breast cancer. Curr Opin Obstet Gynecol. 2015 Feb;27(1):6–13. doi: 10.1097/GCO.0000000000000140. PMID: 25502281. Exclusion: E625502281
Xu L, Zhao Y, Chen Z, . Tamoxifen and risk of contralateral breast cancer among women with inherited mutations in BRCA1 and BRCA2: a meta-analysis. Breast Cancer. 2015 Jul;22(4):327–34. doi: 10.1007/s12282-015-0619-6. PMID: 26022977. Exclusion: E326022977
Yang Q, Flanders WD, Moonesinghe R, . Using lifetime risk estimates in personal genomic profiles: estimation of uncertainty. Am J Hum Genet. 2009 Dec;85(6):786–800. PMID: 19931039. Exclusion: E519931039
Yang Q, Khoury MJ, Rodriguez C, . Family history score as a predictor of breast cancer mortality: prospective data from the Cancer Prevention Study II, United States, 1982-1991. Am J Epidemiol. 1998 Apr 01;147(7):652–9. PMID: 9554604. Exclusion: 29554604
Yin L, Grandi N, Raum E, . Meta-analysis: Circulating vitamin D and ovarian cancer risk. Gynecol Oncol. 2011;121(2):369–75. PMID: 21324518. Exclusion: E521324518
Yip C-H, Taib NA, Choo WY, . Clinical and pathologic differences between BRCA1-, BRCA2-, and non-BRCA-associated breast cancers in a multiracial developing country. World J Surg. 2009 Oct;33(10):2077–81. PMID: 19649760. Exclusion: E519649760
Yoon SY, Thong MK, Lee J, . A study on the impact of pre-test genetic counselling and genetic testing towards the psychological distress and cancer worry in unaffected relatives. Fam Cancer. 2013;12:S20–S1. doi: 10.1007/s10689-013-9605-3. Exclusion: E6
Zakowski SG, Valdimarsdottir HB, Bovbjerg DH, . Predictors of intrusive thoughts and avoidance in women with family histories of breast cancer. Ann Behav Med. 1997 Fall;19(4):362–9. doi: 10.1007/bf02895155. PMID: 9706363. Exclusion: E49706363
Zayhowski K, Park J, Boehmer U, . Cancer genetic counselors’ experiences with transgender patients: A qualitative study. J Genet Couns. 2019 Feb 5 doi: 10.1002/jgc4.1092. PMID: 30720922. Exclusion: E530720922
Zhang D, Bai B, Xi Y, . Is aspirin use associated with a decreased risk of ovarian cancer? A systematic review and meta-analysis of observational studies with dose-response analysis. Gynecol Oncol. 2016 Aug;142(2):368–77. doi: 10.1016/j.ygyno.2016.04.543. PMID: 27151430. Exclusion: E527151430
Zhang LR, Chiarelli AM, Glendon G, . Influence of perceived breast cancer risk on screening behaviors of female relatives from the Ontario site of the Breast Cancer Family Registry. Eur J Cancer Prev. 2011 Jul;20(4):255–62. PMID: 21467941. Exclusion: E521467941
Zhang S, Royer R, Li S, . Frequencies of BRCA1 and BRCA2 mutations among 1,342 unselected patients with invasive ovarian cancer. Gynecol Oncol. 2011 May 1;121(2):353–7. doi: 10.1016/j.ygyno.2011.01.020. PMID: 21324516. Exclusion: 221324516
Zhang Y, Simondsen K, Kolesar JM. Exemestane for primary prevention of breast cancer in postmenopausal women. Am J Health Syst Pharm. 2012 Aug 15;69(16):1384–8. doi: 10.2146/ajhp110585. PMID: 22855103. Exclusion: E922855103
Zikmund-Fisher BJ, Ubel PA, Smith DM, . Communicating side effect risks in a tamoxifen prophylaxis decision aid: The debiasing influence of pictographs. Patient Educ Couns. 2008 Nov;73(2):209–14. doi: 10.1016/j.pec.2008.05.010. PMID: 18602242. Exclusion: E418602242
Zilliacus EM, Meiser B, Lobb EA, . Are videoconferenced consultations as effective as face-to-face consultations for hereditary breast and ovarian cancer genetic counseling? Genet Med. 2011 Nov;13(11):933–41. PMID: 21799430. Exclusion: E3a21799430
Zimovjanova M, Bielčikova Z, Miskovicova M, . Preventive programme for carriers of genetic alteration in BRCA1/2 and other high-risk genes. Czech single institution evaluation-fifteen years experience. Eur J Cancer. 2018;92:S144. Exclusion: E6

## Appendix A5 Criteria for Assessing Internal Validity of Individual Studies^*^

### Systematic Reviews

#### Criteria

- Comprehensiveness of sources considered/search strategy used
- Standard appraisal of included studies
- Validity of conclusions
- Recency and relevance (especially important for systematic reviews)

#### Definition of ratings based on above criteria

Good:: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions
Fair:: Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies
Poor:: Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies

### Case-Control Studies

#### Criteria

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls, with exclusion criteria applied equally to both
- Response rate
- Diagnostic testing procedures applied equally to each group
- Measurement of exposure accurate and applied equally to each group
- Appropriate attention to potential confounding variables

#### Definition of ratings based on above criteria

Good:: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; accurate diagnostic procedures and measurements applied equally to cases and controls; and appropriate attention to confounding variables
Fair:: Recent, relevant, and without major apparent selection or diagnostic workup bias, but response rate less than
  80 percent or attention to some but not all important confounding variables
Poor:: Major selection or diagnostic workup bias, response rate less than 50 percent, or inattention to confounding variables

### RCTs and Cohort Studies

#### Criteria

- Initial assembly of comparable groups:
- For RCTs: Adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
- For cohort studies: Consideration of potential confounders, with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- All important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies or intention-to treat analysis for RCTs

Single arm cohort studies were rated based on initial assembly of group, consideration of potential confounders, important outcomes considered, measurements: equal, reliable, and valid (includes masking of outcome assessment), and reporting of attrition if applicable.

#### Definition of ratings based on above criteria

Good:: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.
Fair:: Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs.
Poor:: Studies are graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

### Diagnostic Accuracy Studies

#### Criteria

- Screening test relevant, available for primary care, and adequately described
- Credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Indeterminate results handled in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Reliable screening test

#### Definition of ratings based on above criteria

Good:: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (>100) of broad-spectrum patients with and without disease
Fair:: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients
Poor:: Has a fatal flaw, such as: Uses inappropriate reference standard; improperly administers screening test; biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients

* Reference: U.S. Preventive Services Task Force Procedure Manual. June 2018. Accessed at https://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes

## Appendix A6 Expert Reviewers of the Draft Report

- Mary Daly MD, PhD, MSPH, Director, Risk Assessment Program, Department of Clinical Genetics, Fox Chase Cancer Center, Temple University
- Lori Erby ScM, PhD, CGC, National Human Genome Research Institute, NIH and the Johns Hopkins University
- Brandy Heckman-Stoddard, PhD, MPH, Chief, Division of Cancer Prevention, NCI
- Kathy Helzlsouer, MD, MHS, Associate Director, Epidemiology and Genomics Research Program, Chief Medical Officer, Division of Cancer Control and Population Sciences, NCI
- Kelly Metcalfe, RN, PhD, University of Toronto, Adjunct Scientist, Familial Breast Cancer Research Institute at the Women’s College Research Institute, Toronto, Canada
- Brandy Peaker, MD, MPH, Centers for Disease Control and Prevention
- Robert Pilarski MS, LGC, MSW, Clinical Cancer Genetics Program, Division of Human Genetics, The Ohio State University
- Goli Samimi PhD, MPH, Program Director, Division of Cancer Prevention, NCI

Note: Reviewers provided comments on a prior version of the draft report and may or may not agree with the report findings