# References

1 U.S. Preventive Services Task Force. Final Recommendation Statement: Pancreatic Cancer: Screening. Rockville, MD: U.S. Preventive Services Task Force; 2004.
2 American Cancer Society. What is pancreatic cancer? : American Cancer Society [2016 November 21]. http://www.cancer.org/cancer/pancreaticcancer/detailedguide/pancreatic-cancer-what-is-pancreatic-cancer.
3 National Cancer Institute. Common Cancer Types. National Cancer Institute [2018 August 10]. https://www.cancer.gov/types/common-cancers.
4 American Cancer Society. Cancer Facts & Figures 2018. Atlanta, GA: American Cancer Society [2018 April 9]. https://www.cancer.org/research/cancer-facts-statistics/all-cancer-facts-figures/cancer-facts-figures-2018.html.
5 Zhou J, Enewold L, Stojadinovic A, . Incidence rates of exocrine and endocrine pancreatic cancers in the United States. Cancer Causes Control. 2010;21(6):853–61. PMID: 20182788.20182788
6 Howlader N, Noone A, Krapcho M, . SEER Cancer Statistics Review, 1975–2014. Bethesda, MD: National Cancer Institute; 2017.
7 National Cancer Institute. SEER Stat Fact Sheets: Pancreas Cancer. National Institutes of Health [2018 April 9]. https://seer.cancer.gov/statfacts/html/pancreas.html.
8 Rahib L, Smith BD, Aizenberg R, . Projecting cancer incidence and deaths to 2030: the unexpected burden of thyroid, liver, and pancreas cancers in the United States. Cancer Res. 2014;74(11):2913–21. PMID: 24840647.24840647
9 American Cancer Society. Cancer Facts & Figures 2013 Special Section: Pancreatic Cancer. American Cancer Society; 2013.
10 Siegel RL, Miller KD, Jemal A. Cancer statistics, 2016. CA Cancer J Clin. 2016;66(1):7–30. PMID: 26742998.26742998
11 Khorana AA, Mangu PB, Berlin J, . Potentially Curable Pancreatic Cancer: American Society of Clinical Oncology Clinical Practice Guideline. J Clin Oncol. 2016;34(21):2541–56. PMID: 27247221.27247221
12 Strohl MP, Raigani S, Ammori JB, . Surgery for Localized Pancreatic Cancer: The Trend Is Not Improving. Pancreas. 2016;45(5):687–93. PMID: 26491905.26491905
13 Shapiro M, Chen Q, Huang Q, . Associations of Socioeconomic Variables With Resection, Stage, and Survival in Patients With Early-Stage Pancreatic Cancer. JAMA Surgery. 2016;151(4):338–45. PMID: 26581025.26581025
14 Swords DS, Mulvihill SJ, Skarda DE, . Hospital-level Variation in Utilization of Surgery for Clinical Stage I-II Pancreatic Adenocarcinoma. Ann Surg. 2017;11:11. PMID: 28700442.28700442
15 Dimou F, Sineshaw H, Parmar AD, . Trends in Receipt and Timing of Multimodality Therapy in Early-Stage Pancreatic Cancer. J Gastrointest Surg. 2016;20(1):93–103; discussion PMID: 26503262.26503262
16 Bilimoria KY, Bentrem DJ, Ko CY, . National failure to operate on early stage pancreatic cancer. Ann Surg. 2007;246(2):173–80. PMID: 17667493.17667493
17 Riall TS, Lillemoe KD. Underutilization of surgical resection in patients with localized pancreatic cancer. Ann Surg. 2007;246(2):181–2. PMID: 17667494.17667494
18 Kendal WS. Pancreatectomy Versus Conservative Management for Pancreatic Cancer: A Question of Lead-time Bias. Am J Clin Oncol. 2015;38(5):483–8. PMID: 24064752.24064752
19 Wasif N, Ko CY, Farrell J, . Impact of tumor grade on prognosis in pancreatic cancer: should we include grade in AJCC staging? Ann Surg Oncol. 2010;17(9):2312–20. PMID: 20422460.20422460
20 Tran Cao HS, Zhang Q, Sada YH, . Value of lymph node positivity in treatment planning for early stage pancreatic cancer. Surgery. 2017;162(3):557–67. PMID: 28666686.28666686
21 Torgeson A, Garrido-Laguna I, Tao R, . Value of surgical resection and timing of therapy in patients with pancreatic cancer at high risk for positive margins. ESMO open. 2018;3(1):e000282. PMID: 29387477.29387477
22 Tao L, Yuan C, Ma Z, . Surgical resection of a primary tumor improves survival of metastatic pancreatic cancer: a population-based study. Cancer Manag Res. 2017;9:471–9. PMID: 29056856.29056856
23 Basturk O, Hong SM, Wood LD, . A Revised Classification System and Recommendations From the Baltimore Consensus Meeting for Neoplastic Precursor Lesions in the Pancreas. Am J Surg Pathol. 2015;39(12):1730–41. PMID: 26559377.26559377
24 Elta GH, Enestvedt BK, Sauer BG, . ACG Clinical Guideline: Diagnosis and Management of Pancreatic Cysts. American Journal of Gastroenterology. 2018;113(4):464–79. PMID: 29485131.29485131
25 Koorstra JB, Feldmann G, Habbe N, . Morphogenesis of pancreatic cancer: role of pancreatic intraepithelial neoplasia (PanINs). Langenbecks Arch Surg. 2008;393(4):561–70. PMID: 18283486.18283486
26 Hruban RH, Takaori K, Klimstra DS, . An illustrated consensus on the classification of pancreatic intraepithelial neoplasia and intraductal papillary mucinous neoplasms. Am J Surg Pathol. 2004;28(8):977–87. PMID: 15252303.15252303
27 Cubilla AL, Fitzgerald PJ. Morphological lesions associated with human primary invasive nonendocrine pancreas cancer. Cancer Res. 1976;36(7 PT 2):2690–8. PMID: 1277176.1277176
28 Pour PM, Sayed S, Sayed G. Hyperplastic, preneoplastic and neoplastic lesions found in 83 human pancreases. Am J Clin Pathol. 1982;77(2):137–52. PMID: 7039298.7039298
29 Patra KC, Bardeesy N, Mizukami Y. Diversity of Precursor Lesions For Pancreatic Cancer: The Genetics and Biology of Intraductal Papillary Mucinous Neoplasm. Clin Transl Gastroenterol. 2017;8(4):e86. PMID: 28383565.28383565
30 Andea A, Sarkar F, Adsay VN. Clinicopathological correlates of pancreatic intraepithelial neoplasia: a comparative analysis of 82 cases with and 152 cases without pancreatic ductal adenocarcinoma. Mod Pathol. 2003;16(10):996–1006. PMID: 14559982.14559982
31 Konstantinidis IT, Vinuela EF, Tang LH, . Incidentally discovered pancreatic intraepithelial neoplasia: what is its clinical significance? Ann Surg Oncol. 2013;20(11):3643–7. PMID: 23748606.23748606
32 Stelow EB, Adams RB, Moskaluk CA. The prevalence of pancreatic intraepithelial neoplasia in pancreata with uncommon types of primary neoplasms. Am J Surg Pathol. 2006;30(1):36–41. PMID: 16330940.16330940
33 Reid-Lombardo KM, St Sauver J, Li Z, . Incidence, prevalence, and management of intraductal papillary mucinous neoplasm in Olmsted County, Minnesota, 1984–2005: a population study. Pancreas. 2008;37(2):139–44. PMID: 18665073.18665073
34 Ball CG, Howard TJ. Natural history of intraductal papillary mucinous neoplasia: How much do we really know? World J Gastrointest Surg. 2010;2(10):368–72. PMID: 21160846.21160846
35 Larson A, Kwon RS. Natural History of Pancreatic Cysts. Dig Dis Sci. 2017;62(7):1770–7. PMID: 28315034.28315034
36 Fritz S, Lerch MM. Natural History and Management of Intraductal Papillary Mucinous Neoplasms: Current Evidence. Viszeralmedizin. 2015;31(1):25–30. PMID: 26288612.26288612
37 Han Y, Lee H, Kang JS, . Progression of Pancreatic Branch Duct Intraductal Papillary Mucinous Neoplasm Associates With Cyst Size. Gastroenterology. 2018;154(3):576–84. PMID: 29074452.29074452
38 Ohno E, Hirooka Y, Kawashima H, . Natural history of pancreatic cystic lesions: A multicenter prospective observational study for evaluating the risk of pancreatic cancer. J Gastroenterol Hepatol. 2018;33(1):320–8. PMID: 28872701.28872701
39 Simons JP, Ng SC, Shah SA, . Malignant intraductal papillary mucinous neoplasm: are we doing the right thing? J Surg Res. 2011;167(2):251–7. PMID: 19765732.19765732
40 Machado NO, Al Qadhi H, Al Wahibi K. Intraductal Papillary Mucinous Neoplasm of Pancreas. N Am J Med Sci. 2015;7(5):160–75. PMID: 26110127.26110127
41 Nakamura M, Miyasaka Y, Sadakari Y, . Comparison of guidelines for intraductal papillary mucinous neoplasm: What is the next step beyond the current guidelines? Annals of Gastroenterological Surgery. 2017;1(2):90–8.29863135
42 Vege SS, Ziring B, Jain R, . American gastroenterological association institute guideline on the diagnosis and management of asymptomatic neoplastic pancreatic cysts. Gastroenterology. 2015;148(4):819–22; quize12–3. PMID: 25805375.25805375
43 Pergolini I, Sahora K, Ferrone CR, . Long-term Risk of Pancreatic Malignancy in Patients With Branch Duct Intraductal Papillary Mucinous Neoplasm in a Referral Center. Gastroenterology. 2017;21:21. PMID: 28739282.28739282
44 Sohn TA, Yeo CJ, Cameron JL, . Intraductal papillary mucinous neoplasms of the pancreas: an updated experience. Ann Surg. 2004;239(6):788–97; discussion 97–9. PMID: 15166958.15166958
45 Girometti R, Pravisani R, Intini SG, . Evolution of incidental branch-duct intraductal papillary mucinous neoplasms of the pancreas: A study with magnetic resonance imaging cholangiopancreatography. World J Gastroenterol. 2016;22(43):9562–70. PMID: 27920477.27920477
46 Vanella G, Crippa S, Archibugi L, . Meta-analysis of mortality in patients with high-risk intraductal papillary mucinous neoplasms under observation. Br J Surg. 2018;105(4):328–38. PMID: 29405253.29405253
47 Testini M, Gurrado A, Lissidini G, . Management of mucinous cystic neoplasms of the pancreas. World J Gastroenterol. 2010;16(45):5682–92. PMID: 21128317.21128317
48 Farrell JJ. Prevalence, Diagnosis and Management of Pancreatic Cystic Neoplasms: Current Status and Future Directions. Gut Liver. 2015;9(5):571–89. PMID: 26343068.26343068
49 Naveed S, Qari H, Banday T, . Mucinous Cystic Neoplasms of Pancreas. Gastroenterology Res. 2014;7(2):44–50. PMID: 27785269.27785269
50 Valsangkar NP, Morales-Oyarvide V, Thayer SP, . 851 resected cystic tumors of the pancreas: a 33-year experience at the Massachusetts General Hospital. Surgery. 2012;152(3 Suppl 1):S4–12. PMID: 22770958.22770958
51 Sakorafas GH, Smyrniotis V, Reid-Lombardo KM, . Primary pancreatic cystic neoplasms revisited: part II. Mucinous cystic neoplasms. Surg Oncol. 2011;20(2):e93–101. PMID: 21251815.21251815
52 Postlewait LM, Ethun CG, McInnis MR, . The Hand-Assisted Laparoscopic Approach to Resection of Pancreatic Mucinous Cystic Neoplasms: An Underused Technique? Am Surg. 2018;84(1):56–62. PMID: 29428029.29428029
53 Basturk O, Coban I, Adsay NV. Pancreatic cysts: pathologic classification, differential diagnosis, and clinical implications. Arch Pathol Lab Med. 2009;133(3):423–38. PMID: 19260748.19260748
54 Haugvik SP, Hedenstrom P, Korsaeth E, . Diabetes, smoking, alcohol use, and family history of cancer as risk factors for pancreatic neuroendocrine tumors: a systematic review and meta-analysis. Neuroendocrinology. 2015;101(2):133–42. PMID: 25613442.25613442
55 Kamisawa T, Wood LD, Itoi T, . Pancreatic cancer. Lancet. 2016;388(10039):73–85. PMID: 26830752.26830752
56 Maisonneuve P, Lowenfels AB. Risk factors for pancreatic cancer: a summary review of meta-analytical studies. Int J Epidemiol. 2015;44(1):186–98. PMID: 25502106.25502106
57 Yabar CS, Winter JM. Pancreatic Cancer: A Review. Gastroenterol Clin North Am. 2016;45(3):429–45. PMID: 27546841.27546841
58 Klein AP. Genetic susceptibility to pancreatic cancer. Mol Carcinog. 2012;51(1):14–24. PMID: 22162228.22162228
59 Permuth-Wey J, Egan KM. Family history is a significant risk factor for pancreatic cancer: results from a systematic review and meta-analysis. Fam Cancer. 2009;8(2):109–17. PMID: 18763055.18763055
60 Jacobs EJ, Chanock SJ, Fuchs CS, . Family history of cancer and risk of pancreatic cancer: a pooled analysis from the Pancreatic Cancer Cohort Consortium (PanScan). Int J Cancer. 2010;127(6):1421–8. PMID: 20049842.20049842
61 Ghiorzo P. Genetic predisposition to pancreatic cancer. World J Gastroenterol. 2014;20(31):10778–89. PMID: 25152581.25152581
62 Bruenderman EH, Martin RC, 2nd. High-risk population in sporadic pancreatic adenocarcinoma: guidelines for screening. J Surg Res. 2015;194(1):212–9. PMID: 25479908.25479908
63 Eldridge RC, Gapstur SM, Newton CC, . Jewish ethnicity and pancreatic cancer mortality in a large U.S. cohort. Cancer Epidemiol Biomarkers Prev. 2011;20(4):691–8. PMID: 21278327.21278327
64 Risch HA, Yu H, Lu L, . Detectable Symptomatology Preceding the Diagnosis of Pancreatic Cancer and Absolute Risk of Pancreatic Cancer Diagnosis. Am J Epidemiol. 2015;182(1):26–34. PMID: 26049860.26049860
65 Salo-Mullen EE, O’Reilly EM, Kelsen DP, . Identification of germline genetic mutations in patients with pancreatic cancer. Cancer. 2015;121(24):4382–8. PMID: 26440929.26440929
66 Matsubayashi H. Familial pancreatic cancer and hereditary syndromes: screening strategy for high-risk individuals. J Gastroenterol. 2011;46(11):1249–59. PMID: 21847571.21847571
67 Stadler ZK, Salo-Mullen E, Patil SM, . Prevalence of BRCA1 and BRCA2 mutations in Ashkenazi Jewish families with breast and pancreatic cancer. Cancer. 2012;118(2):493–9. PMID: 21598239.21598239
68 Raimondi S, Lowenfels AB, Morselli-Labate AM, . Pancreatic cancer in chronic pancreatitis; aetiology, incidence, and early detection. Best Pract Res Clin Gastroenterol. 2010;24(3):349–58. PMID: 20510834.20510834
69 Duell EJ, Lucenteforte E, Olson SH, . Pancreatitis and pancreatic cancer risk: a pooled analysis in the International Pancreatic Cancer Case-Control Consortium (PanC4). Ann Oncol. 2012;23(11):2964–70. PMID: 22767586.22767586
70 Ben Q, Xu M, Ning X, . Diabetes mellitus and risk of pancreatic cancer: A meta-analysis of cohort studies. Eur J Cancer. 2011;47(13):1928–37. PMID: 21458985.21458985
71 Yuan C, Rubinson DA, Qian ZR, . Survival among patients with pancreatic cancer and long-standing or recent-onset diabetes mellitus. J Clin Oncol. 2015;33(1):29–35. PMID: 25403204.25403204
72 Mao Y, Tao M, Jia X, . Effect of Diabetes Mellitus on Survival in Patients with Pancreatic Cancer: A Systematic Review and Meta-analysis. Sci Rep. 2015;5:17102. PMID: 26598798.26598798
73 Damiano J, Bordier L, Le Berre JP, . Should pancreas imaging be recommanded in patients over 50 years when diabetes is discovered because of acute symptoms? Diabetes Metab. 2004;30(2):203–7. PMID: 15223996.15223996
74 Ogawa Y, Tanaka M, Inoue K, . A prospective pancreatographic study of the prevalence of pancreatic carcinoma in patients with diabetes mellitus. Cancer. 2002;94(9):2344–9. PMID: 12015758.12015758
75 Olson SH, Xu Y, Herzog K, . Weight Loss, Diabetes, Fatigue, and Depression Preceding Pancreatic Cancer. Pancreas. 2016;45(7):986–91. PMID: 26692445.26692445
76 Keane MG, Horsfall L, Rait G, . A case-control study comparing the incidence of early symptoms in pancreatic and biliary tract cancer. BMJ Open. 2014;4(11):e005720. PMID: 25410605.25410605
77 Ansary-Moghaddam A, Huxley R, Barzi F, . The effect of modifiable risk factors on pancreatic cancer mortality in populations of the Asia-Pacific region. Cancer Epidemiol Biomarkers Prev. 2006;15(12):2435–40. PMID: 17164367.17164367
78 Zou L, Zhong R, Shen N, . Non-linear dose-response relationship between cigarette smoking and pancreatic cancer risk: evidence from a meta-analysis of 42 observational studies. Eur J Cancer. 2014;50(1):193–203. PMID: 24054979.24054979
79 Bosetti C, Lucenteforte E, Silverman DT, . Cigarette smoking and pancreatic cancer: an analysis from the International Pancreatic Cancer Case-Control Consortium (Panc4). Ann Oncol. 2012;23(7):1880–8. PMID: 22104574.22104574
80 Boffetta P, Hecht S, Gray N, . Smokeless tobacco and cancer. Lancet Oncol. 2008;9(7):667–75. PMID: 18598931.18598931
81 Sponsiello-Wang Z, Weitkunat R, Lee PN. Systematic review of the relation between smokeless tobacco and cancer of the pancreas in Europe and North America. BMC Cancer. 2008;8:356. PMID: 19046421.19046421
82 Lee PN, Hamling J. Systematic review of the relation between smokeless tobacco and cancer in Europe and North America. BMC Med. 2009;7:36. PMID: 19638245.19638245
83 Berrington de Gonzalez A, Sweetland S, Spencer E. A meta-analysis of obesity and the risk of pancreatic cancer. Br J Cancer. 2003;89(3):519–23. PMID: 12888824.12888824
84 Jiao L, Berrington de Gonzalez A, Hartge P, . Body mass index, effect modifiers, and risk of pancreatic cancer: a pooled study of seven prospective cohorts. Cancer Causes Control. 2010;21(8):1305–14. PMID: 20383573.20383573
85 Arslan AA, Helzlsouer KJ, Kooperberg C, . Anthropometric measures, body mass index, and pancreatic cancer: a pooled analysis from the Pancreatic Cancer Cohort Consortium (PanScan). Arch Intern Med. 2010;170(9):791–802. PMID: 20458087.20458087
86 Genkinger JM, Spiegelman D, Anderson KE, . A pooled analysis of 14 cohort studies of anthropometric factors and pancreatic cancer risk. Int J Cancer. 2011;129(7):1708–17. PMID: 21105029.21105029
87 Schauer DP, Feigelson HS, Koebnick C, . Bariatric Surgery and the Risk of Cancer in a Large Multisite Cohort. Ann Surg. 2017. PMID: 2893827028938270.
88 Kim B, Chung MJ, Park SW, . Visceral Obesity is Associated with Poor Prognosis in Pancreatic Adenocarcinoma. Nutr Cancer. 2016;68(2):201–7. PMID: 26847707.26847707
89 Shi YQ, Yang J, Du P, . Effect of Body Mass Index on Overall Survival of Pancreatic Cancer: A Meta-Analysis. Medicine (Baltimore). 2016;95(14):e3305. PMID: 27057903.27057903
90 Genkinger JM, Kitahara CM, Bernstein L, . Central adiposity, obesity during early adulthood, and pancreatic cancer mortality in a pooled analysis of cohort studies. Ann Oncol. 2015;26(11):2257–66. PMID: 26347100.26347100
91 Wang YT, Gou YW, Jin WW, . Association between alcohol intake and the risk of pancreatic cancer: a dose-response meta-analysis of cohort studies. BMC Cancer. 2016;16:212. PMID: 26968702.26968702
92 Kautzky-Willer A, Thurner S, Klimek P. Use of statins offsets insulin-related cancer risk. J Intern Med. 2016. PMID: 2776670027766700.
93 Huang BZ, Chang JI, Li E, . Influence of Statins and Cholesterol on Mortality Among Patients With Pancreatic Cancer. J Natl Cancer Inst. 2017;109(5). PMID: 28040693.28040693
94 Risch HA, Lu L, Streicher SA, . Aspirin Use and Reduced Risk of Pancreatic Cancer. Cancer Epidemiol Biomarkers Prev. 2017;26(1):68–74. PMID: 27999143.27999143
95 Canto MI, Harinck F, Hruban RH, . International Cancer of the Pancreas Screening (CAPS) Consortium summit on the management of patients with increased risk for familial pancreatic cancer. Gut. 2013;62(3):339–47. PMID: 23135763.23135763
96 Poruk KE, Firpo MA, Mulvihill SJ. Screening for pancreatic cancer. Adv Surg. 2014;48:115–36. PMID: 25293611.25293611
97 Bhutani MS, Koduru P, Joshi V, . The role of endoscopic ultrasound in pancreatic cancer screening. Endosc Ultrasound. 2016;5(1):8–16. PMID: 26879161.26879161
98 Shin EJ, Canto MI. Pancreatic cancer screening. Gastroenterol Clin North Am. 2012;41(1):143–57. PMID: 22341255.22341255
99 Chari ST, Kelly K, Hollingsworth MA, . Early detection of sporadic pancreatic cancer: summative review. Pancreas. 2015;44(5):693–712. PMID: 25931254.25931254
100 Chang JC, Kundranda M. Novel Diagnostic and Predictive Biomarkers in Pancreatic Adenocarcinoma. Int J Mol Sci. 2017;18(3). PMID: 28335509.28335509
101 Loosen SH, Neumann UP, Trautwein C, . Current and future biomarkers for pancreatic adenocarcinoma. Tumour Biol. 2017;39(6):1010428317692231. PMID: 28618958.28618958
102 Choe JW, Kim JS, Kim HJ, . Value of Early Check-Up of Carbohydrate Antigen 19-9 Levels for Pancreatic Cancer Screening in Asymptomatic New-Onset Diabetic Patients. Pancreas. 2016;45(5):730–4. PMID: 26646277.26646277
103 Dumstrei K, Chen H, Brenner H. A systematic review of serum autoantibodies as biomarkers for pancreatic cancer detection. Oncotarget. 2016;7(10):11151–64. PMID: 26840568.26840568
104 Herreros-Villanueva M, Bujanda L. Non-invasive biomarkers in pancreatic cancer diagnosis: what we need versus what we have. Ann Transl Med. 2016;4(7):134. PMID: 27162784.27162784
105 Poruk KE, Gay DZ, Brown K, . The clinical utility of CA 19-9 in pancreatic adenocarcinoma: diagnostic and prognostic updates. Curr Mol Med. 2013;13(3):340–51. PMID: 23331006.23331006
106 Zhang Y, Yang J, Li H, . Tumor markers CA19-9, CA242 and CEA in the diagnosis of pancreatic cancer: a meta-analysis. Int J Clin Exp Med. 2015;8(7):11683–91. PMID: 26380005.26380005
107 Chen YZ, Liu D, Zhao YX, . Diagnostic performance of serum macrophage inhibitory cytokine-1 in pancreatic cancer: a meta-analysis and meta-regression analysis. DNA Cell Biol. 2014;33(6):370–7. PMID: 24592997.24592997
108 Vila-Navarro E, Vila-Casadesus M, Moreira L, . MicroRNAs for detection of pancreatic neoplasia: biomarker discovery by next-generation sequencing and validation in 2 independent cohorts. Ann Surg [serial on the Internet]. 2017; 265(6): Available from: http://cochranelibrary-wiley.com/o/cochrane/clcentral/articles/368/CN-01372368/frame.html.
109 Eshleman JR, Norris AL, Sadakari Y, . KRAS and guanine nucleotide-binding protein mutations in pancreatic juice collected from the duodenum of patients at high risk for neoplasia undergoing endoscopic ultrasound. Clin Gastroenterol Hepatol. 2015;13(5):963–9 e4. PMID: 25481712.25481712
110 Kanda M, Sadakari Y, Borges M, . Mutant TP53 in duodenal samples of pancreatic juice from patients with pancreatic cancer or high-grade dysplasia. Clin Gastroenterol Hepatol. 2013;11(6):719–30 e5. PMID: 23200980.23200980
111 Suenaga M, Yu J, Shindo K, . Pancreatic juice mutation concentrations can help predict the grade of dysplasia in patients undergoing pancreatic surveillance. Clin Cancer Res. 2018. PMID: 2930182829301828.
112 Gao J, Zhu F, Lv S, . Identification of pancreatic juice proteins as biomarkers of pancreatic cancer. Oncol Rep. 2010;23(6):1683–92. PMID: 20428826.20428826
113 Long J, Liu Z, Wu X, . Screening for genes and subnetworks associated with pancreatic cancer based on the gene expression profile. Mol Med Rep. 2016;13(5):3779–86. PMID: 27035224.27035224
114 Cohen JD, Li L, Wang Y, . Detection and localization of surgically resectable cancers with a multi-analyte blood test. Science. 2018;359(6378):926–30. PMID: 29348365.29348365
115 Balasenthil S, Huang Y, Liu S, . A Plasma Biomarker Panel to Identify Surgically Resectable Early-Stage Pancreatic Cancer. J Natl Cancer Inst. 2017;109(8). PMID: 28376184.28376184
116 Honda K, Okusaka T, Felix K, . Altered plasma apolipoprotein modifications in patients with pancreatic cancer: protein characterization and multi-institutional validation. PLoS One. 2012;7(10):e46908. PMID: 23056525.23056525
117 Kim J, Bamlet WR, Oberg AL, . Detection of early pancreatic ductal adenocarcinoma with thrombospondin-2 and CA19-9 blood markers. Sci Transl Med. 2017;9(398):12. PMID: 28701476.28701476
118 Fan X, Alekseyenko AV, Wu J, . Human oral microbiome and prospective risk for pancreatic cancer: a population-based nested case-control study. Gut. 2018;67(1):120–7. PMID: 27742762.27742762
119 Xie Z, Chen X, Li J, . Salivary HOTAIR and PVT1 as novel biomarkers for early pancreatic cancer. Oncotarget. 2016;7(18):25408–19. PMID: 27028998.27028998
120 National Comprehensive Cancer Network. NCCN Clinical Practice Guidelines in Oncology: Pancreatic Adenocarcinoma, Version 2.2016. [2016 October 12]. https://www.nccn.org/professionals/physician_gls/pdf/pancreatic.pdf.
121 Parikh P, Shiloach M, Cohen ME, . Pancreatectomy risk calculator: an ACS-NSQIP resource. HPB (Oxford). 2010;12(7):488–97. PMID: 20815858.20815858
122 Heerkens HD, Tseng DS, Lips IM, . Health-related quality of life after pancreatic resection for malignancy. British Journal of Surgery. 2016;103(3):257–66. PMID: 26785646.26785646
123 Kamphues C, Bova R, Schricke D, . Postoperative complications deteriorate long-term outcome in pancreatic cancer patients. Ann Surg Oncol. 2012;19(3):856–63. PMID: 21879265.21879265
124 Halloran CM, Ghaneh P, Bosonnet L, . Complications of pancreatic cancer resection. Dig Surg. 2002;19(2):138–46. PMID: 11979003.11979003
125 Joergensen MT, Gerdes AM, Sorensen J, . Is screening for pancreatic cancer in high-risk groups cost-effective? - Experience from a Danish national screening program. Pancreatology. 2016;16(4):584–92. PMID: 27090585.27090585
126 Harinck F, Konings I, Kluijt I, . A multicentre comparative prospective blinded analysis of EUS and MRI for screening of pancreatic cancer in high-risk individuals. Gut [serial on the Internet]. 2016; 65(9): Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/092/CN-01211092/frame.html.
127 Al-Sukhni W, Borgida A, Rothenmund H, . Screening for pancreatic cancer in a high-risk cohort: an eight-year experience. J Gastrointest Surg. 2012;16(4):771–83. PMID: 22127781.22127781
128 Del Chiaro M, Zerbi A, Capurso G, . Familial pancreatic cancer in Italy. Risk assessment, screening programs and clinical approach: a position paper from the Italian Registry. Dig Liver Dis. 2010;42(9):597–605. PMID: 20627831.20627831
129 Schneider R, Slater EP, Sina M, . German national case collection for familial pancreatic cancer (FaPaCa): ten years experience. Fam Cancer. 2011;10(2):323–30. PMID: 21207249.21207249
130 Mocci E, Guillen-Ponce C, Earl J, . PanGen-Fam: Spanish registry of hereditary pancreatic cancer. Eur J Cancer. 2015;51(14):1911–7. PMID: 26212471.26212471
131 Sol Goldman Pancreatic Cancer Research Center. National Familial Pancreatic Tumor Registry. Baltimore, MD: Johns Hopkins University [2018 April 10]. http://www.path.jhu.edu/pancreas/nfptr/index.php.
132 Memorial Sloan Kettering Cancer Center. Pancreatic Tumor Registry. Memorial Sloan Kettering Cancer Center [2018 April 10]. https://www.mskcc.org/cancer-care/types/pancreatic/clinical-trials/familial-pancreatic-tumor-registry.
133 Verna EC, Hwang C, Stevens PD, . Pancreatic cancer screening in a prospective cohort of high-risk patients: a comprehensive strategy of imaging and genetics. Clinical Cancer Research. 2010;16(20):5028–37. PMID: 20876795.20876795
134 University of Washington. UW Pancreatic Cancer Care. University of Washington [2018 April 10]. http://www.uwgi.org/PancreaticCancer/Pages/Home.aspx.
135 OHSU Knight Cancer Institute. Cancer Registries. Oregon Health & Science University [2018 April 10]. http://www.ohsu.edu/xd/health/services/cancer/patients/resources/cancer-registries.cfm.
136 Mayo Clinic. Mayo Clinic Pancreatic Cancer Spore. Mayo Clinic [2018 April 10]. http://www.mayo.edu/research/centers-programs/cancer-research/research-programs/gastrointestinal-cancer-program/mayo-clinic-pancreatic-cancer-spore/core-resources/clinical-research-core.
137 Fred & Pamela Buffett Cancer Center. Pancreatic Cancer Collaborative Registry (PCCR). University of Nebraska Medical Center [2018 April 10]. http://pccr.unmc.edu/.
138 Jefferson Pancreas Tumor Registry. Philadelphia: Thomas Jefferson University Hospital, Sidney Kimmel Cancer Center [2018 August 3]. https://hospitals.jefferson.edu/departments-and-services/pancreas-biliary-and-related-cancer-center/registry.html.
139 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services, 2nd edition. Baltimore, MD: Williams & Wilkins; 1996.
140 U.S. Preventive Services Task Force. Screening for Pancreatic Cancer: A Brief Evidence Update for the U.S. Preventive Services Task Force. Rockville, MD: U.S. Preventive Services Task Force; 2004.
141 Carrato A, Falcone A, Ducreux M, . A Systematic Review of the Burden of Pancreatic Cancer in Europe: Real-World Impact on Survival, Quality of Life and Costs. J Gastrointest Cancer. 2015;46(3):201–11. PMID: 25972062.25972062
142 Li H, Hu Z, Chen J, . Comparison of ERCP, EUS, and ERCP combined with EUS in diagnosing pancreatic neoplasms: a systematic review and meta-analysis. Tumour Biol. 2014;35(9):8867–74. PMID: 24891188.24891188
143 Banafea O, Mghanga FP, Zhao J, . Endoscopic ultrasonography with fine-needle aspiration for histological diagnosis of solid pancreatic masses: a meta-analysis of diagnostic accuracy studies. BMC Gastroenterol. 2016;16:108. PMID: 27580856.27580856
144 Peters ML, Tseng JF, Miksad RA. Genetic Testing in Pancreatic Ductal Adenocarcinoma: Implications for Prevention and Treatment. Clin Ther. 2016;38(7):1622–35. PMID: 27041411.27041411
145 Thiruvengadam N, Park WG. Systematic Review of Pancreatic Cyst Fluid Biomarkers: The Path Forward. Clin Transl Gastroenterol. 2015;6:e88. PMID: 26065716.26065716
146 Schmidt-Hansen M, Berendse S, Hamilton W. Symptoms of Pancreatic Cancer in Primary Care: A Systematic Review. Pancreas. 2016;45(6):814–8. PMID: 26495795.26495795
147 Wan C, Shen Y, Yang T, . Diagnostic value of microRNA for pancreatic cancer: a meta-analysis. Archives of Medical Science. 2012;8(5):749–55. PMID: 12013001092.23185182
148 Puli SR, Bechtold ML, Buxbaum JL, . How good is endoscopic ultrasound-guided fine-needle aspiration in diagnosing the correct etiology for a solid pancreatic mass?: A meta-analysis and systematic review. Pancreas. 2013;42(1):20–6. PMID: 23254913.23254913
149 Treadwell JR, Zafar HM, Mitchell MD, . Imaging Tests for the Diagnosis and Staging of Pancreatic Adenocarcinoma: A Meta-Analysis. Pancreas. 2016;45(6):789–95. PMID: 26745859.26745859
150 Balaban EP, Mangu PB, Khorana AA, . Locally Advanced, Unresectable Pancreatic Cancer: American Society of Clinical Oncology Clinical Practice Guideline. J Clin Oncol. 2016;34(22):2654–68. PMID: 27247216.27247216
151 Spath C, Nitsche U, Muller T, . Strategies to improve the outcome in locally advanced pancreatic cancer. Minerva Chir. 2015;70(2):97–106. PMID: 25658301.25658301
152 United Nations Development Programme. Human Development Index: 2016 Rankings. United Nations Development Programme [2017 December 1]. http://hdr.undp.org/en/2016-report.
153 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality; 2014.
154 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589.15615589
155 Ludwig E, Olson SH, Bayuga S, . Feasibility and yield of screening in relatives from familial pancreatic cancer families. Am J Gastroenterol. 2011;106(5):946–54. PMID: 21468009.21468009
156 Bartsch DK, Slater EP, Carrato A, . Refinement of screening for familial pancreatic cancer. Gut. 2016;65(8):1314–21. PMID: 27222532.27222532
157 Poley JW, Kluijt I, Gouma DJ, . The yield of first-time endoscopic ultrasonography in screening individuals at a high risk of developing pancreatic cancer. Am J Gastroenterol. 2009;104(9):2175–81. PMID: 19491823.19491823
158 Konings IC, Harinck F, Kuenen MA, . Factors associated with cancer worries in individuals participating in annual pancreatic cancer surveillance. Fam Cancer. 2016. PMID: 2762987427629874.
159 Canto MI, Goggins M, Yeo CJ, . Screening for pancreatic neoplasia in high-risk individuals: an EUS-based approach. Clin Gastroenterol Hepatol. 2004;2(7):606–21. PMID: 15224285.15224285
160 Canto MI, Goggins M, Hruban RH, . Screening for early pancreatic neoplasia in high-risk individuals: a prospective controlled study. Clin Gastroenterol Hepatol. 2006;4(6):766–81; quiz 665. PMID: 16682259.16682259
161 Potjer TP, Schot I, Langer P, . Variation in precursor lesions of pancreatic cancer among high-risk groups. Clin Cancer Res. 2013;19(2):442–9. PMID: 23172884.23172884
162 Vasen H, Ibrahim I, Ponce CG, . Benefit of Surveillance for Pancreatic Cancer in High-Risk Individuals: Outcome of Long-Term Prospective Follow-Up Studies From Three European Expert Centers. J Clin Oncol. 2016;34(17):2010–9. PMID: 27114589.27114589
163 Shin EJ, Topazian M, Goggins MG, . Linear-array EUS improves detection of pancreatic lesions in high-risk individuals: a randomized tandem study. Gastrointest Endosc. 2015;82(5):812–8. PMID: 25930097.25930097
164 Del Chiaro M, Verbeke CS, Kartalis N, . Short-term Results of a Magnetic Resonance Imaging-Based Swedish Screening Program for Individuals at Risk for Pancreatic Cancer. JAMA Surgery. 2015;150(6):512–8. PMID: 25853369.25853369
165 Canto MI, Hruban RH, Fishman EK, . Frequent detection of pancreatic lesions in asymptomatic high-risk individuals. Gastroenterology. 2012;142(4):796–804; quiz e14–5. PMID: 22245846.22245846
166 Hart SL, Torbit LA, Crangle CJ, . Moderators of cancer-related distress and worry after a pancreatic cancer genetic counseling and screening intervention. Psychooncology. 2012;21(12):1324–30. PMID: 21774034.21774034
167 Harinck F, Nagtegaal T, Kluijt I, . Feasibility of a pancreatic cancer surveillance program from a psychological point of view. Genetics in Medicine. 2011;13(12):1015–24. PMID: 21857231.21857231
168 Maheu C, Vodermaier A, Rothenmund H, . Pancreatic cancer risk counselling and screening: impact on perceived risk and psychological functioning. Familial Cancer. 2010;9(4):617–24. PMID: 20623197.20623197
169 Langer P, Kann PH, Fendrich V, . Five years of prospective screening of high-risk individuals from families with familial pancreatic cancer. Gut. 2009;58(10):1410–8. PMID: 19470496.19470496
170 Konings IC, Sidharta GN, Harinck F, . Repeated participation in pancreatic cancer surveillance by high-risk individuals imposes low psychological burden. Psychooncology. 2016;25(8):971–8. PMID: 26632416.26632416
171 Barnes CA, Krzywda E, Lahiff S, . Development of a high risk pancreatic screening clinic using 3.0 T MRI. Fam Cancer. 2018;17(1):101–11. PMID: 29101607.29101607
172 Gangi A, Malafa M, Klapman J. Endoscopic Ultrasound-Based Pancreatic Cancer Screening of High-Risk Individuals: A Prospective Observational Trial. Pancreas. 2018;19:19. PMID: 29683970.29683970
173 Canto MI, Almario JA, Schulick RD, . Risk of Neoplastic Progression in Individuals at High Risk for Pancreatic Cancer Undergoing Long-term Surveillance. Gastroenterology. 2018;155(3):740–51 e2. PMID: 29803839.29803839
174 Committee ASoP, Early DS, Acosta RD, . Adverse events associated with EUS and EUS with FNA. Gastrointest Endosc. 2013;77(6):839–43. PMID: 23684089.23684089
175 Underhill M, Berry D, Dalton E, . Patient experiences living with pancreatic cancer risk. Hered Cancer Clin Pract. 2015;13(1):13. PMID: 26029287.26029287
176 Wong C, Cuggia A, Borgida A, . Germline mutations in seemingly sporadic pancreatic cancer. J Clin Oncol. 2017;35(4_suppl):312–.
177 Munigala S, Singh A, Gelrud A, . Predictors for Pancreatic Cancer Diagnosis Following New-Onset Diabetes Mellitus. Clin Transl Gastroenterol. 2015;6:e118. PMID: 26492440.26492440
178 Illes D, Terzin V, Holzinger G, . New-onset type 2 diabetes mellitus-A high-risk group suitable for the screening of pancreatic cancer? Pancreatology. 2016;16(2):266–71. PMID: 26777407.26777407
179 Batabyal P, Vander Hoorn S, Christophi C, . Association of diabetes mellitus and pancreatic adenocarcinoma: a meta-analysis of 88 studies. Ann Surg Oncol. 2014;21(7):2453–62. PMID: 24609291.24609291
180 Velanovich V. The association of quality-of-life measures with malignancy and survival in patients with pancreatic pathology. Pancreas. 2011;40(7):1063–9. PMID: 21785386.21785386
181 National Institute for Health and Care Excellence. NICE Guideline [NG12] Suspected cancer: recognition and referral. London, U.K.: NICE [2016 November 25]. https://www.nice.org.uk/guidance/ng12/chapter/1-Recommendations-organised-by-site-of-cancer.
182 Zhao D, Weng C. Combining PubMed knowledge and EHR data to develop a weighted bayesian network for pancreatic cancer prediction. J Biomed Inform. 2011;44(5):859–68. PMID: 21642013.21642013
183 QCancer®-2017. United Kingdom: ClinRisk, University of Nottingham [2018 April 5]. http://qcancer.org/.
184 Hippisley-Cox J, Coupland C. Identifying patients with suspected pancreatic cancer in primary care: derivation and validation of an algorithm. Br J Gen Pract. 2012;62(594):e38–45. PMID: 22520674.22520674
185 Hippisley-Cox J. Qcancer: symptom based approach to early diagnosis of cancer. ClinRisk [2018 April 5]. http://qcancer.org/QCancer-Overview-Dec-2012.pdf.
186 Collins GS, Altman DG. Identifying patients with undetected pancreatic cancer in primary care: an independent and external validation of QCancer() (Pancreas). Br J Gen Pract. 2013;63(614):e636–42. PMID: 23998844.23998844
187 Wang W, Chen S, Brune KA, . PancPRO: risk assessment for individuals with a family history of pancreatic cancer. J Clin Oncol. 2007;25(11):1417–22. PMID: 17416862.17416862
188 PancPRO. BayesMendel Lab, Harvard University [2018 April 5]. https://projects.iq.harvard.edu/bayesmendel/pancpro.
189 Leonardi G, Marchi S, Falconi M, . “PancPro” as a tool for selecting families eligible for pancreatic cancer screening: an Italian study of incident cases. Dig Liver Dis. 2012;44(7):585–8. PMID: 22281375.22281375
190 Kim DJ, Rockhill B, Colditz GA. Validation of the Harvard Cancer Risk Index: a prediction tool for individual cancer risk. J Clin Epidemiol. 2004;57(4):332–40. PMID: 15135833.15135833
191 Your Disease Risk: The Source on Prevention. Siteman Cancer Center]. https://siteman.wustl.edu/prevention/ydr/.
192 Hirshberg Foundation for Pancreatic Cancer Research. About the Pancreas: Prognosis. Hirshberg Foundation for Pancreatic Cancer Research [2016 October 12]. http://pancreatic.org/pancreatic-cancer/about-the-pancreas/prognosis/.
193 Sohal DP, Mangu PB, Khorana AA, . Metastatic Pancreatic Cancer: American Society of Clinical Oncology Clinical Practice Guideline. J Clin Oncol. 2016;34(23):2784–96. PMID: 27247222.27247222
194 American Academy of Family Physicians. Summary of Recommendations for Clinical Preventive Services. AAFP [2016 November 25]. http://www.aafp.org/dam/AAFP/documents/patient_care/clinical_recommendations/cps-recommendations.pdf.
195 American Cancer Society. Can pancreatic cancer be found early? : American Cancer Society [2016 November 25]. http://www.cancer.org/cancer/pancreaticcancer/detailedguide/pancreatic-cancer-detection.
196 Syngal S, Brand RE, Church JM, . ACG clinical guideline: Genetic testing and management of hereditary gastrointestinal cancer syndromes. Am J Gastroenterol. 2015;110(2):223–62; quiz 63. PMID: 25645574.25645574
197 Practitioners RACoG. Guidelines for preventive activities in general practice, 9th edition. East Melbourne, Australia: Royal Australian College of General Practitioners [2016 November 25]. http://www.racgp.org.au/your-practice/guidelines/redbook/.
198 National Institute for Health and Care Excellence. Individual research recommendation details: NG12/2. NICE [2016 November 25]. https://www.nice.org.uk/about/what-we-do/research-and-development/research-recommendations/ng12/2.
199 National Institute for Health and Care Excellence. Individual research recommendation details NG12/3. NICE [2016 November 25]. https://www.nice.org.uk/about/what-we-do/research-and-development/research-recommendations/ng12/3.
200 Ducreux M, Cuhna AS, Caramella C, . Cancer of the pancreas: ESMO Clinical Practice Guidelines for diagnosis, treatment and follow-up. Ann Oncol. 2015;26: Suppl 5:v56–68. PMID: 26314780.26314780
201 Cancer Research UK. Pancreatic cancer screening. Cancer Research UK [2016 November 25]. http://www.cancerresearchuk.org/about-cancer/type/pancreatic-cancer/about/screening-for-pancreatic-cancer.
202 Yamaguchi K, Okusaka T, Shimizu K, . EBM-based Clinical Guidelines for Pancreatic Cancer (2013) issued by the Japan Pancreas Society: a synopsis. Jpn J Clin Oncol. 2014;44(10):883–8. PMID: 25205672.25205672
203 Brand RE, Lerch MM, Rubinstein WS, . Advances in counselling and surveillance of patients at risk for pancreatic cancer. Gut. 2007;56(10):1460–9.17872573
204 American Joint Committee on Cancer. Pancreas Cancer Staging, 7th edition. American Joint Committee on Cancer [2018 April 10]. https://cancerstaging.org/references-tools/quickreferences/Documents/PancreasSmall.pdf.
205 Custers JA, van den Berg SW, van Laarhoven HW, . The Cancer Worry Scale: detecting fear of recurrence in breast cancer survivors. Cancer Nurs. 2014;37(1):E44–50. PMID: 23448956.23448956