# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Howard Tracer, MD, at the Agency for Healthcare Research and Quality; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; the National Cancer Institute and the National Institute of Diabetes and Digestive and Kidney Diseases for providing federal partner review of the draft report; Marcia Irene Canto, MD; Teresa Brentall, MD; Paul Pinsky, PhD; Philip Prorok, PhD; and Theresa P. Yeo, PhD, who provided expert review of the draft report, Venu Pillarisetty, MD, FACS, for expert consultation and review of the draft report; Todd Hannon, MLS, for creating and conducting literature searches; Vina Graham and Stephen Perry for administrative assistance; and Gabrielle Gundersen, MPH, for project management assistance.