# Chapter 4 Discussion

## Summary of Evidence

Thirteen fair quality prospective cohort screening studies of asymptomatic individuals at high familial risk for pancreatic adenocarcinoma (n=1317) met inclusion criteria for this review. Other than one study that included a small average risk comparison group (n=138), no screening studies in people without genetic syndromes or a strong family history met our inclusion criteria. All included studies represent new evidence since the previous evidence review, which did not identify any studies of screening for pancreatic adenocarcinoma.^140^ While these populations are at particularly high risk and would normally be outside of the scope of the USPSTF, these represent the most clinically relevant populations for screening.

A summary of the evidence is provided in Tables 15 and 16. We found no studies evaluating whether screening for pancreatic adenocarcinoma impacts morbidity or mortality. We found low strength of evidence that imaging-based screening can detect pancreatic adenocarcinoma and its precursor lesions in individuals at high familial risk, and low strength of evidence that screening is associated with minimal to no psychosocial or procedural harms. We found insufficient evidence to assess measures of diagnostic accuracy, including sensitivity, specificity, predictive value, or false positives. Additionally, we found insufficient evidence to assess the benefits or harms of surgical intervention for screen-detected pancreatic adenocarcinoma.

Table 15 Summary of Evidence by Key Question

Key Question | Studies (k), observations (n), study designs | Summary of Findings | Consistency and Precision | Other Limitations | Strength of Evidence | Applicability
KQ1: Effect of screening on health outcomes | No studies | NA | NA | NA | Insufficient for benefit | NA
KQ2: Diagnostic accuracy of screening | k=13 prospective cohort studies; n=1317; EUS: k=9; n=885; MRI/MRCP: k=8; n=849; CT: k=2; n=294 | Across all studies (n=1317), 18 cases of PDAC were detected; 9 on initial screening. No evidence available for diagnostic accuracy. Pooled yield for all screening tests to detect PDAC on initial screening was 7.8 per 1000 (95% CI 3.6–14.7); and for total yield including both initial screening and repeated screening, was 15.6 per 1000 (95% CI 9.3–24.5). Diagnostic yield similar for EUS/ERCP and MRI/MRCP. Initial screening with CT (n=294) yielded 1 PDAC case (yield 12.8 per 1000). | Inconsistent, imprecise | Small sample sizes; no un-screened comparison groups; little to no subgroup analyses of screening yield in different risk groups. Reporting bias not detected. All studies were of fair quality. | Low for accuracy | Most applicable to populations who are white or with Northern European ancestry with established increased family history or genetic risk for pancreatic cancer seen in tertiary care centers.
KQ3: Harms of screening | Total: k=9 prospective cohort studies; n=938; Procedural harms (k=8; n=675); EUS/ERCP: k=7; n=574; MRI/MRCP: k=2; n=240; CT: k=1; n=78; FNA: k=2; n=45; Psychosocial harms:; k=2 prospective cohort studies; n=271 | Procedural harms:; EUS: 55/216 (25%) mild post-EUS pain; 13/216 (6%) adverse events related to anesthesia.; ERCP: 15/150 (10%) acute pancreatitis, 9 requiring hospitalization; MRI/MRCP: None reported; CT: 1/78 mild reaction to contrast (k=1); FNA: None reported; Psychosocial harms:; Cancer worry: 1 study reported (benefit) decrease in worry between pre-and post-screening; Cancer distress, depression, or anxiety: no evidence of harm | Inconsistent, imprecise | Not all studies reported methods of assessment of harms; few studies assessed psychosocial harms. Reporting bias not detected. All studies were of fair quality. | Low for harms | Most applicable to populations who are white or with Northern European ancestry with established increased family history or genetic risk for pancreatic cancer seen in tertiary care centers.
KQ4: Effect of treatment on health outcomes | No studies | NA | NA | NA | Insufficient for benefit | NA
KQ5: Harms of treatment | k=6 prospective cohort studies; n=32 people receiving surgery | Seven instances of surgical harms were reported in 32 cases of surgery. One (stricture to hepaticojejunal anastomosis) occurred 11 months post-operatively; and the others (diabetes, fistula) in the immediate post-operative period.; No information was reported about assessment or instances of psychosocial harms. | Inconsistent, imprecise | Harms were inconsistently reported, as were the methods of assessing harms. For studies reporting harms, whether they were assessed consistently in all study participants was not well reported. Reporting bias not detected. All studies were of fair quality. | Insufficient for harms | NA

Abbreviations: KQ = key question; PDAC = pancreatic ductal adenocarcinoma; NA = not applicable; EUS = endoscopic ultrasound; ERCP = endoscopic retrograde cholangiopancreatography; CT = computed tomography; MRI = magnetic resonance imaging; MRCP = magnetic resonance cholangiopancreaticography; FNA = fine-needle aspiration

Table 16 Summary of Existing and New Evidence on Screening for Pancreatic Adenocarcinoma

| Rationale and foundational evidence for previous D recommendation (2004)^140^,^1^ | New evidence findings | Limitations of new evidence | Consistency of new evidence with foundational evidence and current understanding
Benefits | Screening: The 2004 evidence update found no direct evidence on the benefits of screening for pancreatic cancer, and no high-quality evidence on the accuracy of screening tests.; Treatment: There was no established evidence of the effectiveness of surgery, adjuvant chemotherapy, or radiation therapy for pancreatic cancer. | Screening: Based on 13 prospective screening studies, imaging-based screening in groups at high familial risk can detect pancreatic adenocarcinoma and its precursor lesions. Across all studies (n=1317), 18 cases of pancreatic adenocarcinoma were detected, 12 at early stage disease. There was no direct evidence of the impact of screening on morbidity or mortality.; Treatment: No included studies. | Screening: Inconsistent reporting of test positives and no follow-up of screen-negative people prohibit assessment of sensitivity or specificity screening tests.; The current evidence applies primarily to populations at high risk due to family history.; Treatment: No included studies. | Screening: Included studies provide new evidence on the diagnostic yield of screening high-risk populations at increased familial risk.; Treatment: A survival advantage associated with surgical intervention for early stage cancer is established, but there continues to be very limited evidence on the outcomes of treatment in screen-detected pancreatic adenocarcinoma.
Harms | Screening: The USPSTF concluded that there is potential for significant harm because of the low prevalence of pancreatic cancer, limited accuracy of screening tests, and the invasive nature of diagnostic tests.; Treatment: The USPSTF concluded that there are poor outcomes from treatment for pancreatic cancer. | Screening: EUS was associated with mild post-EUS pain and adverse events related to anesthesia (7 studies). ERCP was associated with acute pancreatitis. Harms of MRI (2 studies) or CT (1 study) were minimal. There was no evidence of psychosocial harm from screening (2 studies).; Treatment: In 32 cases of surgery, 7 instances of surgical harms were reported, including stricture to hepaticojejunal anastomosis, diabetes, fistula, or unspecified complications. There was no included evidence on the psychosocial harms of surgical intervention. | Screening: Harms were inconsistently reported, as were methods of assessment.; Treatment: Harms were inconsistently reported, as were methods of assessment. | Screening: All studies on screening harms represent new evidence.; Treatment: All studies on treatment harms represent new evidence. While the morbidities of surgical intervention are established, there is little evidence to estimate these events following treatment of screen-detected pancreatic adenocarcinoma.

Abbreviations: USPSTF = U.S. Preventive Services Task Force; EUS = endoscopic ultrasound; ERCP = endoscopic retrograde cholangiopancreatography; CT = computed tomography; MRI = magnetic resonance imaging

### Detection of Pancreatic Adenocarcinoma

The yield of screening to detect pancreatic adenocarcinoma was low even in populations at elevated risk (7.8 per 1000 for initial screening; 15.6 per 1000 for the entire screening program). It appears that imaging-based screening with EUS or MRI can detect pancreatic adenocarcinoma, but there is insufficient evidence to evaluate the impact of screening on morbidity and mortality compared to clinical detection.

Observational data clearly suggest a survival benefit associated with earlier stage at detection, and surgical resection of early stage adenocarcinoma further enhances survival (Chapter 1). In this review, 12 of 18 (66.7%) cases detected through either initial screening or repeat screening were detected at stage I or II, when surgical intervention has the greatest potential to improve survival. This appears to be a more favorable proportion than the 9 percent to 19 percent of individuals who present clinically at early stage (Table 1),^7^ though sample sizes were limited and there was insufficient evidence to directly compare screen-detected and clinically detected pancreatic adenocarcinoma within the present review. Taken together, the included studies suggest that imaging-based screening in high-risk populations may result in stage shift. However, it is unclear if this represents a different spectrum of disease, is a result of lead-time bias, or provides evidence supporting screening. Two individuals reported in the included studies presented with advanced stage cancer during surveillance of abnormal screening findings, suggesting rapid progression of disease. Further, it is unknown if people with screen-detected adenocarcinoma will respond to treatment similarly to those with clinically-detected early stage adenocarcinoma, or if morbidity and mortality outcomes differ for screen-detected pancreatic adenocarcinoma.

### Detection of Precursor Lesions

Detection of precursor lesions of IPMN or PanIN ranged from 0 to 129 per 1000. However, studies did not systematically follow up these lesions for progression to adenocarcinoma, so this level of detection may or may not represent a clinical benefit, since it is yet unclear if detection and management of precursor lesions results in a decrease in cancer incidence, morbidity or mortality. Although the detection and removal of precursor lesions may be a preferable endpoint to pancreatic adenocarcinoma, in the absence of clear evidence about progression and assessment of lead time bias, potential overdiagnosis and subsequent harms associated with treatment of precursor lesions remain a possibility.

### Harms of Screening and Treatment

In addition to the potential for overdiagnosis of precursor lesions, screening, followup testing, and surgical treatment may result in harms. Potential harms of endoscopic screening can include perforation (which can lead to death in a minority of cases), infection, iatrogenic pancreatitis, hemorrhage, bile peritonitis, and malignant seeding.^174^ Screening for pancreatic adenocarcinoma also may be associated with psychosocial harms such as anxiety, depression, or cancer worry.^167,^ ^175^ We found sparse evidence on the harms of screening, but the available evidence suggests few harms beyond a risk of acute pancreatitis following ERCP in two studies. In two studies (n=271) no evidence of psychosocial harm was detected.

Pancreatic surgery is associated with complication rates of 20%–50% in the post-operative period (Chapter 1). However, evidence on the harms of surgical intervention in screen-detected pancreatic adenocarcinoma was very limited, and could indicate an underestimate of harms in this body of evidence.

### Applicability to Other Risk Groups

Although the high-risk populations included here are typically outside of the purview of the USPSTF, they represent the best data available on screening for pancreatic adenocarcinoma. Included populations were at known elevated pancreatic adenocarcinoma risk based on family history, and are enriched with people with known genetic mutations or syndromes. Only about 10 percent of pancreatic adenocarcinoma cases have a familial basis; of those, only about 20 percent are currently attributed to inherited genetic mutations.^55,^ ^61^ Genetic mutations associated with seemingly sporadic pancreatic adenocarcinoma risk may lead to an expanded role for genetic risk stratification for screening,^176^ but would still apply to a minority of people. The implications of these results to other at-risk populations are unknown, including those with new-onset diabetes, smoking history, or chronic pancreatitis.

## Considerations for Risk Assessment in Primary Care

Given the low prevalence of pancreatic adenocarcinoma even in high-risk groups, risk assessment and identifying subgroups at the highest risk for pancreatic adenocarcinoma is critical for improving screening.^96^ Increasingly, screening protocols expanding to include multiple behavioral and genetic risk factors that may be useful for primary care clinicians, including people with new-onset diabetes, smokers, and people over age 50.^62,^ ^66,^ ^99,^ ^177–179^ Clinical identification of people who may be eligible for cancer detection based on presence of a series of otherwise nonspecific symptoms has been suggested, such as abdominal pain, back pain, pain while eating, unintentional weight loss, or diarrhea.^64,^ ^75,^ ^76,^ ^99,^ ^180,^ ^181^ A U.S.-based modeling study demonstrated that incorporating demographic and behavioral risk factors, symptoms, comorbidities, and liver, pancreas, and gallbladder function could inform combined risk assessment, suggesting potential applications for electronic health record alerts.^182^

Several validated risk assessment tools that combine symptoms and genetic and behavioral risk factors may help assess risk for pancreatic adenocarcinoma, and some are available as software packages or online tools with potential relevance to primary care (Table 17). These include QCancer,^183–186^ which was developed and validated in the United Kingdom and provides risk estimates across a range of tumor sites; PancPRO,^187–189^ which uses family history to estimate the probability an individual will develop familial pancreatic adenocarcinoma; and Your Disease Risk,^190,^ ^191^ which offers risk assessments for 12 cancers and other health conditions. These tools ask users to input information, such as age, sex, height, weight, family history of pancreatic adenocarcinoma and other conditions, personal history of cancer, chronic and hereditary conditions, symptoms, smoking status, alcohol use, and diet. Validation studies have shown these tools to have relatively high concordance, with areas under the receiver operating characteristic curve of 0.71^190^ to 0.92.^186^

Table 17 Online Tools and Software Packages for Assessing Risk of PDAC

Tool name | Last update | Sponsoring organization(s) | Location | Description | Data used to assess risk | Populations in which tool has been validated (year) | C statistic^a^ from validation study
QCancer^183–186^ | 2017 | ClinRisk, University of Nottingham | U.K. | Intended for use in the U.K population. Provides risk of undiagnosed cancer for an individual across a range of tumor sites. Algorithms are based on routinely collected data from thousands of general practitioners across the U.K., and are updated and recalibrated annually. | - Age & sex; - Postal code; - Height & weight; - Smoking and alcohol; - Family history (various); - Chronic conditions (various); - Symptoms (various); - Reasons for recent GP visits | 2.15 million U.K. general surgery patients aged 30–84 (2013)^186^; 1.24 million U.K. general surgery patients aged 30–84(2012)^184^ | 2013 study: 0.89 (females); 0.92 (males) (2013)^186^; 2012 study: 0.84 (females); 0.87 (males)^184^
PancPRO^187–189^ | 2015 | Johns Hopkins University, Sidney Kimmel Comprehensive Cancer Research Center | Baltimore, MD (USA) | Statistical model that uses family history to estimate the probability an individual carries a gene effect for PDAC and the probability the individual will develop PDAC. Available for free for research and counseling through the BayesMendel R software package. | Family history (including for the individual and each relative):; - Exact relation to the individual; - PDAC diagnosis (yes or no); - Age at diagnosis; - Current age or age at last followup if unaffected | 6,134 individuals (age NR) with family history of PDAC enrolled in the NFPTR (2007)^187^ | 0.75 (95% CI 0.68 to 0.81)
Your Disease Risk^190,^ ^191^ | 2013 | Siteman Cancer Center at Barnes-Jewish Hospital, Washington University School of Medicine | St. Louis, Mo (USA) | Offers assessments for 12 cancers and other health conditions. The site includes prevalence and relative risk estimates used in the disease risk calculations. Assessments are updated every 3 years after a review of scientific literature, and smaller updates are made as needed, such as after major new research findings. | - Age & sex; - Height & weight; - Personal history of cancer; - Family history of PDAC; - Smoking status; - Presence of diabetes, high blood sugar, chronic pancreatitis; - Diet (vegetable intake) | 71,788 women age 40–70 in the NHS cohort and 38,953 men age 40–70 in the HPFS cohort (2004)^190^ | 0.71 (95% CI 0.66 to 0.76)

Abbreviations: PDAC = pancreatic adenocarcinoma; U.K. = United Kingdom; EHR = electronic health record; NFPTR = National Familial Pancreatic Tumor Registry; NHS = Nurses Health Study; HPFS = Health Professionals Followup Study; N/A = not applicable

a C-statistic is equal to the area under the Receiver Operating Characteristic (ROC) curve and ranges from 0.5 to 1. It gives the probability that a randomly selected patient with a certain condition (such as PDAC) had a higher risk score than a patient who did not have the condition

## Limitations of Included Studies

The included body of evidence is subject to small sample sizes, not unexpected considering the low prevalence of high-risk populations and pancreatic adenocarcinoma. All studies except one^160^ included only high-risk populations without controls, and many studies included a substantial proportion of people with known genetic mutations. Even among the three studies that included 100 percent of their study populations based on family history,^129,^ ^133,^ ^155^ pancreatic adenocarcinoma detection rates varied because of small samples and subsequent detection of previously unknown genetic mutations within populations during study followup.

No randomized trials of screening were included. No studies included a clinical followup or unscreened comparison group, so complete assessment of diagnostic accuracy is not possible. Some studies that evaluated multiple screening tests did not report whether imagers were blinded to results from other imaging and therefore, able to interpret test results independently. In addition, most studies with multiple imaging tests did not report whether pancreatic adenocarcinoma or other pathology findings were detected on one or more screening exams, so we cannot evaluate yield of individual imaging tests.

No included studies reported results stratified by family history, genetic mutation status, or other risk factors. Diagnostic yields were often reported for a multiple-test protocol, so yields within subgroups or attributable to specific screening tests were rarely reported. Harms of screening or treatment were not reported in all studies; of those studies that did, limitations included inadequate description of the methods of assessing harms, including whether all participants were systematically assessed.

## Limitations of Our Approach

We included populations with family history of pancreatic adenocarcinoma, but excluded those whose study populations were solely people with known genetic mutations or syndromes. We did this to focus on evidence for primary care-relevant risk factors; however, this criterion was somewhat arbitrary since familial aggregation represents at least some level of genetic risk, in addition to aggregation of behavioral or environmental risk factors. As such this report should not be interpreted as an estimate of the yield of screening in people with known genetic mutations or syndromes, as studies exclusively focused on those populations were excluded.

We included only treatment studies conducted with screen-detected or asymptomatic populations. While consistent with the goals and key questions of the review, this limited our ability to comment systematically on the extensive literature showing the survival benefits of surgery for early-stage pancreatic adenocarcinoma and the significant morbidities that can occur during the post-operative period. The sparsity of harms reported in the included evidence should be interpreted not that surgical treatment is without risks, but rather that the magnitude of these potential harms is not well understood among people with screen-detected disease.

We excluded study populations with pancreatic endocrine tumors or exocrine tumors other than adenocarcinoma because of the distinct etiologies of these tumors. We limited our literature search to imaging-based screening studies, excluding biomarker-based screening studies, based on consensus in the field that these markers are not yet of sufficient precision to warrant screening studies.

## Future Research Needs

The body of evidence in pancreatic adenocarcinoma would be strengthened with the addition of controlled trials that include screening and usual care groups of people at increased risk for pancreatic adenocarcinoma and the demonstration of improved morbidity or mortality. However, randomized trials would require large sample sizes and adequate followup time, and may not be practical to conduct. In the absence of such evidence, research is needed on how to best evaluate the health outcomes of screening using rigorous observational studies and statistical methods. Further, given the low incidence and severity of pancreatic adenocarcinoma and the potential survival benefits of early intervention, approaches to identifying individuals at the highest risk who should receive screening or followup are needed, such as through multiple risk factor assessments that may include otherwise nonspecific symptoms. As less invasive screening tests emerge, such as serum testing for multiple-biomarker panels, screening studies that include these will be warranted. More research is also needed on the progression rates of various precursor lesions to pancreatic adenocarcinoma, and health outcomes and harms in people with these detected lesions, as well as incidentally-detected cancers. Continued understanding of the harms of screening and treatment, including those associated with the detection of precursor lesions, are also needed.

## Conclusions

Imaging-based screening in groups at high familial risk can detect pancreatic adenocarcinoma and its precursor lesions with limited evidence of minimal harms. However, the impact of screening on morbidity and mortality in groups at high familial risk is not well documented, nor is the impact of screening in in other groups at risk for pancreatic adenocarcinoma due to other behavioral or clinical risk factors. There is insufficient evidence to assess benefits or harms of surgical intervention for screen-detected pancreatic adenocarcinoma.