# Chapter 3 Results

We included 13 unique prospective cohort screening studies, reported in 24 articles (Table 4), none of which were included in the previous evidence review.^140^ No studies reported on the effect of screening for pancreatic adenocarcinoma on cancer morbidity, mortality, or all-cause mortality (KQ1); 13 studies (24 articles)^125–127,^ ^129,^ ^133,^ ^155–173^ reported on the diagnostic accuracy of screening tests for pancreatic adenocarcinoma (KQ2); nine studies (18 articles)^125–127,^ ^129,^ ^133,^ ^155–162,^ ^166–170^ reported on the harms of screening for pancreatic adenocarcinoma (KQ3); no studies reported on the effectiveness of treatment for screen-detected pancreatic adenocarcinoma (KQ4); and six studies (12 articles)^125,^ ^129,^ ^133,^ ^156,^ ^157,^ ^160–163,^ ^165,^ ^169,^ ^173^ reported on the harms of treatment of screen-detected pancreatic adenocarcinoma (KQ5).

Table 4 Included Prospective Cohort Studies of Screening for Pancreatic Adenocarcinoma

Author, year Screening program Country Quality | Screening population | N | Setting | Recruitment method | Recruitment period | Participant selection | Key inclusion / exclusion criteria | Included for KQs
Barnes, 2018^171^; U.S.; Fair | Adults with confirmed genetic mutation or family history of PDAC | 75 enrolled; 65 screened | Pancreatic cancer screening clinic, academic medical center | Referrals from genetic counselors, treating physicians, or patient self-referrals | 2012–2017 | All eligible from referrals | Age 50 or within 10 years of youngest affected relative. Individuals with (a) ≥3 relatives with PDAC, including ≥1 FDR; or (b) 2 FDRs with PDAC; or (c) 1 FDR and 1 SDR with PDAC and PancPRO risk ≥5%; or (d) PJS; or (3) BRCA1, BRCA2, PALB2, ATM, CDKN2A, or Lynch syndrome with 1 FDR or SDR with PDAC | 2
Gangi, 2018 ^172^; U.S.; Fair | Adults with confirmed genetic mutation or family history of PDAC | 58 | Comprehensive cancer center, academic medical center (Moffitt Cancer Center) | Referrals from physicians at Moffitt Cancer Center, other physicians, or by patient self-referral | 2007–2017 | All eligible from referrals | No personal history of PDAC, no prior pancreatic resection, no prior abdominal CT, MRI/MRCP, or EUS in past 3 years, no coexisting cancer, no HIV/AIDS, no pregnancy. Age ≥40 or within 10 years of youngest affected relative, life expectancy ≥5 years. Individuals with (a) ≥2 relatives with PDAC, including ≥1 FDR; or (b) PJS and age >30; or (c) HP; or (d) FAMMM; or (e) BRCA2 and ≥1 FDR or SDR with PDAC | 2
Harinck, 2016^126,^ ^158,^ ^167,^ ^170^; Dutch Familial Pancreatic Cancer Study; Netherlands; Fair | Asymptomatic adults with confirmed genetic mutation or family history of PDAC | 139 (from 81 families) | Academic medical center; multi-site | Recruited and evaluated by clinical geneticists at 5 medical centers in the Netherlands | 2006–2013 | Unknown | No personal history of PDAC, no upper GI tract obstruction, ASA score <3. Asymptomatic, age ≥45 (age ≥30 for PJS patients) or within 10 years of youngest relative with PDAC, and (a) with CDKN2A variant; or (b) with confirmed PJS; or (c) with BRCA1, BRCA2, p53 or mismatch repair gene and family history of PDAC in ≥2 affected relatives; or (d) FDRs of patients with FPC^c^ | 2, 3
Joergensen, 2016^125^; Danish National Screening Program; Denmark; Fair | Adults with HP or family history of PDAC | 71 (from 30 families) | Hereditary pancreatitis registry, academic medical center | HP group: identified from previous population-based study that recruited from HP registry and clinician referral.; FPC group: Referrals from clinical genetics departments from across Denmark | 2006–2014 | Unknown | Age ≥30, able to endure a pancreatic resection. Individuals had (a) HP^d^; or (b) FPC^e^ | 2, 3, 5
Del Chiaro, 2015^164^; Sweden; Fair | Adults with confirmed genetic mutation or family history of PDAC | 40 | Academic medical center (Karolinska University Hospital) | Relatives of patients treated for PDAC at Karolinska University Hospital, referrals from other Swedish centers, referrals from general practitioners | 2010–2013 | Unknown | Age ≥45 or within 10 years of youngest relative with PDAC. Individuals who (a) had 2 relatives (≥1 FDR) in the same lineage with PDAC; or (b) had ≥3 relatives (FDRs, SDRs or TDRs) in the same lineage with PDAC; or (c) had BRCA1, BRCA2, or p16 variant and 1 FDR or SDR with PDAC; or (d) were verified germline carriers of PJS kindreds. | 2
Al-Sukhni, 2012^127,^ ^166,^ ^168^; Toronto Screening Program; Canada; Fair | Adults with confirmed genetic mutation or PJS or HP or family history of PDAC | 262 (from 158 families) | Academic medical center (Mt Sinai Hospital & University Health Network, Toronto) | Cancer-related registries, studies, and research centers in Toronto, polyposis database, physician referral, self-referral, or local genetics center | 2003–2011 | Unknown | Asymptomatic individuals who: (a) were FDRs or SDRs of a PDAC patient in a family with ≥2 PDAC patients in the same lineage; or (b) had p16 or STK11 variants; or (c) had BRCA1 or BRCA2 variants and ≥1 blood relative with PDAC; or (d) had a clinical diagnosis of HP or PJS | 2, 3
Canto, 2012^163,^ ^165^; CAPS3; U.S.; Fair | Adults with PJS or family history of PDAC or HBOC + family history of PDAC | 216 | Academic medical center; multi-site | Identified by participating sites (Johns Hopkins Hospital, Mayo Clinic, UCLA, Dana Farber Cancer Institute, MD Anderson Cancer Center) or through websites (for the CAPS 3 study, Lustgarten Foundation, and clinicaltrials.gov) | 2006–2009 | Consecutive | Karnofsky performance status ≥60, no prior pancreas screening, no suspicion of pancreatic disease, no prior pancreas surgery, no medical conditions that could affect screening.^b^ Age 40–80 or within 10 years of youngest relative with PDAC (or age ≥30 for PJS patients) and (a) had PJS; or (b) had HBOC with ≥1 affected FDR or SDR with PC; or (c) were relatives of patients with FPC with ≥1 affected FDR. | 2, 5
Ludwig, 2011^155^; U.S.; Fair | Adults with family history of PDAC | 109 | Familial pancreatic cancer registry, academic cancer center (MSKCC) | At-risk relatives who met eligibility criteria for the Familial Pancreatic Tumor Registry at Memorial-Sloan Kettering Cancer Center were invited to participate | 2002–2009 | All eligible from registry | Age ≥35, no prior PDAC. Individuals had (a) ≥1 FDR diagnosed with PDAC before age 50; or (b) ≥1 FDR with PDAC and ≥1 other relative with PDAC, including; or (c) ≥3 SDRs with PDAC; or (d) known BRCA mutation and ≥1 relative with PDAC. | 2, 3
Schneider, 2011^129,^ ^156,^ ^161,^ ^162,^ ^169^; FaPaCa; Germany; Fair | Adults with family history of PDAC | 72 | Familial pancreatic cancer registry, academic medical center; multi-site | FaPaCa registry participants who met eligibility criteria for screening program were invited to participate | 2002–2009^h^ | All eligible from registry | FaPaCa registry enrollees who had no personal history of PDAC, were age ≥40 or within 10 years of youngest relative with PDAC and were (a) FDRs of an affected patient of an FPC^f^ family; or (b) members of an FPC^f^ family with a known genetic mutation such as BRCA2, PALB2, or CDKN2A. | 2, 3, 5
Verna, 2010^133^; U.S.; Fair | Adults with family history of PDAC | 51 (from 43 families) | Familial pancreatic cancer registry, academic medical center (Columbia/NY Presbyterian) | Those referred to Pancreas Cancer Prevention and Genetics Program at Columbia University Medical Center/New York Presbyterian Hospital with a family history of pancreatic cancer and interest in their risk of disease were invited to participate | 2005–2008 | Unknown | Moderate risk: ≥2 relatives (FDRs, SDRs, or TDRs) with PDAC; or 1 FDR with PDAC<55 years old but not meeting high risk criteria.; High risk: (a); had FPC^g^; or (b) had known genetic syndrome (PJS, Lynch syndrome, BRCA1, BRCA2, FAMMM, or HP).; Patients at average risk (≥1 relative with PDAC age >55) were generally not recommended for screening unless significant psychological distress led them to prefer to be screened. | 2, 3, 5
Poley, 2009^157^; Netherlands; Fair | Asymptomatic adults with confirmed genetic mutation or family history of PDAC | 44 | Academic medical center | Recruited and evaluated by clinical geneticist | 2005–2007 | Unknown | Asymptomatic, age ≥40 or within 5 years of youngest relative with PDAC, no abdominal imaging in prior 3 years. Individuals had (a) ≥2 FDRs with PDAC; or (b) a known pathogenic mutation; or (c) family history of HBOC, Lynch syndrome, or Li-Fraumeni syndrome and had familial clustering of PDAC in ≥2 relatives. | 2, 3, 5
Canto, 2006^160^; U.S.; Fair | High-risk group: Adults with PJS or family history of PDAC; Controls Adults with no suspicion of pancreatic disease | High-risk: 78; Controls: 161 | Academic medical center (Johns Hopkins) | NFPTR, Johns Hopkins Colorectal Tumor Registry, referral from physician or genetic counselor. Control patients referred by gastroenterologist or endoscopist scheduled to perform EUS and/or ERCP | 2001–2004 | Unknown | Karnofsky performance status ≥60, able to undergo endoscopy, no suspected pancreatic disease, no previous gastrectomy or pancreatic resection.; PJS group: Age ≥30 and with ≥2 criteria for PJS^a^.; Family history group: age ≥40 or within 10 years of youngest relative with PDAC and from a family with ≥3 affected members, including ≥1 affected FDR.; Control group: age ≥30 undergoing EUS and/or ERCP for non-pancreatic indications and with no personal or family history or PDAC and no suspicion of pancreatic disease. | 2, 3, 5
Canto, 2004^159^; U.S.; Fair | Adults with PJS or family history of PDAC | 38 | Familial pancreatic cancer registry, academic medical center (Johns Hopkins) | NFPTR registry, self-referral, physician referral, Johns Hopkins Colorectal Tumor Registry | 1998–2001 | Consecutive | NFPTR group: NFPTR enrollees who: (a) had ≥3 relatives with PDAC, including ≥2 affected FDRs; and (b) were an FDR of ≥1 affected family member; and (c) were age ≥40 or within 10 years of the youngest affected relative.; PJS group: Enrollees in the Johns Hopkins Hereditary Colorectal Tumor Registry who had PJS, pathologically confirmed hamartomatous polyps, family history of PJS, and/or characteristic mucocutaneous pigmentation | 2, 3

Abbreviations: PDAC = pancreatic ductal adenocarcinoma; PJS = Peutz-Jeghers syndrome; HP = hereditary pancreatitis; HBOC = hereditary breast and ovarian cancer; FDR = first-degree relative; SDR = second-degree relative; TDR = third-degree relative; FPC = familial pancreatic cancer; NFPTR = National Familial Pancreas Tumor Registry; CAPS = Cancer of the Pancreas Screening Study; NR = not reported; ASA = American Society of Anaesthesiologists; FaPaCa = German National Case Collection of Familial Pancreatic Cancer; FAMMM = Familial atypical multiple mole melanoma syndrome

a Criteria for PJS include characteristic intestinal hamartomatous polyps, mucocutaneous melanin deposition, and family history of PJS

b Medical conditions that could affect screening include: severe medical illness, bleeding diathesis or thrombocytopenia, renal insufficiency, allergic reaction to radiographic contrast material, morbid obesity, severe claustrophobia, and upper gastrointestinal tract obstruction.

c For Harinck 2016, familial pancreatic cancer was defined as a family with (a) ≥2 affected FDRs; or (b) ≥3 relatives in which the affected cases are FDR or SDRs of each other; or (c) ≥2 SDRs of whom at least one was aged <50 at time of diagnosis.

d For Joergensen 2016, hereditary pancreatitis was defined as having a PRSS1 mutation OR having ≥2 FDRs or ≥3 SDRs in two or more generations with recurrent acute pancreatitis, and/or chronic pancreatitis

e For Joergensen 2016, familial pancreatic cancer was defined as FDRs of patients with PDAC in families with 2 cases of PDAC where one relative was <50 years of age at diagnosis, or where ≥3 FDRs had PDAC

f For Schneider 2011, familial pancreatic cancer was defined as a family with ≥2 FDRs with confirmed diagnosis of PDAC without evidence of another inherited tumor syndrome

g For Verna 2010, familial pancreatic cancer was defined as having (a) ≥3 relatives (FDRs, SDRs, or TDRs) with PDAC; or (b) ≥2 FDRs with PDAC; or (c) 1 FDR and 1 SDR with PDAC, with ≥1 diagnosed age <55.

h FaPaCa registry started recruitment in July 1999, but screening program started in 2002

Articles most commonly were excluded due to lack of relevance to pancreatic adenocarcinoma screening or treatment, ineligible population (populations with personal history of pancreatic adenocarcinoma, symptomatic populations, studies focusing only on populations with known genetic mutations associated with increased risk of pancreatic adenocarcinoma), ineligible study design (comparative effectiveness studies, case reports, case series, narrative reviews), and ineligible outcomes (not reporting morbidity, mortality, quality of life, diagnostic accuracy, screening harms, or treatment harms). The most common reasons for poor quality exclusion were insufficient information on patient recruitment or screening process (Appendix A, Table 1). Appendix C provides a list of all excluded studies, with the main reason for their exclusion.

## Description of Included Studies

In total, 13 included screening studies reported screening results for 1,317 people. All studies used a prospective cohort design. These cohorts were relatively small; the study samples ranged from 38 to 239 people. No included studies included an un-screened comparison arm, and none were designed to evaluate test accuracy. One study included comparison group of individuals undergoing EUS or ERCP for non-pancreatic indications.^160^

Seven studies (n=776) were conducted in the U.S.^133,^ ^155,^ ^159,^ ^160,^ ^165,^ ^171,^ ^172^; one in Canada^127^; and five in Northern European countries (two in the Netherlands;^126,^ ^157^ one in Sweden;^164^ one in Denmark;^125^ and one in Germany^129^). All studies were conducted in or in conjunction with academic medical center settings, typically specialty care settings connected to high-risk surveillance clinics.^127,^ ^129,^ ^159,^ ^160,^ ^164,^ ^165,^ ^171,^ ^172^ All U.S.-based studies were conducted in the context of cancer centers or large tertiary care academic centers.^133,^ ^155,^ ^159,^ ^160,^ ^165,^ ^171,^ ^172^ Non U.S.-based studies were conducted in the context of screening or surveillance programs in countries with national health care systems^125,^ ^126,^ ^129,^ ^164^ or at academic medical centers.^127,^ ^157^ Seven studies used existing familial pancreatic cancer registries to recruit participants.^125,^ ^127,^ ^133,^ ^155,^ ^159,^ ^160^ Other recruitment methods included physician or genetic counselor referral. Three studies were conducted at multiple sites.^126,^ ^129,^ ^165^

### Included Populations

All screening populations except one small comparison group were exclusively in persons at elevated risk for pancreatic adenocarcinoma, and included predominantly people with family history of pancreatic adenocarcinoma, with or without confirmed genetic mutations or syndromes (Table 5). In 10 studies, more than 50 percent of the study population had a family history of cancer; in eight studies, 90 percent to 100 percent of the study population had a family history of cancer.^129,^ ^133,^ ^159,^ ^160,^ ^164,^ ^165,^ ^172^ Only three studies (n=232) exclusively included relatives of people with pancreatic adenocarcinoma.^129,^ ^133,^ ^155^ One study included an asymptomatic control group of people receiving imaging for other clinical indications unrelated to the pancreas (n=138).^160^

Table 5 Population Characteristics for Included Prospective Cohort Studies of Screening for Pancreatic Adenocarcinoma

Author, year Screening program Country Quality | N | Mean age (SD), range, years | Female, n (%) | White race and Jewish ancestry, n (%) | Family history of PDAC, n (%) | Known genetic mutation or syndrome, n (%) | Clinical risk factors, n (%) | Behavioral risk factors, n (%)
Barnes, 2018^171^; U.S.; Fair | 75 enrolled^a^; 65 screened | 56 (14)^b^, NR | 46 (61.3) | White: NR; Jewish: NR | Overall^c^: 33 (44.0); Affected relatives:; ≥2 FDRs: 12 (16.0); ≥3 any-degree relative: 16 (21.3); ≥1 FDR and ≥1 SDR: 5 (6.7) | Overall: 42 (56.0); ATM: 8 (10.7); BRCA1: 6 (8.0); BRCA2: 18 (24.0); PALB2: 3 (4.0); CDKN2A: 4 (5.3); Lynch syndrome: 2 (2.7); PJS: 1 (1.3) | Personal history of non-pancreatic cancer: 32 (42.7); Median BMI (IQR): 29 (8) | Current smokers: 0 (0); Former smokers: 18 (24.0); Never smokers: 56 (74.7); Unknown tobacco history: 1 (1.3)
Gangi, 2018 ^172^; U.S.; Fair | 58 | 60 (NR), NR | 35 (60.3) | White: NR; Jewish: NR | Overall: 57 (98.3); Affected relatives:; ≥3 FDRs: 10 (17.2); 2 FDRs: 29 (50.0); ≥3 any-degree relative, including 1 FDR: 9 (15.5); 1 FDR or 1 SDR: 9 (15.5) | Overall: 10 (17.2); BRCA2: 9 (15.5); PJS: 1 (1.7) | NR | History of smoking: 8 (13.8); History of heavy alcohol use: 6 (10.3)
Harinck, 2016^126,^ ^158,^ ^167,^ ^170^; Dutch FPC Study; Netherlands; Fair | 139 (from 81 families) | 51.1 (9.7), 20–73 | 76 (54.7) | White: NR; Jewish: NR | Overall: 68 (48.9); FPC^d^: 68 (48.9) | Overall: 71 (51.1); PJS (LKB1): 7 (5.0); Li-Fraumeni syndrome (p53): 3 (2.2); BRCA1: 3 (2.2); BRCA2: 20 (14.4); FAMMM syndrome (CDKN2A): 38 (27.3) | Personal history of:; Diabetes: NR; Non-pancreatic cancer: 40 (28.8); Melanoma: 24 (17.3) | Current smokers: 16 (11.5)
Joergensen, 2016^125^; Danish National Screening Program; Denmark; Fair | 71 (from 30 families) | 51.1 (NR), 26–72 | 35 (49.3) | White: NR; Jewish: NR | Overall: 40 (56.3)^e^; N (%) of 30 enrolled families with PDAC:; Any cases: 23 (76.6); 1 case: 2 (6.7); 2 cases: 10 (33.3); 3 cases: 10 (33.3); ≥4 cases: 1 (3.3) | Overall: NR^f^; HP: 31 (43.7); N (%) of 30 enrolled families with PRSS-1: 8 (26.7) | Personal history of:; Diabetes (Type NR): 13 (18.3); Pancreatitis: 26 (36.6); N (%) of 30 enrolled families with cases of:; Breast cancer: 5 (16.7%); Lung cancer: 3 (10%); Colon cancer: 2 (6.7%) | Current smoker: 18 (25.4); Former smoker: 17 (23.9); Never smoker: 36 (50.7)
Del Chiaro, 2015^164^; Sweden; Fair | 40 | 49.9 (NR), 23–76 | 24 (60.0) | White: NR; Jewish: NR | Overall: 38 (95.0); Affected relatives:; 2 relatives: 14 (35.0); 3 relatives: 17 (42.5); 4 relatives: 5 (12.5); 5 relatives: 2 (5.0) | Overall: 8 (20.0)^g^; p16: 4 (10.0); BRCA1: 1 (2.5); BRCA2: 3 (7.5) | Personal history of diabetes: NR | Current smokers: 4 (10.0)
Al-Sukhni, 2012^127,^ ^166,^ ^168^; Toronto Screening Program; Canada; Fair | 262^m^ (from 158 families) | 54 (NR), 22–89 | 173 (66.0) | White: 222 (84.7); Ashkenazi Jewish: 54 (20.6) | Overall: 159 (60.7); ≥2 affected relatives: 159 (60.7) | Overall: 93 (35.5); PJS: 7 (2.7); HP: 2 (0.8); BRCA1: 5 (1.9); BRCA2: 68 (26.0); p16: 11 (4.2) | Personal history of:; Diabetes (Type NR): 13 (5.0)^i^,^n^; Pancreatitis: 3 (1.2)^i^; Non-pancreatic cancers: 62 (23.6); Family history of multiple primary cancers: 10 (3.8); BMI ≥30: 41 (17.0)^i^; BMI 25–29.9: 87 (36.1)^i^; BMI <25: 113 (46.9)^i^ | Current smoker: 29 (11.8)^i^; Former smoker: 89 (36.2)^i^; Never smoker: 128 (52.0)^i^; Alcohol intake:; ≥1 drink/day: 44 (18.1)^i^; 1–6 drink/week: 76 (31.3)^i^; <1 drink/week: 59 (24.3)^i^; <1 drink/month or never: 64 (26.3)^i^
Canto, 2012^163,^ ^165^; CAPS3; U.S.; Fair | 216 | 56.1 (NR), 28–79 | 116 (53.6) | White: 212 (98.1); Ashkenazi Jewish: 28 (13.0) | Overall: 195 (90.3); Affected FDRs:; 2 FDRs: 75 (34.7); ≥3 FDRs: 120 (55.6) | Overall: 21 (9.9); PJS: 2 (0.9); BRCA 2+ relative with PDAC: 19 (8.9) | Personal history of Type II diabetes: 9 (4.2) | Ever smoker: 18 (8.3); Regular or heavy alcohol use: 120 (55.6)
Ludwig, 2011^155^; U.S.; Fair | 109 | 54 (11.4), 33–86 | 78 (71.6) | White: 100 (91.7); Jewish: 36 (33.0) | Overall: 109 (100); Affected FDRs:; 1 FDR: 16 (14.7); 2 FDRs: 56 (51.4); 3 FDRs: 21 (19.8); 4 FDRs: 11 (10.3); 5 FDRs: 3 (2.8) | Overall: 7 (6.4); BRCA1/2: 7 (6.4) | Personal history of diabetes: NR; Obese BMI: 15 (13.8); Overweight BMI: 24 (22.0); Normal BMI: 70 (64.2) | Current Smokers: 9 (8.3); Past Smokers 37 (33.9); Never Smokers: 63 (57.8)
Schneider, 2011^129,^ ^156,^ ^161,^ ^162,^ ^169^; FaPaCa; Germany; Fair | 76 | 60 (NR), 35–85 | NR (NR) | White: 76 (100); Ashkenazi Jewish: 0 | Overall: 76 (100); Affected relatives:; 2 FDRs or from MPCS family without genetic mutation: 44 (57.9); 3 relatives: 15 (19.7); 4 relatives: 13 (17.1); 5 relatives: 3 (3.9) | Overall: 2 (2.7); BRCA2: 2 (2.7) | Personal history of diabetes: NR; Family history of:; Diabetes: 1 (1.3); Pancreatitis: 2 (2.6); Breast cancer: 11 (14.5); Colon cancer: 8 (10.5); Lung cancer: 5 (6.6) | Smoking status: NR
Verna, 2010^133^; U.S.; Fair | 51 (from 43 families) | 52 (12.3), 29–77 | 33 (64.7) | White: 49 (96.1); Ashkenazi Jewish: 25 (49.0) | Overall: 51 (100); Affected FDRs:; 0 FDRs: 7 (13.7); 1 FDRs: 29 (56.9); 2 FDRs: 12 (23.5); ≥3 FDRs: 3 (5.9); Affected relatives:; 1 relative: 16 (31.4); 2 relatives: 22 (43.1); ≥3 relatives: 13 (25.5) | Overall: 7 (13.7)^h^; BRCA1/2: 7 (13.7)^h^; Family history suggestive of:; BRCA1/2: 17 (33.3); HNPCC: 3 (5.9); FAMMM syndrome: 3 (5.9) | Personal history of:; Type II diabetes: 2 (3.9); Non-pancreatic cancer: 15 (29.4) | Ever smoker: 17 (33.3); Previous heavy alcohol use: 3 (5.9); Social or occasional alcohol use: 39 (76.5); No alcohol use: 9 (17.6)
Poley, 2009^157^; Netherlands; Fair | 44 | NR (NR), 32–75 | 26 (59.1) | White: 44 (100); Jewish: NR | Overall: 21 (47.7); ≥2 affected FDRs: 21 (47.7) | Overall: 23 (52.3); PJS: 2 (4.5); HP^k^: 2 (4.5); FAMMM syndrome (CDKN2A): 13 (29.5); BRCA1: 3 (6.8); BRCA2: 2 (4.5); Li-Fraumeni syndrome (p53): 1 (2.3) | Personal history of diabetes: NR | Smoking status: NR
Canto, 2006^160^; U.S.; Fair | High risk group: 78 | 52 (NR), 32–77 | 44 (56.4) | White: 73 (94.0); Ashkenazi Jewish: 31 (40.0) | Overall: 72 (92.3); Affected FDRs:; 1 FDR: 49 (62.8); 2 FDRs: 16 (20.5); 3 FDRs: 6 (7.7); 4 FDRs: 1 (1.3); Affected^l^ relatives:; 3 relatives: 39 (50.0); 4 relatives: 19 (24.4); 5 relatives: 12 (15.4); 6 relatives: 2 (2.6); From kindred with young-onset PDAC (age <60): 48 (61.5) | Overall: 8 (10.3); PJS: 6 (7.7); BRCA2: 2 (2.6) | Personal history of:; Diabetes (Type NR): 19 (24.4); Pancreatitis: 3 (3.8); Breast or ovarian cancer: 5 (6.4); Family history of:; Diabetes: 33 (42.3); Breast or ovarian cancer: 27 (34.6) | Current smoker: 15 (19.2); Ever smoker: 35 (44.9); Regular alcohol intake:^j^ 31 (39.7)
Canto, 2006^160^; U.S.; Fair | Control group: 161 | 54 (NR), 30–80 | 69 (42.9) | White: 143 (88.8); Ashkenazi Jewish: 10 (6.2) | Overall: 0 (0) | NR | Personal history of diabetes (Type NR): 37 (23.0) | Current smoker: 32 (19.9); Ever smoker: 82 (50.9); Regular alcohol intake:^j^ 69 (42.9)
Canto, 2004^159^; U.S.; Fair | 38 | 56.5 (NR), NR | 23 (60.5) | White: NR; Ashkenazi Jewish: 5 (13.2) | Overall: 37 (97.4); Affected FDRs:; 1 FDR: 21 (55.3); 2 FDRs: 5 (13.2); 3 FDRs: 9 (23.7); 4 FDRs: 2 (5.3); Affected relatives:; 0 relatives: 1 (2.6); 2 relatives: 6 (15.8); 3 relatives: 13 (34.2); 4 relatives: 11 (28.9); 6 relatives: 4 (10.5); 7 relatives: 3 (7.9) | Overall: 1 (2.6); PJS: 1 (2.6) | Personal history of:; Diabetes (Type NR): 7 (18.4); Pancreatitis: 0 (0); Non-pancreatic cancer: 12 (31.6); Family history of:; Diabetes: 26 (68.4); Pancreatitis: 11 (28.9); Breast cancer: 21 (55.3) | Current smoker: 5 (13.2); Ever smoker: 18 (47.4); Regular alcohol intake:^j^ 16 (42.1)

Abbreviations: PDAC = pancreatic ductal adenocarcinoma; PJS = Peutz-Jeghers syndrome; HP = hereditary pancreatitis; HBOC = hereditary breast and ovarian cancer; FDR = first-degree relative; SDR = second-degree relative; TDR = third-degree relative; FPC = familial pancreatic cancer; CAPS = Cancer of the Pancreas Screening Study; NR = not reported; FaPaCa = German National Case Collection of Familial Pancreatic Cancer; FAMMM = Familial atypical multiple mole melanoma syndrome; HNPCC: hereditary nonpolyposis colorectal cancer

a For Barnes 2018, population characteristics are provided for the 75 individuals enrolled in the study. Population characteristics are not reported separately for the 65 individuals who underwent screening.

b Barnes 2018 reports age as median (interquartile range) rather than mean (standard deviation)

c For Barnes 2018, 33 participants were classified as having “familial pancreatic cancer” [defined as having (a) ≥3 relatives with PDAC, including ≥1 FDR; or (b) 2 FDRs with PDAC; or (c) 1 FDR and 1 SDR with PDAC and PancPRO risk ≥5%]. The remaining 42 individuals were classified as having a known genetic mutation; however, the inclusion criteria specify that those with BRCA1, BRCA2, PALB2, ATM, CDKN2A, or Lynch syndrome also had to have ≥1 FDR or SDR with PDAC. Only patients with PJS (n=1) could be enrolled in the study regardless of family history of PDAC.

d For Harinck 2016, 68 participants were classified as having “familial pancreatic cancer” [defined as a member of a family with (a) ≥2 affected FDRs; or (b) ≥3 relatives in which the affected cases are FDR or SDRs of each other; or (c) ≥2 SDRs of whom at least one was aged <50 at time of diagnosis]. The remaining 71 participants (classified as having a known genetic mutation) have a range of 0–7 relatives with PDAC; the authors do not report the total number of study participants who have relatives with PDAC.

e For Joergensen 2016, the population was classified as the familial pancreatic cancer group (n=40; 56.3%) and the hereditary pancreatitis group (n=31; 43.7%). However, some patients in the hereditary pancreatitis group also had a family history of PDAC. The authors report that 76.6% of the 30 enrolled families had a family history of PDAC, but they do not report the number of enrolled individuals with a family history of PDAC.

f For Joergensen 2016, 26.7% of the 30 enrolled families had a PRSS-1 variant. The authors do not report the number of enrolled individuals with this variant.

g For Del Chiaro 2015, genetic testing during the study identified 4 patients (10.0%) with a p16 variant, 3 patients (7.5%) with BRCA2 variant, and 1 patient (2.5%) with BRCA1 variant. The authors do not report whether there is overlap in these populations (i.e., whether any patients had multiple variants)

h For Verna 2010, 19 patients were tested for BRCA1 and BRCA2, and 7 of the 19 (36.8%) tested positive for BRCA1 or BRCA2.

i For Al-Sukhni 2012, the denominators differ for various baseline characteristics based on which participants enrolled, dropped out, and returned the baseline questionnaire. The denominator is n=262 except for the following: personal history of diabetes or pancreatitis (n=250), smoking status (n=246), frequency of alcohol use (n=243), and BMI (n=241)

j For Canto 2004 and Canto 2006, regular alcohol intake was defined as ≥2 drinks/week for women; ≥3 drinks/week for men

k For Poley 2009, one of the patients with hereditary pancreatitis had a known PRSS-1 mutation

l For Verna 2010, “affected relatives” refers to first-, second-, or third-degree relatives

m For Al-Sukhni 2012, baseline characteristics are reported for 262 patients enrolled in program; however, only 175 patients underwent screening. The study does not report baseline characteristics separately for the 175 patients who underwent screening.

n For Al-Sukhni 2012, N (%) for diabetes represents individuals diagnosed with diabetes mellitus prior to 1 year ago. No other studies report time since diagnosis of diabetes.

Definitions of family history varied widely across studies, but all studies had inclusion criteria aimed at identifying those at greatest risk for pancreatic adenocarcinoma. Inclusion criteria generally required at least two affected relatives and at least one affected first-degree relative for study entry. For example, two U.S.-based studies limited study entry to people with three or more relatives with pancreatic adenocarcinoma, one or two of which were first-degree relatives.^159,^ ^160^ Another U.S.-based study required two or more relatives with pancreatic adenocarcinoma or one with pancreatic adenocarcinoma at age less than 55 years to be considered moderate risk; 43 percent of the study population had two affected relatives, while an additional 26 percent had three or more affected relatives.^133^

Twelve studies included people with confirmed genetic mutations or syndromes; typically these populations made up less than 25 percent of the study population with the exception of three studies whose populations exceeded 50 percent people with confirmed genetic conditions; one was conducted in the U.S.^171^ and the other two were conducted in the Netherlands: the Dutch Familial Pancreatic Cancer (FPC) study (n=139)^126,^ ^158,^ ^167,^ ^170^ and the study by Poley and colleagues (n=44).^157^ No studies reported on flow through the screening program separately for individuals with confirmed genetic mutations or syndromes.

Personal history of other types of cancer or diabetes also were reported. Diabetes status was reported in six studies, and ranged from 4 percent to 24 percent of the study population.^125,^ ^127,^ ^133,^ ^159,^ ^160,^ ^165^ Two studies specified that patients with diabetes (3.9%^133^ and 4.2%^165^ of study population) had type 2 diabetes; the other 4 studies did not specify type of diabetes. One study specified that patients with diabetes (5.0% of study population) were diagnosed prior to 1 year ago;^127^ the other five studies did not report time since diagnosis. Personal history of non-pancreatic cancer was reported in six studies which ranged from 6 percent to 43 percent of the study populations.^126,^ ^127,^ ^133,^ ^159,^ ^160,^ ^171^

Study populations contained a slightly higher proportion of female participants compared to male (range of female participants 53.6% to 71.6%; the population in the single study with an asymptomatic comparison group was 43% female). Mean age of participants ranged from 50 to 60 years. Race and ethnicity were inconsistently reported across studies. Eight studies reported Ashkenazi Jewish ancestry, which accounted for from less than 10 percent of the study population^129^ to more than 49 percent in one study.^133^ Eight studies also reported race/ethnicity, and in these eight studies the proportion of white participants was 88 percent to 100 percent.

Three of the six studies that did not report on white race/ethnicity were conducted in Northern European countries (Sweden, Denmark, and the Netherlands).^125,^ ^126,^ ^164^ The other three studies that did not report on white race/ethnicity were based in the U.S.: One was based at Johns Hopkins University^159^ and reported that 13.2 percent of participants were of Ashkenazi Jewish ancestry, one was at the Greater Midwest Pancreatic Screening Clinic in Wisconsin,^171^ and one was at the Moffitt Cancer Center in Florida.^172^

Various behavioral risk factors were included in eleven studies. All eleven reported on smoking status, in which the proportion of current smokers ranged from 0 percent to 25 percent. Alcohol use was reported in six studies; measures of alcohol use varied across studies but ranged from 40 percent to 56 percent in studies reporting “regular” use. One study reported social or occasional alcohol use at 77 percent,^133^ and one reported history of heavy alcohol use at 10 percent.^172^

### Protocols for Initial and Repeated Screening

#### Initial Screening Protocols

A total of nine small, prospective, fair quality studies (n=885) evaluated EUS (with or without additional imaging) as the initial screening test for pancreatic abnormalities. Four studies evaluated EUS as the sole screening test: one at Johns Hopkins University in the U.S. (n=38);^159^ one at the Moffitt Cancer Center in the U.S. (n=58);^172^ one from the Danish National Screening Program (n=71);^125^ and one from the Netherlands (n=44, a study that pre-dated the Dutch Familial Pancreatic Cancer Study).^157^ Two additional studies from the U.S. evaluated multiple screening modalities in which the screeners were blinded to the results from either test: EUS and CT screening (n=78 high-risk people and 138 asymptomatic controls who underwent EUS only) at Johns Hopkins Hospital,^160^ and EUS, CT, and MRI screening (n=216) within the Cancer of the Pancreas Screening Study 3 (CAPS3) consortium including 5 U.S. hospitals.^165^ The last three studies evaluated EUS plus MRI (or MRCP) in: the Dutch FPC Study (n=139),^126^ the U.S. (n=31),^133^ and the Familial Pancreatic Cancer (FaPaCa) study in Germany (n=72).^129^

Two small, prospective, fair quality studies (n=294) evaluated CT imaging to screen for pancreatic abnormalities.^160,^ ^165^ Both took place in the U.S. and were led by the same author, but do not overlap in populations. One evaluated CT and EUS screening in 78 people (screeners were blinded to the results of either screening test)^160^ and the other evaluated CT with EUS and MRI in 216 people (again screeners were blinded to the results of any other test).^165^

A total of eight small, prospective, fair quality studies (n=849) evaluated MRI or MRCP as the initial screening test for pancreatic abnormalities. Three studies evaluated MRI as the sole screening test, one from the Greater Midwest Pancreatic Cancer Screening Clinic in the U.S. (n=65),^171^ one from the Toronto Screening Program in Canada (n=175)^127^ and the other from Sweden (n=40);^164^ one additional study from the U.S. evaluated MRCP alone (n=109).^155^ Three studies evaluated MRI and/or MRCP as initial screening tests along with EUS: the Dutch FPC Study in the Netherlands (n=139),^126^ a study based at Columbia University Medical Center (n=51),^133^ and the FaPaCa study in Germany (n=72).^129^ One study, the CAPS3 study from the U.S., evaluated MRI plus EUS and CT (n=216).^165^

All studies had final pathology determined using samples obtained by FNA and/or surgery.

#### Surveillance and Clinical Followup

After initial screening, followup time ranged from 12 to 60 months. All studies included at least 12 months of followup after screening. Eleven studies conducted annual followup repeat screening for screen-negatives; while one study used a 1- to 3-year range for followup testing.^165^ For people with abnormal results, screening protocols typically had branches for immediate biopsy (typically with EUS-guided FNA) or surgery for solid lesions or those otherwise likely malignancies, or surveillance at 3–6 months for less concerning abnormalities. Detailed descriptions of all included screening programs are in Table 6. All studies reported final pathology of detected cases of pancreatic adenocarcinoma.

Table 6 Description of Screening Programs for Pancreatic Adenocarcinoma From Included Prospective Cohort Studies

Author, year Screening program Country Quality | Screening population | Initial screening protocol | Diagnostic workup^b^ | Blinding procedures | Repeated screening and surveillance protocol | Follow-up, in months | Outcomes assessed
Barnes, 2018^171^; U.S.; Fair | Adults with confirmed genetic mutation or family history of PDAC | MRI | Patients with suspicious lesions on MRI underwent EUS +/- FNA. Those with abnormalities on EUS/FNA were discussed at a multidisciplinary conference and managed according to the consensus of the clinical team, including referral to surgery if needed. | EUS was assessed with knowledge of MRI test results | Patients with no pancreatic abnormalities were rescreened annually using the same screening protocol. Surveillance for patients with abnormalities were individualized according to the consensus of the multidisciplinary conference. | NR | Diagnostic yield
Gangi, 2018 ^172^; U.S.; Fair | Adults with confirmed genetic mutation or family history of PDAC | EUS | Patients with lesions ≥1 cm on EUS underwent FNA. If FNA results were consistent with cancer, patients underwent standard workup and staging with radiology studies and surgical and/or oncologic evaluation. | NR | Patients with no pancreatic abnormalities were rescreened annually using the same screening protocol for 5 years. Patients with lesions <1 cm underwent repeat EUS at 3 months followed by MRI/MRCP at 6 months followed by annual MRI/MRCP if lesions were unchanged in size. Patients with benign or indeterminate results on FNA underwent CT. Those with indeterminate CT results underwent repeat EUS in 3 months. | Planned 60.0 | Diagnostic yield
Harinck, 2016^126,^ ^158,^ ^167,^ ^170^; Dutch FPC Study; Netherlands; Fair | Asymptomatic adults with confirmed genetic mutation or family history of PDAC | EUS and MRI | Patients with lesions detected on EUS had a case description and video recording reviewed by endosonographers. Patients with suspected malignancy or premalignant lesions were referred for surgery. | MRI and EUS were assessed without knowledge of other test results | Patients with lesions of unknown significance were rescreened in 3 months. Those with cysts or side-branch IPMN with diameter 10–30mm without malignant features were rescreened in 6 months. Those with negative findings on initial screen were rescreened annually. | Planned 12.0 | Diagnostic yield; Screening harms; Treatment outcomes
Joergensen, 2016^125^; Danish National Screening Program; Denmark; Fair | Adults with HP or family history of PDAC | EUS^a^ | Patients with suspicious masses on EUS underwent FNA. If FNA identified potential malignancy or dysplasia, diagnostic laparoscopic US +/- biopsy was performed. Those with suspected or confirmed malignancy or dysplasia were referred to surgery. | NR | Patients with suspected lesions but negative biopsy results underwent control EUS. All patients who screened negative remained in the screening program and continued receiving annual EUS and CA 19-9 testing. | Mean 60.0 (range 2.0–92.0) | Diagnostic yield; Screening harms; Treatment outcomes; Treatment harms
Del Chiaro, 2015^164^,^b^; Sweden; Fair | Adults with confirmed genetic mutation or family history of PDAC | MRI | Patients with abnormalities on MRI underwent EUS +/- FNA and/or CT. Those with suspected cancer or premalignant lesions were referred for surgery. | NR | Patients with unspecified findings or IPMN without indication for surgery were recommended for a 6-month followup MRI. Those who screened negative on initial MRI were rescreened after 1 year using the same screening protocol. | Mean 12.9 (range 0–36.0) | Diagnostic yield
Al-Sukhni, 2012^127,^ ^166,^ ^168^; Toronto Screening Program; Canada; Fair | Adults with confirmed genetic mutation or PJS or HP or family history of PDAC | MRI | Patients with abnormal findings on MRI underwent followup MRI plus CT, EUS, and/or ECRP within 3–6 months. If followup testing identified suspected malignancy or dysplasia, surgery was recommended. | NR | All patients, including those who screened negative on initial testing and resected patients who did not have invasive cancer, underwent annual testing under the same screening protocol. | Mean 50.4 (range 0–98.4) | Diagnostic yield; Screening harms; Treatment outcomes
Canto, 2012^163,^ ^165^; CAPS3; U.S.; Fair | Adults with PJS or family history of PDAC or HBOC + family history of PDAC | EUS and CT and MRI/MRCP | Patients with abnormalities on any of the 3 initial screening tests underwent FNA as part of the EUS procedure. ERCP was performed at the discretion of the clinical team. Those with suspected pancreatic neoplasms were referred for surgery. | MRI, CT, and EUS were assessed without knowledge of other test results | Patients with worrisome lesions but no resection scheduled were rescreened at 3 months. Those with small cysts or non-worrisome lesions were rescreened at 6–12 months. Those with normal pancreas or pancreatitis-like abnormalities were rescreened at 1–3 years. | Mean 28.8 (range 14.0–47.2) | Diagnostic yield; Treatment harms
Ludwig, 2011^155^; U.S.; Fair | Adults with family history of PDAC | MRCP or CT for those unwilling to undergo MRCP | Patients with lesions on MRCP underwent EUS. Those with suspected pre-malignant or malignant lesions on EUS underwent immediate FNA. Those with suspected pre-malignant or malignant lesions on followup testing were referred for surgery. | NR | Patients with normal results on initial screening continued to undergo annual testing under same screening protocol. | Planned 24.0 | Diagnostic yield; Screening harms
Schneider, 2011^129,^ ^156,^ ^161,^ ^162,^ ^169^; FaPaCa; Germany; Fair | Adults with family history of PDAC | EUS and MRI/MRCP | Patients with suspicious lesions underwent repeat EUS in 6 weeks or EUS-FNA if lesions were potentially suggestive of malignancy. Those with suspected malignancy or pre-malignancy on followup tests were referred to surgery. | MRI assessed without knowledge of other test results | Patients who screened negative continued to undergo annual screening. Interdisciplinary board could recommend close followup (repeated EUS and MRI/MRCP after 12 weeks, re-evaluation after 6 months and 12 months). | Median 44.0 | Diagnostic yield; Screening harms; Treatment outcomes; Treatment harms
Verna, 2010^133^,^b^; U.S.; Fair | Adults with family history of PDAC | EUS or MRI | Patients with abnormalities underwent EUS-FNA. ECRP was performed at the discretion of the interventional endoscopist. | Radiologist was blinded to patient’s pancreatic risk factors | High-risk patients and those who underwent partial pancreatectomies were re-screened every 6 months. Those at moderate risk underwent annual imaging. Those at average risk returned for annual visits and further testing if they developed symptoms or new onset diabetes. | NR | Diagnostic yield; Screening harms; Treatment outcomes; Treatment harms
Poley, 2009^157^; Netherlands; Fair | Asymptomatic adults with confirmed genetic mutation or family history of PDAC | EUS | Patients with abnormalities on EUS underwent CT and/or MRI. Criteria for referral to surgery NR. | NR | Patients with small cystic lesions were followed up bi-annually with EUS and MRI. | NR | Diagnostic yield; Screening harms; Treatment outcomes; Treatment harms
Canto, 2006^160^,^b^; U.S.; Fair | High-risk: Adults with PJS or family history of PDAC; Controls: Adults with no suspicion of pancreatic disease | High-risk: EUS and CT; Controls: EUS and/or ERCP | Both groups: Patients with abnormalities on EUS underwent EUS-FNA during the same procedure and were offered ERCP. Those with suspected malignancy or dysplasia on followup testing were referred for surgery. | EUS, FNA and CT were assessed without knowledge of other test results. | Both groups: Patients who had abnormalities on EUS but did not have surgery were offered followup EUS, FNA, and CT within 3–6 months. All patients were offered repeat EUS within 1 year of the initial screening. | Planned 12.0 | Diagnostic yield; Screening harms; Treatment outcomes; Treatment harms
Canto, 2004^159^; U.S.; Fair | Adults with PJS or family history of PDAC | EUS | Patients with abnormalities on EUS underwent EUS-FNA at the same procedure, underwent CT, and were offered ERCP. Those with suspected malignancy or dysplasia on followup testing were referred for surgery. | FNA and CT were assessed without knowledge of other test results. | Patients who had abnormalities on EUS but did not undergo surgery were offered followup EUS, FNA, and CT within 3–6 months. All patients were offered repeat EUS within 1 year of initial screening and were followed until the end of the study. | Mean 22.4 (range 11.3–50.5) | Diagnostic yield; Screening harms; Treatment outcomes

Abbreviations: PDAC = pancreatic ductal adenocarcinoma; PJS = Peutz-Jeghers syndrome; HP = hereditary pancreatitis; FPC = familial pancreatic cancer; NFPTR = National Familial Pancreas Tumor Registry; CAPS = Cancer of the Pancreas Screening Study; NR = not reported; FaPaCa = German National Case Collection of Familial Pancreatic Cancer; EUS = endoscopic ultrasound; CT = computed tomography; MRI = magnetic resonance imaging; MRCP = magnetic resonance cholangiopancreaticography; OGTT = oral glucose tolerance test; HBOC = hereditary breast and ovarian cancer; FNA = fine-needle aspiration

a Two patients underwent US due to severe claustrophobia

b Final pathology was determined by surgery except as noted. For Del Chiaro 2015 and Verna 2010, final pathology was determined by surgery or FNA. For the control group for Canto 2006, final pathology was determined by ERCP

### Outcome Assessment

#### Diagnostic Accuracy Outcomes

All included studies conducted followup diagnostic testing only on individuals with abnormal screening results, and did not provide followup data on screen-negative populations. Further, test-positive rates were not consistently reported, and many cases of precursor lesions were detected and removed surgically. Therefore, only diagnostic yield of each screening test is possible, whereas sensitivity, specificity, predictive value, and other measures of diagnostic accuracy are not available. Most studies with multiple imaging tests did not report whether pancreatic adenocarcinoma or other pathology findings were detected on one or more screening exams, so we cannot evaluate yield based on individual imaging tests. No included studies reported results separately for risk-based subgroups of family history, known genetic mutations, or other risk factors.

#### Screening Harms (Procedural)

Eight studies (n=763) reported screening procedure harms.^125,^ ^126,^ ^129,^ ^133,^ ^155,^ ^157,^ ^159,^ ^160^ However, five of these studies do not report how harms were assessed or if they were assessed routinely for all participants for which procedures.^125,^ ^126,^ ^129,^ ^133,^ ^157^ Three studies (n=386) assessed procedure-related harms by calling patients within a week after the procedure.^155,^ ^159,^ ^160^ Of these, all three studies reported harms of EUS or ERCP (one with or without FNA^159^); one reported harms of CT,^160^ and one reported harms of MRI.^155^

Further, overdiagnosis as a potential harm of screening was difficult to assess, since pathology data is often not available before surgical intervention, and the detection and surgical removal of precursor lesions may represent clinical benefit.

#### Screening Harms (Psychosocial)

Two screening programs (n=271), the Dutch FPC^126,^ ^158,^ ^167,^ ^170^ and Toronto programs,^127,^ ^166,^ ^168^ assessed potential psychosocial harms longitudinally between pre- and post-screening. The Dutch FPC program (n=140) assessed outcomes via survey before the initial screening, shortly after initial screening, as well as four other time points during subsequent screenings (up to 2 years and 2 subsequent screenings). Outcomes assessed included perceived risk, cancer worry, and anxiety and depression, as well as a battery of individual items that assessed concern about a variety of potential issues that could arise from screening from informing children or family.^126,^ ^158,^ ^167,^ ^170^ The Toronto study (n=131) assessed, also via survey, perceived pancreatic cancer risk and worry, as well as a measure of general distress derived from the Brief Symptom Inventory (BSI) before initial screening and 3 months after screening in people with familial pancreatic cancer.^127,^ ^166,^ ^168^ Neither study’s assessment of harms included a comparison group or reference population.

#### Clinical Followup of Detected Cases (Treatment Effectiveness)

Possibly due to sparse detection of pancreatic adenocarcinoma, studies typically reported details of detected cases in a case report format. Details were variably provided across studies and included risk factors, family history, stage at detection, whether detected on initial or repeated screening, treatment received, and possibly clinical status at followup.

#### Treatment Harms

Surgical harms were reported in six studies (n=32 people receiving surgery).^125,^ ^129,^ ^133,^ ^157,^ ^160,^ ^165^ Methods of harm assessment were inconsistently reported across studies. Two studies assessed surgical procedure-related harms through clinical followup of all patients for at least 12 months;^160,^ ^165^ no other studies reported how surgical harms were assessed or if they were assessed routinely for all participants or all procedures.

### Quality

All studies were fair quality. In all studies, only participants with positive screening results underwent the reference test. More than half of studies had small sample sizes (<75 participants). Five studies reported blinding during the screening process.^126,^ ^129,^ ^159,^ ^160,^ ^165^ In four studies, screeners were blinded to each patient’s other test results. In one study, the radiologist was blinded to patient risk factors. Less common were issues with incomplete reporting of the participant selection process, the threshold for a positive screening result, participant flow through the screening program, intervals between the screening test and the reference standard, and how harms were assessed. Follow-up rates were reported in six studies and ranged from 67.0 percent to 97.1 percent.

## KQ1 Does Screening for Pancreatic Adenocarcinoma Improve Cancer Morbidity or Mortality or All-Cause Mortality?

## KQ1a Does Screening Effectiveness Vary by Clinically Relevant Subpopulations (e.g., by Age Group, Family History of Pancreatic Cancer, Personal History of New-Onset Diabetes, or Other Risk Factors)?

No studies met inclusion criteria for KQ1 or KQ1a.

## KQ2 What Is the Diagnostic Accuracy of Screening Tests for Pancreatic Adenocarcinoma?

### Summary of Results

Of 1317 people screened, 57 people underwent surgery; 14 ended up having confirmed pancreatic cancer and 38 having precursor lesions. Four additional people had advanced pancreatic cancer diagnosed without surgical intervention.

Across all studies (n=1317), 18 cases of pancreatic adenocarcinoma were detected: nine on initial screening, eight on repeat screening, and one case in which the timing of detection was not reported. Six studies (n=824) found no cases of pancreatic adenocarcinoma on initial screening;^125,^ ^127,^ ^160,^ ^165,^ ^171,^ ^172^ three of these found 6 cases of pancreatic adenocarcinoma on repeat screening. The remaining seven studies (n=493) found a total of nine cases on initial screening and an additional two cases on repeat screening.^126,^ ^133,^ ^155,^ ^157,^ ^159,^ ^164^ The single study reporting screening results in an average risk comparison population (n=138) found no cases of pancreatic adenocarcinoma or precursor lesions.^160^ Pooled yield for all screening tests to detect pancreatic adenocarcinoma on initial screening in high-risk populations was 7.8 per 1000 (95% CI, 3.6 to 14.7); and for total yield including both initial and repeat screening, it was 15.6 per 1000 (95% CI 9.3 to 24.5) (Figure 2)

Figure 2 Diagnostic Yield of Prospective Cohort Screening Studies in Individuals At High Risk Of Pancreatic Adenocarcinoma

* Control group for Canto 2006 (n=161) not included in total N or total diagnostic yield

Figure 2 is a forest plot depicting the diagnostic yield and 95% confidence interval for the detection of pancreatic adenocarcinoma in included screening programs of high-risk populations. For the initial screening, diagnostic yield ranged from 0 to 68.2 per 1000 persons, with a pooled yield across studies of 7.8 per 1000 (95% CI, 3.6 to 14.7). For the entire screening program (including both initial screening and repeat screening), diagnostic yield ranged from 0 to 75 per 1000 persons, with a pooled yield across studies of 15.6 per 1000 (95% CI 9.3 to 24.5).

EUS was the most commonly reported initial screening modality. Across studies using EUS or MRI screening, diagnostic yield for pancreatic adenocarcinoma ranged from 0 to 75.0 per 1000 (7.5%), with three of the smallest studies finding the largest yields and wide confidence intervals around the estimates. For studies with larger sample sizes, yields ranged from 0 to 28.2 per 1000 (2.8%). The yield of CT for pancreatic adenocarcinoma ranged from zero to 12.8 per 1000 across two studies.

All screening modalities detected precursor lesions of IPMN, PanIN, or IPMN/PanIn combined. For detection of these precursor lesions, diagnostic yield ranged from 17.2 to 105.3 per 1000 (1.72% to 10.53%) for EUS alone, to 0 to 50.0 per 1000 for MRI/MRCP alone. For detection of precursor lesions across studies using multiple screening modalities, yields ranged from 7.2 to 129.0 per 1000.

### Detailed Results

Of 1317 people screened across all studies, screen positive results were inconsistently reported across studies, prohibiting assessment of false positive rates. Biopsy rates were also inconsistently reported. In total, 57 surgeries were reported across all studies; of these, 14 resulted in a diagnosis of pancreatic adenocarcinoma. Of the remaining 43 surgeries, 38 removed precursor lesions with IPMN or PanIN, and 5 contained either neuroendocrine tumors, liver hyperplasia, or benign serious cystadenoma. Four additional people had advanced pancreatic adenocarcinoma diagnosed without surgical intervention (Table 7).

Table 7 Findings From Screening Programs for Pancreatic Adenocarcinoma Across Included Prospective Cohort Studies

Finding | N
People screened | 1317
Abnormal findings (test positive) | Inconsistently reported (~323)
Received FNA/biopsy | Inconsistently reported (~93)
Confirmed pancreatic adenocarcinoma on biopsy/FNA/CT (advanced disease, no surgical intervention) | 4
Surgeries performed | 57
Confirmed pancreatic adenocarcinoma on surgery | 14
Other confirmed findings on surgery | 43
IPMN | 5
PanIN | 9
IPMN + PanIN | 20
SCA + PanIN | 4
Other (NET; SCA; liver hyperplasia) | 5

Abbreviations: FNA = fine-needle aspiration; CT = computed tomography; IPMN = Intraductal papillary mucinous neoplasm; PanIN = Pancreatic Intraepithelial Neoplasia; SCA = serous cystadenoma

In total, 18 cases of pancreatic adenocarcinoma were detected: nine on initial screening, eight on repeated screening or during surveillance of abnormal screening results, and one at an unspecified point during the screening program (Tables 8 and 9). All cases of pancreatic adenocarcinoma were detected in high-risk study populations.

Table 8 Results From Prospective Cohort Studies of Screening for Pancreatic Adenocarcinoma^a^

Author, year Screening program Country Quality | Initial screening test | Screened with initial test, N | Definition of abnormal results on initial screening test | Abnormal results on initial test, N^g^ | PDAC detected, N | PDAC yield per 1000 persons (95% CI)^i^ | PDAC stage at detection: N | IPMN, PanIN and other pathology | Other pathology, N^b^ | Other pathology, yield per 1000 persons
Gangi, 2018 ^172^; U.S.; Fair | EUS | 58 | Presence of a mass or cyst | 19 | 0 | 0 (0–61.6)^i^ | N/A | IPMN + PanIN | 1 | 17.2
Joergensen, 2016^125^; Danish National Screening Program; Denmark; Fair | EUS | 71 | Suspicious mass suggestive of PDAC or high-grade dysplasia | NR | 2 | 28.2 (3.4–98.1) | T3N0M0 (Stage IIA): 1^k^; T1N0M0 (Stage IA): 1^k^ | NR | NR | N/A
Poley, 2009^157^; Netherlands; Fair | EUS | 44 | Mass lesions, cystic lesions, duct aberrations and signs of chronic pancreatitis | 11^e^ | 3 | 68.2 (14.3–186.6) | T3N1M0 (Stage IIB): 2; T1N0M0 (Stage IA): 1 | NR | NR | N/A
Canto, 2004^159^; U.S.; Fair | EUS | 38 | (a) Presence of focal lesion such as a mass, nodule, or cyst; or (b) ≥3 of 9 EUS features of chronic pancreatitis | 29 | 1 | 26.3 (0.7–138.1) | T2N1M0 (Stage IIB): 1 | IPMN + PanIN | 1 | 26.3
Canto, 2004^159^; U.S.; Fair | EUS | 38 | (a) Presence of focal lesion such as a mass, nodule, or cyst; or (b) ≥3 of 9 EUS features of chronic pancreatitis | 29 | 1 | 26.3 (0.7–138.1) | T2N1M0 (Stage IIB): 1 | PanIN | 2 | 52.6
Canto, 2004^159^; U.S.; Fair | EUS | 38 | (a) Presence of focal lesion such as a mass, nodule, or cyst; or (b) ≥3 of 9 EUS features of chronic pancreatitis | 29 | 1 | 26.3 (0.7–138.1) | T2N1M0 (Stage IIB): 1 | PanIN + SCA | 2 | 52.6
Canto, 2004^159^; U.S.; Fair | EUS | 38 | (a) Presence of focal lesion such as a mass, nodule, or cyst; or (b) ≥3 of 9 EUS features of chronic pancreatitis | 29 | 1 | 26.3 (0.7–138.1) | T2N1M0 (Stage IIB): 1 | SCA | 1 | 26.3
Canto, 2006^160^,^a^; U.S.; Fair | EUS and CT | 78 | (a) Presence of focal lesion such as a mass, nodule, or cyst; or (b) ≥3 of 9 EUS features of chronic pancreatitis | EUS: 17; CT: NR | 1 | 12.8 (0.3–69.4) | Metastatic to the liver (Stage NR)^k^ | IPMN | 1 | 12.8
Canto, 2006^160^,^a^; U.S.; Fair | EUS and CT | 78 | (a) Presence of focal lesion such as a mass, nodule, or cyst; or (b) ≥3 of 9 EUS features of chronic pancreatitis | EUS: 17; CT: NR | 1 | 12.8 (0.3–69.4) | Metastatic to the liver (Stage NR)^k^ | PanIN | 1 | 12.8
Canto, 2006^160^,^a^; U.S.; Fair | EUS and CT | 78 | (a) Presence of focal lesion such as a mass, nodule, or cyst; or (b) ≥3 of 9 EUS features of chronic pancreatitis | EUS: 17; CT: NR | 1 | 12.8 (0.3–69.4) | Metastatic to the liver (Stage NR)^k^ | IPMN + PanIN | 5 | 64.1
Canto, 2006^160^,^a^; U.S.; Fair | EUS and/or ERCP | EUS: 138^h^; ERCP: 23^h^ | (a) Presence of focal lesion such as a mass, nodule, or cyst; or (b) ≥3 of 9 EUS features of chronic pancreatitis | EUS: 1; ERCP: 0 | 0 | 0 (0–26.4)^i^; ERCP: 0 (0–148.2)^i^ | N/A | Any precursor lesions | 0 | 0
Canto, 2012^163,^ ^165^; CAPS3; U.S.; Fair | EUS and CT and MRI/MRCP | 216 | Main pancreatic duct dilation (duct diameter, >3mm in the head, 2mm in the body, and 1mm in the tail). Reporting of imaging findings was standardized across MRI, CT, and EUS using nomenclature developed at a prior 2004 CAPS consensus. | CT: 24; EUS: 92; MRI: 72 | 0 | 0 (0–16.9)^i^ | N/A | IPMN + PanIN (multifocal) | 5 | 23.1
Harinck, 2016^126,^ ^158,^ ^167,^ ^170^; Dutch FPC Study; Netherlands; Fair | EUS and MRI | 139 | Solid lesions of any size and cystic lesions larger than 10mm. These include all solid lesions suspicious for malignancy and any lesion that fulfils the revised Sendai criteria for surgery or close followup^d^ | EUS: 8 MRI: 9 | 1 | 7.2 (0.2–39.4) | T1N0M0 (Stage IA):1 | PanIN (multifocal) | 1 | 7.2
Al-Sukhni, 2012^127,^ ^166,^ ^168^; Toronto Screening Program; Canada; Fair | MRI | 175 | Pancreatic mass, main duct dilation suggesting MD-IPMN or mass causing duct obstruction, branch duct dilation with communication to the main duct suggesting BD-IPMN, or extra-pancreatic mass or lesions. | 19 | 3 | 17.1 (3.5–49.3) | T1N1M0 (Stage IIB):1^k^; Unresected mass >3cm (Stage NR): 2^k^ | IPMN | 1 | 5.7
Al-Sukhni, 2012^127,^ ^166,^ ^168^; Toronto Screening Program; Canada; Fair | MRI | 175 | | 19 | 3 | 17.1 (3.5–49.3) | T1N1M0 (Stage IIB):1^k^; Unresected mass >3cm (Stage NR): 2^k^ | IPMN + PanIN | 1 | 5.7
Al-Sukhni, 2012^127,^ ^166,^ ^168^; Toronto Screening Program; Canada; Fair | MRI | 175 | | 19 | 3 | 17.1 (3.5–49.3) | T1N1M0 (Stage IIB):1^k^; Unresected mass >3cm (Stage NR): 2^k^ | Neuroendocrine tumor | 1 | 5.7
Schneider, 2011^129,^ ^156,^ ^161,^ ^162,^ ^169^,^m^; FaPaCa; Germany; Fair | EUS and MRI/MRCP | 72 | Detectable solid or cystic lesions that could not be classified as a benign or malignant lesion by imaging, cases of diffuse parenchymal irregularities. MRI/MRCP images evaluated for filling defects, stenoses, duct interruption, focal lesions, focal hypoenhancement | 26 | 1 | 13.9 (3.5–75.0) | Stage NR: 1^l^ (patient had lung metastases on 12 month followup) | IPMN + PanIN | 2 | 27.8
Schneider, 2011^129,^ ^156,^ ^161,^ ^162,^ ^169^,^m^; FaPaCa; Germany; Fair | EUS and MRI/MRCP | 72 | | 26 | 1 | 13.9 (3.5–75.0) | Stage NR: 1^l^ (patient had lung metastases on 12 month followup) | PanIN | 3 | 41.7
Schneider, 2011^129,^ ^156,^ ^161,^ ^162,^ ^169^,^m^; FaPaCa; Germany; Fair | EUS and MRI/MRCP | 72 | | 26 | 1 | 13.9 (3.5–75.0) | Stage NR: 1^l^ (patient had lung metastases on 12 month followup) | PanIN + SCA | 1 | 13.9
Schneider, 2011^129,^ ^156,^ ^161,^ ^162,^ ^169^,^m^; FaPaCa; Germany; Fair | EUS and MRI/MRCP | 72 | | 26 | 1 | 13.9 (3.5–75.0) | Stage NR: 1^l^ (patient had lung metastases on 12 month followup) | SCA | 2 | 27.8
Schneider, 2011^129,^ ^156,^ ^161,^ ^162,^ ^169^,^m^; FaPaCa; Germany; Fair | EUS and MRI/MRCP | 72 | | 26 | 1 | 13.9 (3.5–75.0) | Stage NR: 1^l^ (patient had lung metastases on 12 month followup) | Liver hyperplasia | 1 | 13.9
Verna, 2010^133^,^a^; U.S.; Fair | EUS or MRI | EUS: 31 MRI: 33 | EUS: mass lesions, IPMNs, cysts, and chronic pancreatitis-like parenchymal changes MRI: NR | EUS: 27 MRI: 11 | 2 | EUS: 64.5 (7.9–214.2); MRI: 60.6 (7.4–202.3) | Stage IV metastatic:1; Resectable PDAC with multifocal IPMN + PanIN2: 1 | IPMN + PanIN (multifocal) | 4 | EUS: 129.0; MRI: 121.2
Barnes, 2018^171^; U.S.; Fair | MRI | 65 | Any lesion with (a) serial growth; (b) size >20mm; (c) solid component; or (d) mural nodule. | 28 | 0 | 0 (0–55.2)^i^ | N/A | Any precursor lesions^j^ | 0 | 0
Del Chiaro, 2015^164^,^a^; Sweden; Fair | MRI | 40 | Solid nodules and suspected IPMN lesions. | 16 | 3^c^ | 75.0 (15.7–203.9) | T1N0M0 (Stage IA): 1; T3N0M0 (Stage IIA) with IPMN: 1^k^; T4N1M0 (Stage III): 1^c^,^k^ | IPMN with progression | 2 | 50.0
Ludwig, 2011^155^; U.S.; Fair | MRCP | 109 | Cystic lesions with a solid or nodular component, pancreatic duct dilation, pancreatitis or other lesions deemed concerning by a multidisciplinary group | 18 | 1 | 9.2 (0.2–50.1) | T3N0M0 (Stage IIA): 1 | IPMN | 1 | 9.2
Ludwig, 2011^155^; U.S.; Fair | MRCP | 109 | Cystic lesions with a solid or nodular component, pancreatic duct dilation, pancreatitis or other lesions deemed concerning by a multidisciplinary group | 18 | 1 | 9.2 (0.2–50.1) | T3N0M0 (Stage IIA): 1 | IPMN + PanIN | 1 | 9.2
Ludwig, 2011^155^; U.S.; Fair | MRCP | 109 | Cystic lesions with a solid or nodular component, pancreatic duct dilation, pancreatitis or other lesions deemed concerning by a multidisciplinary group | 18 | 1 | 9.2 (0.2–50.1) | T3N0M0 (Stage IIA): 1 | PanIN | 2 | 18.3
Ludwig, 2011^155^; U.S.; Fair | MRCP | 109 | Cystic lesions with a solid or nodular component, pancreatic duct dilation, pancreatitis or other lesions deemed concerning by a multidisciplinary group | 18 | 1 | 9.2 (0.2–50.1) | T3N0M0 (Stage IIA): 1 | PanIN + SCA | 1 | 9.2

Abbreviations: PDAC = pancreatic ductal adenocarcinoma; EUS = endoscopic ultrasound; CT = computed tomography; MRI = magnetic resonance imaging; MRCP = magnetic resonance cholangiopancreaticography; IPMN = Intraductal papillary mucinous neoplasm; PanIN = Pancreatic Intraepithelial Neoplasia; SCA = serous cystadenoma; CAPS = Cancer of the Pancreas Screening Study; N/A = not applicable; FPC = familial pancreatic cancer

Note: Yield calculated as (number of patients with final pathology ÷ number receiving screening test) * 1000 persons

a Final pathology was determined by surgery except as noted. For Del Chiaro 2015 and Verna 2010, final pathology was determined by surgery or FNA. For the control group for Canto 2006, final pathology was determined by ERCP.

b Represents final pathologies as determined by surgery or FNA. Does not include suspected IPMNs and PanINs followed in surveillance.

c For Del Chiaro 2015, one detected PDAC cases was found at initial screening (T1N0M0; Stage IA), one case was under surveillance for a branch-duct IPMN and after 2 years of surveillance PDAC was found (T3N0M0; Stage IIA), and one case (T4N1M0; Stage III) was detected at 36 months having missed an annual screening.

d Criteria were: cysts ≥3cm, cysts with thickened/enhancing cyst walls and/or mural nodules and/or solid component, main branch IPMN with main pancreatic duct ≥10mm and side branch IPMN with side duct dilations/cysts>10mm.

e Screening detected 12 abnormal findings in 11 individuals

f For Joergensen 2016, the population was classified as the familial pancreatic cancer group (n=40; 56.3%) and the hereditary pancreatitis group (n=31; 43.7%). However, some patients in the hereditary pancreatitis group also had a family history of PDAC. The authors report that 76.6% of the 30 enrolled families had a family history of PDAC, but they do not report the number of enrolled individuals with a family history of PDAC.

g Represents number of patients with abnormal results as defined by each individual study, according to the criteria in the “definition of abnormal results” column. These criteria often were designed to detect not only PDAC and precursor lesions, but also findings such as pancreatitis or neuroendocrine tumors

h Canto 2006 reports that 161 patients were enrolled in the control group, and reports results separately for abnormalities on EUS among 138 controls and abnormalities on ERCP for 23 patients.

i Confidence intervals were calculated based on the data provided in each study. For most studies, confidence intervals are 95% CIs and are two sided. For studies that detected 0 relevant findings (Canto 2006 control group, Canto 2012, Gangi 2018, Barnes 2018), confidence intervals are 97.5% CIs and are one-sided.

j Barnes 2018 reports that two patients had suspected branch-duct IPMN on EUS, one of which was negative for malignancy on cytology. However, neither IPMN was confirmed by surgical pathology.

k Detected during repeat screening, not on initial screen

l Schneider 2011 does not report whether case was detected on initial screening or repeat screening

m Three articles report longer term followup of the FaPaCa cohort combined with other cohorts. One article^161^ reports results from a cohort in Leiden (Germany) and separately reports results from the FaPaCa cohort extending 2 years beyond the Schneider 2011 article; this article reports on the detection of 1 PDAC case in the FaPaCa cohort, which is the same number of PDAC cases reported in Schneider 2011. Two other articles^156,^ ^162^ report combined results from the Leiden cohort, a cohort in Madrid (Spain), and the FaPaCa cohort extending 6 years beyond the Schneider 2011 article; these articles report on the detection of 1 PDAC case^162^ or 2 PDAC cases^156^ but do not report results separately by site

Table 9 Yield on Initial and Repeated Screening for Pancreatic Adenocarcinoma From Prospective Cohort Studies

Author, year | Initial screening test | Screened with initial test, N | Abnormal results on initial test, N | PDAC detected following initial screen, N | PDAC yield following initial screen, per 1000 persons, (95% CI)^c^ | PDAC detected on repeated screen, N | Total PDAC detected, N | Total PDAC yield per 1000 persons, (95% CI)^c^
Gangi, 2018 ^172^ | EUS | 58 | 19 | 0 | 0 (0–61.6)^d^ | 0 | 0 | 0 (0–61.6)^d^
Joergensen, 2016^125^ | EUS | 71 | NR | 0 | 0 (0–50.6)^d^ | 2 | 2 | 28.2 (3.4–98.1)
Poley, 2009^157^ | EUS | 44 | 11 | 3 | 68.2 (14.3–186.6) | 0 | 3 | 68.2 (14.3–186.6)
Canto, 2004^159^ | EUS | 38 | 29 | 1 | 26.3 (0.7–138.1) | 0 | 1 | 26.3 (0.7–138.1)
Canto, 2006^160^ | High risk: EUS and CT | 78 | EUS: 17; CT: NR | 0 | 0 (0–46.2)^d^ | 1 | 1 | 12.8 (0.3–69.4)
Canto, 2006^160^ | Controls: EUS and/or ERCP | EUS: 138; ERCP: 23 | 1 | 0 | EUS: 0 (0–26.4)^d^; ERCP: 0 (0–148.2)^d^ | 0 | 0 | 0 (0–26.4)^d^
Canto, 2012^163,^ ^165^ | EUS and CT and MRI/MRCP | 216 | CT: 24; EUS: 92; MRI: 72 | 0 | 0 (0–16.9)^d^ | 0 | 0 | 0 (0–16.9)^d^
Harinck, 2016^126,^ ^158,^ ^167,^ ^170^ | EUS and MRI | 139 | EUS: 8 MRI: 9 | 1 | 7.2 (0.2–39.4) | 0 | 1 | 7.2 (0.2–39.4)
Al-Sukhni, 2012^127,^ ^166,^ ^168^ | MRI | 175 | 19 | 0 | 0 (0–20.9)^d^ | 3 | 3^e^ | 17.1 (3.5–49.3)
Schneider, 2011^129,^ ^156,^ ^161,^ ^162,^ ^169^ | EUS and MRI/MRCP | 72 | 26 | NR | NR | NR | 1 | 13.9 (3.5–75.0)
Verna, 2010^133^,^a^ | EUS or MRI | EUS: 31 MRI: 33 | EUS: 27 MRI: 11 | 2 | EUS: 64.5 (7.9–214.2); MRI: 60.6 (7.4–202.3) | 0 | 2 | EUS: 64.5 (7.9–214.2); MRI: 60.6 (7.4–202.3)
Barnes, 2018^171^ | MRI | 65 | 28 | 0 | 0 (0–55.2)^d^ | 0 | 0 | 0 (0–55.2)^d^
Del Chiaro, 2015^164^ | MRI | 40 | 16 | 1 | 25.0 (0.6–131.6) | 2 | 3^a^ | 75.0 (15.7–203.9)
Ludwig, 2011^155^ | MRCP | 109 | 18 | 1 | 9.2 (0.2–50.1) | 0 | 1 | 9.2 (0.2–50.1)
TOTAL | | 1156^b^ | | 9 | 7.8 (3.6–14.7) | 8 | 18 ^f^ | 15.6 (9.3–24.5)

Abbreviations: PDAC = pancreatic ductal adenocarcinoma; EUS = endoscopic ultrasound; CT = computed tomography; MRI = magnetic resonance imaging; MRCP = magnetic resonance cholangiopancreaticography; CAPS = Cancer of the Pancreas Screening Study; N/A = not applicable; FPC = familial pancreatic cancer

Note: Yield calculated as (number of patients with final pathology ÷ number receiving screening test) * 1000 persons

a For Del Chiaro 2015, one detected PDAC case (T1N0M0; Stage IA) was found at initial screening, one case (T3N0M0; Stage IIA) was found after 2 years of being in surveillance for a branch-duct IPMN, and one case (T4N1M0; Stage III) was detected at 36 months having missed an annual screening

b Total excludes controls from Canto 2006 and includes 51 total high risk cases from Verna 2010

c Confidence intervals were calculated based on the data provided in each study. Confidence intervals are 95% CIs and are two sided, except as noted.

d Confidence interval is 97.5% CI and is one-sided.

e For Al Sukhni 2012, two PDAC cases (one Stage IV, and one T1N1M0; Stage IIB) were detected on repeat screening. Another case (Stage IV) was detected after 16 months of being in surveillance for cysts identified on initial screen.

f Total includes one PDAC case detected in Schneider 2011 study, but study did not report whether this case was detected on initial or repeated screen

Detected cases were in persons with a mean age of 59.9 years at detection (range 44 to 81); 12 of 18 cases were in women (66.7%). The mean number of affected relatives was three (range 1 to 7 relatives) in 15 persons with a diagnosis of cancer. Nine of 18 cases (52.9%) were detected on initial screening, and eight were detected on repeated screening (one NR). Seven of 11 cases (63.6%) had a known genetic mutation (2 FAMMM, 4 BRCA2, 1 CDKN2A).

Twelve of 18 cases (66.6%) were detected at stage I or II or classified as “resectable.” Of these, eight were detected through initial screening, three were detected on repeat screening, and one was detected during surveillance following previous abnormal findings (a person with IPMN on initial screening and stage IIA cancer detected at 24 months; Case #5 in Table 10). Of the six cases detected at stage III or IV, one was detected at initial screening, three were detected on repeat screening, one was detected at an unspecified point in the screening program, and one was detected during surveillance following previous abnormal findings (a person with cysts identified on initial screening, duct abnormalities detected at 12 months, and an unresectable mass at 14 months that was later confirmed as stage IV disease; Case #9 in Table 10).

Table 10 Treatment and Followup of Pancreatic Adenocarcinoma Cases Identified in Prospective Cohort Screening Studies

Case # | Author, year Study name or Country | Age at diagnosis | Sex | Number of affected relatives (total) | Genetic variant, ancestry | Detected at initial vs. repeat screening | PDAC stage at detection | Treatment | Follow-up time (months) | Status at time of followup
1 | Harinck, 2016^126,^ ^158,^ ^167,^ ^170^; Dutch FPC Study | 52 | Female | 7 | CDKN2A | Initial | T1N0M0, Stage IA | Surgery | 36 ^c^ | Local recurrence with metastases, PDAC death (36 mos)
2 | Joergensen, 2016^125^; Danish Natl Prgm | 63 | Male | 3 | NR | Repeat^e^ | T1N0M0, Stage IA | Surgery | 63 ^d^ | Alive
3 | Joergensen, 2016^125^; Danish Natl Prgm | 60 | Female | 3 | NR | Repeat^f^ | T3N0M0, Stage IIA | Surgery | 7^d^ | Died from complications of unrelated cardiac surgery, not further specified
4 | Del Chiaro, 2015 ^164^; Sweden | 49 | Female | 2 | None | Initial | T1N0M0, Stage IA | Surgery | NR | NR
5 | Del Chiaro, 2015 ^164^; Sweden | 62 | Female | 3 | None | Surveillance of IPMN^g^ | T3N0M0, Stage IIA | Surgery | 24 ^c^ | NR
6 | Del Chiaro, 2015 ^164^; Sweden | 44 | Male | 2 | None | Repeat | T4N1M0, Stage III | Surgery | NR | NR
7 | Al-Sukhni, 2012^127,^ ^166,^ ^168^; Canada | 57 | Female | 2 | NR^a^ | Repeat | T1N1M0, Stage IIB | Surgery and chemotherapy | 36^c^ | Local recurrence (30 mos), PDAC death (36 mos)
8 | Al-Sukhni, 2012^127,^ ^166,^ ^168^; Canada | 65 | Female | 1 | BRCA2 ^a^ | Repeat | Stage IV^b^,^h^ | Chemotherapy | NR | Alive, tumor reduction from treatment
9 | Al-Sukhni, 2012^127,^ ^166,^ ^168^; Canada | 81 | Male | 1 | NR | Surveillance of cysts^i^ | Stage IV^b^ | None | < 6^c^ | PDAC death (<6 mos from detection)
10 | Ludwig, 2011 ^155^; USA | 58 | Female | 2 | NR | Initial | T3N0M0, Stage IIA | Surgery | NR | NR
11 | Schneider, 2011^129,^ ^156,^ ^161,^ ^162,^ ^169^; FaPaCa | 52 | Female | NR | NR | NR | Stage IV^j^ | Surgery | 12 | Alive, lung metastases
12 | Verna, 2010 ^133^; USA | 61 | Male | 2 | BRCA2 | Initial | Resectable PC, stage NR | Surgery | NR | Alive
13 | Verna, 2010 ^133^; USA | 58 | NR | 2 | NR | Initial | Stage IV^b^ | Chemotherapy | NR | Alive
14 | Poley, 2009^157^; Netherlands | 69 | Male | 2 | BRCA2 | Initial | T3N1M0, Stage IIB | Surgery | 16^d^ | Local recurrence, died (16 mos after surgery)^k^
15 | Poley, 2009^157^; Netherlands | 51 | Female | NR | FAMMM | Initial | T1N0M0, Stage IA | Surgery | 16 ^d^ | Alive, local recurrence and liver metastases
16 | Poley, 2009^157^; Netherlands | 76 | Female | NR | FAMMM | Initial | T3N1M0, Stage IIB | Surgery | 18 ^d^ | Alive
17 | Canto, 2006^160^; USA | 76 | Female | 6 | BRCA2 ^a^ | Repeat | Liver and pancreatic mass; adenocarcinoma by percutaneous biopsy | No surgery, unspecified treatment | NR | Alive, undergoing treatment for metastatic pancreatic cancer
18 | Canto, 2004 ^159^; USA | 45 | Female | 7 | None | Initial | T2N1M0, Stage IIB | Surgery, postoperative radiation and chemotherapy | 60 | Alive

Abbreviations: PDAC = pancreatic ductal adenocarcinoma; FAMMM = familial atypical multiple mole melanoma; FPC = familial pancreatic cancer; NR = not reported; FaPaCa = German National Case Collection of Familial Pancreatic Cancer;

Note: Staging information is based on data provided in the studies and the American Joint Committee on Cancer’s staging criteria^204^

a Indicates individual has Ashkenazi Jewish ancestry

b Patient had liver metastases

c Followup time since diagnosis of PDAC

d Followup time since surgery

e Diagnosed on fourth EUS screening examination

f Diagnosed on second EUS screening examination

g IPMN detected on initial screen, progression identified at 24 months. Patient underwent surgery at 24 months

h Patient had normal pancreas on 3 consecutive MRIs, then missed her fourth annual appointment. Nine months later, patient presented with pancreas tumor and metastases

i Cysts were identified at initial screen, and followed at 6 month intervals. At 1 year in surveillance, MRI showed cut-off peripheral duct branches in the pancreatic head. CT showed no evidence of a mass and before EUS could be performed patient developed jaundice, weight loss and diabetes. Two months later CT showed unresectable mass at the head of the pancreas. Liver metastases was detected on another CT 2 months later, and confirmed by percutaneous biopsy

j Assumed stage IV, authors report that patient has lung metastases

k Authors report that patient had an uneventful recovery from surgery. However, 10 months later, a local recurrence of the tumor was shown and the patient died 16 months after surgery. The authors do not report whether the death was attributable to PDAC

### Yield of Screening EUS to Detect Pancreatic Adenocarcinoma

The yield of EUS-based screening in nine studies (n=885) ranged from 0 to 68.2 cases per 1,000 high-risk persons. Among 11 total pancreatic adenocarcinoma cases detected with EUS across all nine studies, seven were detected on initial screening, three were detected on repeat screening, and one was detected at an unspecified point in the screening program. Of these pancreatic adenocarcinoma cases, three were detected at stage I, one was stage IIA, three were stage IIB, three were metastatic, and one was reported as resectable with no stage given.

Two small studies found diagnostic yields of 68.2 per 1000 (6.8%)^157^ and 64.5 per 1000 (6.45 %),^133^ but confidence intervals were wide in both studies. In the Dutch study by Poley and colleagues (n=44), the population was 52.3 percent people with known genetic mutations or syndromes;^157^ in a study based at Columbia University Medical Center (n=51), 100 percent of the study population had a family history of pancreatic adenocarcinoma.^133^ In the Dutch study by Poley and colleagues, all three detected pancreatic adenocarcinoma cases were people with known mutations (2 with FAMMM and one with BRCA2).^157^

### Yield of Screening CT to Detect Pancreatic Adenocarcinoma

In two studies reporting CT (n=294),^160,^ ^165^ the yield of CT for pancreatic adenocarcinoma ranged from zero to 12.8 per 1000.

### Yield of Screening MRI to Detect Pancreatic Adenocarcinoma

Across eight studies reporting MRI screening results (n=849), the yield of pancreatic ductal adenocarcinoma following MRI screening ranged from 0 to 75.0 cases per 1,000 persons. Among a total of 11 pancreatic adenocarcinoma cases detected across all eight studies, five were detected on initial screening, three were detected on repeat screening, one was detected at an unspecified point in the screening program, and two were detected during surveillance of IPMN or other cysts. Of these pancreatic adenocarcinoma cases, two were detected at stage IA, two were stage IIA, one was stage IIB, one was stage III, four had metastatic disease, and the remaining case was reported as resectable with no stage given.

### Detection of IPMN or PanIn Precursor Lesions

In total, the screening programs identified a total of 38 individuals with IPMN (n=5), PanIN (n=13) or both IPMN and PanIN (n=20). (Table 8) It is unclear if the clinical significance of these findings suggests potential clinical benefit or potential harm from overdiagnosis.

## KQ3 What Are the Harms of Screening for Pancreatic Adenocarcinoma?

### Summary of Results

Procedural harms of screening were evaluated in eight screening studies (n=675);^125,^ ^126,^ ^129,^ ^133,^ ^155,^ ^157,^ ^159,^ ^160^ psychological harms were assessed in two studies (n=271).^126,^ ^127^ Details on the assessment of harms were variably reported. In two studies (n=277)^159,^ ^160^ in which 150 individuals underwent ERCP as a diagnostic followup test, 15 people (10%) reported acute pancreatitis, nine of which required hospitalization. No evidence of increased worry, distress, depression, or anxiety after screening was reported, compared to before screening.^168,^ ^170^

### Detailed Results

#### Procedural Harms

Eight screening studies (n=675) reported screening procedure-related harms (Table 11).^125,^ ^126,^ ^129,^ ^133,^ ^155,^ ^157,^ ^159,^ ^160^ Five studies (n=485) reported harms of EUS alone,^125,^ ^126,^ ^133,^ ^155,^ ^157,^ ^160^ two studies (n=150) reported harms of diagnostic followup ERCP,^159,^ ^160^ and two studies (n=45) reported harms of diagnostic followup FNA.^129,^ ^159^ Two studies (n=160) reported harms of MRI and one (n=98) reported harms of MRCP.^155^ One study reported harms of CT.^160^

Table 11 Screening Procedure-Related Harms in Prospective Cohort Studies of Screening for Pancreatic Adenocarcinoma

Author, year Screening program Country, Quality | Test type | N receiving test | Definition of harms | N with harm | % with harm
Joergensen, 2016^125^; Danish National Screening Program; Denmark, Fair | EUS | 71 | Any complications | 0 | 0
Harinck, 2016^126,^ ^158,^ ^167,^ ^170^; Dutch FPC Study; Netherlands, Fair | EUS | 139 | Any procedure related adverse events | 0 | 0
Poley, 2009^157^; Netherlands, Fair | EUS | 44 | Any complications | 0 | 0
Verna, 2010^133^; U.S., Fair | EUS or MRI | 51 | Any complications | 0 | 0
Ludwig, 2011^155^,^e^; U.S., Fair | MRI | 109 | Complications related to screening | 0 | 0
Ludwig, 2011^155^,^e^; U.S., Fair | EUS | 15 | Any complications (including poor tolerance of the procedure) | 0 | 0
Ludwig, 2011^155^,^e^; U.S., Fair | MRCP | 98 | Requiring intravenous sedation for MRCP | 0 | 0
Schneider, 2011^129,^ ^156,^ ^161,^ ^162,^ ^169^; FaPaCa; Germany, Fair | FNA | 7 | Adverse events of FNA | 0 | 0
Canto, 2006^160^,^e^; U.S., Fair | CT | HR: 78; CG: NR^d^ | Mild contrast allergic reaction (in controls), resolved | HR: 0; CG: 1 | HR: 0; CG: NR
Canto, 2006^160^,^e^; U.S., Fair | EUS | HR: 78; CG: 138 | Mild post-procedure abdominal pain^b^ | HR: 22; CG: 33 | HR: 28%^a^; CG: 24%
Canto, 2006^160^,^e^; U.S., Fair | EUS | HR: 78; CG: 138 | Prolonged sedation, muscle aches, nausea, vomiting related to sedation or general anesthesia | HR: 6; CG: 7 | HR: 7.5%^a^; CG: 5%
Canto, 2006^160^,^e^; U.S., Fair | ERCP | HR: 67; CG: 59 | Acute pancreatitis not requiring hospitalization | HR: 1; CG: 4 | HR: 1.5%^a^; CG: 6.8%
Canto, 2006^160^,^e^; U.S., Fair | ERCP | HR: 67; CG: 59 | Acute pancreatitis requiring hospitalization^c^ | HR: 4; CG: 4 | HR: 6.0%^a^; CG: 6.8%
Canto, 2004^159^,^e^; U.S., Fair | EUS +/- FNA | 38 | Fever, bleeding, abdominal pain or pancreatitis | 0 | 0
Canto, 2004^159^,^e^; U.S., Fair | ERCP | 24 | Post-ERCP mild pancreatitis | 2 (1 requiring hospitalization) | 8.3%

Abbreviations: PDAC = pancreatic ductal adenocarcinoma; EUS = endoscopic ultrasound; CT = computed tomography; MRI = magnetic resonance imaging; MRCP = magnetic resonance cholangiopancreaticography; ERCP = endoscopic retrograde cholangiopancreatography; FNA = fine needle aspiration; HR = high-risk group; CG = control group; FaPaCa = German National Case Collection of Familial Pancreatic Cancer; FPC = familial pancreatic cancer

Note: Italics indicate N was calculated from author-reported percentage

a p-value not significant when comparing HR to controls for mild procedure-related abdominal pain (p = 0.51), symptoms related to sedation or general anesthesia (p = 0.48), or for acute pancreatitis (p = 0.38)

b None required treatment

c Mean hospitalization stay was 8.25 days, range 2–12 days

d Canto 2006 does not report the number of patients from the control group who underwent CT

e Three studies (Ludwig 2011, Canto 2006, Canto 2004) assessed procedure-related harms by calling all patients within a week after the procedure. The other 5 studies do not report how harms were assessed or if they were assessed routinely for all participants or all procedures.

Six of eight studies (n=421) identified no harms related to screening procedures.^125,^ ^126,^ ^129,^ ^133,^ ^155,^ ^157^ Two studies identified harms from EUS, CT, and followup ERCP for abnormal EUS.^159,^ ^160^

##### Harms of EUS Plus or Minus Followup ERCP and/or FNA

Five studies (n=340) reported no complications related to EUS.^125,^ ^126,^ ^133,^ ^157^ One study (n=38) reported no fever, bleeding, pain, or pancreatitis^159^ for EUS with or without FNA. One study found that in 216 people receiving EUS, mild post-EUS pain was reported in 55 (25.5%), and adverse events related to anesthesia were reported in 13 people (6.0%).^159^

Of 150 individuals who underwent ERCP as an intermediate test across two studies,^159,^ ^160^ 15 people (10%) reported acute pancreatitis, nine of which required hospitalization. One study (n=24 receiving ERCP) found two cases of acute pancreatitis, one requiring hospitalization^159^ and the other (n=126 receiving ERCP) found eight cases (6.3%) of pancreatitis requiring hospitalization (mean hospital stay 8.25 days) and five cases not requiring hospitalization. Cases of acute pancreatitis were similar between high risk and control groups.

Across two studies^129,^ ^159^ and 45 people receiving EUS-guided FNA for diagnostic followup from initial EUS screening, no adverse events were reported.

##### Harms of MRI or MRCP

No complications were reported in two studies describing 240 people receiving screening MRI or MRCP.

##### Harms of CT

In 78 high-risk individuals and an unreported number of asymptomatic participants receiving CT in a single study,^160^ there was one case (0.005%) of mild reaction to contrast that resolved.

#### Psychosocial Harms

Two screening studies (n=271)^126,^ ^127^ assessed psychosocial harms (Table 12). In the Dutch FPC study,^126,^ ^158,^ ^167,^ ^170^ the majority of respondents reported normal levels of distress at all time points.^170^ Cancer Worry Scale scores decreased steadily and significantly over time (14.4 at baseline, 12.1 at 3 years, p<0.01), indicating reduced levels of worry from pre-screening to post-screening. Though there is no hard threshold for scoring the CWS, a score of 12 or higher (on a scale of 8, lower worry to 32, higher worry) may indicate severe worry levels,^170^ so this change may indicate some clinical relevance.

Table 12 Perceived Risk, Cancer Worries, Anxiety and Depression From Dutch FPC Prospective Cohort Study of Screening for Pancreatic Adenocarcinoma, n=140

| T0 | T1 | T2 | T3 | T4 | T5 | Average
Perceived risk of developing PDAC without surveillance, mean (scale 0–100) | 34 | 46 | 46 | 42 | 46 | 47 | 44.3
Perceived risk of developing PDAC with surveillance, mean (scale 0–100) | 24 | 28 | 32 | 26 | 32 | 33 | 29.4
Cancer Worry Scale score, mean (scale 8–32)^b^ | 14.4 | 14.0 | 13.3 | 12.4 | 12.5 | 12.1 | 13.0^a^
HADS-A score, mean (scale 0–21) | 5.3 | 4.6 | 4.3 | 4.3 | 4.4 | 4.5 | 4.5
HADS-A score categories:; - Normal level of anxiety (score <8, %); - Elevated distress (score 8–10, %); - Significant distress (score >10, %) | 69; 14; 17 | 81; 13; 6 | 84; 9; 7 | 75; 19; 6 | 80; 14; 6 | 78; 12; 10 | 79%; 14%; 7%
HADS-D score, mean (scale 0–21) | 2.5 | 2.4 | 2.6 | 2.9 | 3.2 | 2.8 | 2.8
HADS-D score categories:; - Normal level of anxiety (score <8, %); - Elevated distress (score 8–10, %); - Significant distress (score >10, %) | 91; 3; 6 | 90; 6; 4 | 93; 4; 3 | 92; 4; 4 | 87; 6; 7 | 90; 6; 4 | 91%; 5%; 5%

Abbreviations: PC, pancreatic cancer; HADS-A, Hospital Anxiety and Depression Scale, 7-item subscale for anxiety; HADS-D, Hospital Anxiety and Depression Scale, 7-item subscale for depression

Note: Data are from Konings 2016^170^ article as part of Dutch Familial Pancreatic Cancer (FPC) study. Time periods are represented as T0: after genetic counseling (pre-screening); T1: after intake by gastroenterologist; T2: after initial MRI/EUS screening; T3: after second MRI/EUS screening; T4: after third MRI/EUS; T5: after fourth MRI/EUS

a significant intra-individual decrease over time (in comparison with first assessment at T0), non-proportional analysis, p<0.01

b Eight item scale, scored 8–32. Cut-off is not clearly described, but a score C14 could indicate moderate to high levels of cancer worries^205^

In the Toronto program,^127,^ ^166,^ ^168^ scores of perceived pancreatic cancer risk, pancreatic cancer worry, and general distress were all similar between baseline and 3 months post-screening (Table 13).^168^ On a self-rated worry scale from 1 (not at all) to 4 (a lot) point Likert scale, mean scores were between 1 and 2 and were similar at baseline and 3 months followup. Levels of distress were in the normal range at both time points; perceived risk as a self-reported percentage chance was 42.07 percent at baseline and 37.68 percent at 3 months followup (change not significant).

Table 13 Perceived Risk, Cancer Worries, and Distress Among FPC Group (n=131) From Canadian Prospective Cohort Study of Screening for Pancreatic Adenocarcinoma

| N | Pre-screening, mean (SD) | 3-month post-screening, mean (SD)
Perceived pancreatic cancer risk^a^ | 83 | 42.07 (23.8) | 37.68 (23.0)
Pancreatic cancer worry^b,^ ^c^ | 89 | 1.59 (0.14) | 1.55 (0.12)
General distress^d^ | 63 | 33 (45) | 29 (42)

Abbreviations: FPC = familial pancreatic cancer; SD = standard deviation

Note: Data are from Maheu 2010^168^ article as part of Toronto Screening Study.

a Self-rated perceived lifetime risk of developing pancreatic cancer on a scale from 0 to 100%.

b Self-rated frequency of worry about developing pancreatic cancer in the previous month on a 4-point Likert scale (values were: 1 = not at all/rarely, 2 = sometimes, 3 = often, 4 = a lot).

c The authors reported that cancer worry decreased significantly among subgroups of people with 2 relatives with pancreatic cancer (p<0.001) or ≥3 relatives with pancreatic cancer (p<0.007; data not shown in paper).

d BSI-18 comprises (a) three subscales measuring the psychological symptoms of somatization, depression, and anxiety and (b) one global index of distress, the Global Severity Index (GSI). The GSI represents the sum of the three subscales, providing an overall score of individuals’ psychological distress. Raw GSI scores are converted to standardized T scores based on gender-keyed norms; for example, a converted T score of 60 represents a raw male score of 46 or a raw female score of 68. A converted T score ≥60 identifies levels consistent with clinical distress

## KQ4 Does Treatment of Screen-Detected or Asymptomatic Pancreatic Adenocarcinoma Improve Cancer Mortality, All-Cause Mortality, or Quality Of Life?

No studies met inclusion criteria for KQ4.

No studies met our criteria, typically because of the lack of comparison groups in the studies designs. This lack of comparison prohibits direct comparison of treatment outcomes in screen-detected compared to clinically-detected cancers. However, some studies reported treatment outcomes for select individual cases; and several studies have published longer-term followup at the cohort level. This information is provided in Appendix D. Briefly, five individuals—out of 10 for which data were available—were alive at 12 to 63 months followup,^125,^ ^129,^ ^157,^ ^159^ two with distant metastases reported at 12 and 16 months.^129,^ ^157^

## KQ5 What Are the Harms of Treatment of Screen-Detected Pancreatic Adenocarcinoma?

Of the 57 people who underwent surgery across all studies, harms of surgery were assessed in six studies including 32 people receiving surgery (56.1%; Table 14).^125,^ ^129,^ ^133,^ ^157,^ ^160,^ ^165^ Methods of assessing harms were only reported in two U.S.-based studies, and were defined as clinical followup at 1 year in one study (n=5 receiving surgery)^165^ and clinical followup at 1 month and 12 months after surgery (n=7 receiving surgery).^160^ In the remaining studies, methods of assessing harms, and whether they were assessed in all study patients, were not reported. No studies reported assessing or identifying psychosocial harms following surgical intervention.

Table 14 Surgery-Related Harms in Prospective Cohort Studies of Screening for Pancreatic Adenocarcinoma

Author, year Screening program Country, Quality | N receiving surgery | Assessment of harms | Definition of harms | N with harm | % with harm
Joergensen, 2016^125^; Danish National Screening Program; Denmark, Fair | 2 | NR | Stricture to hepaticojejunal anastomosis with cholangitis^d^ | 1^b^ | 50%
Joergensen, 2016^125^; Danish National Screening Program; Denmark, Fair | 2 | NR | Postoperative complications, not further specified | 1^c^ | 50%
Canto, 2012^163,^ ^165^; U.S., Fair | 5 | Clinical followup for a minimum of 1 year | Major adverse events, not further specified | 0 | 0
Schneider, 2011^129,^ ^156,^ ^161,^ ^162,^ ^169^; FaPaCa; Germany, Fair | 10 | NR | Pancreatic fistula, not further specified^f^ | 2 | 20%
Schneider, 2011^129,^ ^156,^ ^161,^ ^162,^ ^169^; FaPaCa; Germany, Fair | 10 | NR | Diabetes, not further specified^e^ | 3 | 30%
Verna, 2010^133^; U.S., Fair | 5 | NR | Significant complications, not further specified | 0 | 0
Poley, 2009^157^; Netherlands, Fair | 3 | NR | Harms from surgery, not further specified^a^ | 0 | 0
Canto, 2006^160^; U.S., Fair | 7 | Clinical followup at 1 month and 12 months post-surgery for all surgical patients | Significant post-operative complications, not further specified | 0 | 0
TOTAL | 32 | Mixed | Any harm | 7 | 25%

Abbreviations: PDAC = pancreatic ductal adenocarcinoma; NR = not reported

Note: Of the 6 studies that report ANY harms or assessment of harms, 32 persons had surgery. Of those 32 who had surgery that were eligible for reporting harms, 7 harms were reported (25%). It should be noted that only 3 of the 6 studies assessed harms in a systematic way. Types of surgeries varied across studies, and there was no consistency between surgery type and harms

a Poley 2009 stated that one patient had “an uneventful recovery” from surgery. The paper did not report information on recovery from surgery for the other two patients who underwent surgery.

b Hospital stay of 9 days.

c Hospital stay of 8 days.

d Occurred 11 months post-surgery

e It is not clear from the paper whether these cases were pre-existing or resulting from surgery. The study text provides no information on the resolution of these cases.

f The authors report that fistulas were “treated conservatively.”

Harms following surgery were reported in seven people in two studies.^125,^ ^129^ In the Danish screening program, stricture to the hepaticojejunal anastomosis was reported in one person 11 months after surgery, and unspecified post-operative complications in the other.^125^ In the FaPaCa study of 10 people receiving surgery, two cases of post-operative fistula were reported, as well as three cases of diabetes, though it is not clear whether these were caused by surgery or existing co-morbidities.^129^ In the two studies that systematically assessed harms in all surgical patients (n=12 people receiving surgery), no harms were reported.^160,^ ^165^ The remaining two studies, neither of which reported methods of assessing harms (n=8 people receiving surgery), reported absence of surgical harms.^133,^ ^157^