# Chapter 2 Methods

## Scope and Purpose

The USPSTF will use this evidence review to update their 2004 D recommendation on screening for pancreatic cancer.^1^ This review addresses the benefits and harms associated with screening and treatment of screen-detected pancreatic adenocarcinoma.

## Key Questions and Analytic Framework

We developed an analytic framework with five key questions (KQs) based on the previous review and a scan of the research conducted since the previous review (Figure 1).

Figure 1 Analytic Framework

The analytic framework depicts the five Key Questions (KQs). Specifically, it illustrates the following questions: whether screening for pancreatic adenocarcinoma improves cancer morbidity or mortality or all-cause mortality (KQ1); whether screening effectiveness varies by clinically relevant subpopulations (KQ1a); the diagnostic accuracy of screening tests for pancreatic adenocarcinoma (KQ2); the harms of screening for pancreatic adenocarcinoma (KQ3); whether treatment of screen-detected or asymptomatic pancreatic adenocarcinoma improves cancer mortality, all-cause mortality, or quality of life (KQ4); and the harms of treatment of screen-detected pancreatic adenocarcinoma (KQ5).

### KQs

1. Does screening for pancreatic adenocarcinoma improve cancer morbidity or mortality or all-cause mortality?
  a. Does screening effectiveness vary by clinically relevant subpopulations (e.g., by age group, family history of pancreatic cancer, personal history of new-onset diabetes, or other risk factors)?
2. What is the diagnostic accuracy of screening tests for pancreatic adenocarcinoma?
3. What are the harms of screening for pancreatic adenocarcinoma?
4. Does treatment of screen-detected or asymptomatic pancreatic adenocarcinoma improve cancer mortality, all-cause mortality, or quality of life?
5. What are the harms of treatment of screen-detected pancreatic adenocarcinoma?

## Data Sources and Searches

We worked with a research librarian to develop our literature search (Appendix B). All search strategies were peer-reviewed by a second research librarian.

We re-evaluated all articles included in the previous USPSTF Evidence Report on Pancreatic Cancer Screening.^140^ Bridging from this previous review, we searched for articles published from 2002 to October 3, 2017. We searched Cochrane Central Register of Controlled Trials, MEDLINE, and PubMed, publisher-supplied to locate relevant studies for all KQs (Appendix B). Results of the literature search were imported into EndNote. We supplemented our database searches by reviewing reference lists from recent and relevant systematic reviews.^95,^ ^141–151^ We also searched ClinicalTrials.gov and WHO International Clinical Trials Registry Platform (ICTRP) for relevant ongoing studies (Appendix C). We ran the searches again on April 27, 2018, to capture new literature from the intervening months.

## Study Selection

A total of 19,596 abstracts were reviewed. Initial identification of low-relevance abstracts was conducted using key words relating to exclusion criteria. This identified 2,168 citations that were reviewed by a single investigator. The remaining 17,428 abstracts were dual-reviewed by two independent reviewers using Abstrackr, an online abstract reviewing platform. From the two processes, the team reviewed 824 full-text articles (Appendix A, Figure 1) against specified inclusion criteria (Appendix A, Table 1). We resolved discrepancies through consensus and consultation with a third investigator. We excluded articles that did not meet inclusion criteria or those we rated as poor quality.

For screening key questions (KQs 1, 2, 3), the population of interest was adults 18 years or older with or without risk factors for pancreatic adenocarcinoma (e.g. family history of pancreatic adenocarcinoma, personal history of new-onset diabetes or other risk factors). We excluded studies that focused solely on persons with confirmed genetic syndromes (e.g., Peutz-Jeghers syndrome, Lynch syndrome, hereditary pancreatitis, known mutations in CDKN2A, BRCA1, BRCA2, CTFR, or ATM genes). Studies with persons with high-risk genetic mutations or syndromes in addition to persons with other risk factors were included. We included any imaging-based screening protocol, and excluded studies using biomarker-based initial screening protocols as no validated biomarkers currently exist.^99^ For diagnostic accuracy (KQ2), we included trials or cohort studies. For harms of screening (KQ3), we included randomized, controlled trials; controlled clinical trials; cohort studies; or case-control studies. Outcomes of interest were pancreatic adenocarcinoma-specific morbidity or mortality, all-cause mortality, or quality of life (KQ1); measures of diagnostic accuracy, including sensitivity, predictive value, and diagnostic yield (KQ2); or procedural or psychosocial harms of screening (KQ3).

For key questions on treatment (KQ4, KQ5) the population of interest was adults with screen-detected, asymptomatic, or incidentally detected pancreatic adenocarcinoma. We excluded studies of surgical intervention for early-stage pancreatic adenocarcinoma that was detected clinically or as a result of symptoms, as these study populations may not be an adequate proxy for screen-detected, asymptomatic, or incidentally detected populations. We excluded studies of people with pancreatic endocrine or exocrine tumors other than adenocarcinoma. We included studies reporting on surgical resection with or without chemotherapy or radiation. We excluded studies on chemotherapy or palliative care alone. Studies eligible for KQ4 needed to have a comparison group of either no treatment or delayed treatment; thus, we excluded comparative effectiveness screening or treatment studies. Outcomes of interest were morbidity or mortality, quality of life (KQ4) or any surgical harms (KQ5).

For all key questions we limited studies to settings conducted in countries categorized as “Very High” in the Human Development Index.^152^

## Quality Assessment and Data Abstraction

At least two reviewers independently critically appraised all articles that met the inclusion criteria based on the USPSTF’s design-specific quality criteria for trials (Appendix A, Table 2). We rated articles as good, fair, or poor quality. A good-quality study met all criteria. A fair-quality study did not meet, or it was unclear if it met, at least one criterion but had no known important limitations that could invalidate its results. A poor-quality study had a single fatal flaw or multiple important limitations; we excluded poor-quality studies from this review. Disagreements about critical appraisal were resolved by consensus and, if needed, in consultation with a third independent reviewer.

One reviewer extracted key elements of included studies into a Microsoft Access® database (Microsoft Corporation, Redmond, Washington). A second reviewer checked the data for accuracy. Evidence tables were tailored for each KQ. Tables generally included details on study design and quality, setting and population (e.g., country, inclusion criteria, age, sex, race/ethnicity), screening or treatment details, length of followup, and outcomes.

## Data Synthesis and Analysis

We synthesized results by KQ. We used a standardized summary of evidence table to summarize the overall strength of evidence for each KQ. This table included the number and design of included studies, summary of results, consistency or precision of results, reporting bias, summary of study quality, limitations of the body of evidence, and applicability of the findings.

Because of the limited number of studies and the population heterogeneity, we provided a narrative synthesis of results and used summary tables to allow for comparisons across studies. For screening test performance (KQ2), we could only report on the yield of cancers as the (diagnostic) outcome, as we could not calculate sensitivity and specificity from the included studies. For harms of screening (KQ3), we stratified results by type of harm (i.e., procedural, psychosocial).

For quantitative analyses, we calculated diagnostic yield of pancreatic adenocarcinoma and 95 percent CIs assuming binomial distribution. After confirming that the yield of different imaging modalities was similar across studies, we also calculated a pooled diagnostic yield across studies and produced forest plots to illustrate the range of effects seen across studies. We calculated diagnostic yield from initial screen (baseline) and from initial screening and repeated screening combined where possible. We could not calculate the screening rate for repeat screenings alone because the number of participants undergoing repeated screenings was not clearly or consistently reported across studies.

## Grading the Strength of the Body of Evidence

We graded the strength of evidence by each KQ according to guidance from the Agency for Healthcare Research and Quality (AHRQ) for Evidence-based Practice Centers,^153^ which was informed by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group.^154^ For each KQ we grade the evidence according to consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations). These are four of the five suggested domains; we did not address the fifth required domain—directness—in the summary of evidence as directness is addressed in the design and structure of the key questions (i.e., whether the evidence links the interventions directly to a health outcome).

Consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). Reporting bias was rated as suspected, undetected, or not applicable (e.g., when there is insufficient evidence for a particular outcome). Study quality reflects the quality ratings of the individual trials and indicates the degree to which the included studies for a given outcome have a high likelihood of adequate protection against bias. The body of evidence limitations field highlights important restrictions in answering the overall KQ (e.g., lack of replication of interventions, non-reporting of outcomes important to patients).

We provide an overall assessment of the strength of evidence for each KQ. “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” suggests moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effects. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effects. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimate of an effect. Applicability assesses how the overall body of evidence would apply to the U.S. population based on settings, populations and intervention characteristics. Two independent reviewers rated each KQ according to consistency, precision, reporting bias, and overall strength of evidence grade. We resolved discrepancies through consensus.

## Expert Review and Public Comment

A draft research plan that included the analytic framework, KQs, and inclusion criteria was available for public comment from April 27, 2017 through May 24, 2017. We made no substantive changes to our review methods based on the comments received.

A draft version of this report was reviewed by invited content experts and federal partners, who are listed in the acknowledgements. Comments received during this process were presented to the USPSTF during its deliberation of the evidence and, subsequently, addressed in this version of the report. A draft version of this report was posted for public comment on the USPSTF website from February 5, 2019 through March 4, 2019. All comments were reviewed and considered in finalizing this report; no substantial changes to the content or conclusions were implemented.

## USPSTF Involvement

We worked with four USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and KQs and to resolve issues regarding the scope of the final evidence review. This research was funded by the Agency for Healthcare Research and Quality under a contract to support the work of the USPSTF. Agency staff provided oversight for the project, assisted in external review of the draft report, and reviewed the draft report.