# Chapter 1 Introduction

## Purpose

The United States Preventive Services Task Force (USPSTF) will use this report to update their 2004 recommendation against routine screening for pancreatic cancer.^1^

## Condition Background

### Condition Definition

There are two types of pancreatic tumors: exocrine tumors, which develop from exocrine cells that form glands and ducts that make pancreatic enzymes to digest foods; and endocrine tumors, which develop from endocrine cells that produce hormones such as insulin.^2^

This report focuses on pancreatic ductal adenocarcinoma. Most pancreatic tumors (95%) are exocrine tumors with malignant histologies; 90 percent of these are ductal adenocarcinoma. Typically, pancreatic cancer is synonymous with pancreatic adenocarcinoma. Less than 5 percent of pancreatic tumors are endocrine tumors, also known as neuroendocrine tumors (NETs or PNETs) or islet cell tumors, which are not addressed in this review. Other exocrine tumors include solid-pseudopapillary neoplasm (<1%), acinar cell carcinoma (<1%), pancreatoblastoma (<1%), and serous cystadenocarcinoma, a benign lesion (<1%).

### Prevalence and Burden

Pancreatic adenocarcinoma is the third most common cause of cancer death among men and women in the United States, and the 11th most common case of incident cancer.^3^ In 2018, an estimated 55,440 people will be diagnosed with pancreatic adenocarcinoma, with 44,330 deaths.^4^ Data from the Surveillance Epidemiology and End Results (SEER) registry show the incidence rates of pancreatic adenocarcinoma decreased by 19 percent among men and by 5 percent among women from 1977–2005, possibly due to decreased exposure to risk factors such as smoking.^5^ Between 2005 and 2014, incidence rates of pancreatic adenocarcinoma rose 0.5 percent each year, while death rates (10.9 per 100,000 people per year) over the same time period were stable.^6,^ ^7^ As treatment and screening advances improve for other cancers, pancreatic adenocarcinoma may be the leading cause of cancer mortality by 2030.^8^

SEER data show that men are more likely to be diagnosed with pancreatic adenocarcinoma than women (14.2 new cases in men per 100,000 people versus 11.1 new cases in women per 100,000 people).^6^ The highest incidence rates occur in African-American males (17.0 per 100,000 people) and the lowest incidence rates occur in American Indian/Alaskan Native females (8.3 per 100,000 people).^6,^ ^9^ Incidence increases sharply with increasing age (70.4 cases per 100,000 in people ages 65 and older) with a median age at diagnosis of 71 years.^6,^ ^9^

According to the American Cancer Society, the overall 5-year survival rate for pancreatic adenocarcinoma is 8 percent;^10^ however, survival rates vary by subtype and stage at diagnosis. More than 80 percent of incident cases are detected at advanced stage when surgical intervention is not recommended and 5-year survival is 2 percent to 5 percent. Only 9 percent of cases are detected at stage I or II, when surgery is most likely to improve survival (Table 1). Eligibility for surgical resection improves prognosis but is typically an option only for early stage tumors. Additional factors such as positive resection margins, poor tumor differentiation, larger tumor size, lymph node involvement, and high levels of carbohydrate antigen 19-9 (CA 19-9) adversely impact prognosis.^9^

Table 1 Proportion of Pancreatic Cancers by Clinical and AJCC Stage and Corresponding Survival Ratse

Clinical stage^57,*^ | AJCC stage | Proportion of incident cases | 5-year overall survival rate
Resectable | I/II | 9% | 10%-35%^4,^ ^192^,^‡^
Borderline resectable | II/III | 10% | 10%-35%^192^,^‡^
Locally advanced^†^ | III | 30% | <5%^150^
Metastatic^†^ | IV | 50% | ~2%^193^

Abbreviations: AJCC=American Joint Committee on Cancer

* Clinical stage defined by likelihood of successful surgery. Surgical staging criteria generally overlap with TNM staging criteria, but take into account tumor involvement of major vessels in the upper abdomen, which affect the likelihood of completely resecting the tumor. The TNM Staging System is based on the extent of the tumor (T), the extent of spread to the lymph nodes (N), and the presence of metastasis (M).

† Surgery not recommended

‡ Depending on whether the tumor is completely resected

### Natural History and Prognosis

#### Early- and Late-Stage Pancreatic Adenocarcinoma

The prognosis of pancreatic adenocarcinoma depends largely on stage at diagnosis and whether the tumor can be surgically resected. Typically, resectable tumors include those where the tumor has not grown large enough to invade any major blood vessels. People with resectable cancers are recommended for primary curative surgery if they have a performance status and comorbidity profile capable of withstanding major abdominal surgery.^11^

According to the American Cancer Society, the average 5-year survival rate for patients with early stage disease is 32 percent,^4^ but this varies by whether people underwent surgery. Data from SEER and the National Cancer Database (NCDB) have shown that the median survival among people who underwent surgery ranged from 15 to 27 months.^12–17^ Among people who did not undergo surgery, median survival ranged from 3 to 8 months.^12–17^ All of these observational database studies may be limited by selection bias, where people who did not have surgery may have been sicker to begin with than people who did have surgery. Therefore, survival may not be directly comparable between people who do or do not undergo surgery for pancreatic cancer. One long-term SEER study estimated 10-year overall survival of 14,868 cases of invasive pancreatic adenocarcinoma (any stage) diagnosed between 1973–2009 and not treated with surgery at 1 percent.^18^

Survival among people with early stage disease also varies by patient age, tumor grade, extent of excision, and additional treatment received. A SEER study evaluated pancreatic adenocarcinoma survival stratified by AJCC stage and tumor grade.^19^ Among 8,082 people, all of whom had cancer-directed surgery, higher grade was an independent predictor of survival across all stages; low-grade stage I patients survived a median of 25 months compared with 17 months for high-grade stage I patients.^19^ A study of 19,031 people with stage I or II pancreatic adenocarcinoma from the NCDB, all of whom survived at least 90 days after surgical resection, showed that median survival was 17.6 months in the surgery-only group compared with 22.1 months in the group who underwent surgery plus adjuvant chemotherapy (p<0.001).^20^

Borderline resectable tumors may be treatable by surgery, but often are larger and close to major arteries, raising concerns that resection may be incomplete, thus leaving the patient with positive surgical margins or undetected microscopic metastases. These tumors may be recommended for preoperative therapy, such as chemotherapy, and then restaged before surgical planning.^11^ One study from the NCDB including 44,852 stage IIA-III patients diagnosed from 2004 to 2013 showed that 58 percent did not undergo surgical treatment.^21^ Median survival was 10.3 months for this group compared with 13.1 months for patients who did have surgery with negative surgical margins. Less than 7 percent of the total population received neoadjuvant therapy and median survival for this group was 23.2 months for those that had negative surgical margins, but these results may reflect selection bias.

People with locally advanced disease or metastatic disease generally are not recommended for curative surgery. A small proportion may still undergo palliative surgery; however, survival for these stages is poor overall regardless of treatment received. According to the American Cancer Society, the average 5-year survival rate for patients with regional disease is 12 percent.^4^ Half of all cases of pancreatic adenocarcinoma are diagnosed at a distant stage and the 5-year survival rate is 3 percent.^4^ A SEER study of 28,918 people with stage IV metastatic pancreatic adenocarcinoma showed that 1.6 percent underwent surgery, primarily people younger than 70 years, with smaller tumor sizes located in the head of the pancreas.^22^ The median survival times were 7 months for the group who underwent surgery and 2 months for the group who did not.

#### Potential Precursors to Pancreatic Adenocarcinoma

Diagnosing potential precursor lesions via screening is an active area of research because it has potential to reduce pancreatic cancer incidence; however, surgical treatment of these lesions also has the potential to increase harms. Precursor lesions to invasive pancreatic adenocarcinoma include pancreatic intraepithelial neoplasia (PanIN), intraductal papillary mucinous neoplasm (IPMN), and mucinous cystic neoplasm (MCN); these lesions are classified as low- or high-grade (high-grade also may be called carcinoma in situ).^23^ Typically, high-grade precursor lesions are considered for surgical intervention while low-grade lesions are observed.^24^ IPMN and MCN may co-occur with invasive carcinoma (2%–3% and 1% of all exocrine tumors, respectively).

Pancreatic intraepithelial neoplasia (PanIN) is a microscopic (<5mm) precursor lesion for pancreatic adenocarcinoma located in the pancreatic duct.^23,^ ^25,^ ^26^ PanIN lesions can exhibit papillary or flat growth with mucinous secretion.^23^ They are classified into one of four groups (PanIN-1A, PanIN-1B, PanIN-2, and PanIN-3) reflecting progression of histologic grade toward invasive cancer. A recently proposed classification system suggested reclassifying as 2 groups: low-grade (all except PanIN-3) and high-grade (PanIN-3 only, also referred to as carcinoma in situ).^23^ Two autopsy studies have shown carcinoma in situ may be found in a quarter of cases with pancreatic cancer (whether clinically known or detected on autopsy), but not in controls.^27,^ ^28^

PanIN lesions are difficult to detect on imaging due to their small size;^26,^ ^29^ lesions are often detected post-operatively, so preoperative screening, treatment, and surveillance strategies are unclear.^26^ One study of 152 people who had pancreatic surgery or biopsy for an indication other than pancreatic adenocarcinoma showed 82 (54%) had a PanIN lesion.^30^ A study of 584 people who underwent pancreatic resection for diagnoses other than adenocarcinoma or IPMN at a U.S. cancer center showed that 153 (26%) resected lesions had PanIN histology.^31^ After a median followup of 3 years in 134 of these individuals, only one person (with an initial PanIN-1B diagnosis) developed pancreatic adenocarcinoma. Long-term survival of people with PanIN lesions that do not progress to pancreatic adenocarcinoma is unknown.^31,^ ^32^

Intraductal papillary mucinous neoplasm (IPMN) is a larger (>10mm) precursor lesion for pancreatic adenocarcinoma characterized by papillary growth and mucinous secretion either in the side-branch pancreatic ducts or main pancreatic duct.^23,^ ^25,^ ^26^ A population-based study conducted in Olmsted County, Minnesota estimated the prevalence of IPMN as 26.0 cases per 100,000 persons (95% confidence interval, 14.5 to 37.4).^33^ Side-branch IPMNs have a lower subsequent malignancy rate (estimated between 1 and 25%) compared with main duct IPMNs (estimated between 40 and 50%).^34–38^ IPMNs can be classified as having low-grade, intermediate-grade, or high-grade dysplasia (also referred to as carcinoma in situ); they may also be associated with an invasive carcinoma.^23^ IPMN can be detected on imaging and may be preceded by symptoms similar to pancreatitis, including pain, diabetes, and weight loss; patients also may be asymptomatic.^39,^ ^40^

People with IPMN may be recommended for surgical treatment if they have additional high-risk features such as main duct involvement, cyst size ≥4cm, rapid changes in size over time, or an invasive component.^41,^ ^42^ People with IPMN without invasion may be recommended for regular imaging surveillance. One review suggested that 6 percent to 12 percent of asymptomatic, small, branch duct lesions enlarged or progressed to malignancy over an unspecified amount of time.^34^ A surveillance study of 577 people with branch duct IPMN found that 4.3 percent developed pancreatic adenocarcinoma within 5 years of IPMN diagnosis.^43^ An analysis of 136 people who underwent surgery for IPMN at a U.S. hospital between 1987–2003 found that 38 percent had IPMN associated with invasive carcinoma.^44^ Five-year survival rates were 77 percent for noninvasive IPMNs and 43 percent for IPMNs with invasive carcinoma. Four out of nine deaths in the noninvasive group were due to adenocarcinoma whereas all 21 deaths in the invasive group were from adenocarcinoma.

Unresected IPMN lesions may regress over time, but the evidence on regression is limited.^45^ One study showed that among 664 people with pancreatic cystic lesions (including IPMN), 15 (2.3%) decreased in size over a median follow-up of 33 months.^38^ A systematic review and meta-analysis of studies in people with IPMN who were not surgically treated showed malignant progression to invasive disease occurred in 11.4% of patients over follow-up durations ranging from 25 to 70 months.^46^ The IPMN-specific mortality rate (regardless of progression) was 23 per 1,000 person-years.

Mucinous cystic neoplasm (MCN) typically presents as a large (average 50mm or larger) solitary pancreatic cyst characterized by mucin-producing cells and a thick ovarian-like stroma with estrogen and progesterone receptors.^35,^ ^47–49^ MCN lesions are rarer than IPMN, with one study showing that among 851 resected pancreatic cystic neoplasms from a single U.S. hospital over 33 years, 23 percent were diagnosed as MCN compared with 38 percent as IPMN.^50^ Similar to IPMNs, MCNs are classified as low, intermediate-, or high-grade dysplasia (also referred to as carcinoma in situ) and up to one-third are associated with invasive carcinoma.^23,^ ^47,^ ^48^ MCN can be detected on imaging and can present with symptoms of abdominal pain, abdominal fullness, jaundice, and/or nausea; they also may be detected incidentally without symptoms.^35,^ ^47,^ ^51^ Approximately 95 percent of MCN diagnoses occur in women.^35,^ ^47–49^

Surgical treatment is recommended for all MCN lesions. People with MCN often have better prognosis than people with IPMN due to less aggressive tumor biology.^52,^ ^53^ In addition, 98 percent of MCN lesions occur in the tail of the pancreas (as opposed to the head) where distal pancreatectomy is less complex.^47–49^ The 5-year survival of MCN without associated invasive carcinoma is 100 percent, and additional surveillance following successful surgery is not recommended.^35,^ ^47^ For people with MCN with an invasive component, the 5-year survival is lower, at around 60 percent.^35,^ ^47,^ ^48^ The proportion of MCN lesions that progress to pancreatic adenocarcinoma and timeframe for progression are unclear.^35^

### Risk Factors

Based on data from 2013–2015, approximately 1.6% of people in the general population will be diagnosed with pancreatic cancer during their lifetime.^7^ Germline mutations, older age, family history, diabetes, and tobacco use are well-established risk factors; comorbid conditions such as chronic pancreatitis and obesity also increase risk for pancreatic adenocarcinoma.^54–57^

#### Genetic and Hereditary Factors

##### Family History

Approximately 5–10 percent of cases of pancreatic adenocarcinoma are familial with no known genetic mutations.^55–58^ According to one meta-analysis and one pooled analysis, having a positive family history for pancreatic adenocarcinoma (defined as having at least one first-degree relative with pancreatic adenocarcinoma in most studies) is associated with a relative risk (RR) of 1.8.^59,^ ^60^

##### Known Genetic Mutations

An estimated 3–5 percent of cases of pancreatic adenocarcinoma have inherited genetic mutations.^58^ Mutations in several genes are associated with the development of pancreatic adenocarcinoma, with risk ratios ranging from 3.5 for BRCA2 to 132 for Peutz-Jeghers syndrome.^55,^ ^61^

- Peutz-Jeghers Syndrome, caused by a mutation in the STK11/LKB1 gene
- CDKN2A/p16 mutations
- BRCA1 or BRCA2 mutations
- Hereditary pancreatitis caused by PRSS1 and/or SPINK1 mutations; CTFR mutations
- Lynch syndrome, caused by MLH1, MSH2, MSH6, or PMS2 germline mutations
- ATM mutations^55,^ ^56,^ ^61,^ ^62^

##### Ashkenazi Jewish Heritage

Ashkenazi Jewish individuals have an increased risk of pancreatic adenocarcinoma of with RRs of approximately 1.4^63^ to 1.8^64^ compared with non-Jewish people. These risk estimates may be even higher for Jewish people with one of several genetic mutations (BRCA1, BRCA2, MSH2, or MSH6).^65–67^ Eldridge et al., noted that the increased risk for pancreatic adenocarcinoma in Jewish individuals was not explained by other non-genetic risk factors such as smoking, obesity, and diabetes, and may be predominantly due to genetics.^63^ Individuals with BRCA1, BRCA2, or other high-risk genetic mutations may be recommended for pancreatic adenocarcinoma screening regardless of whether they are of Ashkenazi Jewish ancestry.

##### Hereditary Pancreatitis

Chronic pancreatitis may be hereditary if associated with one of several genetic mutations (PRSS1, SPINK1, and CTFR) and/or an incidence of disease within a family that is higher than one would expect by chance alone. Hereditary pancreatitis has been associated with RRs for pancreatic adenocarcinoma ranging from 50 to 80.^55^ Despite the high increased risk of pancreatic adenocarcinoma associated with pancreatitis, patients with hereditary pancreatitis account for a very small fraction of all cases of pancreatic adenocarcinoma.

#### Other Risk Factors

##### Age

Most cases of pancreatic adenocarcinoma occur in people over age 55.^7^

##### Chronic Pancreatitis

A history of chronic pancreatitis (inflammation of the pancreas that impairs one’s ability to digest food and produce hormones) has been associated with RRs for pancreatic adenocarcinoma ranging from 2.71 to 13.3.^68,^ ^69^ As opposed to acute pancreatitis, which often develops in response to pancreatic injury, chronic pancreatitis involves progressive inflammatory pancreas changes that can lead to permanent structural damage and impairment of exocrine and endocrine function.

##### Existing or New-Onset Diabetes

Diabetes has been studied the most and has been consistently associated with an increased risk of pancreatic adenocarcinoma across seven meta-analyses and seven pooled analyses.^56^ A 2011 meta-analysis with 20,410 cases of pancreatic adenocarcinoma from 35 cohort studies found a summary RR of 1.94 (95% CI, 1.66 to 2.27) associated with diabetes mellitus.^70^ Diabetes also appears to be associated with increased pancreatic adenocarcinoma mortality relative to people with pancreatic adenocarcinoma and no diabetes diagnosis.^71,^ ^72^

New onset diabetes in adulthood may be an early manifestation of pancreatic adenocarcinoma.^73,^ ^74^ In a U.S.-based case control study (510 cases, 463 controls), 15 percent of cases of pancreatic adenocarcinoma had developed new-onset diabetes less than 3 years before diagnosis compared to 3 percent of controls (Adjusted Odds Ratio 6.40; 95% CI, 3.37 to 12.2); a loss of more than 3 percent of body weight also was more common in cases versus controls (71% vs 7%, AOR 27.0; 95% CI, 17.1 to 42.6).^75^ A larger, United Kingdom-based case-control study found similar results in primary care patients: new-onset diabetes less than 2 years before pancreatic adenocarcinoma diagnosis appeared in 13.6 percent of cases and 6 percent of controls (AOR 2.46, 95% CI, 2.16 to 2.80).^76^

##### Tobacco Use

Smoking is the most well-established modifiable risk factor for pancreatic adenocarcinoma. A 2014 review and meta-analysis showed that the relative risk for pancreatic adenocarcinoma associated with any current cigarette use ranged from 1.5 to 2.2.^56^ Relative risk estimates varied by dose in several studies,^77–79^ with one study showing an RR of 1.2 (95% CI, 1.2 to 1.3) among people who smoked 5 cigarettes per day to 2.0 (95% CI, 1.7 to 2.2) among people who smoked 40 cigarettes per day.^78^ The association with history of tobacco use or smokeless tobacco use is less certain. Former cigarette use was associated with an increased risk of pancreatic adenocarcinoma in some studies but not all. Smokeless tobacco was associated with an RR for pancreatic adenocarcinoma of 1.6 (95% CI, 1.1 to 2.2) in one study,^80^ but not in others.^81,^ ^82^

##### Obesity

According to several meta- and pooled-analyses, obesity, as measured by BMI ≥30 kg/m^2^, has been associated with an increased RR for pancreatic adenocarcinoma ranging from 1.19 to 1.47.^83–86^ Several studies have shown a dose-response relationship between BMI and pancreatic adenocarcinoma risk, with the highest risk estimates for people in BMI categories above 35 kg/m^2^.^84,^ ^85^ A large cohort study demonstrated that obese patients undergoing bariatric surgery had a reduced risk of pancreatic cancer (hazard ratio 0.46, 95% CI, 0.22 to 0.97) compared to BMI- and comorbidity-matched people who did not undergo surgery.^87^ Obesity also may be associated with increased risk of pancreatic adenocarcinoma mortality,^88^ with a dose-response relationship associated with obesity in adulthood in one meta-analysis^89^ and one pooled analysis of case-control studies.^90^

##### Other Modifiable Risk Factors

Diet, alcohol, additional medical conditions, and certain types of medication may be associated with pancreatic adenocarcinoma risk.^54,^ ^56^ Red meat, processed meat, and elevated sugar intake may be associated with a moderately increased risk (RR 1.1 to 1.4) of pancreatic adenocarcinoma.^56^ Drinking more than 3 glasses of any alcoholic beverages per day may increase pancreatic adenocarcinoma risk by 20 percent.^56^ A meta-analysis of 19 prospective cohort studies including data on more than 4 million people found that high (≥24g per day)—but not low or moderate—alcohol consumption was associated with increased risk for pancreatic adenocarcinoma (RR 1.15; 95% CI, 1.06 to 1.25).^91^ Several meta-analyses showed Helicobacter pylori infection was associated with increased risk of pancreatic cancer with RRs ranging from 1.28 to 1.65.^56^ The use of antidiabetic drugs other than metformin (e.g. insulin and sulfonylurea) may be associated with a moderate increased risk of pancreatic adenocarcinoma (RR 1.5 to 1.9), whereas metformin has been associated with a reduced risk (RR 0.5 to 0.9).^56^ Statin use may reduce risk for pancreatic adenocarcinoma and reduce mortality.^92,^ ^93^ Aspirin use was associated with reduced risk for pancreatic adenocarcinoma in one study.^94^

### Screening for Pancreatic Cancer

Currently, only a fraction of incident cases of pancreatic adenocarcinoma are detected at resectable (9%) or borderline resectable (10%) stages.^7^ Screening for pancreatic adenocarcinoma could detect more cancer at a stage where resection is possible, and improve survival through surgical resection. By this same reasoning, screening also could improve quality of life and limit harms associated with chemotherapy.

#### Imaging-Based Screening

Several imaging tests are used to detect pancreatic adenocarcinoma, including endoscopic ultrasonography (EUS), endoscopic retrograde cholangiopancreatography (ERCP), magnetic resonance imaging (MRI), magnetic resonance cholangiopancreatography (MRCP), abdominal ultrasonography, and computed topography (CT). EUS and MRI are considered the most accurate of these imaging tools, which are used primarily for diagnostic testing. However, they may also have a role in screening for people at high risk of pancreatic adenocarcinoma, such as those with known genetic mutations or a family history of pancreatic adenocarcinoma.^95,^ ^96^

- Endoscopic ultrasonography (EUS) examines the upper and lower gastrointestinal tract, including the pancreas, via insertion of a small tube with an ultrasound probe through the mouth and down into the stomach. Tissue can be sampled during EUS via fine needle aspiration (FNA) to evaluate lesions for malignancies and subsequent staging.^97^ Endoscopic retrograde cholangiopancreatography (ERCP), a procedure that combines endoscopy with X-rays, can be used as a diagnostic tool.^95^ The International CAPS Consortium discourages the use of ERCP as a screening tool because of risk for post-ERCP acute pancreatitis.^95^
- Magnetic resonance imaging (MRI) allows for imaging of the entire abdomen and pelvis. It does not involve exposure to ionizing radiation and is less invasive than EUS, but cannot sample tissue so may require a separate biopsy procedure, which is invasive and carries risks.^98^ Magnetic resonance cholangiopancreatography (MRCP) also does not involve radiation exposure and is a non-invasive alternative to ERCP for imaging pancreatic ductal anatomy for suspicious lesions.^98^
- Computed topography (CT) for pancreatic adenocarcinoma often involves the use of a contrast dye, given by mouth or injection. CT scans are associated with potential harm from radiation exposure. They are used for diagnosis, tumor staging, and determining resectability.^9,^ ^98^

#### Biomarker-Based Screening

Despite an expanding literature on biomarkers and their potential diagnostic accuracy, there are currently no validated biomarkers for early detection of pancreatic adenocarcinoma.^99–104^

CA 19-9 has long been considered the best single candidate for a screening biomarker for early detection. CA 19-9 is elevated in the serum of people with pancreatic adenocarcinoma and may be used clinically as a prognostic tool in pancreatic cancer management for some patients.^105^ However, its limited sensitivity and specificity have limited its usefulness as a screening method. A meta-analysis found the median sensitivity and specificity of CA 19-9 for the detection of pancreatic adenocarcinoma to be 75.5 percent and 77.6 percent, respectively, with positive predictive value of 0.5 percent to 0.9 percent.^106^

Other potential single biomarker tests include carcinoembryonic antigen (CEA), which is used in the management of several gastrointestinal cancers, but lacks accuracy to support its use as a screening test.^105^ Cell-surface proteins, 283 proteins according to one estimate,^96^ are also overexpressed in pancreatic adenocarcinoma, but discriminatory abilities of these proteins in detecting pancreatic adenocarcinoma are largely unknown.

Micro-RNA patterns from circulating exosomes; hypermethylation of specific genes in circulating DNA (e.g., BNC1, ADAMST1, NPTX2, ppENK, p16, or CDKN2a);^107^ and detection of circulating tumor cells are potential emerging biomarkers.^96,^ ^108^ Mutated DNA and biomarkers may be detected in pancreatic juice,^109–111^ a liquid secreted by the pancreas which contains various enzymes.^112^

Multiple-biomarker panels may have the highest potential as a noninvasive screening test for pancreatic adenocarcinoma, given the heterogeneity of tumor types and the limited accuracy of any single biomarker.^96,^ ^113,^ ^114^ For example, a CA 19-9-based multiple biomarker panel was found to discriminate early-stage pancreatic adenocarcinoma from healthy controls with an area under the curve (AUC) of 0.89 (95% CI, 0.82 to 0.95) for all early-stage cancer (p=0.03) compared to CA 19-9 alone.^115^ Other studies have also found promising results, finding AUCs above 0.9 for multiple biomarker panels.^116,^ ^117^ Most biomarker-based screening would require serum-based testing; however, stool- or saliva-based testing also have been explored.^99,^ ^118,^ ^119^

### Treatment Approaches

There are no known interventions to prevent pancreatic adenocarcinoma. Tobacco cessation or avoidance, healthy diet, and regular exercise may reduce modifiable risk for pancreatic adenocarcinoma along with several other cancers and chronic diseases.

Current treatment recommendations include surgery for early stage cancers (currently about 20% of all new cases), chemotherapy, and radiation (Table 2).

Table 2 Treatment Recommendations for Pancreatic Cancer by Clinical and AJCC Stage

Clinical stage^57,*^ | AJCC stage | Chemotherapy recommendations | Radiation recommendations
Resectable | I/II | Neoadjuvant chemotherapy with high risk profile^†^ with or without adjuvant chemotherapy for 6 months.; 6 months’ adjuvant chemotherapy for all others. | Concurrent with chemotherapy in patients with no neoadjuvant therapy and who have positive margins or node-positive disease
Borderline resectable | II/III | Neoadjuvant chemotherapy or adjuvant chemotherapy for total of 6 months. | Concurrent with chemotherapy in patients with no neoadjuvant therapy and who have positive margins or node-positive disease
Locally advanced - not recommended for surgery | III | Adjuvant chemotherapy for patients with favorable comorbidity profile | Concurrent with chemotherapy in patients who do not develop metastatic disease during initial treatment
Metastatic - not recommended for surgery | IV | Palliative chemotherapy | Palliative radiation therapy

Abbreviations: AJCC=American Joint Committee on Cancer

* Clinical stage defined by likelihood of successful surgery. Surgical staging criteria generally overlap with TNM staging criteria, but take into account tumor involvement of major vessels in the upper abdomen, which affect the likelihood of completely resecting the tumor. The TNM Staging System is based on the extent of the tumor (T), the extent of spread to the lymph nodes (N), and the presence of metastasis (M).

† High risk profile can include people with poor performance status or comorbid conditions that may put them at high risk for abdominal surgery complications; people with high CA 19-9 levels

Surgical resection is the only treatment for pancreatic adenocarcinoma that offers a potential cure, but only people with non-metastatic disease are eligible for surgery.^120^ Pancreatic cancers eligible for surgical treatment are generally classified as “resectable” or “borderline resectable” based on the likelihood of complete surgical resection.^57^ Surgical options include a pancreaticoduodenectomy (a Whipple procedure), which removes the head of the pancreas, gallbladder, bile duct, and parts of the stomach and small intestine; a total pancreatectomy, which removes the whole pancreas, bile duct, gallbladder, spleen, nearby lymph nodes, and parts of the stomach and small intestine; and a distal pancreatectomy, which removes the body and tail of the pancreas as well as the spleen.

Any type of surgical resection for pancreatic adenocarcinoma carries significant morbidity (complication rates 20%–50%) and peri-operative mortality risks (1%–8%).^121^ Patients typically require a 1–3 week post-operative hospital stay and 3–6 months for full recovery.^122^ Complications can include fistula or leakage, delayed gastric emptying, acute pancreatitis, sepsis, and infection.^123,^ ^124^ Since complication rates are lower at high-volume centers, the National Comprehensive Cancer Network (NCCN) recommends pancreatic resections be done at institutions that perform at least 15–20 resections annually.^120^

Despite the favorable impact of surgical intervention on survival for people with early stage pancreatic adenocarcinoma, many patients still do not undergo surgery. In one National Cancer Data Base (NCDB) study (n=9559), 38 percent of people with resectable tumors (stage I only) diagnosed between 1995–2004 were never offered surgery.^16^ A more recent analysis of SEER data (n=6742) found that only 25 percent of people with localized pancreatic adenocarcinoma (excluding anyone with blood vessel or lymph node invasion) underwent surgery between 1988 and 2010, with no change in this proportion over time.^12^ People treated at community hospitals are much less likely to undergo surgery or chemotherapy treatment.^14,^ ^15^

### Current Clinical Practice and Recommendations of Others

No organizations currently recommend population-based screening for pancreatic adenocarcinoma. Screening for pancreatic adenocarcinoma detection in people with known genetic mutations or strong family history is recommended by several organizations (Table 3). Several countries maintain screening programs for people at high risk for pancreatic adenocarcinoma. For example, Denmark has a national screening program for residents with hereditary pancreatitis or a family history of pancreatic adenocarcinoma;^125^ the Netherlands has screening program for people with a family history of pancreatic adenocarcinoma, carriers of known genetic mutations associated with hereditary syndromes, and people with Peutz-Jeghers syndrome;^126^ and the Canadian province of Ontario has a screening program for people with a family history of pancreatic adenocarcinoma, carriers of known genetic mutations, people with Peutz-Jeghers syndrome, and people with hereditary pancreatitis.^127^ Germany, Sweden, and Spain all have national familial pancreatic adenocarcinoma registries with screening recommendations for people aged 18 and older.^128–130^

Table 3 Recent Recommendations of Other Groups on Screening for Pancreatic Cancer

Organization Country Year | Recommendation
American Academy of Family Physicians^194^; U.S.; 2016 | Adopted USPSTF recommendation against routine screening for pancreatic cancer in asymptomatic adults using abdominal palpation, ultrasonography, or serologic markers.
American Cancer Society^2^; U.S.; 2016 | Does not include screening for pancreatic cancer among its cancer screening guidelines. ACS states, “At this time, no major professional groups recommend routine screening for pancreatic cancer in people who are at average risk. This is because no screening test has been shown to lower the risk of dying from this cancer.”^195^
American College of Gastroenterology^196^; U.S.; 2015 | Recommends individuals be considered at risk for hereditary pancreatic cancer if they:; - Have a known genetic syndrome associated with pancreatic cancer;; - Have two relatives (including one first-degree relative) with pancreatic cancer;; - Have three or more relatives with pancreatic cancer; or; - Have a history of hereditary pancreatitis.; ACG also provides recommendations on the genes that should be considered during genetic testing of patients with suspected hereditary pancreatic cancer. According to ACG, due to the low incidence and prevalence of pancreatic cancer, it is not cost-effective to screen an asymptomatic general population.
Royal Australian College of General Practitioners^197^; Australia; 2016 | Does not include screening for pancreatic cancer among its published guidelines on early detection of cancers
National Institute for Health and Care Excellence (NICE)^181^; U.K.; 2015 | Recommends using a suspected cancer pathway referral (for an appointment within 2 weeks) to refer people for pancreatic cancer if they are aged 40 and over and have jaundice.; Recommends consideration of an urgent direct access CT scan (within 2 weeks) or an urgent ultrasound scan to assess for pancreatic cancer in people aged 60 and over with weight loss and one of the following: diarrhea, back pain, abdominal pain, nausea, vomiting, constipation, or new onset diabetes.; NICE also has issued recommendations calling for further research on the diagnostic accuracy of tests available in primary care for suspected pancreatic cancer,^198^ as well as the predictive value of symptoms for pancreatic cancer.^199^
European Society for Medical Oncology^200^; Europe; 2015 | Describes risk factors for pancreatic cancer, including:; - Genetic mutations in BRCA2, p16, ATM, STK11, PRSS1/PRSS2, SPINK1, PALB2, and DNA mismatch repair genes;; - Family history of pancreatic cancer; and; - Tobacco smoking, obesity, alcohol consumption, chronic pancreatitis.; Emphasizes the importance of screening high-risk individuals before symptoms arise, but does not provide an explicit recommendation or guideline for or against screening.
Cancer Research UK^201^; U.K.; 2014 | No recommendation to screen for pancreatic cancer. States, “At the moment, there is no screening test reliable enough to use for pancreatic cancer in people at average risk.”
Japan Pancreas Society^202^; Japan; 2013 | States there is scientific evidence to support the following recommendations (“Grade B” recommendations):; - Patients should undergo further examination to detect pancreatic cancer if they have more than one of the following risk factors:; - Family history of pancreatic cancer or hereditary pancreatic cancer syndrome;; - Accompanying diseases such as diabetes mellitus, chronic pancreatitis, hereditary pancreatitis, intraductal papillary mucinous neoplasm, pancreatic cysts, or obesity; and; - Lifestyle habits such as tobacco use or heavy drinking.; - Patients should undergo further examination to detect pancreatic cancer if they have unexplainable abdominal pain, back pain, jaundice, body weight loss, early-onset diabetes mellitus, or deterioration of diabetes mellitus.; - Ultrasound should be used as the first screening exam for pancreatic cancer.
International Cancer of the Pancreas Screening (CAPS) Consortium^95^; International; 2012 | Recommends against screening in the general population. However, members recommend screening in the following high-risk groups:; - Individuals with 2 or more blood relatives (including at least one first-degree relative) with pancreatic cancer;; - Carriers of p16, BRCA2, and hereditary non-polyposis colorectal cancer (HNPCC) mutations with a first-degree relative with pancreatic cancer; and; - All individuals with Peutz-Jeghers syndrome.
Italian Registry for Familial Pancreatic Cancer^128^; Italy; 2010 | Recommends annual screening with EUS +/- MRI in the following high-risk groups starting at age 45 or 15 years earlier than the earliest occurrence of PDAC in the family:; - Those with ≥3 FDRs, SDRs, or TDRS with PDAC in the same lineage;; - Those with BRCA2, BRCA1, or p16 variants with ≥1 FDR or SDR with PDAC;; - A verified germline carrier of a Peutz-Jeghers syndrome kindred;; - Those with ≥2 relatives in the same lineage affected with PDAC, at least one of whom is an FDR;; - Those with hereditary pancreatitis;; - Those with a ≥10-fold elevated risk of developing pancreatic cancer based on the PancPRO software.^187^
International Symposium of Inherited Diseases of the Pancreas^203^; International; 2007 | Recommends screening in individuals with ≥10-fold elevated risk of developing pancreatic cancer, including:; - FAMMM kindreds with p16 variant and ≥1 case of PDAC in a FDR or SDR;; - Those with Peutz-Jeghers syndrome;; - Those with hereditary pancreatitis;; - Those with ≥3 FDRs, SDRs, or TDRs with PDAC; and; - Possibly those with BRCA2 or BRCA1 variants with ≥1 case of PDAC in a FDR or SDR.; There was no consensus on a screening test, initiation age, or screening interval.

Abbreviations: USPSTF = U.S. Preventive Services Task Force; PDAC = pancreatic ductal adenocarcinoma; FAMMM = familial atypical multiple mole melanoma; FDR = first-degree relative; SDR = second-degree relative; TDR = third-degree relative

Cancer programs in the U.S. also may refer family members of pancreatic adenocarcinoma patients for further evaluation, typically by multidisciplinary teams. U.S. registries for individuals at high risk of pancreatic adenocarcinoma include programs based at Johns Hopkins University,^131^ Memorial Sloan-Kettering Cancer Center,^132^ Columbia University Medical Center/New York Presbyterian Hospital,^133^ University of Washington,^134^ Oregon Health and Science University,^135^ the Mayo Clinic,^136^ University of Nebraska Medical Center^137^ Thomas Jefferson University Hospital/Sidney Kimmel Cancer Center.^138^

## Previous USPSTF Recommendation

In 1996 and again in 2004, the USPSTF recommended against routine screening for pancreatic cancer in asymptomatic adults using abdominal palpation, ultrasonography or serologic markers (D recommendation).^1,^ ^139^

In its 2004 recommendation, the USPSTF concluded there was no evidence that screening for pancreatic cancer is effective in reducing mortality, and that the harms of screening exceeded any potential benefit.^1^ They concluded that there is a potential for significant harm because of the very low prevalence of pancreatic adenocarcinoma, limited accuracy of available screening tests, the invasive nature of diagnostic tests, and the poor outcomes of treatment.

The USPSTF noted in clinical considerations an interest in primary prevention of pancreatic cancer, including tobacco cessation and dietary measures, but that the evidence for diet-based prevention of pancreatic cancer is limited and conflicting.

The brief evidence review supporting the 2004 recommendation did not publish an analytic framework or inclusion and exclusion criteria. The search included systematic reviews, meta-analyses, randomized clinical trials, cost-effectiveness analyses, editorials, and commentaries, but did not include observational studies. This review noted gaps in evidence for the benefit or harm of identifying and screening high-risk groups, including the potential use of tumor markers in screening, and ongoing randomized clinical trials exploring treatment for pancreatic adenocarcinoma.^140^