# Appendix E Ongoing Studies

According to ClinicalTrials.gov there are 823 trials on pancreatic cancer in adults that currently do not have results and are either: recruiting, not yet recruiting, active, and enrolling by invitation. Of those 823, 7 studies mention screening. They are described in the table below by expected completion date (most recent first). The table below also includes a planned cohort study that does not yet have an entry in ClinicalTrials.gov.

NCT # | Title | Recruitment | Conditions | Interventions | Primary Outcome Measures | Sponsor/Collaborators | Enrollment | Funded By | Study Designs | Start Date | Completion Date | URL
N/A | The New-Onset Diabetes (NOD) Cohort Study | Not yet recruiting | Pancreatic cancer | Blood collection | Prevalence of pancreatic cancer in patients with new-onset diabetes | National Cancer Institute; National Institute of Diabetes and Digestive and Kidney Diseases | 10,000 | NCI | Observational Cohort Prospective | Not yet started | Not yet determined | N/A
NCT01662609 | Protocol for High-Risk Assessment, Screening, and Early Detection of Pancreatic Cancer | Active, not recruiting | Pancreatic Cancer | Procedure: Endoscopic Ultrasound (EUS) | Number of Abnormalities Detected by EUS | H. Lee Moffitt Cancer Center and Research Institute | 90 | Other | Observational Case-Only Prospective | Jun 2007 | Dec 2019 | https://ClinicalTrials.gov/show/NCT01662609
NCT02703545 | International CAPS Registry: Pancreas Cancer Cases in Surveillance Programs (CAPS Registry) | Enrolling by invitation | Pancreas Cancer | None | Proportion of patients and resected lesions with pancreatic cancer in situ (high grade dysplasia) or invasive malignancy^a^ | Johns Hopkins University | 100 | Other | Observational Case-Control Prospective | Feb 2014 | Jul 2020 | https://ClinicalTrials.gov/show/NCT02703545
NCT02478892 | Screening for PDAC in BRCA1/2 Patients | Recruiting | Pancreatic Cancer | Device: prophylactic endoscopic ultrasound | Identifying pancreatic neoplastic lesions in patients with BRCA1/2 mutations^b^ | Abramson Cancer Center of the University of Pennsylvania | 200 | Other | Observational Cohort Prospective | May 2015 | May 2020 | https://ClinicalTrials.gov/show/NCT02478892
NCT02000089 | The Cancer of the Pancreas Screening-5 (CAPS5) Study | Recruiting | Pancreas Cancer | Drug: Human synthetic secretin | Evaluate pancreatic juice for early cancer markers | Johns Hopkins University ChiRhoClin, Inc. | 2500 | Other\|Industry | Observational Cohort Prospective | Jan 2014 | Dec 2023 | https://ClinicalTrials.gov/show/NCT02000089
NCT03250078 | A Pancreatic Cancer Screening Study in High Risk Individuals Including Those with New-Onset Diabetes Mellitus | Recruiting | Pancreatic Neoplasms | Diagnostic Test: MRI/MRCP | Early Stage Pancreatic Cancer or Precursor Lesions | Western Connecticut Health Network | 800 | Other | Observational Cohort Prospective | Nov 2016 | Nov 2023 | https://ClinicalTrials.gov/show/NCT03250078
NCT02078245 | Quality Control Study of MR Based Screening of Individual with Increased Risk for Pancreas Cancer. | Recruiting | Hereditary Pancreatitis Hereditary Pancreatic Cancer | Other: MRI | MRI accuracy and outcome of surveillance program | Karolinska University Hospital | 100 | Other | Observational Other Prospective | Aug 2010 | Jan 2025 | https://ClinicalTrials.gov/show/NCT02078245
NCT02309632 | Pancreatic Cancer Screening of High-Risk Individuals in Arkansas | Active, not recruiting | Pancreatic Neoplasms^c^ | Pancreatic Cancer Screening Pathway | Detection rate of PC and precancerous lesion | University of Arkansas | 100 | Other | Non-Randomized Intervention Parallel Assignment | Nov 2015 | Nov 2026 | https://ClinicalTrials.gov/show/NCT02309632

a Additional outcomes: Proportion of specific types of pancreatic neoplasms by lesion type; Incidence of pancreatic in-situ and invasive malignancy after baseline screening; All-cause and disease specific mortality; Survival time from point of diagnosis and treatment

b Additional outcomes: Other less common, but related mutations (ATM, PALB2) as well as mutations identified in the future.

c Additional conditions: Peutz-Jeghers Syndrome; BRCA1 Gene Mutation; BRCA2 Gene Mutation; Ataxia Telangiectasia; Familial Atypical Mole-Malignant Melanoma Syndrome; Colorectal Neoplasms, Hereditary Nonpolyposis; Hereditary Pancreatitis

d Additional conditions: Peutz-Jeghers Syndrome (PJS); Gene Mutation; Germline Mutation Carrier; Lynch Syndrome