# Appendix D Additional Screening Study Information

Appendix D Table 1 Narrative Description of Screening Programs and High-Risk Populations

Screening Program | Screening program procedures | Definition of increased risk for PDAC
Barnes, 2018; U.S.; Fair | Recruitment: Eligible patients were high-risk individuals referred by a genetic counselor, treating physician, or patient self-referral to the Greater Midwest Pancreatic Cancer Screening Clinic at Froedtert Hospital and the Medical College of Wisconsin. Patients provided a detailed three-generation family history, and genetic counseling and testing was offered to patients with a pedigree suggestive of a hereditary cancer syndrome. Patients with a history suggestive of familial pancreatic cancer received 5-year and lifetime risk estimates for pancreatic cancer using the CancerGene PancPRO software.; Initial screen: Baseline evaluation involved MRI, a medical history and physical exam, and measurement of serum creatinine, glycohemoglobin, vitamin D 25-hydroxy, CEA, and CA 19-9.; Diagnostic workup: Those with suspicious lesions on MRI were referred for EUS. During the EUS procedure, FNA was performed at the discretion of the endoscopist during the same sedation, with on-site cytopathologic review of the specimens. If abnormalities were observed, patients were presented at a multidisciplinary pancreatic cancer conference and managed according to the consensus of the clinical team, including referral to surgery if necessary.; Blinding: Gastroenterologists who performed EUS had knowledge of MRI results.; Surveillance: Repeat screening was recommended annually (for those with negative findings on initial screen), or by consensus of the multidisciplinary PC conference (for those with abnormalities on screening).; Harms and outcomes: The study does not report any screening-related harms, clinical followup of PDAC cases, or surgical harms. | Adults age ≥50 or within 10 years of youngest affected relative who had (a) ≥3 relatives with PDAC, including ≥1 FDR; or (b) 2 FDRs with PDAC; or (c) 1 FDR and 1 SDR with PDAC and PancPRO risk ≥5%; or (d) PJS; or (3) BRCA1, BRCA2, PALB2, ATM, CDKN2A, or Lynch syndrome with 1 FDR or SDR with PDAC
Gangi, 2018; U.S.; Fair | Recruitment: Eligible patients were high-risk individuals referred by physicians at Florida s Moffitt Cancer Center or the Lifetime Cancer Screening and Prevention Center, physicians in the community, or by patient-self-referral. Referred patients completed a self-reported risk factor questionnaire.; Initial screen: Baseline evaluation involved EUS.; Diagnostic workup: Those with a mass or cyst ≥1 cm on EUS underwent FNA during the same procedure with the aid of a cytopathology technician in the endoscopy suite. If FNA results were consistent with cancer, patients underwent standard workup and cancer staging of with radiology studies and surgical and/or oncologic evaluation.; Blinding: NR; Surveillance: Those with negative findings on initial screen underwent repeat EUS screening annually for 5 years. Those with lesions <1cm on initial screen underwent repeat EUS at 3 months; if lesions were unchanged, patients underwent repeat MRI/MRCP at 6 months followed by annual MRI/MRCP. Those with benign or indeterminate FNA results underwent a CT scan; if CT scans were indeterminate, patients underwent repeat EUS at 3 months.; Harms and outcomes: The study does not report any screening-related harms, clinical followup of PDAC cases, or surgical harms. | Adults age ≥40 or within 10 years of youngest affected relative who had (a) ≥2 relatives with PDAC, including ≥1 FDR; or (b) PJS and age >30; or (c) HP; or (d) FAMMM; or (e) BRCA2 and ≥1 FDR or SDR with PDAC
Harinck, 2016; Dutch FPC Study; Netherlands; Fair | Recruitment: Eligible patients were asymptomatic high-risk individuals who were evaluated and recruited by clinical geneticists at 5 participating centers in the Netherlands (Erasmus MC-University Medical Center Rotterdam, Academic Medical Center Amsterdam, University Medical Center Groningen and the Netherlands Cancer Institute-Antoni van Leeuwenhoek Hospital). Geneticists verified patient eligibility based on detailed personal and family history, reviewing medical and pathological records for patients and family members, and reviewing genetic test information.; Initial screen: Baseline evaluation involved EUS and MRI.; Diagnostic workup: If lesions (clinically relevant or of unknown significance) were detected on EUS, a case description and video recording was sent to endosonographers for independent review. Final decision-making and further management was made by a multidisciplinary team of gastroenterologists, surgeons and radiologists. Those with solid lesions suspicious for malignancy, cystic lesions with malignancy or >30mm, or main branch IMPN with main pancreatic duct ≥10mm were recommended for surgery.; Blinding: Participating gastroenterologists and radiologists were blinded to the baseline results of EUS or MRI.; Surveillance: Repeat screening was recommended annually (for those with negative findings on initial screen), in 3 months (for those with lesions of unknown significance), and in 6 months (for those with cysts or side-branch IPMN with diameter 10–30mm without malignant features).; Harms and outcomes: Psychosocial screening-related harms were assessed by questionnaires for all patients at baseline, after explanation of study procedures, after initial screening, and after followup screening at 12 months. The study reports that no screening procedure-related harms occurred, but does not report whether such harms were assessed systematically for all patients. The study reports clinical follow-up information, including survival, for screen-detected PDAC cases. The study does not report surgical harms. | Asymptomatic adults age ≥45 (age ≥30 for PJS patients) or within 10 years of youngest relative with PDAC, and (a) with CDKN2A variant; or (b) with confirmed PJS; or (c) with BRCA1, BRCA2, p53 or mismatch repair gene and family history of PDAC in ≥2 affected relatives; or (d) FDRs of patients with FPC^b^
Joergensen, 2016; Danish National Screening Program; Denmark; Fair | Recruitment: Eligible patients were high-risk individuals who were (a) identified from previous population-based study that recruited from a hereditary pancreatitis registry and clinician referral (HP group); or (b) referred from clinical genetics departments across Denmark. The study does not specify how patients were invited to participate.; Initial screen: Baseline evaluation involved EUS (two subjects underwent annual US due to severe claustrophobia) and measurement of CA19-9 and Hba1C.; Diagnostic workup: Those with suspicious masses on EUS underwent FNA. If FNA identified potential malignancy or dysplasia, diagnostic laparoscopic US with or without biopsy was performed. Those with suspected or confirmed malignancy or dysplasia were referred to surgery.; Blinding: NR; Surveillance: Those with suspected lesions but negative biopsy results underwent control EUS. All patients who screened negative remained in surveillance and continued receiving annual EUS and CA 19-9 testing.; Harms and outcomes: The study reports that no screening procedure-related harms occurred, but does not report whether such harms were assessed systematically for all patients. Psychosocial screening-related harms were not assessed or reported. The study reports clinical followup information, including survival and surgical harms, for screen-detected PDAC cases. | Adults age ≥30 who were able to endure a pancreatic resection and who met criteria for (a) HP^c^; or (b) FPC^d^
Del Chiaro, 2015; Sweden; Fair | Recruitment: Eligible patients were high-risk individuals who were (a) relatives of patients treated for PDAC at Karolinska University Hospital; (b) referred from other Swedish centers; or (c) referred by general practitioners. The study does not specify how patients were invited to participate.; Initial screen: Baseline evaluation involved personal and family medical history, clinical exam, genetic testing (for BRCA1, BRCA2, and p16), and MRI.; Diagnostic workup: Those with abnormalities on MRI (solid nodules and suspected IPMN lesions) underwent EUS +/- FNA and/or CT scan. Every patient with a positive finding on screening was discussed at a multidisciplinary conference. Those with suspected cancer or premalignant lesions were referred for surgery.; Blinding: NR; Surveillance: Patients who screened negative on initial MRI were rescreened after 1 year using the same screening protocol. Those with unspecified findings or IPMN without indication for surgery were recommended for a 6-month followup MRI.; Harms and outcomes: The study does not report any screening-related harms, clinical followup of PDAC cases, or surgical harms. | Adults age ≥45 or within 10 years of youngest relative with PDAC who (a) had 2 relatives (≥1 FDR) in the same lineage with PDAC; or (b) had ≥3 relatives (FDRs, SDRs or TDRs) in the same lineage with PDAC; or (c) had BRCA1, BRCA2, or p16 variant and 1 FDR or SDR with PDAC; or (d) were verified germline carriers of PJS kindreds.
Al-Sukhni, 2012; Toronto Screening Program; Canada; Fair | Recruitment: Eligible participants were asymptomatic members of FPC kindreds identified through (a) the clinic-based Familial Gastrointestinal Cancer Registry; (b) the population-based Ontario Pancreas Cancer Study at Mount Sinai Hospital in Toronto; (c) the Familial Breast Cancer Research Unit at Princes Margaret Hospital; (d) the Familial Breast Cancer Clinics at Mount Sinai Hospital and Sunnybrook Regional Cancer Center; (e) a polyposis database with PSJ information; (f) self-referral; (g) physician referral; or (h) local genetics centers. All were contacted by mail with an invitation letter.; Initial screen: Prior to the first appointment, participants underwent genetic counseling and completed a baseline personal history and psychosocial questionnaire. Initial screening and subsequent annual screening involved MRI, meeting with a genetic counselor, and providing a blood sample.; Diagnostic workup: Those with abnormalities on MRI (pancreatic mass, duct dilation suggesting IPMN, or extra-pancreatic mass or lesions) underwent followup MRI plus CT, EUS, and/or ECRP within 3–6 months. Abnormal findings on followup testing were reviewed by a hepatobiliary surgeon and a radiologist specialized in abdominal imaging, and surgery was recommended if malignancy or dysplasia were suspected.; Blinding: NR; Surveillance: All patients, including those who screened negative on initial screening and those who had surgery but did not have invasive cancer, were followed as part of the annual screening protocol.; Harms and outcomes: Psychosocial screening-related harms were assessed by questionnaires mailed to all patients 3 months and 12 months after baseline. Screening procedure-related harms were not assessed or reported. The study reports clinical follow-up information, including survival, for screen-detected PDAC cases. No surgical harms were assessed or reported. | Asymptomatic adults who: (a) were FDRs or SDRs of a PDAC patient in a family with ≥2 PDAC patients in the same lineage; or (b) had p16 or STK11 variants; or (c) had BRCA1 or BRCA2 variants and ≥1 blood relative with PDAC; or (d) had a clinical diagnosis of HP or PJS
Canto, 2012; CAPS3; U.S.; Fair | Recruitment: Eligible patients were asymptomatic high-risk individuals identified by participating sites (Johns Hopkins Hospital, Mayo Clinic, UCLA, Dana Farber Cancer Institute, MD Anderson Cancer Center) or through websites (for the CAPS 3 study, Lustgarten Foundation, and clinicaltrials.gov). The study does not specify how patients were invited to participate.; Initial screen: Baseline evaluation involved screening by MRI/MRCP, CT, and EUS. EUS was performed last to enable FNA for any lesions detected by any of the 3 tests.; Diagnostic workup: Those with abnormalities (pancreatic duct dilation) on any of the 3 initial screening tests underwent FNA as part of the EUS procedure. ERCP also was performed at the discretion of the clinical team. Those with suspected pancreatic neoplasms were referred for surgery.; Blinding: Participating gastroenterologists and radiologists were blinded to the results of the other imaging tests.; Surveillance: All patients were followed for a minimum of 1 year from baseline. Surveillance screening occurred at 3 months for those with worrisome lesions but no resection scheduled; at 6–12 months for those with small cysts or non-worrisome lesions; and at 1–3 years for those with normal pancreas or pancreatitis-like abnormalities.; Harms and outcomes: The study does not report any assessment of screening-related harms. The study assessed surgical harms for those who underwent surgery for precursor lesions. No PDAC cases were detected. | Adults age 40–80 or within 10 years of youngest relative with PDAC (or age ≥30 for PJS patients) and (a) had PJS; or (b) had HBOC with ≥1 affected FDR or SDR with PC; or (c) were relatives of patients with FPC with ≥1 affected FDR.
Ludwig, 2011; U.S.; Fair | Recruitment: Eligible patients were at-risk relatives who met eligibility criteria for the Familial Pancreatic Tumor Registry (FPTR) at Memorial-Sloan Kettering Cancer Center. All at-risk relatives who met eligibility criteria were approached by a study assistant and invited to participate in the registry and screening program.; Initial screen: Baseline evaluation involved MRCP along with an office visit and physical exam. Registry participants also complete a detailed family history and epidemiology questionnaire. Genetic counseling is offered at study entry but is not a requirement.; Diagnostic workup: Those with lesions on MRCP underwent EUS. Those with suspected pre-malignant or malignant lesions on EUS underwent immediate FNA. Following multidisciplinary team review, those with suspected pre-malignant or malignant lesions on followup testing were referred for surgery.; Blinding: NR; Surveillance: Those with normal results on initial screening continued to undergo annual testing under same screening protocol for the 2 years of the study.; Harms and outcomes: Screening procedure-related harms were assessed by a study nurse who called all patients the day after the procedure. Psychosocial screening-related harms were not assessed or reported. No clinical follow-up information of screen-detected PDAC cases was provided. No surgical harms were assessed or reported. | Age ≥35 who had (a) ≥1 FDR diagnosed with PDAC before age 50; or (b) ≥1 FDR with PDAC and ≥1 other relative with PDAC, including; or (c) ≥3 SDRs with PDAC; or (d) known BRCA mutation and ≥1 relative with PDAC.
Schneider, 2011; FaPaCa; Germany; Fair | Recruitment: Eligible patients were high-risk individuals enrolled in the German National Case Collection of Familial Pancreatic Cancer (FaPaCa) who met criteria for the screening program. The study does not specify how patients were invited to participate.; Initial screen: Baseline evaluation involved a physical exam, lab tests (serum assessment of liver & pancreas, blood count, CEA, CA 19-9), EUS, and abdominal MRI/MRCP.; Diagnostic workup: Those with suspicious lesions on initial screening underwent repeat EUS in 6 weeks. Those with abnormalities potentially suggestive of malignancy underwent EUS-FNA. An interdisciplinary board reviewed any pathological findings. Those with suspected malignancy or pre-malignancy were referred to surgery.; Blinding: Two experienced radiologists without knowledge of any clinical or other imaging results independently reviewed all MRIs.; Surveillance: Those who screened negative continued to undergo annual screening. Interdisciplinary board could recommend close followup (repeated EUS and MRI/MRCP after 12 weeks, re-evaluation after 6 months and 12 months).; Harms and outcomes: The study reports that no FNA-related harms occurred, but does not report whether such harms were assessed systematically for all patients. Psychosocial screening-related harms were not assessed or reported. The study reports clinical followup, including metastases and surgical harms, for screen-detected PDAC cases. | FaPaCa registry enrollees who had no personal history of PDAC, were age ≥40 or within 10 years of youngest relative with PDAC and were (a) FDRs of an affected patient of an FPC^e^ family; or (b) members of an FPC^e^ family with a known genetic variant such as BRCA2, PALB2, or CDKN2A.
Verna, 2010; U.S.; Fair | Recruitment: Eligible patients were those referred to Pancreas Cancer Prevention and Genetics Program at Columbia University Medical Center/New York Presbyterian Hospital who had a family history of pancreatic cancer and an interest in their risk of disease. The study does not specify how patients were invited to participate.; Initial screen: Baseline evaluation included a detailed personal and family medical history, physical exam, genetic counseling, blood sample. Patients were offered MRI or EUS as well as an oral glucose tolerance test and serum CA 19-9. Genetic testing was recommended at discretion of clinician and genetic counselor.; Diagnostic workup: Those with abnormalities (mass lesions, cysts, or suspicious lymph nodes) underwent EUS-FNA. ECRP was performed at the discretion of the interventional endoscopist generally when ductal irregularities or changes consistent with IPMN required additional assessment.; Blinding: Radiologist was blinded to patient s pancreatic risk factors.; Surveillance: High-risk patients and those who underwent partial pancreatectomies were re-screened every 6 months. Those at moderate risk underwent annual imaging, and those at average risk returned for annual visits and further testing if they developed symptoms or new onset diabetes.; Harms and outcomes: The study reports that no screening procedure-related harms occurred, but does not report whether such harms were assessed systematically for all patients. Psychosocial screening-related harms were not assessed or reported. The study reports clinical followup information, including survival, for screen-detected PDAC cases. No surgical harms were assessed or reported. | Moderate risk: ≥2 relatives (FDRs, SDRs, or TDRs) with PDAC; or 1 FDR with PDAC<55 years old but not meeting high risk criteria.; High risk: (a); had FPC^f^; or (b) had known genetic syndrome (PJS, Lynch syndrome, BRCA1, BRCA2, FAMMM, or HP).; Patients at average risk (≥1 relative with PDAC age >55) were generally not recommended for screening unless significant psychological distress led them to prefer to be screened.
Poley, 2009; Netherlands; Fair | Recruitment: Eligible patients were asymptomatic at-risk individuals recruited and evaluated by clinical geneticists at an academic medical center in the Netherlands. The study does not specify how patients were invited to participate.; Initial screen: Following extensive evaluation by clinical geneticists, initial screening involved EUS.; Diagnostic workup: Those with abnormalities on EUS (mass lesions, cystic lesions, duct aberrations, and signs of chronic pancreatitis) underwent CT and/or MRI. A multidisciplinary team discussed all findings. Criteria for referral to surgery was not reported.; Blinding: NR; Surveillance: Those with small cystic lesions were followed up bi-annually with EUS and MRI. No other surveillance strategy is reported.; Harms and outcomes: The study reports that no screening procedure-related harms occurred, but does not report whether such harms were assessed systematically for all patients. Psychosocial screening-related harms were not assessed or reported. The study reports clinical followup information, including survival, for screen-detected PDAC cases. No surgical harms were assessed or reported. | Asymptomatic adults age ≥40 or within 5 years of youngest relative with PDAC who had (a) ≥2 FDRs with PDAC; or (b) a known pathogenic mutation; or (c) family history of HBOC, Lynch syndrome, or Li-Fraumeni syndrome and had familial clustering of PDAC in ≥2 relatives.
Canto, 2006; U.S.; Fair | Recruitment: Eligible patients were asymptomatic high-risk individuals identified through (a) referral by physician or genetic counselor; or (b) invited by letter to participate through the National Familial Pancreas Tumor Registry (NFPTR) or the Johns Hopkins Hereditary Colorectal Tumor Registry. Those not already enrolled in the NFPTR were referred for enrollment to confirm eligibility. Consecutive patients undergoing EUS and/or ERCP for non-pancreatic indications at Johns Hopkins Hospital were enrolled as control patients.; Initial screen: Baseline evaluation involved a family history and personal medical history questionnaire, physical exam, blood sample, genetic counseling, and screening by EUS and CT. Control patients underwent EUS and/or ERCP with the same procedures as the high-risk patients.; Diagnostic workup: Those with abnormalities on EUS (focal lesion such as a mass, nodule, or cyst; or ≥3 of 9 EUS features of chronic pancreatitis) underwent EUS-guided FNA at the same procedure and were offered ERCP, usually at a separate visit. Those with abnormal findings on followup testing (suspected pancreatic mass, cystic lesion, nodule, or severe dysplasia) were referred to a pancreatic surgeon. Control patients underwent the same followup testing procedures as the high-risk patients.; Blinding: EUS, FNA and CT results were assessed without knowledge of other test results.; Surveillance: Patients who had abnormalities on EUS but did not have surgery were offered followup EUS, FNA, and CT within 3–6 months. All patients were offered repeat EUS within 1 year of the initial screening.; Harms and outcomes: Screening procedure-related harms were assessed by telephone calls to all patients within 7 days after EUS and ERCP procedures. Psychosocial screening-related harms were not assessed or reported. The study reports clinical follow-up information, including survival, for screen-detected PDAC cases. The study also reports surgical harms among those who underwent surgery for precursor lesions. | PJS group: Age ≥30 and with ≥2 criteria for PJS^a^.; Family history group: age ≥40 or within 10 years of youngest relative with PDAC and from a family with ≥3 affected members, including ≥1 affected FDR.; Control group: age ≥30 undergoing EUS and/or ERCP for non-pancreatic indications and with no personal or family history or PDAC and no suspicion of pancreatic disease.
Canto, 2004; U.S.; Fair | Recruitment: Eligible patients were asymptomatic high-risk individuals identified through (a) the National Familial Pancreas Tumor Registry (NFPTR); (b) self-referral or physician referral because of a family history of pancreatic cancer; or (c) the Johns Hopkins Hereditary Colorectal Tumor Registry, which tracks patients and their families with Peutz Jeghers syndrome. Eligible NFPTR patients were contacted by mail with an invitation letter; the first 30 patients who agreed to participate were enrolled. Seven patients identified through self-referral or physician referral were invited to enroll in the NFPTR and the screening program, and one PJS patient identified through the Johns Hopkins Hereditary Colorectal Tumor Registry also enrolled in the screening program.; Initial screen: Baseline evaluation involved a complete history, physical exam, genetic counseling, and screening with EUS.; Diagnostic workup: Those with abnormalities on EUS (focal lesion such as a mass, nodule, or cyst; or ≥3 of 9 EUS features of chronic pancreatitis) underwent EUS-guided FNA at the same procedure. Those with abnormal EUS also underwent CT and were offered ERCP. Those with abnormal findings on followup testing (suspected pancreatic cancer because of a mass or severe dysplasia) were referred to a pancreatic surgeon.; Blinding: FNA and CT results were assessed without knowledge of other test results.; Surveillance: All patients were offered repeat EUS within 1 year of the initial screening and were followed until the end of the study (mean 22.4 months).; Harms and outcomes: Screening procedure-related harms were assessed by telephone calls to all patients within 7 days after EUS and ERCP procedures. Psychosocial screening-related harms were not assessed or reported. The study reports clinical follow-up information, including survival, for screen-detected PDAC cases. No surgical harms were assessed or reported. | NFPTR group: NFPTR enrollees who: (a) had ≥3 relatives with PDAC, including ≥2 affected FDRs; and (b) were an FDR of ≥1 affected family member; and (c) were age ≥40 or within 10 years of the youngest affected relative.; PJS group: Enrollees in the Johns Hopkins Hereditary Colorectal Tumor Registry who had PJS, pathologically confirmed hamartomatous polyps, family history of PJS, and/or mucocutaneous pigmentation

Abbreviations: PDAC = pancreatic ductal adenocarcinoma; PJS = Peutz-Jeghers syndrome; HP = hereditary pancreatitis; HBOC = hereditary breast and ovarian cancer; FDR = first-degree relative; SDR = second-degree relative; TDR = third-degree relative; FPC = familial pancreatic cancer; NFPTR = National Familial Pancreas Tumor Registry; CAPS = Cancer of the Pancreas Screening Study; NR = not reported; ASA = American Society of Anaesthesiologists; FaPaCa = German National Case Collection of Familial Pancreatic Cancer; FAMMM = Familial atypical multiple mole melanoma syndrome; EUS = endoscopic ultrasound; CT = computed tomography; MRI = magnetic resonance imaging; FNA = fine-needle aspiration; MRCP = magnetic resonance cholangiopancreaticography; CEA = carcinoembryonic antigen; CA 19-9 = carbohydrate antigen 19-9

a Criteria for PJS include characteristic intestinal hamartomatous polyps, mucocutaneous melanin deposition, and family history of PJS

b For Harinck 2016, familial pancreatic cancer was defined as a family with (a) ≥2 affected FDRs; or (b) ≥3 relatives in which the affected cases are FDR or SDRs of each other; or (c) ≥2 SDRs of whom at least one was aged <50 at time of diagnosis.

c For Joergensen 2016, hereditary pancreatitis was defined as having a PRSS1 mutation OR having ≥2 FDRs or ≥3 SDRs in two or more generations with recurrent acute pancreatitis, and/or chronic pancreatitis

d For Joergensen 2016, familial pancreatic cancer was defined as FDRs of patients with PDAC in families with 2 cases of PDAC where one relative was <50 years of age at diagnosis, or where ≥3 FDRs had PDAC

e For Schneider 2011, familial pancreatic cancer was defined as a family with ≥2 FDRs with confirmed diagnosis of PDAC without evidence of another inherited tumor syndrome

f For Verna 2010, familial pancreatic cancer was defined as having (a) ≥3 relatives (FDRs, SDRs, or TDRs) with PDAC; or (b) ≥2 FDRs with PDAC; or (c) 1 FDR and 1 SDR with PDAC, with ≥1 diagnosed age <55.

## Treatment outcomes of 18 screen-detected cases in included studies

In total, 18 cases of pancreatic adenocarcinoma were reported in 10 studies (Evidence Report, Table 10).^1–10^ Fourteen of the 18 individuals with pancreatic adenocarcinoma underwent surgical intervention. Status at followup at a defined time period was reported for 10 people across seven studies.^2,^ ^5–10^ Six individuals were alive at 12 63 months followup,^2,^ ^7,^ ^9,^ ^10^ two with distant metastases reported at 12 and 16 months.^7^ Four people were deceased, one from other causes at 7 months followup and three with local recurrence (one with distant metastasis) at 16 36 months.^5–7,^ ^9^ The most common surgical treatment underwent was total pancreatectomy (n=9, removing the entire pancreas, gallbladder, part of the stomach and small intestine, and spleen) followed by distal pancreatectomy (n=3, removing only the tail of the pancreas and spleen) and pancreaticoduodenectomy (n=2, removing the head of the pancreas). Four individuals with metastatic pancreatic adenocarcinoma underwent no surgery, although two did underwent chemotherapy treatment.

## Longer-term followup results

Longer-term followup data is available for two included screening programs: The FaPaCa screening program in Germany,^10–14^ and the U.S.-based CAPS3 screening program^15–17^ (Appendix D, Table 3). It is not possible to identify which of the 18 cases included in the evidence report are represented in these data, as cohorts were combined before reporting these longer followup data. Taken together, these studies suggest that longer-term survival has been observed in people with screen-detected pancreatic adenocarcinoma, but direct comparison to clinically detected populations is not possible.

## FaPaCa

Three articles^12–14^ provide followup data on the FaPaCa screening program^10,^ ^11^ combined with results from screening programs at Leiden University Medical Center in the Netherlands, and at Ramon y Cajal University Hospital in Spain.

As reported in the Schneider 2011^10^ and Langer 2009^11^ articles, the FaPaCa program detected one case of pancreatic adenocarcinoma over 7 years of followup, and this individual was alive with lung metastases 12 months after surgery. The number of pancreatic cancer cases identified in the longer-term followup articles are: 1 case detected over 9 years followup, survival not reported;^12^ 1 case detected over 13 years followup, died 38 months after surgery from metastatic disease;^13^ and 2 cases detected over 13 years followup, survival not reported.^14^ However, it is not possible to determine whether each of these cases were part of the FaPaCa cohort, since the articles combine FaPaCa with results from other screening programs.

## CAPS3

One article accepted for publication after our last literature search provides longer-term followup data on patients from the CAPS3 cohort^15,^ ^16^ and the CAPS4 cohort (results not published), as well as previously reported results from the Canto 2004^2^ and Canto 2006^1^ studies. The article does not report results separately by study cohort.

Together, the CAPS3,^15,^ ^16^ Canto 2004,^2^ and Canto 2006^1^ studies detected 2 cases of pancreatic adenocarcinoma over 1 to 2 years followup. The longer-term followup article^17^ combining data on these three studies and the unpublished CAPS4 study reports that 14 cases of pancreatic adenocarcinoma were detected over a median followup of 5.6 years. Ten of the 14 cases were detected as part of the screening programs, including 5 patients who underwent surgery and were alive at 2 to 11 years after diagnosis, 4 patients who underwent surgery and died at 1 to 12 years after diagnosis, and 1 patient who did not undergo surgery and died less than 3 months after diagnosis. Four of the 14 pancreatic cancer cases were detected outside the screening programs (after late or stopped surveillance), including 1 patient who underwent surgery and died 4 years after diagnosis and 3 patients who did not undergo surgery and died 4 to 26 months after diagnosis.

Appendix D Table 2 Summary of Findings From Longer-Term Followup Papers

Article | Population | N | Screening Period | N PDAC detected | PDAC details
Schneider, 2011^10^ (main FaPaCa paper) | FaPaCa only | 72 | 2002–2009 | 1 | Stage NR (pt had lung metastases on 12-mo f/u), alive at time of writing
Potjer 2012^12^ | FaPaCa only | 125 | 2002–2011 | 1 | Found in pancreatic head, survival NR
Vasen 2016^13^ | FaPaCa (n=184) and Madrid (n=30)^*^ | 214 | 2002–2015 | 1 | Metastatic disease, died 38 mos after surgery
Bartsch 2016^14^ | FaPaCa (n=210), Madrid (n=30) and Leiden (n=13)^*^ | 253 | 2002–2015 | 2 | Stage 1 (n=1), Stage IIB (n=1). Survival not reported.
Canto 2018^17^ | Canto 2004 (n=38);; Canto 2006 (n=78);; CAPS3 (n=216);; CAPS4 (n=249) | 354^†^ | 1998–2016 | 14 | 10 cases detected during surveillance; - 2 of 10 were Stage IV; - 5 resected patients alive 2–11 years after diagnosis; - 4 resected patients died 1–12 years after diagnosis; - 1 unresected patient died <3 mos after diagnosis; 4 cases detected outside surveillance (late or stopped screening); - 3 of 4 were Stage IV; - 1 resected patient died 4 years after diagnosis; - 3 unresected patients died 4–26 mos after diagnosis

* Results not reported separately by site

† Excluded 227 patients who continued surveillance at an outside institution or who had less than six months of followup after baseline screening. The study does not report the number of patients excluded separately by cohort.

Appendix D Table 3 Surgery Type by Study

Author, year | Number of patients receiving surgery | Type of surgery
Gangi, 2018 | 1 | Distal pancreatectomy (n = 1)
Harinck, 2016 | 2 | Distal pancreatectomy with splenectomy (n = 1)^*^; Pancreaticoduodenectomy (n = 1)
Joergensen, 2016 | 2 | Total pancreatectomy (n = 2)**
Del Chiaro, 2015 | 5 | Total pancreatectomy (n = 2)**; Distal pancreatectomy (n = 1); Pancreatoduodenectomy (n = 1)^*^; 3 enucleations (n = 1)
Al-Sukhni, 2012 | 4 | Total pancreatectomy (n = 1)^*^; Whipple (n = 1); Spleen preserving distal pancreatectomy (n = 1); Laproscopic distal pancreatectomy (n = 1)
Canto, 2012 | 5 | Pancreatectomy (n = 5)
Ludwig, 2011 | 6 | Distal pancreatectomy (n = 4) *; Pancreaticoduodenectomy (n = 2)
Schneider, 2011 | 10 | Exploration liver-wedge (n = 1); Distal pancreatectomy plus splenectomy (n = 3); Spleen preserving distal pancreatectomy (n = 3); Total pancreatectomy (n = 3)^*^
Verna, 2010 | 5 | Total pancreatectomy (n = 1)^*^; Distal pancreatectomy (n = 3); Central pancreatectomy (n = 1)
Poley, 2009 | 3 | Pancreatic tail and spleen resection (n = 1)^*^; Surgical resection of the pancreatic body and tail with en bloc resection of the spleen (n = 1)^*^; EN bloc resection of the pancreatic body, tail and spleen (n = 1)^*^
Canto, 2006 | 7 | Pyloric-sparing pancreaticduodenectomy (extended and non-extended) (n = 5); Distal pancreatectomy with en bloc splenectomy (n = 1); Distal pancreatectomy and splenectomy (n = 1)
Canto, 2004 | 7 | Whipple (n = 4)^*^; Distal pancreatectomy (n = 3)

* = number of PDAC cases with that procedure

## References

1 Canto MI, Goggins M, Hruban RH, . Screening for early pancreatic neoplasia in high-risk individuals: a prospective controlled study. Clin Gastroenterol Hepatol. 2006;4(6):766–81; quiz 665. PMID: 16682259.16682259
2 Canto MI, Goggins M, Yeo CJ, . Screening for pancreatic neoplasia in high-risk individuals: an EUS-based approach. Clin Gastroenterol Hepatol. 2004;2(7):606–21. PMID: 15224285.15224285
3 Ludwig E, Olson SH, Bayuga S, . Feasibility and yield of screening in relatives from familial pancreatic cancer families. Am J Gastroenterol. 2011;106(5):946–54. PMID: 21468009.21468009
4 Verna EC, Hwang C, Stevens PD, . Pancreatic cancer screening in a prospective cohort of high-risk patients: a comprehensive strategy of imaging and genetics. Clinical Cancer Research. 2010;16(20):5028–37. PMID: 20876795.20876795
5 Al-Sukhni W, Borgida A, Rothenmund H, . Screening for pancreatic cancer in a high-risk cohort: an eight-year experience. J Gastrointest Surg. 2012;16(4):771–83. PMID: 22127781.22127781
6 Harinck F, Konings I, Kluijt I, . A multicentre comparative prospective blinded analysis of EUS and MRI for screening of pancreatic cancer in high-risk individuals. Gut [serial on the Internet]. 2016; 65(9): Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/092/CN-01211092/frame.html.
7 Poley JW, Kluijt I, Gouma DJ, . The yield of first-time endoscopic ultrasonography in screening individuals at a high risk of developing pancreatic cancer. Am J Gastroenterol. 2009;104(9):2175–81. PMID: 19491823.19491823
8 Del Chiaro M, Verbeke CS, Kartalis N, . Short-term Results of a Magnetic Resonance Imaging-Based Swedish Screening Program for Individuals at Risk for Pancreatic Cancer. JAMA Surgery. 2015;150(6):512–8. PMID: 25853369.25853369
9 Joergensen MT, Gerdes AM, Sorensen J, . Is screening for pancreatic cancer in high-risk groups cost-effective? - Experience from a Danish national screening program. Pancreatology. 2016;16(4):584–92. PMID: 27090585.27090585
10 Schneider R, Slater EP, Sina M, . German national case collection for familial pancreatic cancer (FaPaCa): ten years experience. Fam Cancer. 2011;10(2):323–30. PMID: 21207249.21207249
11 Langer P, Kann PH, Fendrich V, . Five years of prospective screening of high-risk individuals from families with familial pancreatic cancer. Gut. 2009;58(10):1410–8. PMID: 19470496.19470496
12 Potjer TP, Schot I, Langer P, . Variation in precursor lesions of pancreatic cancer among high-risk groups. Clin Cancer Res. 2013;19(2):442–9. PMID: 23172884.23172884
13 Vasen H, Ibrahim I, Ponce CG, . Benefit of Surveillance for Pancreatic Cancer in High-Risk Individuals: Outcome of Long-Term Prospective Follow-Up Studies From Three European Expert Centers. J Clin Oncol. 2016;34(17):2010–9. PMID: 27114589.27114589
14 Bartsch DK, Slater EP, Carrato A, . Refinement of screening for familial pancreatic cancer. Gut. 2016;65(8):1314–21. PMID: 27222532.27222532
15 Canto MI, Hruban RH, Fishman EK, . Frequent detection of pancreatic lesions in asymptomatic high-risk individuals. Gastroenterology. 2012;142(4):796–804; quiz e14–5. PMID: 22245846.22245846
16 Shin EJ, Topazian M, Goggins MG, . Linear-array EUS improves detection of pancreatic lesions in high-risk individuals: a randomized tandem study. Gastrointest Endosc. 2015;82(5):812–8. PMID: 25930097.25930097
17 Canto MI, Almario JA, Schulick RD, . Risk of Neoplastic Progression in Individuals at High Risk for Pancreatic Cancer Undergoing Long-term Surveillance. Gastroenterology. 2018;155(3):740–51 e2. PMID: 29803839.29803839