# Appendix C Excluded Studies

Exclusion codes

E Codes
E1. Not relevant
E2. Not English
E3. Not original research
E4. Publication date; (exclude articles published 2001 and earlier)
E5. Ineligible SETTING (see very high HDI list below)
E6. Ineligible POPULATION; E6a. (For KQs 1-3) Persons with history of PC; E6b. (For KQs 1-3) Persons with known genetic syndrome comprise the entire study population; E6c. (For KQs 1-3) Children, adolescents, any other ineligible population; E6d. (For KQs 4, 5) Symptomatic or non-screen-detected populations; E6e. (For KQs 4, 5) Persons with pancreatic endocrine, exocrine or other non-adenocarcinoma tumors
E7. Ineligible SCREENING (e.g. biomarker testing)
E8. Ineligible TREATMENT (e.g. chemotherapy or palliative care alone)
E9. Ineligible OUTCOMES; E9a. (for KQ 3): Incidentally identified lesions; E9b. Incomplete study / protocol only; E9c. Other ineligible outcomes (see table below)
E10. Ineligible STUDY DESIGN; E10a. (for KQ 1, 2, 4): No comparison group; E10b. Comparative effectiveness study; E10c. Other ineligible design (see table below)
E11. Irretrievable
E12. Poor QUALITY

1 Grade B pancreatic fistulas do not affect survival after pancreatectomy for pancreatic cancer: a multicenter observational study. Surgery (United States). 160 (2) (pp 293–305), 2016. Date of Publication: 01 Aug 2016. 2016; PMID: CN-01197238. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E6.
2 Aahlin EK, Olsen F, Uleberg B, . Major postoperative complications are associated with impaired long-term survival after gastro-esophageal and pancreatic cancer surgery: a complete national cohort study. BMC Surgery. 2016;161:32. PMID: 27193578. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E9c.27193578
3 Abu Hilal M, Richardson JR, de Rooij T, . Laparoscopic radical ‘no-touch’ left pancreatosplenectomy for pancreatic ductal adenocarcinoma: technique and results. Surg Endosc. 2016;309:3830–8. PMID: 26675941. KQ1E1, KQ2E1, KQ3E1, KQ4E8, KQ5E8.26675941
4 Addeo P, Delpero JR, Paye F, . Pancreatic fistula after a pancreaticoduodenectomy for ductal adenocarcinoma and its association with morbidity: a multicentre study of the French Surgical Association. HPB (Oxford). 2014;161:46–55. PMID: 23461663. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E6.23461663
5 Alemanno G, Bergamini C, Martellucci J, . Surgical outcome of pancreaticoduodenectomy: high volume center or multidisciplinary management?. Minerva Chirurgica. 2016;711:8–14. PMID: 25922054. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.25922054
6 Alexander BM, Fernandez-Del Castillo C, Ryan DP, . Intraductal papillary mucinous adenocarcinoma of the pancreas: clinical outcomes, prognostic factors, and the role of adjuvant therapy. Gastrointest Cancer Res. 2011;44:116–21. PMID: 22368734. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.22368734
7 Al-Haddad M, Gill KR, Raimondo M, . Safety and efficacy of cytology brushings versus standard fine-needle aspiration in evaluating cystic pancreatic lesions: a controlled study. Endoscopy. 2010;422:127–32. PMID: 19998218. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E1.19998218
8 Allen PJ, Jaques DP, D’Angelica M, . Cystic lesions of the pancreas: selection criteria for operative and nonoperative management in 209 patients. J Gastrointest Surg. 2003;78:970–7. PMID: 14675706. KQ1E1, KQ2E6, KQ3E9, KQ4E1, KQ5E1.14675706
9 Ambe CM, Mahipal A, Fulp J, . Effect of metformin use on survival in resectable pancreatic cancer: a single-institution experience and review of the literature. PLoS One. 2016;113:e0151632. PMID: 26967162. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E92.26967162
10 Amin S, Lucas ALFrucht H. Evidence for treatment and survival disparities by age in pancreatic adenocarcinoma: a population-based analysis. Pancreas. 2013;422:249–53. PMID: 22836862. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.22836862
11 Andreou A, Klein F, Schmuck RB, . Incidence and oncological implications of previously undetected tumor multicentricity following pancreaticoduodenectomy for pancreatic adenocarcinoma in patients undergoing salvage pancreatectomy. Anticancer Res. 2017;379:5269–5275. PMID: 28870964. KQ1E1, KQ2E1, KQ3E1, KQ4E8, KQ5E8.28870964
12 Anonymous Summaries for patients. Detecting pancreatic cancer and its spread.[Original report in Ann Intern Med. 2004 Nov 16;141(10):753–63; PMID: 15545675]. Ann Intern Med. 2004;14110:I46. PMID: 15545671. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.15545671
13 Antolino L, La Rocca M, Todde F, . Can pancreatic cancer be detected by adrenomedullin in patients with new-onset diabetes? The PaCANOD cohort study protocol. Tumori. 2017;:0. PMID: 29192743. KQ1E9b, KQ2E9b, KQ3E9b, KQ4E9b, KQ5E9b2.28777425
14 Antonini F, Belfiori V, Pagano N, . Endoscopic ultrasonography may select subjects having asymptomatic chronic pancreatic hyperenzymemia who require a stricter follow-up. Pancreas. 2017;464:524–527. PMID: 28196017. KQ1E1, KQ2E10a, KQ3E1, KQ4E1, KQ5E1.28196017
15 Aoki S, Miyata H, Konno H, . Risk factors of serious postoperative complications after pancreaticoduodenectomy and risk calculators for predicting postoperative complications: a nationwide study of 17,564 patients in Japan. J Hepatobiliary Pancreat Sci. 2017;245:243–251. PMID: 28196308. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6e.28196308
16 Arabul M, Karakus F, Alper E, . Comparison of multidetector CT and endoscopic ultrasonography in malignant pancreatic mass lesions. Hepatogastroenterology. 2012;59117:1599–603. PMID: 22155849. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.22155849
17 Ardengh JC, Lopes CV, de Lima-Filho ER, . Impact of endoscopic ultrasound-guided fine-needle aspiration on incidental pancreatic cysts. A prospective study. Scand J Gastroenterol. 2014;491:114–20. PMID: 24188361. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.24188361
18 Ardengh JC, Paulo GAFerrari AP. Pancreatic carcinomas smaller than 3.0 cm: endosonography (EUS) in diagnosis, staging and prediction of resectability. HPB (Oxford). 2003;54:226–230. PMID: CN-01380781. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.
19 Are C, Chowdhury S, Ahmad H, . Predictive global trends in the incidence and mortality of pancreatic cancer based on geographic location, socio-economic status, and demographic shift. J Surg Oncol. 2016;1146:736–742. PMID: 27511902. KQ1E10, KQ2E10, KQ3E10, KQ4E1, KQ5E12.27511902
20 Artinyan A, Hellan M, Mojica-Manosa P, . Improved survival with adjuvant external-beam radiation therapy in lymph node-negative pancreatic cancer: a United States population-based assessment. Cancer. 2008;1121:34–42. PMID: 18000805. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.18000805
21 Arvaniti M, Danias N, Theodosopoulou E, . Quality of life variables assessment, before and after pancreatoduodenectomy (pd): prospective study. Glob J Health Sci. 2015;86:203–10. PMID: 26755486. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E9.26755486
22 Aspinwall LG, Taber JM, Leaf SL, . Genetic testing for hereditary melanoma and pancreatic cancer: a longitudinal study of psychological outcome. Psychooncology. 2013;222:276–89. PMID: 23382133. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E1.23382133
23 Assifi MM, Zhang S, Leiby BE, . Tumor recurrence is independent of pancreatic fistula in patients after pancreaticoduodenectomy for pancreatic ductal adenocarcinoma. J Am Coll Surg. 2013;2174:621–7. PMID: 23810574. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.23810574
24 Atema JJ, Eshuis WJ, Busch OR, . Association of preoperative symptoms of gastric outlet obstruction with delayed gastric emptying after pancreatoduodenectomy. Surgery. 2013;1543:583–8. PMID: 23972659. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.23972659
25 Augustin T, Burstein MD, Schneider EB, . Frailty predicts risk of life-threatening complications and mortality after pancreatic resections. Surgery. 2016;1604:987–96. PMID: 27545992. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.27545992
26 Azizi A, Kumbhari V, Gill R, . Diagnostic yield of SurePath in solid pancreatic and GIST lesions. J Gastroenterol Hepatol (Aust). 2014;29:48–9. PMID: CN-01056306. KQ1E10, KQ2E10, KQ3E10, KQ4E1, KQ5E1.
27 Baghbanian M, Salmanroghani H, Baghbanian A, . Resectability of the pancreatic adenocarcinoma: a study from Iran. Adv Biomed Res. 2014;3:265. PMID: 25625104. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.25625104
28 Baine MJ, Menning M, Smith LM, . Differential gene expression analysis of peripheral blood mononuclear cells reveals novel test for early detection of pancreatic cancer. Cancer Biomark. 2011;111:1–14. PMID: 22820136. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E1.22820136
29 Baiocchi GL, Portolani N, Grazioli L, . Management of pancreatic intraductal papillary mucinous neoplasm in an academic hospital (2005–2010): what follow-up for unoperated patients?. Pancreas. 2013;424:696–700. PMID: 23160482. KQ1E6d, KQ2E9, KQ3E9, KQ4E1, KQ5E1.23160482
30 Baiocchi GL, Portolani N, Missale G, . Intraductal papillary mucinous neoplasm of the pancreas (IPMN): clinico-pathological correlations and surgical indications. World J Surg Oncol. 2010;8:25. PMID: 20374620. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E1.20374620
31 Bakens MJ, van Gestel YR, Bongers M, . Hospital of diagnosis and likelihood of surgical treatment for pancreatic cancer. Br J Surg. 2015;10213:1670–5. PMID: 26437024. KQ1E1, KQ2E1, KQ3E1, KQ4E9, KQ5E9.26437024
32 Ball CG, Howard TJ. Natural history of intraductal papillary mucinous neoplasia: How much do we really know? World J Gastrointest Surg. 2010;210:368–72. PMID: 21160846. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.21160846
33 Ballehaninna UK, Chamberlain RS. Serum CA 19-9 as a biomarker for pancreatic cancer-a comprehensive review. Indian J Surg Oncol. 2011;22:88–100. PMID: 22693400. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.22693400
34 Balzano G, Capretti G, Callea G, . Overuse of surgery in patients with pancreatic cancer. A nationwide analysis in Italy. HPB (Oxford). 2016;185:470–8. PMID: 27154812. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E62.27154812
35 Banafea O, Mghanga FP, Zhao J, . Endoscopic ultrasonography with fine-needle aspiration for histological diagnosis of solid pancreatic masses: a meta-analysis of diagnostic accuracy studies. BMC Gastroenterol. 2016;16:108. PMID: 27580856. KQ1E1, KQ2E7, KQ3E7, KQ4E1, KQ5E1.27580856
36 Barbas AS, Turley RS, Ceppa EP, . Comparison of outcomes and the use of multimodality therapy in young and elderly people undergoing surgical resection of pancreatic cancer. J Am Geriatr Soc. 2012;602:344–50. PMID: 22211710. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.22211710
37 Barbier L, Jamal W, Dokmak S, . Impact of total pancreatectomy: short- and long-term assessment. HPB (Oxford). 2013;1511:882–92. PMID: 23458647. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6e.23458647
38 Barbier L, Turrini O, Gregoire E, . Pancreatic head resectable adenocarcinoma: preoperative chemoradiation improves local control but does not affect survival.[Erratum appears in HPB (Oxford). 2011 Dec;13(12):899]. HPB (Oxford). 2011;131:64–9. PMID: 21159106. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E9.21159106
39 Barral M, Faraoun SA, Fishman EK, . Imaging features of rare pancreatic tumors. Diagn Interv Imaging. 2016;9712:1259–1273. PMID: 27825642. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.27825642
40 Barton JG, Bois JP, Sarr MG, . Predictive and prognostic value of CA 19-9 in resected pancreatic adenocarcinoma. J Gastrointest Surg. 2009;1311:2050–8. PMID: 19756875. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.19756875
41 Barton JG, Schnelldorfer T, Lohse CM, . Patterns of pancreatic resection differ between patients with familial and sporadic pancreatic cancer. J Gastroint Surg. 2011;155:836–42. PMID: 21359597. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.21359597
42 Bartsch DK, Dietzel K, Bargello M, . Multiple small “imaging” branch-duct type intraductal papillary mucinous neoplasms (IPMNs) in familial pancreatic cancer: indicator for concomitant high grade pancreatic intraepithelial neoplasia?. Familial Cancer. 2013;121:89–96. PMID: 23179793. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E9.23179793
43 Bassi C, Stocken DD, Olah A, Friess H, . Influence of surgical resection and post-operative complications on survival following adjuvant treatment for pancreatic cancer in the ESPAC-1 randomized controlled trial. Digest Surg. 2005;225:353–363. PMID: CN-00561527. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E62.
44 Bassi C, Molinari E, Malleo G, . Early versus late drain removal after standard pancreatic resections: results of a prospective randomized trial. Ann Surg. 2010;2522:207–14. PMID: 20622661. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.20622661
45 Bauman MD, Becerra DG, Kilbane EM, . Laparoscopic distal pancreatectomy for pancreatic cancer is safe and effective. Surg Endosc. 2017;22:22. PMID: 28643065. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.28643065
46 Becker AE, Hernandez YG, Frucht H, Lucas AL. Pancreatic ductal adenocarcinoma: risk factors, screening, and early detection. World J Gastroenterol. 2014;2032:11182–98. PMID: 25170203. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.25170203
47 Becker AE, Hernandez YG, Frucht H, Lucas AL. Pancreatic ductal adenocarcinoma: risk factors, screening, and early detection. World J Gastroenterol. 2014;2032:11182–98. PMID: 25170203. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.25170203
48 Beliao S, Ferreira A, Vierasu I, . MR imaging versus PET/CT for evaluation of pancreatic lesions. Eur J Radiol. 2012;8110:2527–32. PMID: 22209433. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.22209433
49 Bell R, Ao BT, Ironside N, . Meta-analysis and cost effective analysis of portal-superior mesenteric vein resection during pancreatoduodenectomy: impact on margin status and survival. Surg Oncol. 2017;261:53–62. PMID: 28317585. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.28317585
50 Beltrame V, Gruppo M, Pastorelli D, . Outcome of pancreaticoduodenectomy in octogenarians: single institution’s experience and review of the literature. J Visc Surg. 2015;1525:279–84. PMID: 26117303. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E6.26117303
51 Belyaev O, Herzog T, Chromik AM, . Early and late postoperative changes in the quality of life after pancreatic surgery. Langenbecks Arch Surg. 2013;3984:547–55. PMID: 23503698. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.23503698
52 Bergeron JP, Perry KD, Houser PM, Yang J. Endoscopic ultrasound-guided pancreatic fine-needle aspiration: potential pitfalls in one institution’s experience of 1212 procedures. Cancer Cytopathol. 2015;1232:98–107. PMID: 25410732. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.25410732
53 Best LM, Rawji V, Pereira SP, . Imaging modalities for characterising focal pancreatic lesions. Cochrane Database Syst Rev. 2017;4:CD010213. PMID: 28415140. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.28415140
54 Bhattacharyya M, Lemoine NR. Gene therapy developments for pancreatic cancer. Best Pract Res Clin Gastroenterol. 2006;202:285–98. PMID: 16549328. KQ1E1, KQ2E1, KQ3E1, KQ4E3, KQ5E3.16549328
55 Bhutani MS, Koduru P, Joshi V, . The role of endoscopic ultrasound in pancreatic cancer screening. Endosc Ultrasound. 2016;51:8–16. PMID: 26879161. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.26879161
56 Bhutani MS, Verma D, Guha S, . Is endoscopic ultrasound “sound” for pancreatic cancer screening? J Clin Gastroenterol. 2009;439:797–802. PMID: 19652621. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.19652621
57 Bilimoria KY, Bentrem DJ, Ko CY, . National failure to operate on early stage pancreatic cancer. Ann Surg. 2007;2462:173–80. PMID: 17667493. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E9.17667493
58 Billings BJ, Christein JD, Harmsen WS, . Quality-of-life after total pancreatectomy: is it really that bad on long-term follow-up? J Gastrointest Surg. 2005;98:1059–66; discussion 1066–7. PMID: 16269376. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.16269376
59 Bingley PJ, Rafkin LE, Matheson D, . Use of dried capillary blood sampling for islet autoantibody screening in relatives: a feasibility study. Diabetes Technol Ther. 2015;1712:867–71. PMID: 26375197. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E12.26375197
60 Birnbaum DJ, Gaujoux S, Berbis J, . Surgery for pancreatic neoplasms: How accurate are our surgical indications? Surgery. 2017;1621:112–119. PMID: 28237644. KQ1E1, KQ2E10a, KQ3E6, KQ4E1, KQ5E1.28237644
61 Bjerregaard JK, Mortensen MB, Schonnemann KR, Pfeiffer P. Characteristics, therapy and outcome in an unselected and prospectively registered cohort of pancreatic cancer patients. Eur J Cancer. 2013;491:98–105. PMID: 22909997. KQ1E1, KQ2E1, KQ3E1, KQ4E6d, KQ5E9.22909997
62 Boggi U, Napoli N, Costa F, . Robotic-assisted pancreatic resections. World J Surg. 2016;4010:2497–506. PMID: 27206401. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.27206401
63 Boggi U, Signori S, De Lio N, . Feasibility of robotic pancreaticoduodenectomy. Br J Surg. 2013;1007:917–25. PMID: 23640668. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.23640668
64 Bose D, Tamm E, Liu J, . Multidisciplinary management strategy for incidental cystic lesions of the pancreas. J Am Coll Surg. 2010;2112:205–15. PMID: 20670858. KQ1E10, KQ2E9, KQ3E9, KQ4E1, KQ5E1.20670858
65 Botsis T, Anagnostou VK, Hartvigsen G, . Modeling prognostic factors in resectable pancreatic adenocarcinomas. Cancer Inform. 2010;7:281–91. PMID: 20508721. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E9.20508721
66 Bouvier AM, Bossard N, Colonna M, . Trends in net survival from pancreatic cancer in six European Latin countries: results from the SUDCAN population-based study. Eur J Cancer Prev. 2017;26:S63–S69. PMID: 28005607. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E62.28005607
67 Boyd CA, Branch DW, Sheffield KM, . Hospital and medical care days in pancreatic cancer. Ann Surg Oncol. 2012;198:2435–42. PMID: 22451235. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E9.22451235
68 Brand RE, Lerch MM, Rubinstein WS, . Advances in counselling and surveillance of patients at risk for pancreatic cancer. Gut. 2007;5610:1460–1469. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.
69 Brand RE, Nolen BM, Zeh HJ, . Serum biomarker panels for the detection of pancreatic cancer. Clin Cancer Res. 2011;174:805–816. PMID: CN-00888220. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E12.
70 Brasiniene B, Juozaityte E. The effect of combined treatment methods on survival and toxicity in patients with pancreatic cancer. Medicina (Kaunas). 2007;439:716–725. PMID: CN-00620775. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.
71 Brasiuniene B, Juozaityte E. The effect of combined treatment methods on survival and toxicity in patients with pancreatic cancer. Medicina (Kaunas). 2007;439:716–25. PMID: 17986845. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.17986845
72 Breitkopf CR, Sinicrope PS, Rabe KG, . Factors influencing receptivity to future screening options for pancreatic cancer in those with and without pancreatic cancer family history. Hered Cancer Clin Pract. 2012;101:8. PMID: 22738386. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.22738386
73 Brentnall TA, Bronner MP, Byrd DR, . Early diagnosis and treatment of pancreatic dysplasia in patients with a family history of pancreatic cancer. Ann Intern Med. 1999;1314:247–55. PMID: 10454945. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E12.10454945
74 Brentnall TA. Management strategies for patients with hereditary pancreatic cancer. Curr Treat Options Oncol. 2005;65:437–445. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.
75 Bressan AK, Ouellet JF, Tanyingoh D, . Temporal trends in the use of diagnostic imaging for inpatients with pancreatic conditions: how much ionizing radiation are we using? Can J Surg. 2016;593:188–96. PMID: 27240285. KQ1E10, KQ2E10, KQ3E9, KQ4E1, KQ5E12.27240285
76 Brower V. Genomic research advances pancreatic cancer’s early detection and treatment. J Natl Cancer Inst. 2015;1077:. PMID: 26142448. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.26142448
77 Brozzetti S, Mazzoni G, Miccini M, . Surgical treatment of pancreatic head carcinoma in elderly patients. Arch Surg. 2006;1412:137–42. PMID: 16490889. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.16490889
78 Bruenderman EH, Martin RC 2nd. High-risk population in sporadic pancreatic adenocarcinoma: guidelines for screening. J Surg Res. 2015;1941:212–9. PMID: 25479908. KQ1E10, KQ2E10, KQ3E10, KQ4E1, KQ5E12.25479908
79 Bruenderman EH, Martin RC 2nd. High-risk population in sporadic pancreatic adenocarcinoma: guidelines for screening. J Surg Res. 2015;1941:212–9. PMID: 25479908. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.25479908
80 Bruenderman E, Martin RC 2nd. A cost analysis of a pancreatic cancer screening protocol in high-risk populations. Am J Surg. 2015;2103:409–16. PMID: 26003200. KQ1E9, KQ2E9, KQ3E9, KQ4E1, KQ5E12.26003200
81 Burmeister EA, Jordan SJ, O’Connell DL, . Using a Delphi process to determine optimal care for patients with pancreatic cancer. Asia Pac J Clin Oncol. 2016;122:105–14. PMID: 26800012. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E12.26800012
82 Busquets J, Fabregat J, Borobia FG, . Organ-preserving surgery for benign lesions and low-grade malignancies of the pancreatic head: a matched case-control study. Surg Today. 2010;402:125–31. PMID: 20107951. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E10.20107951
83 Butturini G, Partelli S, Crippa S, . Perioperative and long-term results after left pancreatectomy: a single-institution, non-randomized, comparative study between open and laparoscopic approach. Surg Endosc. 2011;259:2871–8. PMID: 21424200. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.21424200
84 Butturini G, Stocken DD, Wente MN, . Influence of resection margins and treatment on survival in patients with pancreatic cancer: meta-analysis of randomized controlled trials. Arch Surg. 2008;1431:75–83; discussion 83. PMID: 18209156. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.18209156
85 Caglar E, Senturk H, Atasoy D, . The role of EUS and EUS-FNA in the management of pancreatic masses: five-year experience. Hepatogastroenterology. 2013;60124:896–9. PMID: 23321061. KQ1E1, KQ2E1, KQ3E1, KQ4E9, KQ5E9.23321061
86 Cai QC, Chen Y, Xiao Y, . A prediction rule for estimating pancreatic cancer risk in chronic pancreatitis patients with focal pancreatic mass lesions with prior negative EUS-FNA cytology. Scand J Gastroenterol. 2011;464:464–70. PMID: 21114434. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.21114434
87 Cai Y, Ran X, Xie S, . Surgical management and long-term follow-up of solid pseudopapillary tumor of pancreas: a large series from a single institution. J Gastrointest Surg. 2014;185:935–40. PMID: 24519038. KQ1E6e, KQ2E6e, KQ3E6e, KQ4E6e, KQ5E6e.24519038
88 Cameron JL, Riall TS, Coleman J, Belcher KA. One thousand consecutive pancreaticoduodenectomies. Ann Surg. 2006;2441:10–5. PMID: 16794383. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.16794383
89 Camus M, Trouilloud I, Villacis AL, . Effectiveness of combined endoscopic ultrasound-guided fine-needle aspiration biopsy and stenting in patients with suspected pancreatic cancer. Eur J Gastroenterol Hepatol. 2012;2411:1281–7. PMID: 22890210. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.22890210
90 Canto MI, Harinck F, Hruban RH, . International Cancer of the Pancreas Screening (CAPS) Consortium summit on the management of patients with increased risk for familial pancreatic cancer.[Erratum appears in Gut. 2014 Dec;63(12):1978 Note: Hammell, Pascal [corrected to Hammel, Pascal]]. Gut. 2013;623:339–47. PMID: 23135763. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.23135763
91 Canto MI. Strategies for screening for pancreatic adenocarcinoma in high-risk patients. Semin Oncol. 2007;344:295–302. PMID: 17674957. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.17674957
92 Canto MI. Value of EUS screening in patients with high risk factors for pancreatic cancer (focus on familial pancreatic cancer). Pancreatology. Conference: 20th meeting of the International Association of Pancreatology, IAP 2016. Japan. 2016;164 Supplement 1:S19–s20. KQ1E10, KQ2E9b, KQ3E9b, KQ4E1, KQ5E1.
93 Canto MI, Hruban RH. Diagnosis: a step closer to screening for curable pancreatic cancer? Nat Rev Gastroenterol Hepatol. 2015;128:431–2. PMID: 26122477. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.26122477
94 Canto MI, Hruban RH. Diagnosis: a step closer to screening for curable pancreatic cancer?. Nat Rev Gastroenterol Hepatol. 2015;128:431–2. PMID: 26122477. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.26122477
95 Capello M, Bantis LE, Scelo G, . Sequential validation of bloodbased protein biomarker candidates for early-stage pancreatic cancer. Cancer research. Conference: 17th annual meeting of the american association for cancer research, AACR 216. United States. Conference start: 216416. Conference end: 21642. 2016;7614 Supplement) (no pagination:. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E12.
96 Capurso G, Signoretti M, Valente R, . Methods and outcomes of screening for pancreatic adenocarcinoma in high-risk individuals. World J Gastroint Endosc. 2015;79:833–42. PMID: 26240684. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.26240684
97 Caraiani C, Tantau M, Rotaru M, . Cystic pancreatic lesion discovered in the setting of abdominal trauma: a diagnostic challenge. J Gastrointest Liver Dis. 2016;253:272. PMID: 27689188. KQ1E10c, KQ2E10c, KQ3E10c, KQ4E10c, KQ5E10c.27689188
98 Carr RA, Roch AM, Zhong X, . Prospective evaluation of associations between cancer-related pain and perineural invasion in patients with resectable pancreatic adenocarcinoma. J Gastrointest Surg. 2017;7:7. PMID: 28785934. KQ1E1, KQ2E1, KQ3E1, KQ4E9, KQ5E9.28785934
99 Carrara S, Arcidiacono PG, Mezzi G, . Pancreatic endoscopic ultrasound-guided fine needle aspiration: complication rate and clinical course in a single centre. Digest Liver Dis. 2010;427:520–3. PMID: 19955025. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.19955025
100 Carrato A, Falcone A, Ducreux M, . A Systematic review of the burden of pancreatic cancer in Europe: real-world impact on survival, quality of life and costs. J Gastrointest Cancer. 2015;463:201–11. PMID: 25972062. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E9.25972062
101 Casadei R, Monari F, Buscemi S, . Total pancreatectomy: indications, operative technique, and results: a single centre experience and review of literature. Updates Surg. 2010;621:41–6. PMID: 20845100. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.20845100
102 Casadei R, Ricci C, Lazzarini E, . Pancreatic resection in patients 80 years or older: a meta-analysis and systematic review. Pancreas. 2014;438:1208–18. PMID: 25333405. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E6.25333405
103 Casadei R, Ricci C, Taffurelli G, . Impact of surgery and surveillance in the management of branch duct intraductal papillary mucinous neoplasms of the pancreas according to Fukuoka guidelines: the Bologna experience. Updates Surg. 2017;7:7. PMID: 28593459. KQ1E1, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.28593459
104 Catanzaro A, Richardson S, Veloso H, . Long-term follow-up of patients with clinically indeterminate suspicion of pancreatic cancer and normal EUS. Gastrointest Endosc. 2003;586:836–40. PMID: 14652549. KQ1E10, KQ2E6, KQ3E6, KQ4E1, KQ5E1.14652549
105 Cauley CE, Waters JA, Dumas RP, . Outcomes of primary surveillance for intraductal papillary mucinous neoplasm. J Gastrointest Surg. 2012;162:258–67; discussion 266. PMID: 22089952. KQ1E10, KQ2E9, KQ3E9, KQ4E1, KQ5E1.22089952
106 Chahla E, Cheesman A, Mahon SM, . Frequency and significance of abnormal pancreatic imaging in patients with BRCA1 and BRCA2 genetic mutations. Scientifica. 2016;2016:5619358. PMID: 27069714. KQ1E9, KQ2E6b, KQ3E9, KQ4E1, KQ5E1.27069714
107 Chan C, Franssen B, Dominguez I, . Impact on quality of life after pancreatoduodenectomy: a prospective study comparing preoperative and postoperative scores. J Gastrointest Surg. 2012;167:1341–6. PMID: 22547348. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.22547348
108 Chang DC, Zhang Y, Mukherjee D, . Variations in referral patterns to high-volume centers for pancreatic cancer. J Am Coll Surg. 2009;2096:720–6. PMID: 19959040. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.19959040
109 Chang MC, Chen CH, Liang JD, . Hepatitis B and C viruses are not risks for pancreatic adenocarcinoma. World J Gastroenterol. 2014;2017:5060–5. PMID: 24803819. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.24803819
110 Chang MC, Wong JM, Chang YT. Screening and early detection of pancreatic cancer in high risk population. World J Gastroenterol. 2014;209:2358–64. PMID: 24605033. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.24605033
111 Chang MC, Wu CH, Yang SH, . Pancreatic cancer screening in different risk individuals with family history of pancreatic cancer-a prospective cohort study in Taiwan. Am J Cancer Res. 2017;72:357–369. PMID: 28337383. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.28337383
112 Chari ST, Leibson CL, Rabe KG, . Probability of pancreatic cancer following diabetes: a population-based study. Gastroenterology. 2005;1292:504–11. PMID: 16083707. KQ1E7, KQ2E1, KQ3E1, KQ4E1, KQ5E1.16083707
113 Chari ST, Yadav D, Smyrk TC, . Study of recurrence after surgical resection of intraductal papillary mucinous neoplasm of the pancreas. Gastroenterology. 2002;1235:1500–7. PMID: 12404225. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.12404225
114 Chari ST. Detecting early pancreatic cancer: problems and prospects. Semin Oncol. 2007;344:284–94. PMID: 17674956. KQ1E3, KQ2E3, KQ3E1, KQ4E1, KQ5E1.17674956
115 Chatterjee D, Katz MH, Rashid A, . Pancreatic intraepithelial neoplasia and histological changes in non-neoplastic pancreas associated with neoadjuvant therapy in patients with pancreatic ductal adenocarcinoma. Histopathology. 2013;636:841–51. PMID: 24111684. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E9.24111684
116 Chen CH, Yang CCYeh YH. Endosonography for pancreatic duct dilatation without definite pathology on ultrasonography. Hepatogastroenterology. 2014;61131:842–8. PMID: 26176084. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.26176084
117 Chen FM, Ni JM, Zhang ZY, . Presurgical evaluation of pancreatic cancer: a comprehensive imaging comparison of CT versus MRI. AJR Am J Roentgenol. 2016;2063:526–35. PMID: 26901008. KQ1E6a, KQ2E6a, KQ3E1, KQ4E1, KQ5E1.26901008
118 Chen KH, Hsu HM, Hsu GC, . Therapeutic strategies for pancreatic pseudocysts: experience in Taiwan. Hepatogastroenterology. 2008;5585:1470–4. PMID: 18795714. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.18795714
119 Cheng Y, Briarava M, Lai M, . Pancreaticojejunostomy versus pancreaticogastrostomy reconstruction for the prevention of postoperative pancreatic fistula following pancreaticoduodenectomy. Cochrane Database Syst Rev. 2017;9:Cd012257. PMID: 28898386. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.28898386
120 Chernyak V, Flusberg M, Haramati LB, . Incidental pancreatic cystic lesions: is there a relationship with the development of pancreatic adenocarcinoma and all-cause mortality? Radiology. 2015;2741:161–9. PMID: 25117591. KQ1E10a, KQ2E10a, KQ3E9, KQ4E1, KQ5E1.25117591
121 Cho CS, Russ AJ, Loeffler AG, . Preoperative classification of pancreatic cystic neoplasms: the clinical significance of diagnostic inaccuracy. Ann Surg Oncol. 2013;209:3112–9. PMID: 23595223. KQ1E9, KQ2E9, KQ3E9, KQ4E1, KQ5E1.23595223
122 Choe JW, Kim JS, Kim HJ, . Value of early check-up of carbohydrate antigen 19-9 levels for pancreatic cancer screening in asymptomatic new-onset diabetic patients. Pancreas. 2016;455:730–4. PMID: 26646277. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E12.26646277
123 Choe JW, Kim JS, Kim HJ, . Value of early check-up of carbohydrate antigen 19-9 levels for pancreatic cancer screening in asymptomatic new-onset diabetic patients. Pancreas. 2016;455:730–4. PMID: 26646277. KQ1E10a, KQ2E7, KQ3E7, KQ4E1, KQ5E1.26646277
124 Chu CK, Mazo AE, Goodman M, . Preoperative diabetes mellitus and long-term survival after resection of pancreatic adenocarcinoma. Ann Surg Oncol. 2010;172:502–13. PMID: 19885697. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.19885697
125 Chu D, Kohlmann WA, Douglas G. Identification and screening of individuals at increased risk for pancreatic cancer with emphasis on known environmental and genetic factors and hereditary syndromes. JOP. 2010;113:203–212. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.
126 Chua TC, Yang TX, Gill AJ, Samra JS. Systematic review and meta-analysis of enucleation versus standardized resection for small pancreatic lesions. Ann Surg Oncol. 2016;232:592–9. PMID: 26307231. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.26307231
127 Chua TC, Saxena A. Extended pancreaticoduodenectomy with vascular resection for pancreatic cancer: a systematic review. J Gastrointest Surg. 2010;149:1442–52. PMID: 20379794. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.20379794
128 Cirocchi R, Partelli S, Coratti A, . Current status of robotic distal pancreatectomy: a systematic review. Surg Oncol. 2013;223:201–7. PMID: 23910929. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.23910929
129 Cleary SP, Gryfe R, Guindi M, . Prognostic factors in resected pancreatic adenocarcinoma: analysis of actual 5-year survivors. J Am Coll Surg. 2004;1985:722–31. PMID: 15110805. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.15110805
130 Collins GS, Altman DG. Identifying patients with undetected pancreatic cancer in primary care: an independent and external validation of QCancer (Pancreas). Br J Gen Pract. 2013;63614:e636–42. PMID: 23998844. KQ1E9, KQ2E7, KQ3E9, KQ4E1, KQ5E1.23998844
131 Conrad C, Basso V, Passot G, . Comparable long-term oncologic outcomes of laparoscopic versus open pancreaticoduodenectomy for adenocarcinoma: a propensity score weighting analysis. Surg Endosc. 2017; PMID: 2820503128205031. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.
132 Cooper AB, Holmes HM, des Bordes JK, . Role of neoadjuvant therapy in the multimodality treatment of older patients with pancreatic cancer. J Am Coll Surg. 2014;2191:111–20. PMID: 24856952. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E9.24856952
133 Cooper AB, Parmar AD, Riall TS, . Does the use of neoadjuvant therapy for pancreatic adenocarcinoma increase postoperative morbidity and mortality rates? J Gastrointest Surg. 2015;191:80–6; discussion 86–7. PMID: 25091851. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.25091851
134 Cooper M, Newman NA, Ibrahim AM, . Unnecessary tests and procedures in patients presenting with solid tumors of the pancreas. J Gastrointest Surg. 2013;177:1218–23. PMID: 23645419. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.23645419
135 Correa-Gallego C, Ferrone CR, Thayer SP, . Incidental pancreatic cysts: do we really know what we are watching? Pancreatology. 2010;102–3:144–50. PMID: 20484954. KQ1E9, KQ2E6, KQ3E9, KQ4E6, KQ5E6.20484954
136 Creighton N, Walton R, Roder DM, . Pancreatectomy is underused in NSW regions with low institutional surgical volumes: a population data linkage study. Med J Aust. 2017;2061:23–29. PMID: 28076733. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.28076733
137 Cronin-Fenton DP, Erichsen R, Mortensen FV, . Pancreatic cancer survival in central and northern Denmark from 1998 through 2009: a population-based cohort study. Clin Epidemiol. 2011;23: Suppl 1:19–25. PMID: 21814466. KQ1E7, KQ2E9, KQ3E9, KQ4E6, KQ5E6.21814466
138 Cucchetti A, Ercolani G, Cescon M, . Estimation of the survival benefit obtainable from screening for the early detection of pancreatic cancer. Pancreas. 2016;455:714–9. PMID: 26646274. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E102.26646274
139 DaCosta Byfield S, Nash Smyth E, Mytelka D, . Healthcare costs, treatment patterns, and resource utilization among pancreatic cancer patients in a managed care population. J Med Econ. 2013;1612:1379–86. PMID: 24074258. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.24074258
140 Dandona M, Linehan D, Hawkins W, . Influence of obesity and other risk factors on survival outcomes in patients undergoing pancreaticoduodenectomy for pancreatic cancer. Pancreas. 2011;406:931–7. PMID: 21747317. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.21747317
141 D’Angelo F, Antolino L, Farcomeni A, . Neoadjuvant treatment in pancreatic cancer: evidence-based medicine? A systematic review and meta-analysis. Med Oncol. 2017;345:85. PMID: 28391577. KQ1E1, KQ2E1, KQ3E1, KQ4E8, KQ5E8.28391577
142 Darnis B, Lebeau R, Chopin-Laly X, Adham M. Postpancreatectomy hemorrhage (PPH): predictors and management from a prospective database. Langenbecks Arch Surg. 2013;3983:441–8. PMID: 23435636. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.23435636
143 Date K, Ohtsuka T, Nakamura S, . Surveillance of patients with intraductal papillary mucinous neoplasm with and without pancreatectomy with special reference to the incidence of concomitant pancreatic ductal adenocarcinoma. Surgery. 2018;1632:291–299. PMID: 29221879. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E62.29221879
144 Daude M, Muscari F, Buscail C, . Outcomes of nonresected main-duct intraductal papillary mucinous neoplasms of the pancreas. World J Gastroenterol. 2015;219:2658–67. PMID: 25759534. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E6e, KQ5E6e.25759534
145 de Castro SM, de Nes LC, Nio CY, . Incidence and characteristics of chronic and lymphoplasmacytic sclerosing pancreatitis in patients scheduled to undergo a pancreatoduodenectomy. HPB (Oxford). 2010;121:15–21. PMID: 20495640. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.20495640
146 de Leede EM, Sibinga Mulder BG, Bastiaannet E, . Common variables in European pancreatic cancer registries: The introduction of the EURECCA pancreatic cancer project. Eur J Surg Oncol. 2016;429:1414–9. PMID: 27061790. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E102.27061790
147 De Moor V, Arvanitakis M, Nagy N, . Intraductal papillary mucinous neoplasms of the pancreas: clinicopathological features and long term outcome related to histopathological group. Hepatogastroenterology. 2012;59114:565–9. PMID: 22353525. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.22353525
148 De Reuver PR, Mittal A, Neale M, . Extended pancreatoduodenectomy as defined by the International Study Group for Pancreatic Surgery is associated with worse survival but not with increased morbidity. Surgery. 2015;1581:183–90. PMID: 25920909. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.25920909
149 de Rooij T, Lu MZ, Steen MW, . Minimally invasive versus open pancreatoduodenectomy: systematic review and meta-analysis of comparative cohort and registry studies. Ann Surg. 2016;2642:257–67. PMID: 26863398. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.26863398
150 de Rooij T, Tol JA, van Eijck CH, . Outcomes of distal pancreatectomy for pancreatic ductal adenocarcinoma in the netherlands: a nationwide retrospective analysis. Ann Surg Oncol. 2016;232:585–91. PMID: 26508153. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E6.26508153
151 de Rooij T, van Hilst J, Busch OR, . Laparoscopic distal pancreatectomy for pancreatic ductal adenocarcinoma: time for a randomized controlled trial? Results of an all-inclusive national observational study. Ann Surg. 2016;11:11. PMID: 27607310. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.
152 Del Chiaro M, Zerbi A, Capurso G, . Familial pancreatic cancer in Italy. Risk assessment, screening programs and clinical approach: a position paper from the Italian Registry. Digest Liver Dis. 2010;429:597–605. PMID: 20627831. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.20627831
153 Del Frate C, Zanardi R, Mortele K, Ros PR. Advances in imaging for pancreatic disease. Curr Gastroenterol Rep. 2002;42:140–8. PMID: 11900679. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.11900679
154 Delitto D, Luckhurst CM, Black BS, . Oncologic and perioperative outcomes following selective application of laparoscopic pancreaticoduodenectomy for periampullary malignancies. J Gastrointest Surg. 2016;207:1343–9. PMID: 27142633. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E10.27142633
155 Derogar M, Blomberg J, Sadr-Azodi O. Hospital teaching status and volume related to mortality after pancreatic cancer surgery in a national cohort. Br J Surg. 2015;1025:548–57; discussion 557. PMID: 25711855. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E9.25711855
156 Deshwar AB, Sugar E, Torto D, . Diagnostic intervals and pancreatic ductal adenocarcinoma (PDAC) resectability: a single-center retrospective analysis. Ann Pancreat Cancer. 2018;1:. PMID: 29683142. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E12.29683142
157 Deutsch JC. EUS screening of subjects at risk for familial pancreatic cancer: what to do and what to expect. Gastrointest Endosc. 2007;661:68–9. PMID: 17591475. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.17591475
158 Dewitt J, Devereaux BM, Lehman GA, . Comparison of endoscopic ultrasound and computed tomography for the preoperative evaluation of pancreatic cancer: a systematic review. Clin Gastroenterol Hepatol. 2006;46:717–25; quiz 664. PMID: 16675307. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.16675307
159 di Sebastiano P, Festa L, De Bonis A, . A modified fast-track program for pancreatic surgery: a prospective single-center experience. Langenbecks Arch Surg. 2011;3963:345–51. PMID: 20703500. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.20703500
160 Dimou F, Sineshaw H, Parmar AD, . Trends in receipt and timing of multimodality therapy in early-stage pancreatic cancer. J Gastrointest Surg. 2016;201:93–103; discussion 103. PMID: 26503262. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.26503262
161 D’Onofrio M, Canestrini S, De Robertis R, . CEUS of the pancreas: Still research or the standard of care. Eur J Radiol. 2015;849:1644–9. PMID: 25796427. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.25796427
162 Driedger MR, Dixon E, Mohamed R, . The diagnostic pathway for solid pancreatic neoplasms: are we applying too many tests?. J Surg Res. 2015;1991:39–43. PMID: 25953217. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.25953217
163 Du C, Chai NL, Linghu EQ, . Incidents and adverse events of endoscopic ultrasound-guided fine-needle aspiration for pancreatic cystic lesions. World J Gastroenterol. 2017;2330:5610–5618. PMID: 28852320. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.28852320
164 Duffy A, Capanu M, Allen P, . Pancreatic adenocarcinoma (PAC) in a younger patient population: 10-year experience at Memorial Sloan-Kettering Cancer Center (MSKCC). J Clin Oncol. 2008;2615_suppl:4623. PMID: 27948551. KQ1E1, KQ2E1, KQ3E1, KQ4E6d, KQ5E6d.
165 Dugnani E, Gandolfi A, Balzano G, . Diabetes associated with pancreatic ductal adenocarcinoma is just diabetes: results of a prospective observational study in surgical patients. Pancreatology. 2016;165:844–52. PMID: 27546476. KQ1E1, KQ2E1, KQ3E1, KQ4E9, KQ5E9.27546476
166 Dumitrascu T, Barbu ST, Ionescu M, Popescu I. POSSUM, a potentially useful tool for prediction of morbidity in patients undergoing central pancreatectomy. Chirurgia (Bucuresti). 2012;1074:447–53. PMID: 23025110. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.23025110
167 Dumitrascu T, Barbu ST, Purnichescu-Purtan R, . Risk factors for surgical complications after central pancreatectomy. Hepatogastroenterology. 2012;59114:592–8. PMID: 22353528. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.22353528
168 Duskova J, Krechler T, Dvorak M. Endoscopic ultrasound-guided fine needle aspiration biopsy of pancreatic lesions. An 8-year analysis of single institution material focusing on efficacy and learning progress. Cytopathology. 2017;282:109–115. PMID: 27658926. KQ1E6d, KQ2E6a, KQ3E6a, KQ4E1, KQ5E1.27658926
169 Dzeletovic I, Harrison ME, Crowell MD, . Pancreatitis before pancreatic cancer: clinical features and influence on outcome. J Clin Gastroenterol. 2014;489:801–5. PMID: 24153158. KQ1E10a, KQ2E10a, KQ3E9, KQ4E10, KQ5E9.24153158
170 Ecker BL, Simmons KD, Zaheer S, . Blood transfusion in major abdominal surgery for malignant tumors: a trend analysis using the National Surgical Quality Improvement Program. JAMA Surg. 2016;1516:518–25. PMID: 26763765. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.26763765
171 El Nakeeb A, El Shobary M, El Dosoky M, . Prognostic factors affecting survival after pancreaticoduodenectomy for pancreatic adenocarcinoma (single center experience). Hepatogastroenterology. 2014;61133:1426–38. PMID: 25436321. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.25436321
172 El-Jurdi NH, Saif MW. Pancreatic cancer: new hopes for early detection and a future screening tool? JOP. 2014;154:358–9. PMID: 25076343. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.25076343
173 Eloubeidi MA, Fusaroli P, Kypraios D, Caletti GG. Pancreaticobiliary EUS: a systematic review of current indications, test performance, and clinical outcome according to the levels of evidence. Gastrointest Endosc. 2012;754 suppl. 1:Ab184–ab185. PMID: CN-01005176. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E12.
174 Eloubeidi MA, Chen VK, Eltoum IA, . Endoscopic ultrasound-guided fine needle aspiration biopsy of patients with suspected pancreatic cancer: diagnostic accuracy and acute and 30-day complications. Am J Gastroenterol. 2003;9812:2663–8. PMID: 14687813. KQ1E9, KQ2E6, KQ3E6, KQ4E1, KQ5E1.14687813
175 Eloubeidi MA, Tamhane A, Varadarajulu SWilcox CM. Frequency of major complications after EUS-guided FNA of solid pancreatic masses: a prospective evaluation. Gastrointest Endosc. 2006;634:622–9. PMID: 16564863. KQ1E1, KQ2E1, KQ3E6, KQ4E1, KQ5E1.16564863
176 El-Rayes BF, Jasti P, Severson RK, . Impact of race, age, and socioeconomic status on participation in pancreatic cancer clinical trials. Pancreas. 2010;397:967–71. PMID: 20467351. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.20467351
177 Elta GH, Enestvedt BK, Sauer BG, Lennon AM. ACG Clinical Guideline: diagnosis and management of pancreatic cysts. Am J Gastroenterol. 2018;1134:464–479. PMID: 29485131. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.29485131
178 Epelboym I, DiNorcia J, Winner M, . Neoadjuvant therapy and vascular resection during pancreaticoduodenectomy: shifting the survival curve for patients with locally advanced pancreatic cancer. World J Surg. 2014;385:1184–95. PMID: 24305935. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.24305935
179 Epelboym I, Winner M, DiNorcia J, . Quality of life in patients after total pancreatectomy is comparable with quality of life in patients who undergo a partial pancreatic resection. J Surg Res. 2014;1871:189–96. PMID: 24411300. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.24411300
180 Eppsteiner RW, Csikesz NG, McPhee JT, . Surgeon volume impacts hospital mortality for pancreatic resection. Ann Surg. 2009;2494:635–40. PMID: 19300225. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.19300225
181 Eshuis WJ, Hermanides J, van Dalen JW, . Early postoperative hyperglycemia is associated with postoperative complications after pancreatoduodenectomy. Ann Surg. 2011;2534:739–44. PMID: 21475014. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.21475014
182 Eshuis WJ, van der Gaag NA, Rauws EA, . Therapeutic delay and survival after surgery for cancer of the pancreatic head with or without preoperative biliary drainage. Ann Surg. 2010;2525:840–9. PMID: 21037440. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.21037440
183 Fan F, Lai EC, Xie F, . Intraductal papillary mucinous neoplasms of the pancreas-predictors of malignancy. Hepatogastroenterology. 2010;5799–100:635–9. PMID: 20698241. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.20698241
184 Fan X, Alekseyenko AV, Wu J, . Human oral microbiome and prospective risk for pancreatic cancer: a population-based nested case-control study. Gut. 2018;671:120–127. PMID: 27742762. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E102.27742762
185 Fan Z, Li Y, Yan K, . Application of contrast-enhanced ultrasound in the diagnosis of solid pancreatic lesions-a comparison of conventional ultrasound and contrast-enhanced CT. Eur J Radiol. 2013;829:1385–90. PMID: 23727375. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.23727375
186 Faraj W, Alameddine R, Mukherji D, . Postoperative outcomes following pancreaticoduodenectomy: how should age affect clinical practice? World J Surg Oncol. 2013;11:131. PMID: 23742036. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.23742036
187 Farrokhzad S, Nedjat S, Kamangar F, . Validity and reliability of a questionnaire designed to assess risk factors of pancreatic cancer in Iran. Arch Iran Med. 2014;172:102–5. PMID: 24527969. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.24527969
188 Ferrone CR, Brennan MF, Gonen M, . Pancreatic adenocarcinoma: the actual 5-year survivors. J Gastrointest Surg. 2008;124:701–6. PMID: 18027062. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E6.18027062
189 Fest J, Ruiter R, van Rooij FJ, . Underestimation of pancreatic cancer in the national cancer registry - reconsidering the incidence and survival rates. Eur J Cancer. 2016;72:186–191. PMID: 28033529. KQ1E10, KQ2E9, KQ3E9, KQ4E6, KQ5E92.28033529
190 Fiederling J, Shams AZ, Haug U. Validity of self-reported family history of cancer: a systematic literature review on selected cancers. Int J Cancer. 2016;1397:1449–60. PMID: 27222437. KQ1E10, KQ2E10, KQ3E10, KQ4E1, KQ5E12.27222437
191 Fisher JM, Gordon SR, Gardner TB. The impact of prior biliary stenting on the accuracy and complication rate of endoscopic ultrasound fine-needle aspiration for diagnosing pancreatic adenocarcinoma. Pancreas. 2011;401:21–4. PMID: 20881899. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.20881899
192 Fitzgerald TL, Seymore NM, Kachare SD, . Measuring the impact of multidisciplinary care on quality for pancreatic surgery: transition to a focused, very high-volume program. Am Surg. 2013;798:775–80. PMID: 23896243. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.23896243
193 Fitzgerald TL, Smith AJ, Ryan M, . Surgical treatment of incidentally identified pancreatic masses. Can J Surg. 2003;466:413–8. PMID: 14680347. KQ1E1, KQ2E1, KQ3E9a, KQ4E6d, KQ5E6d.14680347
194 Flusberg M, Paroder V, Kobi M, . Patients 65 years and older with incidental pancreatic cysts: Is there a relationship between all-cause mortality and imaging follow-up? Eur J Radiol. 2016;856:1115–20. PMID: 27161060. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.27161060
195 Fong Y, Gonen M, Rubin D, . Long-term survival is superior after resection for cancer in high-volume centers. Ann Surg. 2005;2424:540–4; discussion 544–7. PMID: 16192814. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.16192814
196 Fong ZV, Alvino DM, Castillo CF, . Health-related quality of life and functional outcomes in 5-year survivors after pancreaticoduodenectomy. Ann Surg. 2017;2664:685–692. PMID: 28657944. KQ1E1, KQ2E1, KQ3E1, KQ4E10c, KQ5E6.28657944
197 Fontes PR, Waechter FL, Nectoux M, . Low mortality rate in 97 consecutive pancreaticoduodenectomies: the experience of a group. Arq Gastroenterol. 2014;511:29–33. PMID: 24760061. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.24760061
198 Franko J, Puri DR, Goldman CD. Impact of radiation therapy sequence on survival among patients with resected pancreatic head ductal carcinoma. Ann Surg Oncol. 2012;191:26–30. PMID: 21735324. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.21735324
199 Fric P, Sedo A, Skrha J, . Early detection of sporadic pancreatic cancer: time for change. Eur J Gastroenterol Hepatol. 2017;298:885–891. PMID: 28471824. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.28471824
200 Fristrup C, Detlefsen S, Hansen CP, Ladekarl M. Danish pancreatic cancer database. Clin Epidemiol. 2016;8:645–648. PMID: 27822112. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E102.27822112
201 Fujii T, Kato K, Kodera Y, . Prognostic impact of pancreatic margin status in the intraductal papillary mucinous neoplasms of the pancreas. Surgery. 2010;1482:285–90. PMID: 20434746. KQ1E6, KQ2E6, KQ3E6, KQ4E10, KQ5E6.20434746
202 Fujino Y, Suzuki Y, Yoshikawa T, . Outcomes of surgery for intraductal papillary mucinous neoplasms of the pancreas. World J Surg. 2006;3010:1909–14; discussion 1915. PMID: 16850142. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.16850142
203 Fukuda Y, Yamada D, Eguchi H, . CT Density in the pancreas is a promising imaging predictor for pancreatic ductal adenocarcinoma. Ann Surg Oncol. 2017;249:2762–2769. PMID: 28634666. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.28634666
204 Fusai G, Warnaar N, Sabin CA, . Outcome of R1 resection in patients undergoing pancreatico-duodenectomy for pancreatic cancer. Eur J Surg Oncol. 2008;3412:1309–15. PMID: 18325723. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E6.18325723
205 Fusaroli P, Spada A, Mancino MG, Caletti G. Contrast harmonic echo-endoscopic ultrasound improves accuracy in diagnosis of solid pancreatic masses. Clin Gastroenterol Hepatol. 2010;87:629–34.e1–2. PMID: 20417721. KQ1E9, KQ2E6, KQ3E9, KQ4E1, KQ5E1.20417721
206 Gaag NA, Rauws EA, Eijck CH, . Preoperative biliary drainage for cancer of the head of the pancreas. New Engl J Med. 2010;3622:129–137. PMID: CN-00729627. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.
207 Gangl O, Froschl U, Fugger R. Surgical quality data and survival after pancreatic cancer resections: a comparison of results for octogenarians and younger patients. Wien Klin Wochenschr. 2014;12623–24:757–61. PMID: 25249303. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E6.25249303
208 Gangl O, Sahora K, Kornprat P, . Preparing for prospective clinical trials: a national initiative of an excellence registry for consecutive pancreatic cancer resections. World J Surg. 2014;382:456–62. PMID: 24121365. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E6.24121365
209 Gaujoux S, Brennan MF, Gonen M, . Cystic lesions of the pancreas: changes in the presentation and management of 1,424 patients at a single institution over a 15-year time period. J Am Coll Surg. 2011;2124:590–600; discussion 600–3. PMID: 21463795. KQ1E10, KQ2E9, KQ3E9, KQ4E6, KQ5E6.21463795
210 Ge L, Pan B, Song F, . Comparing the diagnostic accuracy of five common tumour biomarkers and CA19-9 for pancreatic cancer: a protocol for a network meta-analysis of diagnostic test accuracy. BMJ Open. 2017;712:e018175. PMID: 29282264. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E12.29282264
211 Ge PS, Gaddam S, Keach JW, . Early predictors for surgical referral in patients with pancreatic cystic lesions undergoing endoscopic ultrasound: results from a large multicenter cohort study. Pancreas. 2016;451:51–57. PMID: CN-01209243. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E12.
212 Gemmel C, Eickhoff A, Helmstadter L, Riemann JF. Pancreatic cancer screening: state of the art. Expert Rev Gastroenterol Hepatol. 2009;31:89–96. PMID: 19210116. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.19210116
213 Gianotti L, Tamini N, Gavazzi F, . Consequences of increases in antibiotic resistance pattern on outcome of pancreatic resection for cancer. J Gastrointest Surg. 2017;5:5. PMID: 28681215. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.28681215
214 Gilliam AD, Lobo DN, Rowlands BJ, Beckingham IJ. The ‘two-week’ target for the diagnosis of pancreatic carcinoma: an achievable aim? Eur J Surg Oncol. 2003;297:575–9. PMID: 12943622. KQ1E9, KQ2E9, KQ3E9, KQ4E1, KQ5E1.12943622
215 Giovinazzo F, Turri G, Katz MH, . Meta-analysis of benefits of portal-superior mesenteric vein resection in pancreatic resection for ductal adenocarcinoma. Br J Surg. 2016;1033:179–91. PMID: 26663252. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.26663252
216 Girometti R, Pravisani R, Intini SG, . Evolution of incidental branch-duct intraductal papillary mucinous neoplasms of the pancreas: a study with magnetic resonance imaging cholangiopancreatography. World J Gastroenterol. 2016;2243:9562–9570. PMID: 27920477. KQ1E9, KQ2E6, KQ3E9, KQ4E1, KQ5E1.27920477
217 Glasgow RE, Jackson HH, Neumayer L, . Pancreatic resection in Veterans Affairs and selected university medical centers: results of the patient safety in surgery study. J Am Coll Surg. 2007;2046:1252–60. PMID: 17544083. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E12.17544083
218 Glasgow RE, Jackson HH, Neumayer L, . Pancreatic resection in Veterans Affairs and selected university medical centers: results of the patient safety in surgery study. J Am Coll Surg. 2007;2046:1252–60. PMID: 17544083. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.17544083
219 Glebova NO, Hicks CW, Tosoian JJ, . Outcomes of arterial resection during pancreatectomy for tumor presented at the vascular and endovascular surgery society paper session 2 at the 2015 Vascular Annual Meeting of the Society for Vascular Surgery, Chicago, Ill, June 17–20, 2015. J Vasc Surg. 2016;633:722–729.e1. PMID: CN-01171725. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E10.
220 Gnerlich JL, Luka SR, Deshpande AD, . Microscopic margins and patterns of treatment failure in resected pancreatic adenocarcinoma. Arch Surg. 2012;1478:753–60. PMID: 22911074. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E9.22911074
221 Goh BK, Tan YM, Cheow PC, . Cystic lesions of the pancreas: an appraisal of an aggressive resectional policy adopted at a single institution during 15 years. Am J Surg. 2006;1922:148–54. PMID: 16860621. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.16860621
222 Gomatos IP, Halloran C, Ghaneh P, . Management and outcome of 64 patients with pancreatic serous cystic neoplasms. Digest Surg. 2016;333:203–12. PMID: 26918360. KQ1E6e, KQ2E6e, KQ3E6e, KQ4E6e, KQ5E6e.26918360
223 Gomes RM, Bal M, Patkar S, . Unexpected benign histopathology after pancreatoduodenectomy for presumed malignancy: accepting the inevitable. Langenbecks Arch Surg. 2016;4012:169–79. PMID: 26811147. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.26811147
224 Gong Z, Holly EA, Bracci PM. Obesity and survival in population-based patients with pancreatic cancer in the San Francisco Bay area. Cancer Causes Control. 2012;2312:1929–37. PMID: 23015286. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.23015286
225 Gonzalo-Marin J, Vila JJ, Perez-Miranda M. Role of endoscopic ultrasound in the diagnosis of pancreatic cancer. World J Gastrointest Oncol. 2014;69:360–8. PMID: 25232461. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.25232461
226 Goshima S, Kanematsu M, Nishibori H, . CT of the pancreas: comparison of anatomic structure depiction, image quality, and radiation exposure between 320-detector volumetric images and 64-detector helical images. Radiology. 2011;2601:139–147. PMID: CN-00801245. KQ1E9, KQ2E10, KQ3E9, KQ4E1, KQ5E1.
227 Goto T, Matsumoto I, Toyama H, . Complications after laparoscopic distal pancreatectomy. Surgical Endoscopy and Other Interventional Techniques. Conference: 23rd International Congress of the European Association for Endoscopic Surgery, EAES 2015 Bucharest Romania. Conference Start: 20150603 Conference End: 20150606. Conference Publication: 2016;30:S136. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.
228 Govindarajan A, Tan JC, Baxter NN, . Variations in surgical treatment and outcomes of patients with pancreatic cancer: a population-based study. Ann Surg Oncol. 2008;151:175–85. PMID: 17909913. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.17909913
229 Grant FM, Protic M, Gonen M, . Intraoperative fluid management and complications following pancreatectomy. J Surg Oncol. 2013;1075:529–35. PMID: 23136127. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E6e.23136127
230 Greer JB, Brand RE. Screening for pancreatic cancer: current evidence and future directions. Gastroenterol Hepatol. 2007;312:929–38. PMID: 21960811. KQ1E3, KQ2E3, KQ3E3, KQ4E1, KQ5E1.21960811
231 Greer SE, Pipas JM, Sutton JE, . Effect of neoadjuvant therapy on local recurrence after resection of pancreatic adenocarcinoma. J Am Coll Surg. 2008;2063:451–7. PMID: 18308215. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E6.18308215
232 Grieser C, Heine G, Stelter L, . Morphological analysis and differentiation of benign cystic neoplasms of the pancreas using computed tomography and magnetic resonance imaging. Rofo. 2013;1853:219–27. PMID: 23196834. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.23196834
233 Groot VP, Rezaee N, Wu W, . Patterns, timing, and predictors of recurrence following pancreatectomy for pancreatic ductal adenocarcinoma. Ann Surg. 2018;2675:936–945. PMID: 28338509. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E62.28338509
234 Grose D, McIntosh D, Jamieson N, . The role of induction chemotherapy + chemoradiotherapy in localised pancreatic cancer: initial experience in Scotland. J Gastrointest Oncol. 2017;84:683–695. PMID: 28890819. KQ1E1, KQ2E1, KQ3E1, KQ4E8, KQ5E8.28890819
235 Grover S, Jajoo K. Screening for pancreatic cancer in high-risk populations. Gastroenterol Clin North Am. 2016;451:117–27. PMID: 26895684. KQ1E3, KQ2E3, KQ3E3, KQ4E1, KQ5E12.26895684
236 Gruppo M, Angriman I, Martella B, . Can pancreatic cancer be detected by adrenomedullin in patients with new-onset diabetes? The PaCANOD cohort study protocol. ANZ J Surg. 2017;3010:14262. PMID: 0. KQ1E1, KQ2E1, KQ3E1, KQ4E6d, KQ5E6d2.
237 Gudjonsson B. Pancreatic cancer: 80 years of surgery-percentage and repetitions. HPB Surg. 2016;2016:6839687. PMID: 27847403. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E102.27847403
238 Guo C, Chen X, Wang Z, . Differentiation of pancreatic neuroendocrine carcinoma from pancreatic ductal adenocarcinoma using magnetic resonance imaging: the value of contrast-enhanced and diffusion weighted imaging. Oncotarget. 2017;826:42962–42973. PMID: 28487490. KQ1E5, KQ2E5, KQ3E5, KQ4E1, KQ5E1.28487490
239 Guo Q, Kang M, Zhang B, . Elevated levels of CA 19-9 and CEA in pancreatic cancer-associated diabetes. J Cancer Res Clin Oncol. 2010;13611:1627–31. PMID: 20174821. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.20174821
240 Gupta PK, Turaga KK, Miller WJ, . Determinants of outcomes in pancreatic surgery and use of hospital resources. J Surg Oncol. 2011;1046:634–40. PMID: 21520092. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E6d.21520092
241 Halloran CM, Cox TF, Chauhan S, . Partial pancreatic resection for pancreatic malignancy is associated with sustained pancreatic exocrine failure and reduced quality of life: a prospective study. Pancreatology. 2011;116:535–45. PMID: 22094930. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.22094930
242 Halloran CM, Ghaneh P, Bosonnet L, . Complications of pancreatic cancer resection. Digest Surg. 2002;192:138–46. PMID: 11979003. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E3.11979003
243 Halloran CM, Ghaneh P, Costello ENeoptolemos JP. Trials of gene therapy for pancreatic carcinoma. Curr Gastroenterol Rep. 2005;73:165–9. PMID: 15913472. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.15913472
244 Hanada K, Okazaki A, Hirano N, . Effective screening for early diagnosis of pancreatic cancer. Best Pract Res Clin Gastroenterol. 2015;296:929–39. PMID: 26651254. KQ1E3, KQ2E3, KQ3E3, KQ4E1, KQ5E12.26651254
245 Harada T, Baril P, Gangeswaran R, . Identification of genetic alterations in pancreatic cancer by the combined use of tissue microdissection and array-based comparative genomic hybridisation. Br J Cancer. 2007;962:373–82. PMID: 17242705. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.17242705
246 Harada T, Chelala C, Crnogorac-Jurcevic T, Lemoine NR. Genome-wide analysis of pancreatic cancer using microarray-based techniques. Pancreatology. 2009;91–2:13–24. PMID: 19077451. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.19077451
247 Hardacre JM, Simo K, McGee MF, . Pancreatic resection in octogenarians. J Surg Res. 2009;1561:129–32. PMID: 19592032. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.19592032
248 Harima H, Kaino S, Shinoda S, . Differential diagnosis of benign and malignant branch duct intraductal papillary mucinous neoplasm using contrast-enhanced endoscopic ultrasonography. World J Gastroenterol. 2015;2120:6252–60. PMID: 26034360. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.26034360
249 Hartwig W, Gluth A, Hinz U, . Outcomes after extended pancreatectomy in patients with borderline resectable and locally advanced pancreatic cancer. Br J Surg. 2016;10312:1683–1694. PMID: 27686238. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.27686238
250 Hartwig W, Hackert T, Hinz U, . Pancreatic cancer surgery in the new millennium: better prediction of outcome. Ann Surg. 2011;2542:311–9. PMID: 21606835. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.21606835
251 Hasegawa S, Eguchi H, Tomokuni A, . Increased erythropoietin levels as a biomarker of pancreatic adenocarcinoma: a case report. Oncol Lett. 2016;112:1560–1566. doi: 10.3892/ol.2015.4057. Epub 2015 Dec 24. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E102.
252 Hashemi-Sadraei N, Gbolahan OB, Salfity H, . The ‘T’ now Matters: The Eighth Edition of the Union for International Cancer Control Classification of Pancreatic Adenocarcinoma. Am J Clin Oncol. 2017;2910:409. PMID: 0. KQ1E10, KQ2E10, KQ3E10, KQ4E1, KQ5E12.
253 Hashimoto D, Chikamoto A, Taki K, . Residual total pancreatectomy: short- and long-term outcomes. Pancreatology. 2016;164:646–51. PMID: 27189919. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.27189919
254 Hasselgren K, Halldestam I, Fraser MP, . Does the introduction of laparoscopic distal pancreatectomy jeopardize patient safety and well-being? Scand J Surg. 2016; PMID: 2692928226929282. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E10.
255 Hassenpflug M, Hinz U, Strobel O, . Teres ligament patch reduces relevant morbidity after distal pancreatectomy (the DISCOVER randomized controlled trial). Ann Surg. 2016;2645:723–730. PMID: 27455155. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.27455155
256 Hatzaras I, Schmidt C, Klemanski D, . Pancreatic resection in the octogenarian: a safe option for pancreatic malignancy. J Am Coll Surg. 2011;2123:373–7. PMID: 21227721. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E62.21227721
257 Hazard L, Tward JD, Szabo A, Shrieve DC. Radiation therapy is associated with improved survival in patients with pancreatic adenocarcinoma: results of a study from the Surveillance, Epidemiology, and End Results (SEER) registry data. Cancer. 2007;11010:2191–201. PMID: 17918259. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.17918259
258 He J, Edil BH, Cameron JL, . Young patients undergoing resection of pancreatic cancer fare better than their older counterparts. J Gastrointest Surg. 2013;172:339–44. PMID: 23184271. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.23184271
259 He W, Zhao H, Chan W, . Underuse of surgical resection among elderly patients with early-stage pancreatic cancer. Surgery. 2015;1585:1226–34. PMID: 26138347. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E9.26138347
260 He XY, Li JF, Yao WY, Yuan YZ. Resolution of new-onset diabetes after radical pancreatic resection predicts long-term survival in patients with pancreatic ductal cell adenocarcinoma. Ann Surg Oncol. 2013;2012:3809–16. PMID: 23943021. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.23943021
261 Heerkens HD, Tseng DS, Lips IM, . Health-related quality of life after pancreatic resection for malignancy. Br J Surgery. 2016;1033:257–266. PMID: CN-01288888. KQ1E1, KQ2E1, KQ3E1, KQ4E6d, KQ5E6d2.
262 Heerkens HD, Tseng DS, Lips IM, . Health-related quality of life after pancreatic resection for malignancy. Br J Surgery. 2016;1033:257–266. PMID: CN-01288888. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.
263 Heerkens HD, Tseng DS, Lips IM, . Health-related quality of life after pancreatic resection for malignancy. Br J Surgery. 2016;1033:257–66. PMID: 26785646. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E6.26785646
264 Heerkens HD, van Berkel L, Tseng DS, . Long-term health-related quality of life after pancreatic resection for malignancy in patients with and without severe postoperative complications. HPB (Oxford). 2018;202:188–195. PMID: 29092792. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E62.29092792
265 Heinrich S, Pestalozzi B, Lesurtel M, . Adjuvant gemcitabine versus NEOadjuvant gemcitabine/oxaliplatin plus adjuvant gemcitabine in resectable pancreatic cancer: a randomized multicenter phase III study (NEOPAC study). BMC Cancer. 2011;11. PMID: CN-01016237. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.
266 Helm JF, Centeno BA, Coppola D, . Outcomes following resection of pancreatic adenocarcinoma: 20-year experience at a single institution. Cancer Control. 2008;154:288–94. PMID: 18813196. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.18813196
267 Helmstaedter L, Riemann JF. Pancreatic cancer-EUS and early diagnosis. Langenbecks Arch Surg. 2008;3936:923–7. PMID: 18247044. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.18247044
268 Hendifar AE, Chang JI, Huang BZ, . Cachexia, and not obesity, prior to pancreatic cancer diagnosis worsens survival and is negated by chemotherapy. J Gastrointest Oncol. 2018;91:17–23. PMID: 29564167. KQ1E1, KQ2E1, KQ3E1, KQ4E8, KQ5E82.29564167
269 Herrmann K, Erkan M, Dobritz M, . Comparison of 3’-deoxy-3’-[18F]fluorothymidine positron emission tomography (FLT PET) and FDG PET/CT for the detection and characterization of pancreatic tumours. Eur J Nucl Med Mol Imaging. 2012;395:846–51. PMID: 22278320. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.22278320
270 Hilendarov AD, Deenichin GP, Velkova KG. Imaging investigation of pancreatic cystic lesions and proposal for therapeutic guidelines. World J Radiol. 2012;48:372–8. PMID: 22937216. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.22937216
271 Hill JS, Zhou Z, Simons JP, . A simple risk score to predict in-hospital mortality after pancreatic resection for cancer. Ann Surg Oncol. 2010;177:1802–7. PMID: 20155401. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.20155401
272 Hippisley-Cox J, Coupland C. Identifying patients with suspected pancreatic cancer in primary care: derivation and validation of an algorithm. Br J Gen Pract. 2012;62594:e38–45. PMID: 22520674. KQ1E10, KQ2E10, KQ3E10, KQ4E1, KQ5E1.22520674
273 Hirata Y, Kobayashi T, Nishiumi S, . Identification of highly sensitive biomarkers that can aid the early detection of pancreatic cancer using GC/MS/MS-based targeted metabolomics. Clin Chim Acta. 2017;468:98–104. PMID: 28215548. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E12.28215548
274 Hocke M, Ignee A, Dietrich CF. Advanced endosonographic diagnostic tools for discrimination of focal chronic pancreatitis and pancreatic carcinoma-elastography, contrast enhanced high mechanical index (CEHMI) and low mechanical index (CELMI) endosonography in direct comparison. Zeitschr Gastroenterol. 2012;502:199–203. PMID: 22298098. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.22298098
275 Hoem D, Viste A. Improving survival following surgery for pancreatic ductal adenocarcinoma-a ten-year experience. Eur J Surg Oncol. 2012;383:245–51. PMID: 22217907. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E9.22217907
276 Hoffman DH, Ream JM, Hajdu CH, Rosenkrantz AB. Utility of whole-lesion ADC histogram metrics for assessing the malignant potential of pancreatic intraductal papillary mucinous neoplasms (IPMNs). Abdom Radiol (NY). 2017;424:1222–1228. PMID: 27900458. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.27900458
277 Hsu CC, Wolfgang CL, Laheru DA, . Early mortality risk score: identification of poor outcomes following upfront surgery for resectable pancreatic cancer. J Gastrointest Surg. 2012;164:753–61. PMID: 22311282. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E9.22311282
278 Hur C, Tramontano AC, Dowling EC, . Early pancreatic ductal adenocarcinoma survival is dependent on size: positive implications for future targeted screening. Pancreas. 2016;457:1062–6. PMID: 26692444. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E92.26692444
279 Huttner FJ, Fitzmaurice C, Schwarzer G, . Pylorus-preserving pancreaticoduodenectomy (pp Whipple) versus pancreaticoduodenectomy (classic Whipple) for surgical treatment of periampullary and pancreatic carcinoma. Cochrane Database Syst Rev. 2016;2:CD006053. PMID: 26905229. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E10.26905229
280 Iglesias-Garcia J, Larino-Noia J, Dominguez-Munoz JE. Early diagnosis of pancreatic cancer, time to screen high-risk individuals? Minerva Gastroenterol Diet. 2011;572:205–12. PMID: 21587149. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.21587149
281 Ikemoto J, Hanada K, Minami T, . Prospective follow-up study of the recurrence of pancreatic cancer diagnosed at an early stage: the value of endoscopic ultrasonography for early diagnosis of recurrence in the remnant pancreas. Pancreas. 2018;474:482–488. PMID: 29517631. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E62.29517631
282 Ikeuchi N, Itoi T, Sofuni A, . Prognosis of cancer with branch duct type IPMN of the pancreas. World J Gastroenterol. 2010;1615:1890–5. PMID: 20397268. KQ1E10, KQ2E9, KQ3E9, KQ4E1, KQ5E1.20397268
283 Ikezawa K, Uehara H, Sakai A, . Risk of peritoneal carcinomatosis by endoscopic ultrasound-guided fine needle aspiration for pancreatic cancer. J Gastroenterol. 2013;488:966–72. PMID: 23065024. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.23065024
284 Illes D, Terzin V, Holzinger G, . New-onset type 2 diabetes mellitus-A high-risk group suitable for the screening of pancreatic cancer? Pancreatology. 2016;162:266–71. PMID: 26777407. KQ1E10, KQ2E12, KQ3E9, KQ4E1, KQ5E1.26777407
285 Imamura M, Doi R, Imaizumi T, . A randomized multicenter trial comparing resection and radiochemotherapy for resectable locally invasive pancreatic cancer. Surgery. 2004;1365:1003–11. PMID: 15523393. KQ1E1, KQ2E1, KQ3E1, KQ4E10c, KQ5E9.15523393
286 Imazu H, Kanazawa K, Mori N, . Novel quantitative perfusion analysis with contrast-enhanced harmonic EUS for differentiation of autoimmune pancreatitis from pancreatic carcinoma. Scand J Gastroenterol. 2012;477:853–60. PMID: 22507131. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.22507131
287 Imbe K, Nagata N, Hisada Y, . Validation of the American Gastroenterological Association guidelines on management of intraductal papillary mucinous neoplasms: more than 5 years of follow-up. Eur Radiol. 2018;28(1):170–178. PMID: 28770404. KQ1E10, KQ2E6, KQ3E9, KQ4E1, KQ5E1.28770404
288 Ingkakul T, Sadakari Y, Ienaga J, . Predictors of the presence of concomitant invasive ductal carcinoma in intraductal papillary mucinous neoplasm of the pancreas. Ann Surg. 2010;2511:70–5. PMID: 20009749. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.20009749
289 Inui K, Yoshino J, Miyoshi H, . Development of pancreatic ductal adenocarcinoma associated with intraductal papillary mucinous neoplasia. ISRN Gastroenterol. 2011;2011:940378. PMID: 22191040. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.22191040
290 Iott M, Neben-Wittich M, Quevedo JF, Miller RC. Adjuvant chemoradiotherapy for resected pancreas cancer. World J Gastrointest Surg. 2010;211:373–80. PMID: 21160900. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.21160900
291 Ippolito D, Allegranza P, Bonaffini PA, . Diagnostic accuracy of 256-detector row computed tomography in detection and characterization of incidental pancreatic cystic lesions. Gastroenterol Res Pract. 2015;2015:707546. PMID: 26136775. KQ1E10c, KQ2E10, KQ3E9, KQ4E1, KQ5E1.26136775
292 Iqbal J, Ragone A, Lubinski J, . The incidence of pancreatic cancer in BRCA1 and BRCA2 mutation carriers. Br J Cancer. 2012;10712:2005–9. PMID: 23099806. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E62.23099806
293 Iqbal N, Lovegrove RE, Tilney HS, . A comparison of pancreaticoduodenectomy with extended pancreaticoduodenectomy: a meta-analysis of 1909 patients. Eur J Surg Oncol. 2009;351:79–86. PMID: 18356005. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E6d.18356005
294 Itchins M, Arena J, Nahm CB, . Retrospective cohort analysis of neoadjuvant treatment and survival in resectable and borderline resectable pancreatic ductal adenocarcinoma in a high volume referral centre. Eur J Surg Oncol. 2017;439:1711–1717. PMID: 28688722. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E8.28688722
295 Jaap K, Fluck M, Hunsinger M, . Analyzing the impact of compliance with national guidelines for pancreatic cancer care using the National Cancer Database. J Gastrointest Surg. 2018;2810:018–3742. PMID: 0. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E62.
296 Jabbar KS, Verbeke C, Hyltander AG, . Proteomic mucin profiling for the identification of cystic precursors of pancreatic cancer. J Natl Cancer Inst. 2014;1062. PMID: CN-01209493. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E12.
297 James TA, Sheldon DG, Rajput A, . Risk factors associated with earlier age of onset in familial pancreatic carcinoma. Cancer. 2004;10112:2722–6. PMID: 15534880. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.15534880
298 James TA, Gibbs JF. Pancreatic cancer screening: identifying premalignant disease. Future Oncol. 2005;12:191–5. PMID: 16555989. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.16555989
299 Jang DK, Lee SH, Lee JK, . Comparison of cytological and histological preparations in the diagnosis of pancreatic malignancies using endoscopic ultrasound-guided fine needle aspiration. Hepatobiliary Pancreat Dis Int. 2017;164:418–423. PMID: 28823373. KQ1E10b, KQ2E10b, KQ3E10b, KQ4E1, KQ5E1.28823373
300 Jang JY, Kang JS, Han Y, . Long-term outcomes and recurrence patterns of standard versus extended pancreatectomy for pancreatic head cancer: a multicenter prospective randomized controlled study. J Hepatobiliary Pancreat Sci. 2017;247:426–433. PMID: 28514000. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.28514000
301 Jang JY, Kang MJ, Heo JS, . A prospective randomized controlled study comparing outcomes of standard resection and extended resection, including dissection of the nerve plexus and various lymph nodes, in patients with pancreatic head cancer. Ann Surg. 2014;2594:656–64. PMID: 24368638. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E6.24368638
302 Jang KM, Kim SH, Kim YK, . Missed pancreatic ductal adenocarcinoma: assessment of early imaging findings on prediagnostic magnetic resonance imaging. Eur J Radiol. 2015;848:1473–9. PMID: 26032128. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E1, KQ5E1.26032128
303 Jenssen C, Kahl S. Management of incidental pancreatic cystic lesions. Viszeralmedizin. 2015;311:14–24. PMID: 26288611. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.26288611
304 Jiang HY, Kohtakangas EL, Asai K, Shum JB. Predictive power of the NSQIP risk calculator for early post-operative outcomes after Whipple: experience from a regional center in Northern Ontario. J Gastrointest Cancer. 2018;49(3):288–294. PMID: 28462447. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.28462447
305 Jones MJ, Buchanan AS, Neal CP, . Imaging of indeterminate pancreatic cystic lesions: a systematic review. Pancreatology. 2013;134:436–42. PMID: 23890144. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.23890144
306 Jooste V, Dejardin O, Bouvier V, . Pancreatic cancer: wait times from presentation to treatment and survival in a population-based study. Int J Cancer. 2016;1395:1073–80. PMID: 27130333. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E62.27130333
307 Kalogeraki A, Papadakis GZ, Tamiolakis D, . EUS - fine- needle aspiration biopsy (fnab) in the diagnosis of pancreatic adenocarcinoma: a review. Rom J Intern Med. 2016;541:24–30. PMID: 27141567. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.27141567
308 Kamal S, Firpo MA, Scaife CL, . Plasma basigin as an early detection biomarker for pancreatic adenocarcinoma. Cancer research. Conference: AACR special conference on pancreatic cancer: innovations in research and treatment 214 New Orleans, LA United States. Conference start: 214518 conference end: 214521. Conference publication: (var.pagings). 2015;7513 SUPPL. 1) (no pagination:. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E12.
309 Kamata K, Kitano M, Kudo M, . Value of EUS in early detection of pancreatic ductal adenocarcinomas in patients with intraductal papillary mucinous neoplasms.[Erratum appears in Endoscopy. 2014 Apr;46(4):358]. Endoscopy. 2014;461:22–9. PMID: 24218310. KQ1E10a, KQ2E6, KQ3E9, KQ4E1, KQ5E1.24218310
310 Kamisawa T, Wood LD, Itoi T, Takaori K. Pancreatic cancer. Lancet. 2016;38810039:73–85. PMID: 26830752. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.26830752
311 Kamphues C, Bova R, Schricke D, . Postoperative complications deteriorate long-term outcome in pancreatic cancer patients. Ann Surg Oncol. 2012;193:856–63. PMID: 21879265. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E6d.21879265
312 Kang HJ, Lee JM, Joo I, . Assessment of malignant potential in intraductal papillary mucinous neoplasms of the pancreas: comparison between multidetector CT and MR imaging with MR cholangiopancreatography. Radiology. 2016;2791:128–39. PMID: 26517448. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.26517448
313 Kang JS, Jang JY, Heo JS, . Long-term outcomes and recurrence patterns of standard versus extended pancreatectomy in terms with pancreatic head cancer-a multicenter prospective randomized controlled study. Journal of hepato-biliary-pancreatic sciences. Conference: joint congress of the 6th biennial congress of the asian-pacific hepato-pancreato-biliary association and the 29th meeting of japanese society of hepato-biliary-pancreatic surgery. Japan. 2017;24:A162. PMID: 28514000. KQ1E1, KQ2E1, KQ3E1, KQ4E8, KQ5E8.
314 Kang KM, Lee JM, Shin CI, . Added value of diffusion-weighted imaging to MR cholangiopancreatography with unenhanced mr imaging for predicting malignancy or invasiveness of intraductal papillary mucinous neoplasm of the pancreas. J Magn Reson Imaging. 2013;383:555–63. PMID: 23390008. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.23390008
315 Kang MJ, Jang JY, Lee KB, . Long-term prospective cohort study of patients undergoing pancreatectomy for intraductal papillary mucinous neoplasm of the pancreas: implications for postoperative surveillance. Ann Surg. 2014;2602:356–63. PMID: 24378847. KQ1E1, KQ2E1, KQ3E1, KQ4E9, KQ5E9.24378847
316 Kantor O, Talamonti MS, Sharpe S, . Laparoscopic pancreaticoduodenectomy for adenocarcinoma provides short-term oncologic outcomes and long-term overall survival rates similar to those for open pancreaticoduodenectomy. Am J Surg. 2017;2133:512–515. PMID: 28049562. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.28049562
317 Kargozaran H, Vu V, Ray P, . Invasive IPMN and MCN: same organ, different outcomes? Ann Surg Oncol. 2011;182:345–51. PMID: 20809175. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.20809175
318 Kasi PM, Pedersen KS, McWilliams RR. BRCA2-associated pancreatic cancer and current screening guidelines. Cancer. 2015;12117:3046. PMID: 26018189. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.26018189
319 Kassauei K, Habbe N, Mullendore ME, . Mitochondrial DNA mutations in pancreatic cancer. Int J Gastrointest Cancer. 2006;372–3:57–64. PMID: 17827523. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.17827523
320 Kasumova GG, Eskander MF, de Geus SW, . Regional variation in the treatment of pancreatic adenocarcinoma: decreasing disparities with multimodality therapy. Surgery. 2017;1622:275–284. PMID: 28487044. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E6.28487044
321 Katuchova J, Bober J, Radonak J. Postoperative complications and survival rates for pancreatic cancer patients. Wien Klin Wochenschr. 2011;1233–4:94–9. PMID: 21253778. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E6.21253778
322 Katz MH, Savides TJ, Moossa AR, Bouvet M. An evidence-based approach to the diagnosis and staging of pancreatic cancer. Pancreatology. 2005;56:576–90. PMID: 16110256. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.16110256
323 Kauhanen S, Rinta-Kiikka I, Kemppainen J, . Accuracy of 18F-FDG PET/CT, multidetector CT, and MR imaging in the diagnosis of pancreatic cysts: a prospective single-center study. J Nucl Med. 2015;568:1163–8. PMID: 26045314. KQ1E10, KQ2E6, KQ3E9, KQ4E1, KQ5E1.26045314
324 Kauhanen SP, Komar G, Seppanen MP, . A prospective diagnostic accuracy study of 18F-fluorodeoxyglucose positron emission tomography/computed tomography, multidetector row computed tomography, and magnetic resonance imaging in primary diagnosis and staging of pancreatic cancer. Ann Surg. 2009;2506:957–63. PMID: 19687736. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.19687736
325 Kaur S, Smith LM, Patel A, . A combination of MUC5AC and CA19-9 improves the diagnosis of pancreatic cancer: a multicenter study. Am J Gastroenterol. 2017;1121:172–183. PMID: CN-01300667. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E12.
326 Kawada N, Tanaka S, Uehara H, . Feasibility of second-generation transabdominal ultrasound-elastography to evaluate solid pancreatic tumors: preliminary report of 36 cases. Pancreas. 2012;416:978–80. PMID: 22781915. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.22781915
327 Kawai M, Murakami Y, Motoi F, . Grade B pancreatic fistulas do not affect survival after pancreatectomy for pancreatic cancer: a multicenter observational study. Surgery. 2016;1602:293–305. PMID: 27083480. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.27083480
328 Keane MG, Horsfall L, Rait G, Pereira SP. A case-control study comparing the incidence of early symptoms in pancreatic and biliary tract cancer. BMJ Open. 2014;411:e005720. PMID: 25410605. KQ1E10, KQ2E10, KQ3E9, KQ4E1, KQ5E1.25410605
329 Kelly KJ, Greenblatt DY, Wan Y, . Risk stratification for distal pancreatectomy utilizing ACS-NSQIP: preoperative factors predict morbidity and mortality. J Gastrointest Surg. 2011;152:250–9, discussion 259–61. PMID: 21161427. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.21161427
330 Kendal WS. Pancreatectomy versus conservative management for pancreatic cancer: a question of lead-time bias. Am J Clin Oncol. 2015;385:483–8. PMID: 24064752. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E9.24064752
331 Kendrick ML, Cusati D. Total laparoscopic pancreaticoduodenectomy: feasibility and outcome in an early experience. Arch Surg. 2010;1451:19–23. PMID: 20083750. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.20083750
332 Khaled YS, Mohsin M, Fatania K, . Outcome of long interval radiological surveillance of side branch pancreatic duct-involved intraductal papillary mucinous neoplasm in selected patients. HPB (Oxford). 2016;1811:879–885. PMID: 27591177. KQ1E10, KQ2E6, KQ3E9, KQ4E10, KQ5E9.27591177
333 Khannoussi W, Vullierme MP, Rebours V, . The long term risk of malignancy in patients with branch duct intraductal papillary mucinous neoplasms of the pancreas. Pancreatology. 2012;123:198–202. PMID: CN-01005122. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E62.
334 Khannoussi W, Vullierme MP, Rebours V, . The long term risk of malignancy in patients with branch duct intraductal papillary mucinous neoplasms of the pancreas. Pancreatology. 2012;123:198–202. PMID: CN-01005122. KQ1E10, KQ2E6, KQ3E9, KQ4E1, KQ5E1.
335 Kharofa J, Tsai S, Kelly T, . Neoadjuvant chemoradiation with IMRT in resectable and borderline resectable pancreatic cancer. Radiother Oncol. 2014;1131:41–6. PMID: 25443499. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.25443499
336 Khashab MA, Kim K, Lennon AM, . Should we do EUS/FNA on patients with pancreatic cysts? The incremental diagnostic yield of EUS over CT/MRI for prediction of cystic neoplasms. Pancreas. 2013;424:717–21. PMID: 23558241. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.23558241
337 Kim AW, McCarthy WJ 3rd, Maxhimer JB, . Vascular complications associated with pancreaticoduodenectomy adversely affect clinical outcome. Surgery. 2002;1324:738–44; discussion 744–7. PMID: 12407360. KQ1E1, KQ2E1, KQ3E1, KQ4E9, KQ5E6.12407360
338 Kim ER, Bae SY, Lee KH, . Is health screening beneficial for early detection and prognostic improvement in pancreatic cancer? Gut Liver. 2011;52:194–9. PMID: 21814600. KQ1E10, KQ2E12, KQ3E9, KQ4E10, KQ5E9.21814600
339 Kim GE, Shin SS, Kim JW, . Incidental, small (< 3 cm), unilocular, pancreatic cysts: factors that predict lesion progression during imaging surveillance. Korean J Radiol. 2017;186:915–925. PMID: 29089824. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E62.29089824
340 Kim H, Song KB, Hwang DW, . A single-center experience with the laparoscopic Warshaw technique in 122 consecutive patients. Surg Endosc. 2016;309:4057–64. PMID: 26743107. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E10b.26743107
341 Kim HJ, Kim JS, Lee JM, . What is the reasonable option for elderly patients with incidental pancreatic cystic neoplasms? Follow-up observation versus surgical resection. Geriatr Gerontol Int. 2017;172:256–261. PMID: 26792664. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E6d, KQ5E6d.26792664
342 Kim J, Bamlet WR, Oberg AL, . Detection of early pancreatic ductal adenocarcinoma with thrombospondin-2 and CA19-9 blood markers. Sci Transl Med. 2017;9398:12. PMID: 28701476. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E12.28701476
343 Kim JE, Lee KT, Lee JK, . Clinical usefulness of carbohydrate antigen 19-9 as a screening test for pancreatic cancer in an asymptomatic population. J Gastroenterol Hepatol. 2004;192:182–6. PMID: 14731128. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E1.14731128
344 Kim KW, Park SH, Pyo J, . Imaging features to distinguish malignant and benign branch-duct type intraductal papillary mucinous neoplasms of the pancreas: a meta-analysis. Ann Surg. 2014;2591:72–81. PMID: 23657084. KQ1E9, KQ2E6, KQ3E6, KQ4E1, KQ5E1.23657084
345 Kim R, Tan A, Lai KK, . Prognostic roles of human equilibrative transporter 1 (hENT-1) and ribonucleoside reductase subunit M1 (RRM1) in resected pancreatic cancer. Cancer. 2011;11714:3126–34. PMID: 21264835. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.21264835
346 Kim SY, Fink MA, Perini M, . Age 80 years and over is not associated with increased morbidity and mortality following pancreaticoduodenectomy. ANZ J Surg. 2018;88(5):E445–E450. PMID: 28593708. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E9.28593708
347 Kim SY, Weinberg L, Christophi C, Nikfarjam M. The outcomes of pancreaticoduodenectomy in patients aged 80 or older: a systematic review and meta-analysis. HPB (Oxford). 2017;196:475–482. PMID: 28292633. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.28292633
348 Kim Y, Kim SC, Song KB, . Improved survival after palliative resection of unsuspected stage IV pancreatic ductal adenocarcinoma. HPB (Oxford). 2016;184:325–31. PMID: 27037201. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.27037201
349 Kimmey MB, Bronner MP, Byrd DR, Brentnall TA. Screening and surveillance for hereditary pancreatic cancer. Gastrointest Endosc. 2002;564 Suppl:S82–6. PMID: 12297755. KQ1E10a, KQ2E6, KQ3E6, KQ4E1, KQ5E12.12297755
350 Kimura H, Ohtsuka T, Matsunaga T, . Predictors and diagnostic strategies for early-stage pancreatic ductal adenocarcinoma: a retrospective study. Pancreas. 2015;447:1148–54. PMID: 26284536. KQ1E10a, KQ2E10, KQ3E9, KQ4E10a, KQ5E9.26284536
351 Kimura W, Moriya T, Hirai I, . Multicenter study of serous cystic neoplasm of the Japan Pancreas Society.[Erratum appears in Pancreas. 2013 Jan;42(1):186 Note: Hirai, Ichiro [added]]. Pancreas. 2012;413:380–7. PMID: 22415666. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.22415666
352 Kimura Y, Kikuyama M, Kodama Y. Acute pancreatitis as a possible indicator of pancreatic cancer: the importance of mass detection. Intern Med. 2015;5417:2109–14. PMID: 26328633. KQ1E9, KQ2E6, KQ3E9, KQ4E1, KQ5E1.26328633
353 King J, Kazanjian K, Matsumoto J, . Distal pancreatectomy: incidence of postoperative diabetes. J Gastrointest Surg. 2008;129:1548–53. PMID: 18543045. KQ1E1, KQ2E1, KQ3E1, KQ4E9, KQ5E6.18543045
354 Kinney T. Evidence-based imaging of pancreatic malignancies. Surg Clin North Am. 2010;902:235–49. PMID: 20362784. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.20362784
355 Kitano M, Sakamoto H, Komaki T, Kudo M. New techniques and future perspective of EUS for the differential diagnosis of pancreatic malignancies: contrast harmonic imaging. Digest Endosc. 2011;23: Suppl 1:46–50. PMID: 21535201. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.21535201
356 Klapman JB, Chang KJ, Lee JG, Nguyen P. Negative predictive value of endoscopic ultrasound in a large series of patients with a clinical suspicion of pancreatic cancer. Am J Gastroenterol. 2005;10012:2658–61. PMID: 16393216. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.16393216
357 Klein AP, Brune KA, Petersen GM, . Prospective risk of pancreatic cancer in familial pancreatic cancer kindreds. Cancer Res. 2004;647:2634–2638. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E12.
358 Kleive D, Sahakyan MA, Berstad AE, . Trends in indications, complications and outcomes for venous resection during pancreatoduodenectomy. Br J Surg. 2017;10411:1558–1567. PMID: 28815556. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E8.28815556
359 Klompmaker S, van Zoggel D, Watkins AA, . Nationwide evaluation of patient selection for minimally invasive distal pancreatectomy using American College of Surgeons’ National Quality Improvement Program. Ann Surg. 2017;266(6):1055–1061. PMID: 27607097. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.27607097
360 Kluger MD, Epelboym I, Schrope BA, . Single-institution experience with irreversible electroporation for T4 pancreatic cancer: first 50 patients. Ann Surg Oncol. 2016;235:1736–43. PMID: 26714959. KQ1E1, KQ2E1, KQ3E1, KQ4E8, KQ5E8.26714959
361 Kluijt I, Cats A, Fockens P, . Atypical familial presentation of FAMMM syndrome with a high incidence of pancreatic cancer: case finding of asymptomatic individuals by EUS surveillance. J Clin Gastroenterol. 2009;439:853–7. PMID: 19417680. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E1, KQ5E1.19417680
362 Kobayashi G, Fujita N, Maguchi H, . Natural history of branch duct intraductal papillary mucinous neoplasm with mural nodules: a Japan Pancreas Society multicenter study. Pancreas. 2014;434:532–8. PMID: 24717801. KQ1E9, KQ2E6, KQ3E9, KQ4E9, KQ5E9.24717801
363 Kochman ML. EUS in pancreatic cancer. Gastrointest Endosc. 2002;564 Suppl:S6–S12. PMID: 12297741. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.12297741
364 Kohli DR, Kapoor A, BouHaidar D, Vachhani R. Requirement of a single high-risk feature as an indication for EUS for the diagnosis of asymptomatic pancreatic cysts. Pancreatology. 2016;166:1015–1019. PMID: 27568846. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.27568846
365 Kong F, Zhu J, Kong X, . Rapid on-site evaluation does not improve endoscopic ultrasound-guided fine needle aspiration adequacy in pancreatic masses: a meta-analysis and systematic review. PLoS One. 2016;119:e0163056. PMID: 27657529. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.27657529
366 Konstantinidis IT, Vinuela EF, Tang LH, . Incidentally discovered pancreatic intraepithelial neoplasia: what is its clinical significance? Ann Surg Oncol. 2013;2011:3643–7. PMID: 23748606. KQ1E10a, KQ2E6d, KQ3E9, KQ4E1, KQ5E1.23748606
367 Konstantinou F, Syrigos KN, Saif MW. Pancreatic cancer: what about screening and detection? JOP. 2013;144:312–5. PMID: 23846915. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.23846915
368 Kostro J, Sledzinski Z. Quality of life after surgical treatment of pancreatic cancer. Acta Chir Belg. 2008;1086:679–84. PMID: 19241917. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.19241917
369 Kow AW, Sadayan NA, Ernest A, . Is pancreaticoduodenectomy justified in elderly patients? Surgeon. 2012;103:128–36. PMID: 22525414. KQ1E1, KQ2E1, KQ3E1, KQ4E9, KQ5E9.22525414
370 Krishna SG, Rao BB, Ugbarugba E, . Diagnostic performance of endoscopic ultrasound for detection of pancreatic malignancy following an indeterminate multidetector CT scan: a systemic review and meta-analysis. Surg Endosc. 2017;4:4. PMID: 28378082. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.28378082
371 Kromrey ML, Bulow R, Hubner J, . Prospective study on the incidence, prevalence and 5-year pancreatic-related mortality of pancreatic cysts in a population-based study. Gut. 2018;67(1):138–145. PMID: 28877981. KQ1E10, KQ2E10, KQ3E10, KQ4E1, KQ5E1.28877981
372 Kuhlmann KF, Gouma DJ, Wesseling JG. Adenoviral gene therapy for pancreatic cancer: where do we stand? Digest Surg. 2008;254:278–92. PMID: 18635930. KQ1E1, KQ2E1, KQ3E1, KQ4E3, KQ5E3.18635930
373 Kuhn Y, Koscielny A, Glowka T, . Postresection survival outcomes of pancreatic cancer according to demographic factors and socio-economic status. Eur J Surg Oncol. 2010;365:496–500. PMID: 19748206. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.19748206
374 Kulig P, Pach R, Pietruszka S, . Abdominal ultrasonography in detecting and surgical treatment of pancreatic carcinoma. Pol Przegl Chir. 2012;846:285–92. PMID: 22842740. KQ1E6, KQ2E6, KQ3E6, KQ4E9, KQ5E9.22842740
375 Kunstman JW, Fonseca AL, Ciarleglio MM, . Comprehensive analysis of variables affecting delayed gastric emptying following pancreaticoduodenectomy. J Gastrointest Surg. 2012;167:1354–61. PMID: 22450953. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.22450953
376 Kuroki-Suzuki S, Kuroki Y, Nasu K, . Pancreatic cancer screening employing noncontrast magnetic resonance imaging combined with ultrasonography. Jpn J Radiol. 2011;294:265–71. PMID: 21607840. KQ1E9, KQ2E12, KQ3E9, KQ4E1, KQ5E1.21607840
377 Kutlu OC, Lee JE, Katz MH, . Open pancreaticoduodenectomy case volume predicts outcome of laparoscopic approach: a population-based analysis. Ann Surg. 2018;267(3):552–560. PMID: 28045744. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E10.28045744
378 Kwok KH, Rizk J, Coleman M, Fenton-Lee D. Pancreaticoduodenectomy - outcomes from an Australian institution. ANZ J Surg. 2010;809:605–8. PMID: 20840402. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.20840402
379 Kwong WT, Lawson RD, Hunt G, . Rapid growth rates of suspected pancreatic cyst branch duct intraductal papillary mucinous neoplasms predict malignancy. Digest Dis Sci. 2015;609:2800–6. PMID: 25924899. KQ1E9, KQ2E6, KQ3E9, KQ4E9, KQ5E9.25924899
380 Lachter J, Cooperman JJ, Shiller M, . The impact of endoscopic ultrasonography on the management of suspected pancreatic cancer-a comprehensive longitudinal continuous evaluation. Pancreas. 2007;352:130–4. PMID: 17632318. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E12.17632318
381 Lafemina J, Katabi N, Klimstra D, . Malignant progression in IPMN: a cohort analysis of patients initially selected for resection or observation. Ann Surg Oncol. 2013;202:440–7. PMID: 23111706. KQ1E10, KQ2E6, KQ3E9, KQ4E1, KQ5E1.23111706
382 Lahat G, Ben Haim M, Nachmany I, . Pancreatic incidentalomas: high rate of potentially malignant tumors. J Am Coll Surg. 2009;2093:313–9. PMID: 19717035. KQ1E10, KQ2E9, KQ3E9, KQ4E10, KQ5E6.19717035
383 Lahat G, Sever R, Lubezky N, . Pancreatic cancer: surgery is a feasible therapeutic option for elderly patients. World J Surg Oncol. 2011;9:10. PMID: 21272335. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.21272335
384 Lahav M, Maor Y, Avidan B, . Nonsurgical management of asymptomatic incidental pancreatic cysts. Clin Gastroenterol Hepatol. 2007;57:813–7. PMID: 17544874. KQ1E10, KQ2E9, KQ3E9, KQ4E1, KQ5E12.17544874
385 Lahav M, Maor Y, Avidan B, . Nonsurgical management of asymptomatic incidental pancreatic cysts. Clin Gastroenterol Hepatol. 2007;57:813–7. PMID: 17544874. KQ1E10, KQ2E9, KQ3E9, KQ4E1, KQ5E1.17544874
386 Laitinen I, Sand J, Peromaa P, . Quality of life in patients with pancreatic ductal adenocarcinoma undergoing pancreaticoduodenectomy. Pancreatology. 2017;173:445–450. PMID: 28274687. KQ1E1, KQ2E1, KQ3E1, KQ4E6d, KQ5E6d2.28274687
387 Lakatos G, Balazs A, Kui B, . Pancreatic cancer: multicenter prospective data collection and analysis by the Hungarian Pancreatic Study Group. J Gastrointestin Liver Dis. 2016;252:219–25. PMID: 27308654. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E62.27308654
388 Lami G, Biagini MR, Galli A. Endoscopic ultrasonography for surveillance of individuals at high risk for pancreatic cancer. World J Gastrointest Endosc. 2014;67:272–85. PMID: 25031786. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.25031786
389 Larghi A, Verna EC, Lecca PG, Costamagna G. Screening for pancreatic cancer in high-risk individuals: a call for endoscopic ultrasound. Clin Cancer Res. 2009;156:1907–14. PMID: 19276278. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.19276278
390 Larsson SC, Hakansson N, Giovannucci E, Wolk A. Folate intake and pancreatic cancer incidence: a prospective study of Swedish women and men. J Natl Cancer Inst. 2006;986:407–13. PMID: 16537833. KQ1E10, KQ2E10, KQ3E10, KQ4E1, KQ5E1.16537833
391 Law JK, Hruban RH, Lennon AM. Management of pancreatic cysts: a multidisciplinary approach. Curr Opinion Gastroenterol. 2013;295:509–16. PMID: 23872487. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.23872487
392 Lawrence SA, Attiyeh MA, Seier K, . Should patients with cystic lesions of the pancreas undergo long-term radiographic surveillance? Results of 3024 patients evaluated at a single institution. Ann Surg. 2017;2663:536–544. PMID: 28657939. KQ1E10, KQ2E6, KQ3E9, KQ4E1, KQ5E1.28657939
393 Le AT, Huang B, Hnoosh D, . Effect of complications on oncologic outcomes after pancreaticoduodenectomy for pancreatic cancer. J Surg Res. 2017;214:1–8. PMID: 28624029. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.28624029
394 Le Scodan R, Mornex F, Partensky C, . Histopathological response to preoperative chemoradiation for resectable pancreatic adenocarcinoma: the French Phase II FFCD 9704-SFRO Trial. Am J Clin Oncol. 2008;316:545–52. PMID: 19060585. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.19060585
395 Leblanc JK, Rawl S, Juan M, . Endoscopic ultrasound-guided celiac plexus neurolysis in pancreatic cancer: a prospective pilot study of safety using 10mL versus 20mL alcohol. Diagn Ther Endosc. 2013;2013:327036. PMID: 23365492. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.23365492
396 Lee CH, Shingler G, Mowbray NG, . Surgical outcomes for duodenal adenoma and adenocarcinoma: a multicentre study in Australia and the United Kingdom. ANZ J Surg. 2017; PMID: 2812240528122405. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.
397 Lee DY, Schwartz JA, Wexelman B, . Outcomes of pancreaticoduodenectomy for pancreatic malignancy in octogenarians: an American College of Surgeons National Surgical Quality Improvement Program analysis. Am J Surg. 2014;2074:540–8. PMID: 24560585. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.24560585
398 Lee JH, Kim SA, Park HY, . New-onset diabetes patients need pancreatic cancer screening? J Clin Gastroenterol. 2012;467:e58–61. PMID: 22138846. KQ1E9, KQ2E7, KQ3E9, KQ4E1, KQ5E1.22138846
399 Lee KH, Lee SJ, Lee JK, . Prediction of malignancy with endoscopic ultrasonography in patients with branch duct-type intraductal papillary mucinous neoplasm.[Erratum appears in Pancreas. 2015 Jul;44(5):844]. Pancreas. 2014;438:1306–11. PMID: 25036913. KQ1E9, KQ2E6, KQ3E9, KQ4E10, KQ5E9.25036913
400 Lee LS, Saltzman JR, Bounds BC, . EUS-guided fine needle aspiration of pancreatic cysts: a retrospective analysis of complications and their predictors. Clin Gastroenterol Hepatol. 2005;33:231–6. PMID: 15765442. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E1.15765442
401 Lee SH, Shin CM, Park JK, . Outcomes of cystic lesions in the pancreas after extended follow-up. Digest Dis Sci. 2007;5210:2653–9. PMID: 17404855. KQ1E10, KQ2E9, KQ3E9, KQ4E1, KQ5E1.17404855
402 Lee SY, Allen PJ, Sadot E, . Distal pancreatectomy: a single institution’s experience in open, laparoscopic, and robotic approaches. J Am Coll Surg. 2015;2201:18–27. PMID: 25456783. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.25456783
403 Lee SY, Lee KT, Lee JK, . Long-term follow up results of intraductal papillary mucinous tumors of pancreas. J Gastroenterol Hepatol. 2005;209:1379–84. PMID: 16105124. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.16105124
404 Lefebvre AC, Maurel J, Boutreux S, . Pancreatic cancer: incidence, treatment and survival trends-1175 cases in Calvados (France) from 1978 to 2002. Gastroenterol Clin Biol. 2009;3310–11:1045–51. PMID: 19773140. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.19773140
405 Lekkerkerker SJ, Besselink MG, Busch OR, . Long-term follow-up of neoplastic pancreatic cysts without high-risk stigmata: how often do we change treatment strategy because of malignant transformation? Scand J Gastroenterol. 2016;519:1138–43. PMID: 27175891. KQ1E9, KQ2E6, KQ3E9, KQ4E1, KQ5E1.27175891
406 Lemke A, Laun FB, Klauss M, . Differentiation of pancreas carcinoma from healthy pancreatic tissue using multiple b-values: comparison of apparent diffusion coefficient and intravoxel incoherent motion derived parameters. Invest Radiol. 2009;4412:769–75. PMID: 19838121. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.19838121
407 Lener MR, Scott RJ, Wiechowska-Kozlowska A, . Serum concentrations of selenium and copper in patients diagnosed with pancreatic cancer. Cancer Res Treat. 2016;483:1056–64. PMID: 26727715. KQ1E10, KQ2E10, KQ3E9, KQ4E1, KQ5E12.26727715
408 Leng KM, Wang ZD, Zhao JB, . Impact of pancreatic margin status and lymph node metastases on recurrence after resection for invasive and noninvasive intraductal papillary mucinous neoplasms of the pancreas: a meta-analysis. Digest Surg. 2012;293:213–25. PMID: 22677789. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.22677789
409 Lennon AM, Manos LL, Hruban RH, . Role of a multidisciplinary clinic in the management of patients with pancreatic cysts: a single-center cohort study. Ann Surg Oncol. 2014;2111:3668–74. PMID: 24806116. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.24806116
410 Lennon AM, Canto MI. Pancreatic cysts - part 2: should we be less cyst centric? Pancreas. 2017;466:745–750. PMID: 28609361. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.28609361
411 Leonardi G, Marchi S, Falconi M, . PancPro as a tool for selecting families eligible for pancreatic cancer screening: an Italian study of incident cases. Dig Liver Dis. 2012;447:585–8. PMID: 22281375. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E102.22281375
412 Levy J, Tahiri M, Vanounou T, . Diagnostic laparoscopy with ultrasound still has a role in the staging of pancreatic cancer: a systematic review of the literature. HPB Surgery. 2016;2016:8092109. PMID: 27122655. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.27122655
413 Li D, Morris JS, Liu J, . Body mass index and risk, age of onset, and survival in patients with pancreatic cancer. JAMA. 2009;30124:2553–62. PMID: 19549972. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.19549972
414 Li D, Tanaka M, Brunicardi FC, . Association between somatostatin receptor 5 gene polymorphisms and pancreatic cancer risk and survival. Cancer. 2011;11713:2863–72. PMID: 21692047. KQ1E10, KQ2E7, KQ3E9, KQ4E10, KQ5E9.21692047
415 Li H, Hu Z, Chen J, Guo X. Comparison of ERCP, EUS, and ERCP combined with EUS in diagnosing pancreatic neoplasms: a systematic review and meta-analysis. Tumour Biol. 2014;359:8867–74. PMID: 24891188. KQ1E9, KQ2E6, KQ3E6, KQ4E9, KQ5E9.24891188
416 Li S, Tian B. Acute pancreatitis in patients with pancreatic cancer: timing of surgery and survival duration. Medicine. 2017;963:e5908. PMID: 28099352. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.28099352
417 Li XZ, Song J, Sun ZX, . Diagnostic performance of contrast-enhanced ultrasound for pancreatic neoplasms: a systematic review and meta-analysis. Digest Liver Dis. 2018;502:132–138. PMID: 29162410. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E12.29162410
418 Liao R, Yang J, Zhou BY, . Conditional survival of pancreatic ductal adenocarcinoma in surgical and nonsurgical patients: a retrospective analysis report from a single institution in China. World J Surg Oncol. 2015;13:196. PMID: 26048469. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.26048469
419 Lightner AM, Glasgow RE, Jordan TH, . Pancreatic resection in the elderly. J Am Coll Surg. 2004;1985:697–706. PMID: 15110802. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.15110802
420 Lim LG, Lakhtakia S, Ang TL, . Factors determining diagnostic yield of endoscopic ultrasound guided fine-needle aspiration for pancreatic cystic lesions: a multicentre Asian study. Digest Dis Sci. 2013;586:1751–7. PMID: 23314918. KQ1E9, KQ2E9, KQ3E9, KQ4E1, KQ5E1.23314918
421 Lim PW, Dinh KH, Sullivan M, . Thirty-day outcomes underestimate endocrine and exocrine insufficiency after pancreatic resection. HPB (Oxford). 2016;184:360–6. PMID: 27037206. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.27037206
422 Lin JL, Barthel JS, Keshishian J, . Negative predictive value of positron emission tomography/computed tomography in patients with a clinical suspicion of pancreatic cancer. Pancreas. 2011;405:653–6. PMID: 21602734. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.21602734
423 Linder S, Bostrom L, Nilsson B. Pancreatic carcinoma incidence and survival in Sweden in 1980–2000: a population-based study of 16,758 hospitalized patients with special reference to different therapies. Eur J Surg Oncol. 2007;335:616–22. PMID: 17317081. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.17317081
424 Lindquist CM, Miller FH, Hammond NA, Nikolaidis P. Pancreatic cancer screening. Abdom Radiol. 2017:1–9. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.
425 Lindquist CM, Miller FH, Hammond NA, Nikolaidis P. Pancreatic cancer screening. Abdom Radiol. 2018;432:264–272. PMID: 28840303. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.28840303
426 Liu Q, Liu A, Gao F, . Coupling technique of random amplified polymorphic DNA and nanoelectrochemical sensor for mapping pancreatic cancer genetic fingerprint. Int J Nanomed. 2011;6:2933–9. PMID: 22162652. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.22162652
427 Loehrer AP, Chang DC, Hutter MM, . Health insurance expansion and treatment of pancreatic cancer: does increased access lead to improved care? J Am Coll Surg. 2015;2216:1015–22. PMID: 26611798. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.26611798
428 Loren D, Kowalski T, Siddiqui A, . Influence of integrated molecular pathology test results on real-world management decisions for patients with pancreatic cysts: analysis of data from a national registry cohort. Diagn Pathol. 2016;11:5. PMID: 26790950. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E1.26790950
429 Lu C, Xu CF, Wan XY, . Screening for pancreatic cancer in familial high-risk individuals: a systematic review. World J Gastroenterol. 2015;2128:8678–86. PMID: 26229410. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.26229410
430 Lu C, Xu CF, Wan XY, . Screening for pancreatic cancer in familial high-risk individuals: a systematic review. World J Gastroenterol. 2015;2128:8678–86. PMID: 26229410. KQ1E10, KQ2E10, KQ3E10, KQ4E1, KQ5E12.26229410
431 Lu F, Soares KC, He J, . Neoadjuvant therapy prior to surgical resection for previously explored pancreatic cancer patients is associated with improved survival. Hepatobil Surg Nutr. 2017;63:144–153. PMID: 28652997. KQ1E1, KQ2E1, KQ3E1, KQ4E8, KQ5E8.28652997
432 Lu Y, Chen L, Li C, . Diagnostic utility of endoscopic ultrasonography-elastography in the evaluation of solid pancreatic masses: a meta-analysis and systematic review. Med Ultrason. 2017;192:150–158. PMID: 28440348. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E62.28440348
433 Lucas AL, Tarlecki A, Van Beck K, . Self-reported questionnaire detects family history of cancer in a pancreatic cancer screening program. J Genet Couns. 2016; PMID: 2803965728039657. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E92.
434 Maguchi H, Tanno S, Mizuno N, . Natural history of branch duct intraductal papillary mucinous neoplasms of the pancreas: a multicenter study in Japan. Pancreas. 2011;403:364–70. PMID: 21289527. KQ1E10a, KQ2E6, KQ3E9, KQ4E1, KQ5E1.21289527
435 Maire F, Couvelard A, Palazzo L, . Pancreatic intraepithelial neoplasia in patients with intraductal papillary mucinous neoplasms: the interest of endoscopic ultrasonography. Pancreas. 2013;428:1262–6. PMID: 24152960. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.24152960
436 Malak M, Masuda D, Ogura T, . Yield of endoscopic ultrasound-guided fine needle aspiration and endoscopic retrograde cholangiopancreatography for solid pancreatic neoplasms. Scand J Gastroenterol. 2016;513:360–7. PMID: 26365063. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.26365063
437 Malleo G, Maggino L, Marchegiani G, . Pancreatectomy with venous resection for pT3 head adenocarcinoma: perioperative outcomes, recurrence pattern and prognostic implications of histologically confirmed vascular infiltration. Pancreatology. 2017;175:847–857. PMID: 28843714. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.28843714
438 Marten A, Schmidt J, Debus J, . CapRI: final results of the open-label, multicenter, randomized phase III trial of adjuvant chemoradiation plus interferon-{alpha}2b (CRI) versus 5-FU alone for patients with resected pancreatic adenocarcinoma (PAC). J Clin Oncol. 2010;2818 Suppl:950. PMID: CN-00791233. KQ1E1, KQ2E1, KQ3E1, KQ4E6d, KQ5E6d.
439 Matsubayashi H. Familial pancreatic cancer and hereditary syndromes: screening strategy for high-risk individuals. J Gastroenterol. 2011;4611:1249–59. PMID: 21847571. KQ1E3, KQ2E3, KQ3E3, KQ4E1, KQ5E12.21847571
440 Matsumoto I, Murakami Y, Shinzeki M, . Proposed preoperative risk factors for early recurrence in patients with resectable pancreatic ductal adenocarcinoma after surgical resection: a multi-center retrospective study. Pancreatology. 2015;156:674–80. PMID: 26467797. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.26467797
441 Matsumoto I, Shirakawa S, Shinzeki M, . 18-Fluorodeoxyglucose positron emission tomography does not aid in diagnosis of pancreatic ductal adenocarcinoma. Clin Gastroenterol Hepatol. 2013;116:712–8. PMID: 23353642. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.23353642
442 Matthaei H, Schulick RD, Hruban RH, Maitra A. Cystic precursors to invasive pancreatic cancer. Nat Rev Gastroenterol Hepatol. 2011;83:141–50. PMID: 21383670. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.21383670
443 Mavros MN, Xu L, Maqsood H, . Perioperative blood transfusion and the prognosis of pancreatic cancer surgery: systematic review and meta-analysis. Ann Surg Oncol. 2015;2213:4382–91. PMID: 26293837. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.26293837
444 Mayerle J, Beyer G, Simon P, . Prospective cohort study comparing transient EUS guided elastography to EUS-FNA for the diagnosis of solid pancreatic mass lesions. Pancreatology. 2016;161:110–4. PMID: 26602088. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.26602088
445 Mayerle J, Kalthoff H, Reszka R, . Metabolic biomarker signature to differentiate pancreatic ductal adenocarcinoma from chronic pancreatitis. Gut. 2018;671:128–137. PMID: 28108468. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E12.28108468
446 Mbah N, Brown RE, St Hill CR, . Impact of post-operative complications on quality of life after pancreatectomy. JOP. 2012;134:387–93. PMID: 22797394. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.22797394
447 McDade TP, Hill JS, Simons JP, . A national propensity-adjusted analysis of adjuvant radiotherapy in the treatment of resected pancreatic adenocarcinoma. Cancer. 2010;11613:3257–66. PMID: 20564625. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E9.20564625
448 McWilliams RR, Maisonneuve P, Bamlet WR, . Risk factors for early-onset and very-early-onset pancreatic adenocarcinoma: a Pancreatic Cancer Case-Control Consortium (PanC4) analysis. Pancreas. 2016;452:311–6. PMID: 26646264. KQ1E1, KQ2E1, KQ3E1, KQ4E9, KQ5E9.26646264
449 Megibow AJ. Are we really closer to predicting the development of pancreatic cancer? Radiology. 2010;2543:642–6. PMID: 20177080. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.20177080
450 Mei M, Ni J, Liu D, . EUS elastography for diagnosis of solid pancreatic masses: a meta-analysis. Gastrointest Endosc. 2013;774:578–89. PMID: 23199646. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.23199646
451 Meinhold CL, Dodd KW, Jiao L, . Available carbohydrates, glycemic load, and pancreatic cancer: is there a link? Am J Epidemiol. 2010;17111:1174–1182. PMID: CN-00767100. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E12.
452 Melis M, Marcon F, Masi A, . The safety of a pancreaticoduodenectomy in patients older than 80 years: risk vs. benefits. HPB (Oxford). 2012;149:583–8. PMID: 22882194. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E6.22882194
453 Menon VG, Puri VC, Annamalai AA, . Outcomes of vascular resection in pancreaticoduodenectomy: single-surgeon experience. Am Surg. 2013;7910:1064–7. PMID: 24160800. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.24160800
454 Merkow RP, Bilimoria KY, Tomlinson JS, . Postoperative complications reduce adjuvant chemotherapy use in resectable pancreatic cancer. Ann Surg. 2014;2602:372–7. PMID: 24374509. KQ1E1, KQ2E1, KQ3E1, KQ4E9, KQ5E6.24374509
455 Mertz HR, Sechopoulos P, Delbeke D, Leach SD. EUS, PET, and CT scanning for evaluation of pancreatic adenocarcinoma. Gastrointest Endosc. 2000;523:367–371. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E12.
456 Mesic D, Rifatbegovic Z, Ljuca F, . Surgical treatment and complications of treating pancreatic tumor. Med Arh. 2011;655:308–11. PMID: 22073859. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E52.22073859
457 Mesleh MG, Stauffer JA, Bowers SP, Asbun HJ. Cost analysis of open and laparoscopic pancreaticoduodenectomy: a single institution comparison. Surg Endosc. 2013;2712:4518–23. PMID: 23943116. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.23943116
458 Metreveli RE, Sahm K, Abdel-Misih R, Petrelli NJ. Major pancreatic resections for suspected cancer in a community-based teaching hospital: lessons learned. J Surg Oncol. 2007;953:201–6. PMID: 17323334. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.17323334
459 Michl P, Ripka S, Gress T, Buchholz M. Screening technologies for target identification in pancreatic cancer. Cancers. 2010;31:79–90. PMID: 24212607. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.24212607
460 Miller-Ocuin JL, Zenati MS, Ocuin LM, . Failure to treat: audit of an institutional cancer registry database at a large comprehensive cancer center reveals factors affecting the treatment of pancreatic cancer. Ann Surg Oncol. 2017;248:2387–2396. PMID: 28534079. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E9.28534079
461 Minato Y, Kamisawa T, Tabata T, . Pancreatic cancer causing acute pancreatitis: a comparative study with cancer patients without pancreatitis and pancreatitis patients without cancer. J Hepatobil Pancreat Sci. 2013;206:628–33. PMID: 23494612. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.23494612
462 Mishra MV, Champ CE, Keith SW, . Conditional survival probabilities for patients with resected pancreatic adenocarcinoma. Am J Clin Oncol. 2014;372:107–11. PMID: 23111364. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E9.23111364
463 Miura JT, Krepline AN, George B, . Use of neoadjuvant therapy in patients 75 years of age and older with pancreatic cancer. Surgery. 2015;1586:1545–55. PMID: 26243342. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.26243342
464 Mizuno S, Isayama H, Nakai Y, . Prevalence of pancreatic cystic lesions is associated with diabetes mellitus and obesity: an analysis of 5296 individuals who underwent a preventive medical examination. Pancreas. 2017;466:801–805. PMID: 28609369. KQ1E9, KQ2E12, KQ3E9, KQ4E1, KQ5E12.28609369
465 Mizuno S, Nakai Y, Isayama H, . Risk factors and early signs of pancreatic cancer in diabetes: screening strategy based on diabetes onset age. J Gastroenterol. 2013;482:238–46. PMID: 22735942. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E102.22735942
466 Mocci E, Guillen-Ponce C, Earl J, . PanGen-Fam: Spanish registry of hereditary pancreatic cancer. Eur J Cancer. 2015;5114:1911–7. PMID: 26212471. KQ1E9, KQ2E6, KQ3E6, KQ4E9, KQ5E9.26212471
467 Mohamadnejad M, Mullady D, Early DS, . Increasing number of passes beyond 4 does not increase sensitivity of detection of pancreatic malignancy by endoscopic ultrasound-guided fine-needle aspiration. Clin Gastroenterol Hepatol. 2017;157:1071–1078.e2. PMID: 28025154. KQ1E10, KQ2E6, KQ3E9, KQ4E1, KQ5E1.28025154
468 Mohammad Alizadeh AH, Shahrokh S, Hadizadeh M, . Diagnostic potency of EUS-guided FNA for the evaluation of pancreatic mass lesions. Endosc Ultrasound. 2016;51:30–4. PMID: 26879164. KQ1E1, KQ2E10b, KQ3E10b, KQ4E1, KQ5E1.26879164
469 Mok SR, Ho HC, Gaughan JP, Elfant AB. Therapeutic endoscopy can be performed safely in an ambulatory surgical center: a multicenter, prospective study. Diagn Ther Endosc. 2016;2016. PMID: CN-01243673. KQ1E9, KQ2E6b, KQ3E6b, KQ4E1, KQ5E1.
470 Mollberg N, Rahbari NN, Koch M, . Arterial resection during pancreatectomy for pancreatic cancer: a systematic review and meta-analysis. Ann Surg. 2011;2546:882–93. PMID: 22064622. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E10.22064622
471 Moningi S, Walker AJ, Hsu CC, . Correlation of clinical stage and performance status with quality of life in patients seen in a pancreas multidisciplinary clinic. J Oncol Pract. 2015;112:e216–21. PMID: 25563703. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E10.25563703
472 Moody JS, Sawrie SM, Kozak KR, . Adjuvant radiotherapy for pancreatic cancer is associated with a survival benefit primarily in stage IIB patients. J Gastroenterol. 2009;441:84–91. PMID: 19159077. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E9.19159077
473 Morganti AG, Valentini V, Macchia G, . Adjuvant radiotherapy in resectable pancreatic carcinoma. Eur J Surg Oncol. 2002;285:523–30. PMID: 12217306. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E6.12217306
474 Moris M, Bridges MD, Pooley RA, . Association between advances in high-resolution cross-section imaging technologies and increase in prevalence of pancreatic cysts from 2005 to 2014. Clin Gastroenterol Hepatol. 2016;144:585–593 e3. PMID: 26370569. KQ1E10, KQ2E10, KQ3E9, KQ4E1, KQ5E12.26370569
475 Moriya T, Hashimoto Y, Traverso LW. The duration of symptoms predicts the presence of malignancy in 210 resected cases of pancreatic intraductal papillary mucinous neoplasms. J Gastrointest Surg. 2011;155:762–70; discussion 770–1. PMID: 21380634. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.21380634
476 Moriya T, Traverso W. Fate of the pancreatic remnant after resection for an intraductal papillary mucinous neoplasm: a longitudinal level II cohort study. Arch Surg. 2012;1476:528–34. PMID: 22351878. KQ1E10a, KQ2E6d, KQ3E9, KQ4E1, KQ5E1.22351878
477 Mornex F, Girard N, Scoazec JY, . Feasibility of preoperative combined radiation therapy and chemotherapy with 5-fluorouracil and cisplatin in potentially resectable pancreatic adenocarcinoma: the French SFRO-FFCD 97-04 Phase II trial. Int J Radiat Oncol Biol Physics. 2006;655:1471–1478. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E62.
478 Morris-Stiff G, Falk GA, Chalikonda S, Walsh RM. Natural history of asymptomatic pancreatic cystic neoplasms. HPB (Oxford). 2013;153:175–81. PMID: 23374357. KQ1E10a, KQ2E9, KQ3E9, KQ4E1, KQ5E1.23374357
479 Mosquera C, Vohra NA, Fitzgerald TL, Zervos EE. Discharge with pancreatic fistula after pancreaticoduodenectomy independently predicts hospital readmission. Am Surg. 2016;828:698–703. PMID: 27657584. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.27657584
480 Moss RA, Lee C. Current and emerging therapies for the treatment of pancreatic cancer. Onco Targets Ther. 2010;3:111–27. PMID: 20856847. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.20856847
481 Mueller M, Mason RA, Kratzer W, . Sonographically guided puncture of the pancreas: incidence of complications, and risk factors. J Med Ultrason. 2013;401:19–26. PMID: 27276920. KQ1E9, KQ2E7, KQ3E6, KQ4E1, KQ5E1.27276920
482 Mukewar SS, Sharma A, Phillip N, . Risk of pancreatic cancer in patients with pancreatic cysts and family history of pancreatic cancer. Clin Gastroenterol Hepatol. 2018; PMID: 2942578029425780. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E62.
483 Muller MW, Friess H, Kleeff J, . Is there still a role for total pancreatectomy?. Ann Surg. 2007;2466:966–74; discussion 974–5. PMID: 18043098. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.18043098
484 Murakami M, Nagai Y, Tenjin A, Tanaka Y. Proposed cut-off value of CA19-9 for detecting pancreatic cancer in patients with diabetes: a case-control study. Endocr J. 2018;11:11. PMID: 29643268. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E12.29643268
485 Murphy MM, Simons JP, Hill JS, . Pancreatic resection: a key component to reducing racial disparities in pancreatic adenocarcinoma. Cancer. 2009;11517:3979–90. PMID: 19514091. KQ1E1, KQ2E1, KQ3E1, KQ4E9, KQ5E9.19514091
486 Mutyal NN, Radosevich AJ, Bajaj S, . In vivo risk analysis of pancreatic cancer through optical characterization of duodenal mucosa. Pancreas. 2015;445:735–41. PMID: 25906443. KQ1E10a, KQ2E10a, KQ3E9, KQ4E1, KQ5E1.25906443
487 Nachmany I, Pencovich N, Ben-Yehuda A, . Laparoscopic distal pancreatectomy: learning curve and experience in a tertiary center. J Laparoendosc Adv Surg Tech A. 2016;266:470–4. PMID: 27149307. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.27149307
488 Nagai K, Doi R, Kida A, . Intraductal papillary mucinous neoplasms of the pancreas: clinicopathologic characteristics and long-term follow-up after resection. World J Surg. 2008;322:271–8; discussion 279–80. PMID: 18027021. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.18027021
489 Nagamachi S, Nishii R, Wakamatsu H, . The usefulness of (18)F-FDG PET/MRI fusion image in diagnosing pancreatic tumor: comparison with (18)F-FDG PET/CT. Ann Nucl Med. 2013;276:554–63. PMID: 23580090. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.23580090
490 Nagata N, Kawazoe A, Mishima S, . Development of pancreatic cancer, disease-specific mortality, and all-cause mortality in patients with nonresected IPMNs: a long-term cohort study. Radiology. 2016;2781:125–34. PMID: 26172534. KQ1E10, KQ2E6, KQ3E9, KQ4E10, KQ5E9.26172534
491 Nakagohri T, Asano T, Kenmochi T, . Long-term surgical outcome of noninvasive and minimally invasive intraductal papillary mucinous adenocarcinoma of the pancreas. World J Surg. 2002;269:1166–9. PMID: 12045867. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.12045867
492 Nakagohri T, Kinoshita T, Konishi M, . Surgical outcome of intraductal papillary mucinous neoplasms of the pancreas. Ann Surg Oncol. 2007;1411:3174–80. PMID: 17694416. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.17694416
493 Nakao A, Takeda S, Nomoto S, . Pancreatic head resection with segmental duodenectomy for pancreatic neoplasms. J Hepatobiliary Pancreat Sci. 2010;176:788–91. PMID: 19882374. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.19882374
494 Nakao M, Katayama K, Fukuda J, . Evaluating the ability to detect pancreatic lesions using a special ultrasonography examination focusing on the pancreas. Eur J Radiol. 2017;91:10–14. PMID: 28629555. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.28629555
495 Nakchbandi W, Muller H, Singer MV, . Effects of low-dose warfarin and regional chemotherapy on survival in patients with pancreatic carcinoma. Scand J Gastroenterol. 2006;419:1095–104. PMID: 16938724. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E8.16938724
496 Nanashima A, Abo T, Nonaka T, . Comparison of postoperative morbidity in elderly patients who underwent pancreatic resection. Hepatogastroenterology. 2012;59116:1141–6. PMID: 22580667. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.22580667
497 Nanashima A, Abo T, Sumida Y, . Comparison of results between pylorus-preserving pancreaticoduodenectomy and subtotal stomach-preserving pancreaticoduodenectomy: report at a single cancer institute. Hepatogastroenterology. 2013;60125:1182–8. PMID: 23803381. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.23803381
498 Nayar P, Chandak A, Gupta N, . Postoperative mortality following multi-modality therapy for pancreatic cancer: analysis of the SEER-Medicare data. J Surg Oncol. 2017;1152:158–163. PMID: 28133817. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E6.28133817
499 Nehra D, Oyarvide VM, Mino-Kenudson M, . Intraductal papillary mucinous neoplasms: does a family history of pancreatic cancer matter? Pancreatology. 2012;124:358–63. PMID: 22898638. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.22898638
500 Neoptolemos JP, Stocken DD, Dunn JA, . Meta-analysis of adjuvant chemoradiotherapy and chemotherapy for resectable pancreatic cancer including the final results of the ESPAC-1 trial. Br J Cancer. 2002;86 Suppl 1:S1. PMID: CN-00402073. KQ1E1, KQ2E1, KQ3E1, KQ4E8, KQ5E8.12085157
501 Newhook TE, LaPar DJ, Lindberg JM, . Morbidity and mortality of pancreaticoduodenectomy for benign and premalignant pancreatic neoplasms. J Gastrointest Surg. 2015;196:1072–7. PMID: 25801594. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.25801594
502 Ngamruengphong S, Li F, Zhou Y, . EUS and survival in patients with pancreatic cancer: a population-based study. Gastrointest Endosc. 2010;721:78–83, 83.e1–2. PMID: 20620274. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.20620274
503 Nichols MT, Russ PD, Chen YK. Pancreatic imaging: current and emerging technologies. Pancreas. 2006;333:211–20. PMID: 17003640. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.17003640
504 Nieveen van Dijkum EJ, Kuhlmann KF, Terwee CB, . Quality of life after curative or palliative surgical treatment of pancreatic and periampullary carcinoma. Br J Surg. 2005;924:471–7. PMID: 15672431. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.15672431
505 Nimura Y, Nagino M, Takao S, . Standard versus extended lymphadenectomy in radical pancreatoduodenectomy for ductal adenocarcinoma of the head of the pancreas: long-term results of a Japanese multicenter randomized controlled trial. J Hepatobil Pancreat Sci. 2012;193:230–41. PMID: 22038501. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.22038501
506 Nordby T, Ikdahl T, Bowitz Lothe IM, . Improved survival and quality of life in patients undergoing R1 pancreatic resection compared to patients with locally advanced unresectable pancreatic adenocarcinoma. Pancreatology. 2013;132:180–5. PMID: 23561977. KQ1E1, KQ2E1, KQ3E1, KQ4E8, KQ5E9.23561977
507 Nougaret S, Reinhold C, Chong J, . Incidental pancreatic cysts: natural history and diagnostic accuracy of a limited serial pancreatic cyst MRI protocol. Eur Radiology. 2014;245:1020–9. PMID: 24569848. KQ1E10a, KQ2E10a, KQ3E9, KQ4E1, KQ5E1.24569848
508 Oberaigner W, Ebenbichler C, Oberaigner K, . Increased cancer incidence risk in type 2 diabetes mellitus: results from a cohort study in Tyrol/Austria. BMC Public Health. 2014;14:1058. PMID: 25300498. KQ1E9, KQ2E9, KQ3E9, KQ4E1, KQ5E1.25300498
509 Ocuin LM, Miller-Ocuin JL, Novak SM, . Robotic and open distal pancreatectomy with celiac axis resection for locally advanced pancreatic body tumors: a single institutional assessment of perioperative outcomes and survival. HPB (Oxford). 2016;1810:835–842. PMID: 27506992. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.27506992
510 Oguro S, Shimada K, Kishi Y, . Perioperative and long-term outcomes after pancreaticoduodenectomy in elderly patients 80 years of age and older. Langenbecks Arch Surg. 2013;3984:531–8. PMID: 23462741. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.23462741
511 Ohno E, Hirooka Y, Kawashima H, . Natural history of pancreatic cystic lesions: a multicenter prospective observational study for evaluating the risk of pancreatic cancer. J Gastroenterol Hepatol. 2017;5:5. PMID: 28872701. KQ1E10a, KQ2E6, KQ3E9, KQ4E1, KQ5E1.28872701
512 Ohno E, Hirooka Y, Kawashima H, . Natural history of pancreatic cystic lesions: a multicenter prospective observational study for evaluating the risk of pancreatic cancer. J Gastroenterol Hepatol. 2018;331:320–328. PMID: 28872701. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E12.28872701
513 Ohno E, Itoh A, Kawashima H, . Malignant transformation of branch duct-type intraductal papillary mucinous neoplasms of the pancreas based on contrast-enhanced endoscopic ultrasonography morphological changes: focus on malignant transformation of intraductal papillary mucinous neoplasm. Pancreas. 2012;416:855–62. PMID: 22481289. KQ1E10a, KQ2E6, KQ3E9, KQ4E1, KQ5E1.22481289
514 Ohtsuka T, Ideno N, Aso T, . Role of endoscopic retrograde pancreatography for early detection of pancreatic ductal adenocarcinoma concomitant with intraductal papillary mucinous neoplasm of the pancreas. J Hepatobil Pancreat Sci. 2013;203:356–61. PMID: 22878836. KQ1E10a, KQ2E10b, KQ3E9, KQ4E1, KQ5E1.22878836
515 Ohtsuka T, Kono H, Tanabe R, . Follow-up study after resection of intraductal papillary mucinous neoplasm of the pancreas; special references to the multifocal lesions and development of ductal carcinoma in the remnant pancreas. Am J Surg. 2012;2041:44–8. PMID: 21996346. KQ1E10a, KQ2E6d, KQ3E9, KQ4E1, KQ5E1.21996346
516 Ohtsuka T, Tamura K, Ideno N, . Role of ERCP in the era of EUS-FNA for preoperative cytological confirmation of resectable pancreatic ductal adenocarcinoma. Surg Today. 2014;4410:1887–92. PMID: 24496980. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.24496980
517 Okabayashi T, Shima Y, Iwata J, . Is a surgical approach justified for octogenarians with pancreatic carcinoma? Projecting surgical decision making for octogenarian patients. Am J Surg. 2016;2125:896–902. PMID: 27262755. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E6.27262755
518 Okamura Y, Sano S, Sugiura T, . The 2012 International consensus guidelines of intraductal papillary mucinous neoplasms of the pancreas (Fukuoka criteria) predict the malignant potential, even in actual clinical situations. Pancreas. 2018;473:285–290. PMID: 29401172. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E62.29401172
519 Okano K, Hirao T, Unno M, . Postoperative infectious complications after pancreatic resection. Br J Surg. 2015;10212:1551–60. PMID: 26387569. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.26387569
520 Okano K, Suzuki Y. Strategies for early detection of resectable pancreatic cancer. World J Gastroenterol. 2014;2032:11230–40. PMID: 25170207. KQ1E3, KQ2E3, KQ3E3, KQ4E1, KQ5E1.25170207
521 Olson SH, Hsu M, Wiemels JL, . Serum immunoglobulin e and risk of pancreatic cancer in the prostate, lung, colorectal, and ovarian cancer screening trial. Cancer Epidemiol Biomark Prev. 2014;237:1414–1420. PMID: CN-01117235. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E12.
522 Oppong KW, Dawwas MF, Charnley RM, . EUS and EUS-FNA diagnosis of suspected pancreatic cystic neoplasms: Is the sum of the parts greater than the CEA? Pancreatology. 2015;155:531–7. PMID: 26375415. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E1.26375415
523 O’Reilly EM. Adjuvant therapy for pancreas adenocarcinoma: where are we going?. Exp Rev Anticancer Ther. 2011;112:173–7. PMID: 21342036. KQ1E1, KQ2E1, KQ3E1, KQ4E8, KQ5E8.21342036
524 Ortiz-Gonzalez J, Alvarez-Aguila NPMedina-Castro JM. Adjusted carbohydrate antigen 19-9. Correlation with histological grade in pancreatic adenocarcinoma. Anticancer Res. 2005;255:3625–7. PMID: 16101191. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.16101191
525 Otomi Y, Otsuka H, Terazawa K, . Comparing the performance of visual estimation and standard uptake value of f-18 fluorodeoxyglucose positron emission tomography/computed tomography for detecting malignancy in pancreatic tumors other than invasive ductal carcinoma. J Medical Invest. 2014;611–2:171–179. PMID: CN-01380952. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.
526 Ouaissi M, Sielezneff I, Pirro N, . Pancreatic cancer and pancreaticoduodenectomy in elderly patient: morbidity and mortality are increased. Is it the real life? Hepatogastroenterology. 2008;5588:2242–6. PMID: 19260514. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.19260514
527 Ozkan M, Cakiroglu M, Kocaman O, . Age-based computer-aided diagnosis approach for pancreatic cancer on endoscopic ultrasound images. Endosc Ultrasound. 2016;52:101–7. PMID: 27080608. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.27080608
528 Paiella S, De Pastena M, Pollini T, . Pancreaticoduodenectomy in patients >= 75 years of age: are there any differences with other age ranges in oncological and surgical outcomes? Results from a tertiary referral center. World J Gastroenterol. 2017;2317:3077–3083. PMID: 28533664. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E9c.28533664
529 Paik WH, Yoon H, Park DH, . Utility of endoscopic ultrasound (EUS)-guided fine-needle aspiration for peri-arterial soft tissue cuffs without identifiable pancreas mass on CT and EUS: a prospective comparative study. Ultrasound Med Biol. 2014;407:1463–8. PMID: 24642218. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.24642218
530 Pak LM, D’Angelica MI, DeMatteo RP, . Natural history of patients followed radiographically with mucinous cysts of the pancreas. J Gastrointest Surg. 2017; PMID: 2851631028516310. KQ1E10, KQ2E9, KQ3E9, KQ4E1, KQ5E1.
531 Pan XF, He M, Yu C, . Pancreatic juice mutation concentrations can help predict the grade of dysplasia in patients undergoing pancreatic surveillance. Am J Epidemiol. 2018;34786119:. PMID: 0. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E52.
532 Pandharipande PV, Heberle C, Dowling EC, . Targeted screening of individuals at high risk for pancreatic cancer: results of a simulation model. Radiology. 2015;2751:177–187. PMID: CN-01079887. KQ1E10, KQ2E10, KQ3E1, KQ4E1, KQ5E12.
533 Pandharipande PV, Heberle C, Dowling EC, . Targeted screening of individuals at high risk for pancreatic cancer: results of a simulation model. Radiology. 2015;2751:177–87. PMID: CN-01079887. KQ1E10, KQ2E10, KQ3E10, KQ4E1, KQ5E1.
534 Pandharipande PV, Heberle C, Dowling EC, . Targeted screening of individuals at high risk for pancreatic cancer: results of a simulation model.[Erratum appears in Radiology. 2016 Jan;278(1):306; PMID: 26691000]. Radiology. 2015;2751:177–87. PMID: 25393849. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.26691000
535 Pandharipande PV, Jeon A, Heberle CR, . Screening for pancreatic adenocarcinoma in BRCA2 mutation carriers: results of a disease simulation model. EBioMedicine. 2015;212:1980–6. PMID: 26844277. KQ1E10, KQ2E10, KQ3E10, KQ4E1, KQ5E1.26844277
536 Pang Y, Kartsonaki C, Guo Y, . Diabetes, plasma glucose and incidence of pancreatic cancer: a prospective study of 0.5 million Chinese adults and a meta-analysis of 22 cohort studies. Int J Cancer. 2017;140(8):1781–1788. PMID: 28063165. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E52.28063165
537 Pannala R, Basu A, Petersen GM, Chari ST. New-onset diabetes: a potential clue to the early diagnosis of pancreatic cancer. Lancet Oncol. 2009;101:88–95. PMID: 19111249. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.19111249
538 Papp R, Cseke L, Horvath OP, Kelemen D. Middle segmental pancreatic resection-a single-centre experience. Hepatogastroenterology. 2011;58106:612–5. PMID: 21661441. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E10.21661441
539 Pappas S, Federle MP, Lokshin AE, Zeh HJ, . Early detection and staging of adenocarcinoma of the pancreas. Gastroenterol Clin North Am. 2007;362:413–29, x. PMID: 17533087. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.17533087
540 Park HJ, Jang KM, Song KD, . Value of unenhanced MRI with diffusion-weighted imaging for detection of primary small (<=20 mm) solid pancreatic tumours and prediction of pancreatic ductal adenocarcinoma. Clin Radiol. 2017;4:4. PMID: 28784320. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.28784320
541 Park HJ, Jang KM, Song KD, . Value of unenhanced MRI with diffusion-weighted imaging for detection of primary small (</=20 mm) solid pancreatic tumours and prediction of pancreatic ductal adenocarcinoma. Clin Radiol. 2017;72(12):1076–1084. PMID: 28784320. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.28784320
542 Parker LA, Lumbreras B, Lopez T, . How useful is it clinically to analyse the K-ras mutational status for the diagnosis of exocrine pancreatic cancer? A systematic review and meta-analysis. Eur J Clin Invest. 2011;417:793–805. PMID: 21391995. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.21391995
543 Parmar AD, Vargas GM, Tamirisa NP, . Trajectory of care and use of multimodality therapy in older patients with pancreatic adenocarcinoma. Surgery. 2014;1562:280–9. PMID: 24851723. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.24851723
544 Parra-Membrives P, Martinez-Baena DSanchez-Sanchez F. Late biliary complications after pancreaticoduodenectomy. Am Surg. 2016;825:456–61. PMID: 27215728. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.27215728
545 Passot G, Lebeau R, Hervieu V, . Recurrences after surgical resection of intraductal papillary mucinous neoplasm of the pancreas: a single-center study of recurrence predictive factors. Pancreas. 2012;411:137–41. PMID: 22076564. KQ1E10a, KQ2E6, KQ3E6, KQ4E1, KQ5E1.22076564
546 Paye F, Micelli Lupinacci R, Bachellier P, . Distal pancreatectomy for pancreatic carcinoma in the era of multimodal treatment. Br J Surg. 2015;1023:229–36. PMID: 25533421. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.25533421
547 Pecorelli N, Balzano G, Capretti G, . Effect of surgeon volume on outcome following pancreaticoduodenectomy in a high-volume hospital. J Gastrointest Surg. 2012;163:518–23. PMID: 22083531. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.22083531
548 Pei Q, Zou X, Zhang X, . Diagnostic value of EUS elastography in differentiation of benign and malignant solid pancreatic masses: a meta-analysis. Pancreatology. 2012;125:402–8. PMID: 23127527. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.23127527
549 Pelaez-Luna M, Takahashi N, Fletcher JG, Chari ST. Resectability of presymptomatic pancreatic cancer and its relationship to onset of diabetes: a retrospective review of CT scans and fasting glucose values prior to diagnosis. Am J Gastroenterol. 2007;10210:2157–63. PMID: 17897335. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E10.17897335
550 Pellise M, Castells A, Gines A, . Clinical usefulness of KRAS mutational analysis in the diagnosis of pancreatic adenocarcinoma by means of endosonography-guided fine-needle aspiration biopsy. Aliment Pharmacol Ther. 2003;1710:1299–307. PMID: 12755843. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E1.12755843
551 Pendola F, Gadde R, Ripat C, . Pancreatic neck/body benign and low grade malignant tumors: is central pancreatectomy better than distal pancreatectomy? An update meta-analysis. Annals of Surgical Oncology. Conference: 69th Annual Cancer Symposium of the Society of Surgical Oncology Boston, MA United States. Conference Start: 20160302 Conference End: 20160305. Conference Publication: (var.pagings). 2016;231 suppl. 1:S167–s168. PMID: CN-01173671. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E10.
552 Pendola F, Gadde R, Ripat C, . Distal pancreatectomy for benign and low grade malignant tumors: short-term postoperative outcomes of spleen preservation-a systematic review and update meta-analysis. J Surg Oncol. 2017;1152:137–143. PMID: 28133818. KQ1E9b, KQ2E9b, KQ3E9b, KQ4E9b, KQ5E9b.28133818
553 Pendola F, Gadde R, Ripat C, . Distal pancreatectomy for benign and low grade malignant tumors: short-term postoperative outcomes of spleen preservation a systematic review and update meta-analysis. J Surg Oncol. 2017;1152:137–143. PMID: 28133818. KQ1E1, KQ2E1, KQ3E1, KQ4E6d, KQ5E6d2.28133818
554 Pergolini I, Sahora K, Ferrone CR, . Long-term risk of pancreatic malignancy in patients with branch duct intraductal papillary mucinous neoplasm in a referral center. Gastroenterology. 2017;21:21. PMID: 28739282. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.28739282
555 Petermann D, Demartines N, Schafer M. Severe postoperative complications adversely affect long-term survival after R1 resection for pancreatic head adenocarcinoma. World J Surg. 2013;378:1901–8. PMID: 23564215. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E6.23564215
556 Pezzilli R, Falconi M, Zerbi A, . Clinical and patient-reported outcomes after pancreatoduodenectomy for different diseases: a follow-up study. Pancreas. 2011;406:938–45. PMID: 21562441. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.21562441
557 Pezzilli R, Serra C, Calculli L, . Three-dimensional contrast-enhanced ultrasonography of intraductal papillary mucinous neoplasms of the pancreas: a comparison with magnetic resonance imaging. Pancreas. 2013;427:1164–8. PMID: 23770711. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.23770711
558 Pezzilli R, Calculli L. Branch-type intraductal papillary mucinous neoplasm of the pancreas: clinically and patient-reported outcomes. Pancreas. 2015;442:221–6. PMID: 25423561. KQ1E10, KQ2E10, KQ3E9, KQ4E1, KQ5E1.25423561
559 Philip PA, Chansky K, LeBlanc M, . Historical controls for metastatic pancreatic cancer: benchmarks for planning and analyzing single-arm phase II trials. Clin Cancer Res. 2014;2016:4176–85. PMID: 24914040. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.24914040
560 Picozzi VJ, Oh SY, Edwards A, . Five-year actual overall survival in resected pancreatic cancer: a contemporary single-institution experience from a multidisciplinary perspective. Ann Surg Oncol. 2017;246:1722–1730. PMID: 28054192. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.28054192
561 Pindak D, Tomas M, Dolnik J, . Morbidity, mortality and long term survival in patients with vascular resection in pancreatic cancer - single center experience. Neoplasma. 2017;643:460–463. PMID: 28253726. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.28253726
562 Piper MR, Freedman DM, Robien K, . Vitamin D-binding protein and pancreatic cancer: a nested case-control study. Am J Clin Nutr. 2015;1016:1206–15. PMID: 25904602. KQ1E10, KQ2E10, KQ3E10, KQ4E1, KQ5E1.25904602
563 Pisters PW, Wolff RA, Janjan NA, . Preoperative paclitaxel and concurrent rapid-fractionation radiation for resectable pancreatic adenocarcinoma: toxicities, histologic response rates, and event-free outcome. J Clin Oncol. 2002;2010:2537–44. PMID: 12011133. KQ1E1, KQ2E1, KQ3E1, KQ4E8, KQ5E8.12011133
564 Plotkin A, Ceppa EP, Zarzaur BL, . Reduced morbidity with minimally invasive distal pancreatectomy for pancreatic adenocarcinoma. HPB (Oxford). 2017;193:279–285. PMID: 28161217. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.28161217
565 Poruk KE, Firpo MA, Mulvihill SJ. Screening for pancreatic cancer. Adv Surg. 2014;48:115–36. PMID: 25293611. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.25293611
566 Postlewait LM, Ethun CG, McInnis MR, . A multicenter study of 349 pancreatic mucinous cystic neoplasms: preoperative risk factors for adenocarcinoma. Ann Surg Oncol. 2016;231 suppl. 1:S160. KQ1E6, KQ2E6, KQ3E6, KQ4E9, KQ5E92.
567 Postlewait LM, Ethun CG, McInnis MR, . A multicenter study of 349 pancreatic mucinous cystic neoplasms: preoperative risk factors for adenocarcinoma. Annals of Surgical Oncology. Conference: 69th Annual Cancer Symposium of the Society of Surgical Oncology Boston, MA United States. Conference Start: 20160302 Conference End: 20160305. Conference Publication: (var.pagings). 2016;231 suppl. 1:S160. PMID: CN-01173679. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E1.
568 Pugalenthi A, Protic M, Gonen M, . Postoperative complications and overall survival after pancreaticoduodenectomy for pancreatic ductal adenocarcinoma. J Surg Oncol. 2016;1132:188–93. PMID: 26678349. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.26678349
569 Qin J, Zhang B. Best combination of multiple diagnostic tests for screening purposes. Stat Med. 2010;2928:2905–19. PMID: 20862668. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.20862668
570 Qureshi A, Hassan U, Loya A, . Diagnostic utility of endoscopic ultrasound guided aspiration cytology in evaluation of pancreatic masses. J Coll Physicians Surg Pak. 2013;237:484–6. PMID: 23823952. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.23823952
571 Raigani S, Ammori J, Kim J, Hardacre JM. Trends in the treatment of resectable pancreatic adenocarcinoma. J Gastrointest Surg. 2014;181:113–23. PMID: 24002769. KQ1E1, KQ2E1, KQ3E1, KQ4E9, KQ5E9.24002769
572 Ramirez PJ, Vickers SM. Adenoviral gene therapy for pancreatic adenocarcinoma. Curr Surg. 2004;614:351–8. PMID: 15276339. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.15276339
573 Raptis DA, Fessas C, Belasyse-Smith P, Kurzawinski TR. Clinical presentation and waiting time targets do not affect prognosis in patients with pancreatic cancer. Surgeon. 2010;85:239–46. PMID: 20709279. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.20709279
574 Rautou PE, Levy P, Vullierme MP, . Morphologic changes in branch duct intraductal papillary mucinous neoplasms of the pancreas: a midterm follow-up study. Clin Gastroenterol Hepatol. 2008;67:807–14. PMID: 18304885. KQ1E9, KQ2E9, KQ3E9, KQ4E1, KQ5E1.18304885
575 Ravikumar R, Sabin C, Abu Hilal M, . Portal vein resection in borderline resectable pancreatic cancer: a United Kingdom multicenter study. J Am Coll Surg. 2014;2183:401–11. PMID: 24484730. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.24484730
576 Rebours V, Boutron-Ruault MC, Schnee M, . Risk of pancreatic adenocarcinoma in patients with hereditary pancreatitis: a national exhaustive series. Am J Gastroenterol. 2008;1031:111. PMID: . KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E12.
577 Reddymasu SC, Gupta N, Singh S, . Pancreato-biliary malignancy diagnosed by endoscopic ultrasonography in absence of a mass lesion on transabdominal imaging: prevalence and predictors. Digest Dis Sci. 2011;566:1912–6. PMID: 21188524. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.21188524
578 Rees JR, Macefield RC, Blencowe NS, . A prospective study of patient reported outcomes in pancreatic and peri-ampullary malignancy. World J Surg. 2013;3710:2443–53. PMID: 23716026. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.23716026
579 Ren S, Liu P, Zhou N, . Complications after pancreaticoduodenectomy for pancreatic cancer: a retrospective study. Int Surg. 2011;963:220–7. PMID: 22216700. KQ1E5, KQ2E5, KQ3E5, KQ4E1, KQ5E1.22216700
580 Renz BW, Khalil PN, Mikhailov M, . Pancreaticoduodenectomy for adenocarcinoma of the pancreatic head is justified in elderly patients: a retrospective cohort study. Int J Surg. 2016;28:118–25. PMID: 26906329. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E6.26906329
581 Riall TS, Sheffield KM, Kuo YF, . Resection benefits older adults with locoregional pancreatic cancer despite greater short-term morbidity and mortality. J Am Geriatr Soc. 2011;594:647–54. PMID: 21453378. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E9.21453378
582 Riall TS, Lillemoe KD. Underutilization of surgical resection in patients with localized pancreatic cancer. Ann Surg. 2007;2462:181–2. PMID: 17667494. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.17667494
583 Richter S, Uslar V, Tabriz N, Weyhe D. Progressive postresection program (pPRP) after pancreatic resection for malignancy and precancerous lesions. European surgical research. Conference: 133rd congress of the german society of surgery, DGCH 2016. Germany. 2016;571–2:76. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.
584 Rijkers AP, Valkema R, Duivenvoorden H, Jvan Eijck CH. Usefulness of F-18-fluorodeoxyglucose positron emission tomography to confirm suspected pancreatic cancer: a meta-analysis. Eur J Surg Oncol. 2014;407:794–804. PMID: 24755095. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.24755095
585 Risch HA, Yu H, Lu L, Kidd MS. Detectable symptomatology preceding the diagnosis of pancreatic cancer and absolute risk of pancreatic cancer diagnosis. Am J Epidemiol. 2015;1821:26–34. PMID: 26049860. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.26049860
586 Roch AM, Ceppa EP, Al-Haddad MA, . The natural history of main duct-involved, mixed-type intraductal papillary mucinous neoplasm: parameters predictive of progression. Ann Surg. 2014;2604:680–8; discussion 688–90. PMID: 25203885. KQ1E10a, KQ2E10a, KQ3E9, KQ4E1, KQ5E1.25203885
587 Roch AM, House MG, Cioffi J, . Significance of portal vein invasion and extent of invasion in patients undergoing pancreatoduodenectomy for pancreatic adenocarcinoma. J Gastrointest Surg. 2016;203:479–87; discussion 487. PMID: 26768008. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.26768008
588 Roch AM, Mehrabi S, Krishnan A, . Automated pancreatic cyst screening using natural language processing: a new tool in the early detection of pancreatic cancer. HPB (Oxford). 2015;175:447–53. PMID: 25537257. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.25537257
589 Rodrigues-Pinto E, Jalaj S, Grimm IS, Baron TH. Impact of EUS-guided fine-needle biopsy sampling with a new core needle on the need for onsite cytopathologic assessment: a preliminary study. Gastrointest Endosc. 2016;846:1040–1046. PMID: 27345131. KQ1E6e, KQ2E6e, KQ3E6e, KQ4E1, KQ5E1.27345131
590 Rodriguez-D’Jesus A, Fernandez-Esparrach G, Boadas J, . Impact of endoscopic ultrasonography (EUS) and EUS-guided fine-needle aspiration on the management of pancreatic cystic lesions. Eur J Gastroenterol Hepatol. 2016;289:1094–9. PMID: 27286570. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.27286570
591 Rodriguez-D’Jesus A, Fernandez-Esparrach G, Marra-Lopez C, . Adverse events of EUS-guided FNA of pancreatic cystic and solid lesions by using the lexicon proposed in an ASGE workshop: a prospective and comparative study. Gastrointest Endosc. 2016;834:780–4. PMID: 26301408. KQ1E10, KQ2E10, KQ3E6, KQ4E1, KQ5E1.26301408
592 Rosales-Velderrain A, Bowers SP, Goldberg RF, . National trends in resection of the distal pancreas. World J Gastroenterol. 2012;1832:4342–9. PMID: 22969197. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.22969197
593 Rosok BI, Marangos IP, Kazaryan AM, . Single-centre experience of laparoscopic pancreatic surgery. Br J Surg. 2010;976:902–9. PMID: 20474000. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.20474000
594 Rudloff U, Maker AV, Brennan MF, Allen PJ. Randomized clinical trials in pancreatic adenocarcinoma. Surg Oncol Clin North Am. 2010;191:115–50. PMID: 19914563. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.19914563
595 Ruf J, Lopez Hanninen E, Bohmig M, . Impact of FDG-PET/MRI image fusion on the detection of pancreatic cancer. Pancreatology. 2006;66:512–9. PMID: 17106215. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.17106215
596 Ruiz-Tovar J, Martin-Perez E, Fernandez-Contreras ME, . Identification of prognostic factors in pancreatic cancer. Cir Cir. 2011;794:313–22. PMID: 21951885. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2.21951885
597 Rulyak SJ, Kimmey MB, Veenstra DL, Brentnall TA. Cost-effectiveness of pancreatic cancer screening in familial pancreatic cancer kindreds. Gastrointest Endosc. 2003;571:23–9. PMID: 12518126. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.12518126
598 Rulyak SJ, Brentnall TA. Inherited pancreatic cancer: surveillance and treatment strategies for affected families. Pancreatology. 2001;15:477–85. PMID: 12120228. KQ1E10a, KQ2E12, KQ3E9, KQ4E1, KQ5E12.12120228
599 Rustagi T, Gleeson FC, Chari ST, . Endoscopic ultrasound fine-needle aspiration diagnosis of synchronous primary pancreatic adenocarcinoma and effects on staging and resectability. Clin Gastroenterol Hepatol. 2017;152:299–302.e4. PMID: 27539084. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.27539084
600 Rustemovic N, Kalauz M, Grubelic Ravic K, . Differentiation of pancreatic masses via endoscopic ultrasound strain ratio elastography using adjacent pancreatic tissue as the reference. Pancreas. 2017;463:347–351. PMID: 28099260. KQ1E1, KQ2E6, KQ3E1, KQ4E1, KQ5E1.28099260
601 Rustemovic N, Opacic D, Ostojic Z, . Comparison of elastography methods in patients with pancreatic masses. Endosc Ultrasound. 2014;3 Suppl 1:S4. PMID: 26425528. KQ1E9b, KQ2E9b, KQ3E9b, KQ4E9b, KQ5E9b.26425528
602 Ryozawa S, Iwano H, Taba K, . Genetic diagnosis of pancreatic cancer using specimens obtained by EUS-FNA. Digest Endosc. 2011;23: Suppl 1:43–5. PMID: 21535200. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.21535200
603 Sa Cunha A, Rault A, Beau C, . A single-institution prospective study of laparoscopic pancreatic resection. Arch Surg. 2008;1433:289–95; discussion 295. PMID: 18347277. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.18347277
604 Sadakari Y, Ohuchida K, Nakata K, . Invasive carcinoma derived from the nonintestinal type intraductal papillary mucinous neoplasm of the pancreas has a poorer prognosis than that derived from the intestinal type. Surgery. 2010;1476:812–7. PMID: 20060146. KQ1E9, KQ2E9, KQ3E9, KQ4E1, KQ5E1.20060146
605 Sadeghi A, Mohamadnejad M, Islami F, . Diagnostic yield of EUS-guided FNA for malignant biliary stricture: a systematic review and meta-analysis. Gastrointest Endosc. 2016;832:290–8.e1. PMID: 26422979. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.26422979
606 Sadr-Azodi O, Gudbjornsdottir S, Ljung R. Pattern of increasing HbA1c levels in patients with diabetes mellitus before clinical detection of pancreatic cancer - a population-based nationwide case-control study. Acta Oncologica. 2015;547:986–92. PMID: 25734801. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E1.25734801
607 Saftoiu A, Vilmann P, Gorunescu F, . Accuracy of endoscopic ultrasound elastography used for differential diagnosis of focal pancreatic masses: a multicenter study. Endoscopy. 2011;437:596–603. PMID: 21437851. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.21437851
608 Sagami R, Nishikiori H, Anami K, . Utility of endoscopic ultrasonography screening for small pancreatic cancer and proposal for a new scoring system for screening. Pancreas. 2018;472:257–264. PMID: 29329161. KQ1E9, KQ2E12, KQ3E9, KQ4E1, KQ5E12.29329161
609 Sahakyan MA, Edwin B, Kazaryan AM, . Perioperative outcomes and survival in elderly patients undergoing laparoscopic distal pancreatectomy. J Hepatobil Pancreat Sci. 2017;241:42–48. PMID: 27794204. KQ1E1, KQ2E1, KQ3E1, KQ4E8, KQ5E8.27794204
610 Sahakyan MA, Kazaryan AM, Rawashdeh M, . Laparoscopic distal pancreatectomy for pancreatic ductal adenocarcinoma: results of a multicenter cohort study on 196 patients. Surg Endosc. 2016;308:3409–18. PMID: 26514135. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.26514135
611 Sahakyan MA, Rosok BI, Kazaryan AM, . Impact of obesity on surgical outcomes of laparoscopic distal pancreatectomy: a Norwegian single-center study. Surgery. 2016;1605:1271–1278. PMID: 27498300. KQ1E1, KQ2E1, KQ3E1, KQ4E8, KQ5E8.27498300
612 Saito M, Ishihara T, Tada M, . Use of F-18 fluorodeoxyglucose positron emission tomography with dual-phase imaging to identify intraductal papillary mucinous neoplasm. Clin Gastroenterol Hepatol. 2013;112:181–6. PMID: 23142206. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.23142206
613 Sakamoto H, Harada S, Nishioka N, . A social program for the early detection of pancreatic cancer: the Kishiwada Katsuragi Project. Oncology. 2017;93: Suppl 1:89–97. PMID: 29258101. KQ1E10a, KQ2E6, KQ3E6, KQ4E1, KQ5E12.29258101
614 Salem AI, Alfi M, Winslow E, . Has survival following pancreaticoduodenectomy for pancreas adenocarcinoma improved over time? J Surg Oncol. 2015;1126:643–9. PMID: 26388048. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E6d.26388048
615 Sallinen V, Haglund C, Seppanen H. Outcomes of resected nonfunctional pancreatic neuroendocrine tumors: do size and symptoms matter? Surgery. 2015;1586:1556–63. PMID: 26070847. KQ1E6e, KQ2E6e, KQ3E6e, KQ4E6e, KQ5E6e.26070847
616 Salmiheimo A, Mustonen H, Stenman UH, . Systemic inflammatory response and elevated tumour markers predict worse survival in resectable pancreatic ductal adenocarcinoma. PLoS One. 2016;119:e0163064. PMID: 27632196. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E9.27632196
617 Salvia R, Crippa S, Falconi M, . Branch-duct intraductal papillary mucinous neoplasms of the pancreas: to operate or not to operate? Gut. 2007;568:1086–90. PMID: 17127707. KQ1E9, KQ2E9, KQ3E9, KQ4E1, KQ5E1.17127707
618 Samawi H, Yin Y, Lim HJ, Renouf DJ, Cheung WY. Primary care vs. oncology-driven surveillance following adjuvant chemotherapy in resected pancreas cancer. Journal of clinical oncology. Conference: 217 annual meeting of the american society of clinical oncology, ASCO. United states. 2017;3515 Supplement 1) (no pagination:. KQ1E1, KQ2E1, KQ3E1, KQ4E8, KQ5E82.
619 Samra JS, Bachmann RA, Choi J, . One hundred and seventy-eight consecutive pancreatoduodenectomies without mortality: role of the multidisciplinary approach. Hepatobil Pancreat Dis Int. 2011;104:415–21. PMID: 21813392. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.21813392
620 Sanchez-Cabus S, Adam JP, Pittau G, . Laparoscopic left pancreatectomy: early results after 115 consecutive patients. Surg Endosc. 2016;3010:4480–8. PMID: 26895905. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.26895905
621 Sandanayake NS, Andreola F, Camuzeaux S, . Serum ceacam1 in the preclinical diagnosis of pancreatic adenocarcinoma. Gut. Conference: British Society of Gastroenterology Annual General Meeting 21. United Kingdom. Conference start: 21322. Conference end: 21325. 2010;59:A82. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E12.
622 Sandanayake NS, Andreola F, Camuzeaux S, . Serum ceacam1 in the preclinical diagnosis of pancreatic adenocarcinoma. Gut. Conference: British Society of Gastroenterology Annual General Meeting 2010. United Kingdom. Conference start: 20100322. Conference end: 20100325. 2010;59:A82. KQ1E10, KQ2E10, KQ3E10, KQ4E1, KQ5E1.
623 Sandini M, Bernasconi DP, Fior D, . A high visceral adipose tissue-to-skeletal muscle ratio as a determinant of major complications after pancreatoduodenectomy for cancer. Nutrition. 2016;3211–12:1231–7. PMID: 27261062. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.27261062
624 Santema TB, Visser A, Busch OR, . Hospital costs of complications after a pancreatoduodenectomy. HPB (Oxford). 2015;178:723–31. PMID: 26082095. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.26082095
625 Santhosh S, Mittal BR, Bhasin D, . Role of (18)F-fluorodeoxyglucose positron emission tomography/computed tomography in the characterization of pancreatic masses: experience from tropics. J Gastroenterol Hepatol. 2013;282:255–61. PMID: 23278193. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.23278193
626 Santhosh S, Mittal BR, Bhasin D, . Dual-phase 18F-FDG PET/CT imaging in the characterization of pancreatic lesions: does it offer prognostic information? Nucl Med Commun. 2014;3510:1018–25. PMID: 25023999. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.25023999
627 Sato N, Fukushima N, Matsubayashi H, Goggins M. Identification of maspin and S100P as novel hypomethylation targets in pancreatic cancer using global gene expression profiling. Oncogene. 2004;238:1531–8. PMID: 14716296. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.14716296
628 Sauer BG, Shami VM. Survival in pancreatic cancer: the best is yet to come. Gastrointest Endosc. 2010;721:84–5. PMID: 20620275. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.20620275
629 Sawai Y, Yamao K, Bhatia V, . Development of pancreatic cancers during long-term follow-up of side-branch intraductal papillary mucinous neoplasms.[Erratum appears in Endoscopy. 2011 Jan;43(1):79]. Endoscopy. 2010;4212:1077–84. PMID: 21120776. KQ1E10a, KQ2E9, KQ3E9, KQ4E1, KQ5E1.21120776
630 Scheiman JM. Pancreatic cysts - part 1: using the American Gastroenterological Association Guidelines for the management of pancreatic cysts-a practical approach. Pancreas. 2017;466:742–744. PMID: 28609360. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.28609360
631 Schellhaas B, Vitali F, Wildner D, . Dynamics of Fukuoka criteria and patient management in pancreatic intraductal papillary mucinous neoplasms (IPMNS) during follow-up. Med Sci Monit. 2017;23:1483–1492. PMID: 28348359. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.28348359
632 Schietroma M, Pessia B, Carlei F, Amicucci G. Intestinal permeability changes, systemic endotoxemia, inflammatory serum markers and sepsis after Whipple’s operation for carcinoma of the pancreas head. Pancreatology. 2017;175:839–846. PMID: 28803860. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.28803860
633 Schmidt RL, Witt BL, Matynia AP, . Rapid on-site evaluation increases endoscopic ultrasound-guided fine-needle aspiration adequacy for pancreatic lesions. Digest Dis Sci. 2013;583:872–82. PMID: 23053888. KQ1E10, KQ2E10, KQ3E10, KQ4E1, KQ5E1.23053888
634 Schnelldorfer T, Sarr MG, Nagorney DM, . Experience with 208 resections for intraductal papillary mucinous neoplasm of the pancreas. Arch Surg. 2008;1437:639–46; discussion 646. PMID: 18645105. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.18645105
635 Seppanen H, Juuti A, Mustonen H, . The results of pancreatic resections and long-term survival for pancreatic ductal adenocarcinoma: a single-institution experience. Scand J Surg. 2017;1061:54–61. PMID: 27130378. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.27130378
636 Serrano OK, Chaudhry MA, Leach SD. The role of PET scanning in pancreatic cancer. Adv Surg. 2010;44:313–25. PMID: 20919529. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.20919529
637 Serrano PE, Cleary SP, Dhani N, . Improved long-term outcomes after resection of pancreatic adenocarcinoma: a comparison between two time periods. Ann Surg Oncol. 2015;224:1160–7. PMID: 25348784. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E9.25348784
638 Serrano PE, Herman JM, Griffith KA, . Quality of life in a prospective, multicenter phase 2 trial of neoadjuvant full-dose gemcitabine, oxaliplatin, and radiation in patients with resectable or borderline resectable pancreatic adenocarcinoma. Int J Radiat Oncol Biol Phys. 2014;902:270–7. PMID: 25104069. KQ1E1, KQ2E1, KQ3E1, KQ4E8, KQ5E8.25104069
639 Shah A, Chao KS, Ostbye T, . Trends in racial disparities in pancreatic cancer surgery. J Gastrointest Surg. 2013;1711:1897–906. PMID: 24002757. KQ1E1, KQ2E1, KQ3E1, KQ4E9, KQ5E9.24002757
640 Shah OJ, Gagloo MA, Khan IJ, . Pancreaticoduodenectomy: a comparison of superior approach with classical Whipple’s technique. Hepatobil Pancreat Dis Int. 2013;122:196–203. PMID: 23558075. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.23558075
641 Shaib Y, Davila J, Naumann C, El-Serag H. The impact of curative intent surgery on the survival of pancreatic cancer patients: a U.S. population-based study. Am J Gastroenterol. 2007;1027:1377–82. PMID: 17403071. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E9.17403071
642 Shamali A, De’Ath HD, Jaber B, . Elderly patients have similar short term outcomes and five-year survival compared to younger patients after pancreaticoduodenectomy. Int J Surg. 2017;45:138–143. PMID: 28782662. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E9c.28782662
643 Shapiro M, Chen Q, Huang Q, . Associations of socioeconomic variables with resection, stage, and survival in patients with early-stage pancreatic cancer. JAMA Surg. 2016;1514:338–45. PMID: 26581025. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E9.26581025
644 Shikano T, Nakao A, Kodera Y, . Middle pancreatectomy: safety and long-term results. Surgery. 2010;1471:21–9. PMID: 19682717. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.19682717
645 Shin SH, Kim SC, Song KB, . Appraisal of laparoscopic distal pancreatectomy for left-sided pancreatic cancer: a large volume cohort study of 152 consecutive patients. PLoS One. 2016;119:e0163266. PMID: 27636547. KQ1E1, KQ2E1, KQ3E1, KQ4E8, KQ5E8.27636547
646 Shin SS, Armao DM, Shah M, . Management of branch-duct intraductal papillary mucinous neoplasms of the pancreas: observation with MR imaging. Magn Reson Imaging. 2010;2810:1440–6. PMID: 20833500. KQ1E6d, KQ2E6, KQ3E6d, KQ4E1, KQ5E1.20833500
647 Shirai Y, Shiba H, Horiuchi T, . Assessment of outcome after pancreaticoduodenectomy by junior surgeons. Anticancer Res. 2016;367:3505–10. PMID: 27354615. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.27354615
648 Sho M, Murakami Y, Kawai M, . Prognosis after surgical treatment for pancreatic cancer in patients aged 80 years or older: a multicenter study. J Hepatobil Pancreat Sci. 2016;233:188–97. PMID: 26763744. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.26763744
649 Siddiqui AA, Tierney WM. The role of endoscopic ultrasound in the diagnosis and staging of pancreatic adenocarcinoma. J Okla State Med Assoc. 2005;9811:539–44. PMID: 16379483. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.16379483
650 Simons JP, Ng SC, Shah SA, . Malignant intraductal papillary mucinous neoplasm: are we doing the right thing? J Surg Res. 2011;1672:251–7. PMID: 19765732. KQ1E9, KQ2E9, KQ3E9, KQ4E1, KQ5E1.19765732
651 Smoot RL, Zhang L, Sebo TJ, Que FG. Adenosquamous carcinoma of the pancreas: a single-institution experience comparing resection and palliative care. J Am Coll Surg. 2008;2073:368–70. PMID: 18722942. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.18722942
652 Sohal DP, Shrotriya S, Glass KT, . Predicting early mortality in resectable pancreatic adenocarcinoma: a cohort study. Cancer. 2015;12111:1779–84. PMID: 25676016. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E9.25676016
653 Sohn TA, Yeo CJ, Cameron JL, . Intraductal papillary mucinous neoplasms of the pancreas: an updated experience. Ann Surg. 2004;2396:788–97; discussion 797–9. PMID: 15166958. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.15166958
654 Song KB, Kim SC, Park JB, . Single-center experience of laparoscopic left pancreatic resection in 359 consecutive patients: changing the surgical paradigm of left pancreatic resection. Surg Endosc. 2011;2510:3364–72. PMID: 21556993. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.21556993
655 Soroida Y, Sato M, Hikita H, . Pancreatic cysts in general population on ultrasonography: prevalence and development of risk score. J Gastroenterol. 2016;5112:1133–1140. PMID: 26988361. KQ1E9, KQ2E12, KQ3E9, KQ4E1, KQ5E1.26988361
656 Soyer OM, Baran B, Ormeci AC, . Role of biochemistry and cytological analysis of cyst fluid for the differential diagnosis of pancreatic cysts: a retrospective cohort study. Medicine. 2017;961:e5513. PMID: 28072692. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.28072692
657 Speer AG, Thursfield VJ, Torn-Broers YJefford M. Pancreatic cancer: surgical management and outcomes after 6 years of follow-up. Med J Aust. 2012;1968:511–5. PMID: 22571308. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.22571308
658 Spence RA, Dasari B, Love M, . Overview of the investigation and management of cystic neoplasms of the pancreas. Digest Surg. 2011;285–6:386–97. PMID: 22179508. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.22179508
659 Spier BJ, Johnson EA, Gopal DV, . Predictors of malignancy and recommended follow-up in patients with negative endoscopic ultrasound-guided fine-needle aspiration of suspected pancreatic lesions. Can J Gastroenterol. 2009;234:279–86. PMID: 19373422. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.19373422
660 Staub J, Siddiqui A, Taylor LJ, . Risk of pancreatic cancer in patients with pancreatic cysts and family history of pancreatic cancer. Gastrointest Endosc. 2018;618:30103–2. PMID: 0. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E12.
661 Stauffer JA, Coppola A, Mody K, Asbun HJ. Laparoscopic versus open distal pancreatectomy for pancreatic adenocarcinoma. World J Surg. 2016;406:1477–84. PMID: 26847665. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.26847665
662 Stoffel EM. Screening in GI cancers: the role of genetics. J Clin Oncol. 2015;3316:1721–8. PMID: 25918283. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.25918283
663 Stoita A, Penman ID, Williams DB. Review of screening for pancreatic cancer in high risk individuals. World J Gastroenterol. 2011;1719:2365–71. PMID: 21633635. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.21633635
664 Stolzenberg-Solomon RZ, Amundadottir LT. Epidemiology and inherited predisposition for sporadic pancreatic adenocarcinoma. Hematol Oncol Clin North Am. 2015;294:619–40. PMID: 26226901. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.26226901
665 Strobel O, Brangs S, Hinz U, . Incidence, risk factors and clinical implications of chyle leak after pancreatic surgery. Br J Surg. 2017;1041:108–117. PMID: 27763684. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.27763684
666 Strohl MP, Raigani S, Ammori JB, . Surgery for localized pancreatic cancer: the trend is not improving. Pancreas. 2016;455:687–93. PMID: 26491905. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E9.26491905
667 Struyvenberg MR, Fong ZV, Martin CR, . Impact of treatments on diabetic control and gastrointestinal symptoms after total pancreatectomy. Pancreas. 2017;469:1188–1195. PMID: 28902790. KQ1E1, KQ2E1, KQ3E1, KQ4E9, KQ5E9.28902790
668 Sud A, Wham D, Catalano M, Guda NM. Promising outcomes of screening for pancreatic cancer by genetic testing and endoscopic ultrasound. Pancreas. 2014;433:458–61. PMID: 24622079. KQ1E10a, KQ2E6, KQ3E9, KQ4E1, KQ5E1.24622079
669 Suenaga M, Yu J, Shindo K, . Pancreatic juice mutation concentrations can help predict the grade of dysplasia in patients undergoing pancreatic surveillance. Clin Cancer Res. 2018;24(12):2963–2974. PMID: 29301828. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E12.29301828
670 Sukharamwala P, Thoens J, Szuchmacher M, . Advanced age is a risk factor for post-operative complications and mortality after a pancreaticoduodenectomy: a meta-analysis and systematic review. HPB (Oxford). 2012;1410:649–57. PMID: 22954000. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.22954000
671 Sulpice L, Farges O, Goutte N, . Laparoscopic distal pancreatectomy for pancreatic ductal adenocarcinoma. Ann Surg. 2015;2625:868–74. PMID: CN-01134176. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.
672 Sultana A, Jackson R, Tim G, . What is the best way to identify malignant transformation within pancreatic IPMN: a systematic review and meta-analyses. Clin Transl Gastroenterol. 2015;6:e130. PMID: 26658837. KQ1E10a, KQ2E6, KQ3E9, KQ4E1, KQ5E1.26658837
673 Sun MR, Strickland CD, Tamjeedi B, . Utility of transabdominal ultrasound for surveillance of known pancreatic cystic lesions: prospective evaluation with MRI as reference standard. Abdom Radiol (NY). 2017;0:1–13. PMID: CN-01404098. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E12.
674 Sun MR, Strickland CD, Tamjeedi B, . Utility of transabdominal ultrasound for surveillance of known pancreatic cystic lesions: prospective evaluation with MRI as reference standard. Abdom Radiol (NY). 2017;0:1–13. PMID: 28765979. KQ1E9, KQ2E9, KQ3E9, KQ4E1, KQ5E1.28765979
675 Sutton JM, Kooby DA, Wilson GC, . Perioperative blood transfusion is associated with decreased survival in patients undergoing pancreaticoduodenectomy for pancreatic adenocarcinoma: a multi-institutional study. J Gastrointest Surg. 2014;189:1575–87. PMID: 24944151. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.24944151
676 Suzuki R, Thosani N, Annangi S, . Diagnostic yield of EUS-FNA-based cytology distinguishing malignant and benign IPMNs: a systematic review and meta-analysis. Pancreatology. 2014;145:380–4. PMID: 25278308. KQ1E10a, KQ2E6, KQ3E6, KQ4E1, KQ5E1.25278308
677 Suzuki S, Kaji S, Koike N, . Pancreaticoduodenectomy can be safely performed in the elderly. Surg Today. 2013;436:620–4. PMID: 23104552. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.23104552
678 Suzuki Y, Fujino Y, Ajiki T, . No mortality among 100 consecutive pancreaticoduodenectomies in a middle-volume center. World J Surg. 2005;2911:1409–14. PMID: 16222456. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.16222456
679 Suzuki Y, Okano K, Kuroda Y. Ultrasonic dissection versus conventional dissection techniques in pancreatic surgery: a randomized multicentre study. Ann Surg. 2015;2616:e150. PMID: 24263315. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.24263315
680 Swords DS, Mulvihill SJ, Skarda DE, . Hospital-level variation in utilization of surgery for clinical stage I-II pancreatic adenocarcinoma. Ann Surg. 2017;11:11. PMID: 28700442. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E9.28700442
681 Takagi K, Yagi T, Yoshida R, . Surgical outcome of patients undergoing pancreaticoduodenectomy: analysis of a 17-year experience at a single center. Acta Med Okayama. 2016;703:197–203. PMID: 27339209. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.27339209
682 Takahashi H, Ohigashi H, Ishikawa O, . Serum CA19-9 alterations during preoperative gemcitabine-based chemoradiation therapy for resectable invasive ductal carcinoma of the pancreas as an indicator for therapeutic selection and survival. Ann Surg. 2010;2513:461–9. PMID: 20134315. KQ1E1, KQ2E1, KQ3E1, KQ4E8, KQ5E8.20134315
683 Takeda Y, Saiura A, Takahashi Y, . Asymptomatic pancreatic cancer: does incidental detection impact long-term outcomes? J Gastrointest Surg. 2017;218:1287–1295. PMID: 28397027. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E6d, KQ5E6d.28397027
684 Takuma K, Kamisawa T, Anjiki H, . Predictors of malignancy and natural history of main-duct intraductal papillary mucinous neoplasms of the pancreas. Pancreas. 2011;403:371–5. PMID: 21206326. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.21206326
685 Talamonti MS. Screening strategies for pancreatic cancer in high-risk patients: opportunities to make a real impact but many questions and challenges still ahead. JAMA Surg. 2015;1506:518–9. PMID: 25853232. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.25853232
686 Tanaka S, Nakao M, Ioka T, . Slight dilatation of the main pancreatic duct and presence of pancreatic cysts as predictive signs of pancreatic cancer: a prospective study. Radiology. 2010;2543:965–72. PMID: 20177107. KQ1E6, KQ2E6, KQ3E6, KQ4E9, KQ5E9.20177107
687 Tang K, Lu W, Qin W, Wu Y. Neoadjuvant therapy for patients with borderline resectable pancreatic cancer: a systematic review and meta-analysis of response and resection percentages. Pancreatology. 2016;161:28–37. PMID: 26687001. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.26687001
688 Tani M, Kawai M, Terasawa H, . Complications with reconstruction procedures in pylorus-preserving pancreaticoduodenectomy. World J Surg. 2005;297:881–4. PMID: 15951940. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.15951940
689 Tanno S, Nakano Y, Nishikawa T, . Natural history of branch duct intraductal papillary-mucinous neoplasms of the pancreas without mural nodules: long-term follow-up results. Gut. 2008;573:339–43. PMID: 17660227. KQ1E10, KQ2E9, KQ3E9, KQ4E1, KQ5E1.17660227
690 Tapper EB, Martin D, Adsay NV, . An MRI-driven practice: a new perspective on MRI for the evaluation of adenocarcinoma of the head of the pancreas. J Gastrointest Surg. 2010;148:1292–7. PMID: 20467829. KQ1E1, KQ2E1, KQ3E1, KQ4E9, KQ5E9.20467829
691 The Lancet Oncology pancreatic cancer: cause for optimism? Lancet Oncol. 2016;177:845. PMID: 27396632. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.27396632
692 Thosani N, Thosani S, Qiao W, . Role of EUS-FNA-based cytology in the diagnosis of mucinous pancreatic cystic lesions: a systematic review and meta-analysis. Digest Dis Sci. 2010;5510:2756–66. PMID: 20694512. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E1.20694512
693 Tian X, Gao H, Ma Y, . Surgical treatment and prognosis of 96 cases of intraductal papillary mucinous neoplasms of the pancreas: a retrospective cohort study. Int J Surg. 2015;13:49–53. PMID: 25461854. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.25461854
694 Toft J, Hadden WJ, Laurence JM, . Imaging modalities in the diagnosis of pancreatic adenocarcinoma: a systematic review and meta-analysis of sensitivity, specificity and diagnostic accuracy. Eur J Radiol. 2017;92:17–23. PMID: 28624015. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.28624015
695 Toomey P, Hernandez J, Golkar F, . Pancreatic adenocarcinoma: complete tumor extirpation improves survival benefit despite larger tumors for patients who undergo distal pancreatectomy and splenectomy. J Gastrointest Surg. 2012;162:376–81. PMID: 22135126. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.22135126
696 Toriola AT, Stolzenberg-Solomon R, Dalidowitz L, . Diabetes and pancreatic cancer survival: a prospective cohort-based study. Br J Cancer. 2014;1111:181–5. PMID: 24786605. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E9.24786605
697 Touchefeu Y, Harrington KJ, Galmiche JP, Vassaux G. Review article: gene therapy, recent developments and future prospects in gastrointestinal oncology. Aliment Pharmacol Ther. 2010;328:953–68. PMID: 20937041. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.20937041
698 Tran Cao HS, Zhang Q, Sada YH, . Value of lymph node positivity in treatment planning for early stage pancreatic cancer. Surgery. 2017;1623:557–567. PMID: 28666686. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E6.28666686
699 Tsao RE, Almhanna K, Lazaryan A, . Is adjuvant radiation plus chemotherapy for resectable pancreatic adenocarcinoma associated with improved survival? The Cleveland Clinic experience. J Clin Oncol. 2008;2615_suppl:15528. PMID: 27947314. KQ1E1, KQ2E1, KQ3E1, KQ4E6d, KQ5E6d.
700 Tseng DS, Molenaar IQ, Besselink MG, . pancreatic exocrine insufficiency in patients with pancreatic or periampullary cancer: a systematic review. Pancreas. 2016;453:325–30. PMID: 26495777. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.26495777
701 Tseng JF, Raut CP, Lee JE, . Pancreaticoduodenectomy with vascular resection: margin status and survival duration. J Gastrointest Surg. 2004;88:935–49; discussion 949–50. PMID: 15585381. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.15585381
702 Tseng WW, Deganutti A, Chen MN, . Selective cyclooxygenase-2 inhibitor rofecoxib (Vioxx) induces expression of cell cycle arrest genes and slows tumor growth in human pancreatic cancer. J Gastrointest Surg. 2002;66:838–43; discussion 844. PMID: 12504222. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.12504222
703 Turrini O, Ychou M, Moureau-Zabotto L, . Neoadjuvant docetaxel-based chemoradiation for resectable adenocarcinoma of the pancreas: new neoadjuvant regimen was safe and provided an interesting pathologic response. Eur J Surg Oncol. 2010;3610:987–92. PMID: 20828979. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.20828979
704 Tzeng CW, Abbott DE, Cantor SB, . Frequency and intensity of postoperative surveillance after curative treatment of pancreatic cancer: a cost-effectiveness analysis. Ann Surg Oncol. 2013;207:2197–203. PMID: 23408126. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.23408126
705 Tzeng CW, Katz MH, Fleming JB, . Morbidity and mortality after pancreaticoduodenectomy in patients with borderline resectable type C clinical classification. J Gastrointest Surg. 2014;181:146–55; discussion 155–6. PMID: 24129825. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.24129825
706 Ueda M, Endo I, Nakashima M, . Prognostic factors after resection of pancreatic cancer. World J Surg. 2009;331:104–10. PMID: 19011933. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.19011933
707 Uehara H, Ishikawa O, Katayama K, . Size of mural nodule as an indicator of surgery for branch duct intraductal papillary mucinous neoplasm of the pancreas during follow-up. J Gastroenterol. 2011;465:657–63. PMID: 21085997. KQ1E10, KQ2E6, KQ3E9, KQ4E6, KQ5E6.21085997
708 Uehara H, Nakaizumi A, Ishikawa O, . Development of ductal carcinoma of the pancreas during follow-up of branch duct intraductal papillary mucinous neoplasm of the pancreas. Gut. 2008;5711:1561–5. PMID: 18477671. KQ1E6, KQ2E9, KQ3E9, KQ4E6, KQ5E6.18477671
709 Uemura T, Hibi K, Kaneko T, . Detection of K-ras mutations in the plasma DNA of pancreatic cancer patients. J Gastroenterol. 2004;391:56–60. PMID: 14767735. KQ1E6, KQ2E6, KQ3E6, KQ4E9, KQ5E9.14767735
710 Ueno H, Kosuge T, Matsuyama Y, . A randomised phase III trial comparing gemcitabine with surgery-only in patients with resected pancreatic cancer: Japanese Study Group of Adjuvant Therapy for Pancreatic Cancer. Br J Cancer. 2009;1016:908–15. PMID: 19690548. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.19690548
711 Uggeri F, Caprotti R, Grate L, . Short-term preoperative IL-2 immunotherapy in operable pancreatic cancer: a randomized study. Hepatogastroenterology. 2009;5691–92:861–865. PMID: CN-00718601. KQ1E1, KQ2E1, KQ3E1, KQ4E10b, KQ5E10b.
712 Ulla-Rocha JL, Alvarez-Prechous A, Paz-Esquete J, . The global impact of endoscopic ultrasound (EUS) regarding the survival of a pancreatic adenocarcinoma in a tertiary hospital. J Gastrointest Cancer. 2010;413:165–72. PMID: 20165932. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.20165932
713 Urbach DR, Swanstrom LL, Hansen PD. The effect of laparoscopy on survival in pancreatic cancer. Arch Surg. 2002;1372:191–9. PMID: 11822959. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.11822959
714 Valentini V, Morganti AG, Macchia G, . Intraoperative radiation therapy in resected pancreatic carcinoma: long-term analysis. Int J Radiat Oncol Biol Phys. 2008;704:1094–9. PMID: 18313525. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.18313525
715 Valle JW, Palmer D, Jackson R, . Optimal duration and timing of adjuvant chemotherapy after definitive surgery for ductal adenocarcinoma of the pancreas: ongoing lessons from the ESPAC-3 study. J Clin Oncol. 2014;326:504–12. PMID: 24419109. KQ1E1, KQ2E1, KQ3E1, KQ4E8, KQ5E8.24419109
716 van der Gaag NA, Berkhemer OA, Sprangers MA, . Quality of life and functional outcome after resection of pancreatic cystic neoplasm. Pancreas. 2014;435:755–61. PMID: 24743379. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.24743379
717 van der Gaag NA, Harmsen K, Eshuis WJ, . Pancreatoduodenectomy associated complications influence cancer recurrence and time interval to death. Eur J Surg Oncol. 2014;405:551–8. PMID: 24388408. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E6.24388408
718 van der Geest LG, Besselink MG, Busch OR, . Elderly patients strongly benefit from centralization of pancreatic cancer surgery: a population-based study. Ann Surg Oncol. 2016;236:2002–9. PMID: 26795767. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E62.26795767
719 van der Geest LG, Besselink MG, van Gestel YR, . Pancreatic cancer surgery in elderly patients: balancing between short-term harm and long-term benefit. A population-based study in the Netherlands. Acta Oncol. 2016;553:278–85. PMID: 26552841. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.26552841
720 van Rijssen LB, Koerkamp BG, Zwart MJ, . Nationwide prospective audit of pancreatic surgery: design, accuracy, and outcomes of the Dutch Pancreatic Cancer Audit. HPB (Oxford). 2017;1910:919–926. PMID: 28754367. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6e.28754367
721 Vanderveen KA, Chen SL, Yin D, . Benefit of postoperative adjuvant therapy for pancreatic cancer: a population-based analysis. Cancer. 2009;11511:2420–9. PMID: 19301434. KQ1E1, KQ2E1, KQ3E1, KQ4E6d, KQ5E6d.19301434
722 Vanella G, Crippa S, Archibugi L, . Meta-analysis of mortality in patients with high-risk intraductal papillary mucinous neoplasms under observation. Br J Surg. 2018;1054:328–338. PMID: 29405253. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E62.29405253
723 Varadarajulu S, Bang JY, Holt BA, . The 25-gauge EUS-FNA needle: Good for on-site but poor for off-site evaluation? Results of a randomized trial. Gastrointest Endosc. 2014;806:1056–63. PMID: 24973173. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.24973173
724 Vasen HF, Wasser M, van Mil A, . Magnetic resonance imaging surveillance detects early-stage pancreatic cancer in carriers of a p16-Leiden mutation. Gastroenterology. 2011;1403:850–6. PMID: 21129377. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E10, KQ5E9.21129377
725 Vasile TA, Feier D, Socaciu M, . Contrast enhanced ultrasound and computer tomography diagnosis of solid and mixed pancreatic tumors - analysis of confounders. J Gastrointest Liver Dis. 2012;213:285–92. PMID: 23012670. KQ1E6, KQ2E6, KQ3E6, KQ4E9, KQ5E9.23012670
726 Velanovich V. The association of quality-of-life measures with malignancy and survival in patients with pancreatic pathology. Pancreas. 2011;407:1063–9. PMID: 21785386. KQ1E7, KQ2E7, KQ3E7, KQ4E6, KQ5E9.21785386
727 Vera R, Ferrandez A, Ferrer CJ, . Procedures and recommended times in the care process of the patient with pancreatic cancer: PAN-TIME consensus between scientific societies. Clin Transl Oncol. 2017;197:834–843. PMID: 28105537. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E12.28105537
728 Verma D, Kwok KK, Wu BU. Patient preferences for management of cystic neoplasms of the pancreas: a cross-sectional survey study. Pancreas. 2017;463:352–357. PMID: 28099258. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.28099258
729 Vila-Navarro E, Vila-Casadesus M, Moreira L, . MicroRNAs for detection of pancreatic neoplasia: biomarker discovery by next-generation sequencing and validation in 2 independent cohorts. Ann Surg. 2017;2656:1226–1234. PMID: CN-01372368. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E12.
730 Vladov N, Takorov I, Kazarov K, . Surgical potentialities for the treatment of pancreatic cancer. Hepatogastroenterology. 2012;59113:280–3. PMID: 22251549. KQ1E1, KQ2E1, KQ3E1, KQ4E5, KQ5E5.22251549
731 Vukobrat-Bijedic Z, Husic-Selimovic A, Bijedic N, . Sensitivity of EUS and ERCP endoscopic procedures in the detection of pancreatic cancer during preoperative staging correlated with CT and CT angiography imaging methods. Acta Inform Med. 2014;223:160–3. PMID: 25132706. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.25132706
732 Wada K, Takaori K, Traverso LW, . Clinical importance of Familial Pancreatic Cancer Registry in Japan: a report from kick-off meeting at International Symposium on Pancreas Cancer 2012. J Hepatobil Pancreat Sci. 2013;206:557–66. PMID: 23604538. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.23604538
733 Wada K, Takaori K, Traverso LW. Screening for pancreatic cancer. Surg Clin North Am. 2015;955:1041–52. PMID: 26315522. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.26315522
734 Wagner M, Redaelli C, Lietz M, . Curative resection is the single most important factor determining outcome in patients with pancreatic adenocarcinoma. Br J Surg. 2004;915:586–94. PMID: 15122610. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.15122610
735 Wakeman CJ, Martin IG, Robertson RW, . Pancreatic cancer: management and survival. ANZ J Surg. 2004;7411:941–4. PMID: 15550079. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.15550079
736 Walsh RM, Vogt DP, Henderson JM, . Natural history of indeterminate pancreatic cysts. Surgery. 2005;1384:665–70; discussion 670–1. PMID: 16269295. KQ1E9, KQ2E9, KQ3E9, KQ4E1, KQ5E1.16269295
737 Wang KX, Ben QW, Jin ZD, . Assessment of morbidity and mortality associated with EUS-guided FNA: a systematic review. Gastrointest Endosc. 2011;732:283–90. PMID: 21295642. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E12.21295642
738 Wang SE, Daskalaki D, Masrur MA, . Impact of obesity on robot-assisted distal pancreatectomy. J Laparoendosc Adv Surg Tech A. 2016;267:551–6. PMID: 27248765. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.27248765
739 Wang SE, Shyr YM, Chen TH, . Comparison of resected and non-resected intraductal papillary mucinous neoplasms of the pancreas. World J Surg. 2005;2912:1650–7. PMID: 16311856. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.16311856
740 Wang W, Chen S, Brune KA, . PancPRO: risk assessment for individuals with a family history of pancreatic cancer. J Clin Oncol. 2007;2511:1417–22. PMID: 17416862. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E102.17416862
741 Wang W, Shpaner A, Krishna SG, . Use of EUS-FNA in diagnosing pancreatic neoplasm without a definitive mass on CT. Gastrointest Endosc. 2013;781:73–80. PMID: 23523302. KQ1E10, KQ2E6, KQ3E9, KQ4E9, KQ5E9.23523302
742 Wang YX, Gong JS, Loffroy R. On pancreatic cancer screening by magnetic resonance imaging with the recent evidence by Del Chiaro and colleagues. Chin J Cancer Res. 2015;274:417–22. PMID: 26361411. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.26361411
743 Warnick SJ Jr, Velanovich V. Correlation of patient-derived utility values and quality of life after pancreaticoduodenectomy for pancreatic cancer. J Am Coll Surg. 2006;2026:906–11. PMID: 16735204. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.16735204
744 Wasif N, Ko CY, Farrell J, . Impact of tumor grade on prognosis in pancreatic cancer: should we include grade in AJCC staging? Ann Surg Oncol. 2010;179:2312–20. PMID: 20422460. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.20422460
745 Watanabe Y, Nishihara K, Matsumoto S, . Effect of postoperative major complications on prognosis after pancreatectomy for pancreatic cancer: a retrospective review. Surg Today. 2017;475:555–567. PMID: 27704248. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E6.27704248
746 Weinberg BM, Spiegel BM, Tomlinson JS, Farrell JJ. Asymptomatic pancreatic cystic neoplasms: maximizing survival and quality of life using Markov-based clinical nomograms. Gastroenterology. 2010;1382:531–40. PMID: 19818780. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.19818780
747 Welsch T, Degrate L, Zschabitz S, . The need for extended intensive care after pancreaticoduodenectomy for pancreatic ductal adenocarcinoma. Langenbecks Arch Surg. 2011;3963:353–62. PMID: 20336311. KQ1E1, KQ2E1, KQ3E1, KQ4E10a, KQ5E6.20336311
748 Westgaard A, Clausen OP, Gladhaug IP. Survival estimates after pancreatoduodenectomy skewed by non-standardized histopathology reports. APMIS. 2011;11910:689–700. PMID: 21917006. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.21917006
749 Whitcomb DC, Shelton CA, Brand RE. Genetics and genetic testing in pancreatic cancer. Gastroenterology. 2015;1495:1252–1264 e4. PMID: 26255042. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E32.26255042
750 Wiltberger G, Muhl B, Benzing C, . Pancreaticoduodenectomy in the elderly patient: age-adapted risk assessment. Digest Surg. 2017;341:43–51. PMID: 27434057. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.27434057
751 Winter JM, Brennan MF, Tang LH, . Survival after resection of pancreatic adenocarcinoma: results from a single institution over three decades. Ann Surg Oncol. 2012;191:169–75. PMID: 21761104. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.21761104
752 Winter JM, Cameron JL, Lillemoe KD, . Periampullary and pancreatic incidentaloma: a single institution’s experience with an increasingly common diagnosis. Ann Surg. 2006;2435:673–80; discussion 680–3. PMID: 16633003. KQ1E10, KQ2E10, KQ3E9, KQ4E10, KQ5E6.16633003
753 Winter JM, Narang AK, Mansfield AS, . Resectable pancreatic small cell carcinoma. Rare Tumors. 2011;31:e5. PMID: 21464878. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.21464878
754 Wisnoski NC, Townsend CM, Jr, . 672 patients with acinar cell carcinoma of the pancreas: a population-based comparison to pancreatic adenocarcinoma. Surgery. 2008;1442:141–8. PMID: 18656619. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E9.18656619
755 Witkiewicz AK, Costantino CL, Metz R, . Genotyping and expression analysis of IDO2 in human pancreatic cancer: a novel, active target. J Am Coll Surg. 2009;2085:781–7; discussion 787–9. PMID: 19476837. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.19476837
756 Woo SM, Ryu JK, Lee SH, . Survival and prognosis of invasive intraductal papillary mucinous neoplasms of the pancreas: comparison with pancreatic ductal adenocarcinoma. Pancreas. 2008;361:50–5. PMID: 18192881. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.18192881
757 Woo SM, Ryu JK, Lee SH, . Branch duct intraductal papillary mucinous neoplasms in a retrospective series of 190 patients. Br J Surg. 2009;964:405–11. PMID: 19283746. KQ1E10, KQ2E9, KQ3E9, KQ4E9, KQ5E9.19283746
758 Worni M, Castleberry AW, Clary BM, . Concomitant vascular reconstruction during pancreatectomy for malignant disease: a propensity score-adjusted, population-based trend analysis involving 10,206 patients. JAMA Surg. 2013;1484:331–8. PMID: 23715922. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.23715922
759 Wright GP, Morrow JB, Shaheen M, . Accuracy of endoscopic ultrasound in the evaluation of cystic pancreatic neoplasms: a community hospital experience. Pancreas. 2014;433:465–9. PMID: 24622081. KQ1E10a, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.24622081
760 Wu BU, Sampath K, Berberian CE, . Prediction of malignancy in cystic neoplasms of the pancreas: a population-based cohort study. Am J Gastroenterol. 2014;1091:121–9; quiz 130. PMID: 24080609. KQ1E10a, KQ2E6, KQ3E9, KQ4E1, KQ5E1.24080609
761 Wu J, Jiao Y, Dal Molin M, . Whole-exome sequencing of neoplastic cysts of the pancreas reveals recurrent mutations in components of ubiquitin-dependent pathways. Proc Natl Acad Sci U S A. 2011;10852:21188–93. PMID: 22158988. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E12.22158988
762 Wu JM, Kuo TC, Yang CY, . Resolution of diabetes after pancreaticoduodenectomy in patients with and without pancreatic ductal cell adenocarcinoma. Ann Surg Oncol. 2013;201:242–9. PMID: 22864799. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.22864799
763 Wu LM, Hu JN, Hua J, . Diagnostic value of diffusion-weighted magnetic resonance imaging compared with fluorodeoxyglucose positron emission tomography/computed tomography for pancreatic malignancy: a meta-analysis using a hierarchical regression model. J Gastroenterol Hepatol. 2012;276:1027–35. PMID: 22414092. KQ1E9, KQ2E6, KQ3E9, KQ4E1, KQ5E1.22414092
764 Wu LM, Xu JR, Hua J, . Value of diffusion-weighted imaging for the discrimination of pancreatic lesions: a meta-analysis. Eur J Gastroenterol Hepatol. 2012;242:134–42. PMID: 22241215. KQ1E9, KQ2E6, KQ3E9, KQ4E1, KQ5E1.22241215
765 Wu RI, Yoon WJ, Brugge WR, . Endoscopic ultrasound-guided fine needle aspiration (EUS-FNA) contributes to a triple-negative test in preoperative screening of pancreatic cysts. Cancer Cytopathol. 2014;1226:412–9. PMID: 24327575. KQ1E10a, KQ2E6d, KQ3E6a, KQ4E1, KQ5E1.24327575
766 Wu W, Dodson R, Makary MA, . A Contemporary evaluation of the cause of death and long-term quality of life after total pancreatectomy. World J Surg. 2016;4010:2513–8. PMID: 27177647. KQ1E1, KQ2E1, KQ3E1, KQ4E6d, KQ5E6d2.27177647
767 Wu W, Hong X, Tian R, . An increased total resected lymph node count benefits survival following pancreas invasive intraductal papillary mucinous neoplasms resection: an analysis using the surveillance, epidemiology, and end result registry database. PLoS One. 2014;99:e107962. PMID: 25264746. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.25264746
768 Wu W, Wang X, Wu X, . Total mesopancreas excision for pancreatic head cancer: analysis of 120 cases. Chin J Cancer Res. 2016;284:423–8. PMID: 27647970. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.27647970
769 Wylie N, Adib R, Barbour AP, . Surgical management in patients with pancreatic cancer: a Queensland perspective. ANZ J Surg. 2013;8311:859–64. PMID: 23095039. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.23095039
770 Xie Z, Chen X, Li J, . Salivary HOTAIR and PVT1 as novel biomarkers for early pancreatic cancer. Oncotarget. 2016;718:25408–19. PMID: 27028998. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E52.27028998
771 Xourafas D, Tavakkoli A, Clancy TE, Ashley SW. Noninvasive intraductal papillary mucinous neoplasms and mucinous cystic neoplasms: recurrence rates and postoperative imaging follow-up. Surgery. 2015;1573:473–83. PMID: 25596773. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.25596773
772 Xu MM, Sethi A. Imaging of the pancreas. Gastroenterol Clin North Am. 2016;451:101–16. PMID: 26895683. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.26895683
773 Yamaguchi T, Baba T, Ishihara T, . Long-term follow-up of intraductal papillary mucinous neoplasm of the pancreas with ultrasonography. Clin Gastroenterol Hepatol. 2005;311:1136–43. PMID: 16271346. KQ1E10, KQ2E9, KQ3E9, KQ4E6, KQ5E6.16271346
774 Yamashita Y, Shirabe K, Tsujita E, . Surgical outcomes of pancreaticoduodenectomy for periampullary tumors in elderly patients. Langenbecks Arch Surg. 2013;3984:539–45. PMID: 23412595. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.23412595
775 Yang M, Tian B, Zhang Y, . Epidemiology, diagnosis, surgical treatment and prognosis of the pancreatic neuroendocrine tumors: report of 125 patients from one single center. Indian J Cancer. 2015;523:343–9. PMID: 26905133. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.26905133
776 Yang S, Zhang H, Ren X. The application of high-field magnetic resonance perfusion imaging in the diagnosis of pancreatic cancer. Medicine. 2017;9636:e7571. PMID: 28885324. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.28885324
777 Yang Y, Li L, Qu C, . Endoscopic ultrasound-guided fine needle core biopsy for the diagnosis of pancreatic malignant lesions: a systematic review and meta-analysis. Sci Rep. 2016;6:22978. PMID: 26960914. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.26960914
778 Yang Y, Yan S, Tian H, Bao Y. Macrophage inhibitory cytokine-1 versus carbohydrate antigen 19-9 as a biomarker for diagnosis of pancreatic cancer: a PRISMA-compliant meta-analysis of diagnostic accuracy studies. Medicine. 2018;979:e9994. PMID: 29489701. KQ1E7, KQ2E7, KQ3E7, KQ4E1, KQ5E12.29489701
779 Yen RD, Mullady D, Early DS, . Predictors for diagnosis of malignancy in endoscopic ultrasonography-guided fine needle aspiration (EUS-FNA) of pancreatic masses: results from a multicenter, prospective randomized controlled trial. Gastroenterology. 2013;1445 suppl. 1:S567. PMID: CN-01007264. KQ1E9, KQ2E9, KQ3E9, KQ4E1, KQ5E1.
780 Yeo TP, Hruban RH, Brody J, . Assessment of “gene-environment” interaction in cases of familial and sporadic pancreatic cancer. J Gastrointest Surg. 2009;138:1487–94. PMID: 19459017. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E1, KQ5E1.19459017
781 Ying L, Lin X, Xie ZL, . Clinical utility of endoscopic ultrasound elastography for identification of malignant pancreatic masses: a meta-analysis. J Gastroenterol Hepatol. 2013;289:1434–43. PMID: 23731128. KQ1E9, KQ2E6, KQ3E9, KQ4E1, KQ5E1.23731128
782 Yogi T, Hijioka S, Imaoka H, . Risk factors for postoperative recurrence of intraductal papillary mucinous neoplasms of the pancreas based on a long-term follow-up study: proposals for follow-up strategies. J Hepatobil Pancreat Sci. 2015;2210:757–65. PMID: 26148131. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.26148131
783 Yongfei H, Javed AA, Burkhart R, . Geographical variation and trends in outcomes of laparoscopic spleen-preserving distal pancreatectomy with or without splenic vessel preservation: a meta-analysis. Int J Surg. 2017;45:47–55. PMID: 28735894. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.28735894
784 Yoon KW, Heo JS, Choi DW, Choi SH. Factors affecting long-term survival after surgical resection of pancreatic ductal adenocarcinoma. J Korean Surg Soc. 2011;816:394–401. PMID: 22200040. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.22200040
785 Yoon WJ, Daglilar ES, Fernandez-del Castillo C, . Peritoneal seeding in intraductal papillary mucinous neoplasm of the pancreas patients who underwent endoscopic ultrasound-guided fine-needle aspiration: the PIPE Study. Endoscopy. 2014;465:382–7. PMID: 24619804. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.24619804
786 Yopp AC, Katabi N, Janakos M, . Invasive carcinoma arising in intraductal papillary mucinous neoplasms of the pancreas: a matched control study with conventional pancreatic ductal adenocarcinoma. Ann Surg. 2011;2535:968–74. PMID: 21422912. KQ1E1, KQ2E1, KQ3E1, KQ4E10, KQ5E9.21422912
787 Yoshinaga S, Suzuki H, Oda ISaito Y. Role of endoscopic ultrasound-guided fine needle aspiration (EUS-FNA) for diagnosis of solid pancreatic masses. Digest Endosc. 2011;3: Suppl 1:29–33. PMID: 21535197. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.21535197
788 Ypsilantis E, Courtney ED, Warren H. Increase in annual number of pancreatic head resections does not affect mortality of pancreatic cancer in the United Kingdom. JOP. 2009;104:462–3; author reply 464–5. PMID: 19581759. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.19581759
789 Zhan Q, Deng X, Weng Y, . Outcomes of robotic surgery for pancreatic ductal adenocarcinoma. Chin J Cancer Res. 2015;276:604–10. PMID: 26752935. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.26752935
790 Zhang H, Tan C, Wang X, . Preventive effects of ulinastatin on complications related to pancreaticoduodenectomy: a consort-prospective, randomized, double-blind, placebo-controlled trial. Medicine. 2016;9524:e3731. PMID: 27310952. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.27310952
791 Zhang MM, Yang H, Jin ZD, . Differential diagnosis of pancreatic cancer from normal tissue with digital imaging processing and pattern recognition based on a support vector machine of EUS images. Gastrointest Endosc. 2010;725:978–85. PMID: 20855062. KQ1E6, KQ2E6, KQ3E6, KQ4E1, KQ5E1.20855062
792 Zhang W, Linghu E, Chai N, Li H. New criteria to differentiate between mucinous cystic neoplasm and serous cystic neoplasm in pancreas by endoscopic ultrasound: a preliminarily confirmed outcome of 41 patients. Endosc Ultrasound. 2017;62:116–122. PMID: 28440237. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.28440237
793 Zhang Y, Frampton AE, Martin JL, . 18F-fluorodeoxyglucose positron emission tomography in management of pancreatic cystic tumors. Nucl Med Biol. 2012;397:982–5. PMID: 22560970. KQ1E10a, KQ2E6d, KQ3E6d, KQ4E1, KQ5E1.22560970
794 Zhao D, Weng C. Combining PubMed knowledge and EHR data to develop a weighted bayesian network for pancreatic cancer prediction. J Biomed Inform. 2011;445:859–68. PMID: 21642013. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.21642013
795 Zhao X, Li LX, Fan H, . Segmental portal/superior mesenteric vein resection and reconstruction with the iliac vein after pancreatoduodenectomy. J Int Med Res. 2016;446:1339–1348. PMID: 28322103. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.28322103
796 Zhou J, Li CL, Zhang GW. Surgical treatment of pancreatic carcinoma. Hepatobil Pancreat Dis Int. 2003;21:139–41. PMID: 14607667. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.14607667
797 Zhu M, Xu C, Yu J, . Differentiation of pancreatic cancer and chronic pancreatitis using computer-aided diagnosis of endoscopic ultrasound (EUS) images: a diagnostic test. PLoS One. 2013;85:e63820. PMID: 23704940. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.23704940
798 Zijlstra M, Bernards N, de Hingh IH, . Does long-term survival exist in pancreatic adenocarcinoma? Acta Oncol. 2016;553:259–64. PMID: 26559995. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.26559995
799 Zubarik R, Gordon SR, Lidofsky SD, . Screening for pancreatic cancer in a high-risk population with serum CA 19-9 and targeted EUS: a feasibility study. Gastroint Endosc. 2011;741:87–95. PMID: 21704809. KQ1E6, KQ2E1, KQ3E1, KQ4E1, KQ5E1.21704809
800 Zureikat AH, Nguyen KT, Bartlett DL, . Robotic-assisted major pancreatic resection and reconstruction. Arch Surg. 2011;1463:256–61. PMID: 21079111. KQ1E1, KQ2E1, KQ3E1, KQ4E6e, KQ5E6e.21079111