# Appendix B Included Studies

Ludwig E, Olson SH, Bayuga S, Simon J, Schattner MA, Gerdes H, Feasibility and yield of screening in relatives from familial pancreatic cancer families. Am J Gastroenterol. 2011;106(5):946–54.21468009
Joergensen MT, Gerdes AM, Sorensen J, Schaffalitzky de Muckadell O, Mortensen MB Is screening for pancreatic cancer in high-risk groups cost-effective? - Experience from a Danish national screening program. Pancreatology. 2016;16(4):584–92.27090585
Poley JW, Kluijt I, Gouma DJ, Harinck F, Wagner A, Aalfs C, The yield of first-time endoscopic ultrasonography in screening individuals at a high risk of developing pancreatic cancer. Am J Gastroenterol. 2009;104(9):2175–81.19491823
Canto MI, Goggins M, Yeo CJ, Griffin C, Axilbund JE, Brune K, Screening for pancreatic neoplasia in high-risk individuals: an EUS-based approach. Clin Gastroenterol Hepatol. 2004;2(7):606–21.15224285
Canto MI, Goggins M, Hruban RH, Petersen GM, Giardiello FM, Yeo C, Screening for early pancreatic neoplasia in high-risk individuals: a prospective controlled study. Clin Gastroenterol Hepatol. 2006;4(6):766–81; quiz 665.16682259
Del Chiaro M, Verbeke CS, Kartalis N, Pozzi Mucelli R, Gustafsson P, Hansson J, Short-term Results of a Magnetic Resonance Imaging-Based Swedish Screening Program for Individuals at Risk for Pancreatic Cancer. JAMA Surgery. 2015;150(6):512–8.25853369
Verna EC, Hwang C, Stevens PD, Rotterdam H, Stavropoulos SN, Sy CD, Pancreatic cancer screening in a prospective cohort of high-risk patients: a comprehensive strategy of imaging and genetics. Clin Cancer Res. 2010;16(20):5028–37.20876795
Canto MI Value of EUS screening in patients with high risk factors for pancreatic cancer (focus on familial pancreatic cancer). Pancreatology Conference: 20th meeting of the international association of pancreatology, IAP 2016 Japan [Internet]. 2016; 16(4 Supplement 1):[S19–s20 pp.]. Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/632/CN-01406632/frame.html.
Barnes CA, Krzywda E, Lahiff S, Development of a high risk pancreatic screening clinic using 3.0 T MRI. Fam Cancer. 2018;17(1):101–11. PMID: 29101607.29101607
Gangi A, Malafa M, Klapman J Endoscopic Ultrasound-Based Pancreatic Cancer Screening of High-Risk Individuals: A Prospective Observational Trial. Pancreas. 2018;19:19. PMID: 29683970.29683970

## FaPaCa Study Marburg, Germany

Schneider R, Slater EP, Sina M, Habbe N, Fendrich V, Matthai E, German national case collection for familial pancreatic cancer (FaPaCa): ten years experience. Fam Cancer. 2011;10(2):323–30.21207249
Langer P, Kann PH, Fendrich V, Habbe N, Schneider M, Sina M, Five years of prospective screening of high-risk individuals from families with familial pancreatic cancer. Gut. 2009;58(10):1410–8.19470496
Potjer TP, Schot I, Langer P, Heverhagen JT, Wasser MN, Slater EP, Variation in precursor lesions of pancreatic cancer among high-risk groups. Clin Cancer Res. 2013;19(2):442–9.23172884
Bartsch DK, Slater EP, Carrato A, Ibrahim IS, Guillen-Ponce C, Vasen HF, Refinement of screening for familial pancreatic cancer. Gut. 2016;65(8):1314–21.27222532
Vasen H, Ibrahim I, Ponce CG, Slater EP, Matthai E, Carrato A, Benefit of surveillance for pancreatic cancer in high-risk individuals: outcome of long-term prospective follow-up studies from three European expert centers. J Clin Oncol. 2016;34(17):2010–9.27114589

## Toronto Screening Study

Al-Sukhni W, Borgida A, Rothenmund H, Holter S, Semotiuk K, Grant R, Screening for pancreatic cancer in a high-risk cohort: an eight-year experience. J Gastrointest Surg. 2012;16(4):771–83.22127781
Maheu C, Vodermaier A, Rothenmund H, Gallinger S, Ardiles P, Semotiuk K, Pancreatic cancer risk counselling and screening: impact on perceived risk and psychological functioning. Familial Cancer. 2010;9(4):617–24.20623197
Hart SL, Torbit LA, Crangle CJ, Esplen MJ, Holter S, Semotiuk K, Moderators of cancer-related distress and worry after a pancreatic cancer genetic counseling and screening intervention. Psychooncology. 2012;21(12):1324–30.21774034

## Dutch PC Screening Study

Harinck F, Konings I, Kluijt I, Poley JW, Hooft JE, Dullemen HM, A multicentre comparative prospective blinded analysis of EUS and MRI for screening of pancreatic cancer in high-risk individuals. Gut [Internet]. 2016; 65(9):[1505–13 pp.]. Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/092/CN-01211092/frame.html.
Konings IC, Sidharta GN, Harinck F, Aalfs CM, Poley JW, Kieffer JM, Repeated participation in pancreatic cancer surveillance by high-risk individuals imposes low psychological burden. Psychooncology. 2016;25(8):971–8.26632416
Konings IC, Harinck F, Kuenen MA, Sidharta GN, Kieffer JM, Aalfs CM, Factors associated with cancer worries in individuals participating in annual pancreatic cancer surveillance. Fam Cancer. 2016.
Harinck F, Nagtegaal T, Kluijt I, Aalfs C, Smets E, Poley JW, Feasibility of a pancreatic cancer surveillance program from a psychological point of view. Genet Med. 2011;13(12):1015–24.21857231

## CAPS 3 (5 sites in USA) - MRI, CT, EUS

Canto MI, Hruban RH, Fishman EK, Kamel IR, Schulick R, Zhang Z, Frequent detection of pancreatic lesions in asymptomatic high-risk individuals. Gastroenterology. 2012;142(4):796–804; quiz e14–5.22245846
Shin EJ, Topazian M, Goggins MG, Syngal S, Saltzman JR, Lee JH, Linear-array EUS improves detection of pancreatic lesions in high-risk individuals: a randomized tandem study. Gastrointest Endosc. 2015;82(5):812–8.25930097
Canto MI, Almario JA, Schulick RD, Risk of neoplastic progression in individuals at high risk for pancreatic cancer undergoing long-term surveillance. Gastroenterology. 2018;155(3):740–51 e2. PMID: 29803839.29803839