# Appendix A Detailed Methods

## Literature Search Strategies for Primary Literature

Sources Searched
Ovid MEDLINE(R) without Revisions <1996 to September Week 3 2017>, Ovid MEDLINE(R) Epub Ahead of Print <October 03, 2017>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <October 03, 2017>, Ovid MEDLINE(R) Daily Update <October 03, 2017>
Cochrane Central Register of Controlled Trials (CENTRAL)
PubMed, Publisher Supplied Segment

Key:

- / = subject heading
- $ = truncation
- * = truncation
- ab = word in abstract
- adj# = adjacent within x number of words
- fs = floating subheading
- kw = keyword
- pt = publication type
- ti = word in title

## Ovid Medline

### Pancreatic Adenocarcinoma Screening Trials (KQ1)

1. Pancreatic Neoplasms/
2. Carcinoma, Pancreatic Ductal/
3. Pancreatic Cyst/
4. Pancreatic Pseudocyst/
5. exp Pancreas/
6. Carcinoma in Situ/
7. exp Adenocarcinoma/
8. 6 or 7
9. 5 and 8
10. pancreatic intraepithelial neoplas*.ti,ab.
11. panin.ti,ab.
12. intraductal papillary mucinous neoplas*.ti,ab.
13. ipmn.ti,ab.
14. mucinous cystic neoplas*.ti,ab.
15. ((pancrea* or Acinar* or Acinus or hepatopancreat* or ampull*) adj3 (cancer* or carcinoma* or adenocarcinoma* or apudoma* or adenoma* or carcinoid* or sarcoma* or malignan* or tumor* or tumour* or neoplas* or lesion* or cyst or cysts)).ti.
16. ((pancrea* or Acinar* or Acinus or hepatopancreat* or ampull*) adj3 (cancer* or carcinoma* or adenocarcinoma* or apudoma* or adenoma* or carcinoid* or sarcoma* or malignan* or tumor* or tumour* or neoplas* or lesion* or cyst or cysts)).ti,ab.
17. limit 16 to ("in data review" or in process or “pubmed not medline”)
18. 1 or 2 or 3 or 4 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 17
19. Mass Screening/
20. “Early Detection of Cancer”/
21. exp Ultrasonography/
22. Endoscopic Ultrasound-Guided Fine Needle Aspiration/
23. exp Magnetic Resonance Imaging/
24. Cholangiography/
25. Cholangiopancreatography, Endoscopic Retrograde/
26. Positron-Emission Tomography/
27. exp Tomography, Emission-Computed/
28. Tomography, X-Ray Computed/
29. Angiography/
30. Computed Tomography Angiography/
31. Four-Dimensional Computed Tomography/
32. Positron Emission Tomography Computed Tomography/
33. Single Photon Emission Computed Tomography Computed Tomography/
34. Tomography, Spiral Computed/
35. Multidetector Computed Tomography/
36. screen*.ti,ab.
37. ultrasonogra*.ti,ab.
38. ultrasound*.ti,ab.
39. magnetic resonance imag*.ti,ab.
40. (cholangiography or cholangiopancreato*).ti,ab.
41. positron emission tomograph*.ti,ab.
42. computed tomograph*.ti,ab.
43. (ct scan* or pet scan* or mri or octreoscan* or octreotide scan*).ti,ab.
44. angiograph*.ti,ab.
45. ercp.ti,ab.
46. or/19–45
47. 18 and 46
48. *Pancreatic Neoplasms/di [Diagnosis]
49. *Carcinoma, Pancreatic Ductal/di [Diagnosis]
50. *Pancreatic Cyst/di [Diagnosis]
51. *Pancreatic Pseudocyst/di [Diagnosis]
52. 48 or 49 or 50 or 51
53. 47 or 52
54. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/ or pragmatic clinical trials as topic/
55. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial or pragmatic clinical trial).pt.
56. Random*.ti,ab.
57. control groups/ or double-blind method/ or single-blind method/
58. clinical trial*.ti,ab.
59. controlled trial*.ti,ab.
60. (meta analy* or metaanaly*).ti,ab.
61. 54 or 55 or 56 or 57 or 58 or 59 or 60
62. 53 and 61
63. limit 62 to yr="2002 -Current"
64. limit 63 to english language
65. animals/ not (humans/ and animals/)
66. 64 not 65
67. remove duplicates from 66

### Pancreatic Adenocarcinoma Screening Dx Accuracy (KQ2)

1. Pancreatic Neoplasms/
2. Carcinoma, Pancreatic Ductal/
3. Pancreatic Cyst/
4. Pancreatic Pseudocyst/
5. exp Pancreas/
6. Carcinoma in Situ/
7. exp Adenocarcinoma/
8. 6 or 7
9. 5 and 8
10. pancreatic intraepithelial neoplas*.ti,ab.
11. panin.ti,ab.
12. intraductal papillary mucinous neoplas*.ti,ab.
13. ipmn.ti,ab.
14. mucinous cystic neoplas*.ti,ab.
15. ((pancrea* or Acinar* or Acinus or hepatopancreat* or ampull*) adj3 (cancer* or carcinoma* or adenocarcinoma* or apudoma* or adenoma* or carcinoid* or sarcoma* or malignan* or tumor* or tumour* or neoplas* or lesion* or cyst or cysts)).ti.
16. ((pancrea* or Acinar* or Acinus or hepatopancreat* or ampull*) adj3 (cancer* or carcinoma* or adenocarcinoma* or apudoma* or adenoma* or carcinoid* or sarcoma* or malignan* or tumor* or tumour* or neoplas* or lesion* or cyst or cysts)).ti,ab.
17. limit 16 to (“in data review” or in process or “pubmed not medline”)
18. 1 or 2 or 3 or 4 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 17
19. Mass Screening/
20. “Early Detection of Cancer”/
21. exp Ultrasonography/
22. Endoscopic Ultrasound-Guided Fine Needle Aspiration/
23. exp Magnetic Resonance Imaging/
24. Cholangiography/
25. Cholangiopancreatography, Endoscopic Retrograde/
26. Positron-Emission Tomography/
27. exp Tomography, Emission-Computed/
28. Tomography, X-Ray Computed/
29. Angiography/
30. Computed Tomography Angiography/
31. Four-Dimensional Computed Tomography/
32. Positron Emission Tomography Computed Tomography/
33. Single Photon Emission Computed Tomography Computed Tomography/
34. Tomography, Spiral Computed/
35. Multidetector Computed Tomography/
36. screen*.ti,ab.
37. ultrasonogra*.ti,ab.
38. ultrasound*.ti,ab.
39. magnetic resonance imag*.ti,ab.
40. (cholangiography or cholangiopancreato*).ti,ab.
41. positron emission tomograph*.ti,ab.
42. computed tomograph*.ti,ab.
43. (ct scan* or pet scan* or mri or octreoscan* or octreotide scan*).ti,ab.
44. angiograph*.ti,ab.
45. ercp.ti,ab.
46. or/19–45
47. 18 and 46
48. *Pancreatic Neoplasms/di [Diagnosis]
49. *Carcinoma, Pancreatic Ductal/di [Diagnosis]
50. *Pancreatic Cyst/di [Diagnosis]
51. *Pancreatic Pseudocyst/di [Diagnosis]
52. 48 or 49 or 50 or 51
53. 47 or 52
54. “Sensitivity and Specificity”/
55. “Predictive Value of Tests”/
56. ROC Curve/
57. Receiver operat*.ti,ab.
58. ROC curve*.ti,ab.
59. sensitivit*.ti,ab.
60. specificit*.ti,ab.
61. predictive value.ti,ab.
62. accuracy.ti,ab.
63. false positive*.ti,ab.
64. false negative*.ti,ab.
65. miss rate*.ti,ab.
66. error rate*.ti,ab.
67. False Negative Reactions/
68. False Positive Reactions/
69. Diagnostic Errors/
70. “Reproducibility of Results”/
71. Reference Values/
72. Reference Standards/
73. Observer Variation/
74. or/54–73
75. 53 and 74
76. limit 75 to yr="2002 -Current"
77. limit 76 to english language
78. animals/ not (humans/ and animals/)
79. 77 not 78
80. remove duplicates from 79

### Pancreatic Adenocarcinoma Screening Harms (KQ3)

1. Pancreatic Neoplasms/
2. Carcinoma, Pancreatic Ductal/
3. Pancreatic Cyst/
4. Pancreatic Pseudocyst/
5. exp Pancreas/
6. Carcinoma in Situ/
7. exp Adenocarcinoma/
8. 6 or 7
9. 5 and 8
10. pancreatic intraepithelial neoplas*.ti,ab.
11. panin.ti,ab.
12. intraductal papillary mucinous neoplas*.ti,ab.
13. ipmn.ti,ab.
14. mucinous cystic neoplas*.ti,ab.
15. ((pancrea* or Acinar* or Acinus or hepatopancreat* or ampull*) adj3 (cancer* or carcinoma* or adenocarcinoma* or apudoma* or adenoma* or carcinoid* or sarcoma* or malignan* or tumor* or tumour* or neoplas* or lesion* or cyst or cysts)).ti.
16. ((pancrea* or Acinar* or Acinus or hepatopancreat* or ampull*) adj3 (cancer* or carcinoma* or adenocarcinoma* or apudoma* or adenoma* or carcinoid* or sarcoma* or malignan* or tumor* or tumour* or neoplas* or lesion* or cyst or cysts)).ti,ab.
17. limit 16 to (“in data review” or in process or “pubmed not medline”)
18. 1 or 2 or 3 or 4 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 17
19. Mass Screening/
20. “Early Detection of Cancer”/
21. exp Ultrasonography/
22. Endoscopic Ultrasound-Guided Fine Needle Aspiration/
23. exp Magnetic Resonance Imaging/
24. Cholangiography/
25. Cholangiopancreatography, Endoscopic Retrograde/
26. Positron-Emission Tomography/
27. exp Tomography, Emission-Computed/
28. Tomography, X-Ray Computed/
29. Angiography/
30. Computed Tomography Angiography/
31. Four-Dimensional Computed Tomography/
32. Positron Emission Tomography Computed Tomography/
33. Single Photon Emission Computed Tomography Computed Tomography/
34. Tomography, Spiral Computed/
35. Multidetector Computed Tomography/
36. screen*.ti,ab.
37. ultrasonogra*.ti,ab.
38. ultrasound*.ti,ab.
39. magnetic resonance imag*.ti,ab.
40. (cholangiography or cholangiopancreato*).ti,ab.
41. positron emission tomograph*.ti,ab.
42. computed tomograph*.ti,ab.
43. (ct scan* or pet scan* or mri or octreoscan* or octreotide scan*).ti,ab.
44. angiograph*.ti,ab.
45. ercp.ti,ab.
46. or/19–45
47. 18 and 46
48. *Pancreatic Neoplasms/di [Diagnosis]
49. *Carcinoma, Pancreatic Ductal/di [Diagnosis]
50. *Pancreatic Cyst/di [Diagnosis]
51. *Pancreatic Pseudocyst/di [Diagnosis]
52. 48 or 49 or 50 or 51
53. 47 or 52
54. (harm or harms or harmful or harmed).ti,ab.
55. (adverse effects or mortality).fs.
56. Mortality/
57. Morbidity/
58. death/
59. (death or deaths).ti,ab.
60. (adverse adj (effect* or event* or outcome* or reaction*)).ti,ab.
61. complication*.ti,ab.
62. side effect*.ti,ab.
63. safety.ti,ab.
64. perforat*.ti,ab.
65. exp Infection/
66. Iatrogenic Disease/
67. Cross Infection/
68. iatrogen*.ti,ab.
69. Hemorrhage/
70. Postoperative Hemorrhage/
71. (hemorrhag* or haemorrhag*).ti,ab.
72. Peritonitis/
73. Bile/
74. 72 and 73
75. Neoplasm Seeding/
76. ((neoplas* or malignan*) adj2 seed*).ti,ab.
77. Anxiety/
78. (anxiet* or anxious*).ti,ab.
79. Depression/
80. (cancer adj2 worr*).ti,ab.
81. 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68 or 69 or 70 or 71 or 74 or 75 or 76 or 77 or 78 or 79 or 79 or 80
82. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/ or pragmatic clinical trials as topic/
83. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial or pragmatic clinical trial).pt.
84. Random*.ti,ab.
85. control groups/ or double-blind method/ or single-blind method/
86. clinical trial*.ti,ab.
87. controlled trial*.ti,ab.
88. (meta analy* or metaanaly*).ti,ab.
89. cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/ or retrospective studies/
90. cohort.ti,ab.
91. longitudinal.ti,ab.
92. retrospectiv*.ti,ab.
93. prospectiv*.ti,ab.
94. case-control studies/
95. case control*.ti,ab.
96. 82 or 83 or 84 or 85 or 86 or 87 or 88 or 89 or 90 or 91 or 92 or 93 or 94 or 95
97. 53 and 81 and 96
98. limit 97 to yr="2002 -Current"
99. limit 98 to english language
100. animals/ not (humans/ and animals/)
101. 99 not 100
102. remove duplicates from 101

### Pancreatic Adenocarcinoma Treatment Trials and Cohort Studies (KQ4)

1. Pancreatic Neoplasms/
2. Carcinoma, Pancreatic Ductal/
3. Pancreatic Cyst/
4. Pancreatic Pseudocyst/
5. exp Pancreas/
6. Carcinoma in Situ/
7. exp Adenocarcinoma/
8. 6 or 7
9. 5 and 8
10. pancreatic intraepithelial neoplas*.ti,ab.
11. panin.ti,ab.
12. intraductal papillary mucinous neoplas*.ti,ab.
13. ipmn.ti,ab.
14. mucinous cystic neoplas*.ti,ab.
15. ((pancrea* or Acinar* or Acinus or hepatopancreat* or ampull*) adj3 (cancer* or carcinoma* or adenocarcinoma* or apudoma* or adenoma* or carcinoid* or sarcoma* or malignan* or tumor* or tumour* or neoplas* or lesion* or cyst or cysts)).ti.
16. ((pancrea* or Acinar* or Acinus or hepatopancreat* or ampull*) adj3 (cancer* or carcinoma* or adenocarcinoma* or apudoma* or adenoma* or carcinoid* or sarcoma* or malignan* or tumor* or tumour* or neoplas* or lesion* or cyst or cysts)).ti,ab.
17. limit 16 to (“in data review” or in process or “pubmed not medline”)
18. 1 or 2 or 3 or 4 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 17
19. Treatment Outcome/
20. Treatment Failure/
21. Pancreatectomy/
22. Pancreaticoduodenectomy/
23. pancreatectom*.ti,ab.
24. Pancreaticoduodenectom*.ti,ab.
25. (surger* or surgical).ti.
26. (surger* or surgical).ti,ab.
27. limit 26 to (“in data review” or in process or “pubmed not medline”)
28. resect*.ti,ab.
29. exp Radiotherapy/
30. (radiotherap* or radiation therap* or radio therap*).ti.
31. (radiotherap* or radiation therap* or radio therap*).ti,ab.
32. limit 31 to (“in data review” or in process or “pubmed not medline”)
33. whipple.ti,ab.
34. Chemoradiotherapy/
35. Chemoradiotherapy, Adjuvant/
36. Antineoplastic Combined Chemotherapy Protocols/
37. Chemotherapy, Adjuvant/
38. Consolidation Chemotherapy/
39. Chemotherapy, Cancer, Regional Perfusion/
40. Induction Chemotherapy/
41. Maintenance Chemotherapy/
42. Photochemotherapy/
43. chemotherap*.ti.
44. chemotherap*.ti,ab.
45. limit 44 to (“in data review” or in process or “pubmed not medline”)
46. folfirinox.ti,ab.
47. Leucovorin/
48. Fluorouracil/
49. Capecitabine/
50. gemcitabine.ti,ab.
51. gemzar.ti,ab.
52. 5-fu.ti,ab
53. Paclitaxel/
54. Albumin-Bound Paclitaxel/
55. Camptothecin/
56. Antineoplastic Agents/
57. 19 or 20 or 21 or 22 or 23 or 24 or 25 or 27 or 28 or 29 or 30 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56
58. 18 and 57
59. *Pancreatic Neoplasms/dh, dt, rt, su, th [Diet Therapy, Drug Therapy, Radiotherapy, Surgery, Therapy]
60. *Carcinoma, Pancreatic Ductal/dh, dt, rt, su, th [Diet Therapy, Drug Therapy, Radiotherapy, Surgery, Therapy]
61. *Pancreatic Cyst/dt, rt, su, th [Drug Therapy, Radiotherapy, Surgery, Therapy]
62. *Pancreatic Pseudocyst/dh, dt, rt, su, th [Diet Therapy, Drug Therapy, Radiotherapy, Surgery, Therapy]
63. 59 or 60 or 61 or 62
64. 58 or 63
65. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/ or pragmatic clinical trials as topic/
66. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial or pragmatic clinical trial).pt.
67. Random*.ti,ab.
68. control groups/ or double-blind method/ or single-blind method/
69. clinical trial*.ti,ab.
70. controlled trial*.ti,ab.
71. (meta analy* or metaanaly*).ti,ab.
72. cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/ or retrospective studies/
73. cohort.ti,ab.
74. longitudinal.ti,ab.
75. retrospectiv*.ti,ab.
76. prospectiv*.ti,ab.
77. 65 or 66 or 67 or 68 or 69 or 70 or 71 or 72 or 73 or 74 or 75 or 76
78. 64 and 77
79. limit 78 to yr="2002 -Current"
80. limit 79 to english language
81. animals/ not (humans/ and animals/)
82. 80 not 81

### Pancreatic Adenocarcinoma Treatment Harms (KQ5)

1. Pancreatic Neoplasms/
2. Carcinoma, Pancreatic Ductal/
3. Pancreatic Cyst/
4. Pancreatic Pseudocyst/
5. exp Pancreas/
6. Carcinoma in Situ/
7. exp Adenocarcinoma/
8. 6 or 7
9. 5 and 8
10. pancreatic intraepithelial neoplas*.ti,ab.
11. panin.ti,ab.
12. intraductal papillary mucinous neoplas*.ti,ab.
13. ipmn.ti,ab.
14. mucinous cystic neoplas*.ti,ab.
15. ((pancrea* or Acinar* or Acinus or hepatopancreat* or ampull*) adj3 (cancer* or carcinoma* or adenocarcinoma* or apudoma* or adenoma* or carcinoid* or sarcoma* or malignan* or tumor* or tumour* or neoplas* or lesion* or cyst or cysts)).ti.
16. ((pancrea* or Acinar* or Acinus or hepatopancreat* or ampull*) adj3 (cancer* or carcinoma* or adenocarcinoma* or apudoma* or adenoma* or carcinoid* or sarcoma* or malignan* or tumor* or tumour* or neoplas* or lesion* or cyst or cysts)).ti,ab.
17. limit 16 to (“in data review” or in process or “pubmed not medline”)
18. 1 or 2 or 3 or 4 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 17
19. Treatment Outcome/
20. Treatment Failure/
21. Pancreatectomy/
22. Pancreaticoduodenectomy/
23. pancreatectom*.ti,ab.
24. Pancreaticoduodenectom*.ti,ab.
25. (surger* or surgical).ti.
26. (surger* or surgical).ti,ab.
27. limit 26 to (“in data review” or in process or “pubmed not medline”)
28. resect*.ti,ab.
29. exp Radiotherapy/
30. (radiotherap* or radiation therap* or radio therap*).ti.
31. (radiotherap* or radiation therap* or radio therap*).ti,ab.
32. limit 31 to (“in data review” or in process or “pubmed not medline”)
33. whipple.ti,ab.
34. Chemoradiotherapy/
35. Chemoradiotherapy, Adjuvant/
36. Antineoplastic Combined Chemotherapy Protocols/
37. Chemotherapy, Adjuvant/
38. Consolidation Chemotherapy/
39. Chemotherapy, Cancer, Regional Perfusion/
40. Induction Chemotherapy/
41. Maintenance Chemotherapy/
42. Photochemotherapy/
43. chemotherap*.ti.
44. chemotherap*.ti,ab.
45. limit 44 to (“in data review” or in process or “pubmed not medline”)
46. folfirinox.ti,ab.
47. Leucovorin/
48. Fluorouracil/
49. Capecitabine/
50. gemcitabine.ti,ab.
51. gemzar.ti,ab.
52. 5-fu.ti,ab.
53. Paclitaxel/
54. Albumin-Bound Paclitaxel/
55. Camptothecin/
56. Antineoplastic Agents/
57. 19 or 20 or 21 or 22 or 23 or 24 or 25 or 27 or 28 or 29 or 30 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56
58. 18 and 57
59. *Pancreatic Neoplasms/dh, dt, rt, su, th [Diet Therapy, Drug Therapy, Radiotherapy, Surgery, Therapy]
60. *Carcinoma, Pancreatic Ductal/dh, dt, rt, su, th [Diet Therapy, Drug Therapy, Radiotherapy, Surgery, Therapy]
61. *Pancreatic Cyst/dt, rt, su, th [Drug Therapy, Radiotherapy, Surgery, Therapy]
62. *Pancreatic Pseudocyst/dh, dt, rt, su, th [Diet Therapy, Drug Therapy, Radiotherapy, Surgery, Therapy]
63. 59 or 60 or 61 or 62
64. 58 or 63
65. (harm or harms or harmful or harmed).ti,ab.
66. (adverse effects or mortality).fs.
67. Mortality/
68. Morbidity/
69. death/
70. (death or deaths).ti,ab.
71. (adverse adj (effect* or event* or outcome* or reaction*)).ti,ab.
72. complication*.ti,ab.
73. side effect*.ti,ab.
74. safety.ti,ab.
75. “Drug-Related Side Effects and Adverse Reactions”/
76. Long Term Adverse Effects/
77. Radiation Exposure/
78. Radiation Injuries/
79. Abnormalities, Radiation-Induced/
80. Cardiotoxicity/
81. Leukemia, Radiation-Induced/
82. Neoplasms, Radiation-Induced/
83. Osteoradionecrosis/
84. Radiation Pneumonitis/
85. Radiodermatitis/
86. (radiation adj2 (expos* or damag* or induce* or injur*)).ti,ab.
87. osteoradionecrosis.ti,ab.
88. radiodermatitis.ti,ab.
89. cardiotoxic*.ti,ab.
90. Nausea/
91. (nausea or nauseous*).ti,ab.
92. Vomiting/
93. vomit*.ti,ab.
94. Diarrhea/
95. diarrhea.ti,ab.
96. diarrhoea.ti,ab.
97. Alopecia/
98. alopeci*.ti,ab.
99. (hair* adj3 loss*).ti,ab.
100. (appetite adj3 loss*).ti,ab.
101. Fatigue/
102. (fatigu* or letharg*).ti,ab.
103. Fever/
104. fever*.ti,ab.
105. (mouth adj2 (sore or sores)).ti,ab.
106. Pain/
107. pain*.ti.
108. Constipation/
109. constipat*.ti,ab.
110. Contusions/
111. bruis*.ti,ab.
112. ((lung* or pulmonary or heart or cardiac or cardio* or kidney* or renal or nephro* or nerve* or neural*) adj2 (damag* or injur*)).ti,ab.
113. exp Postoperative Complications/
114. 65 or 66 or 67 or 68 or 69 or 70 or 71 or 72 or 73 or 74 or 75 or 76 or 77 or 78 or 79 or 80 or 81 or 82 or 83 or 84 or 85 or 86 or 87 or 88 or 89 or 90 or 91 or 92 or 93 or 94 or 95 or 96 or 97 or 98 or 99 or 100 or 101 or 102 or 103 or 104 or 105 or 106 or 107 or 108 or 109 or 110 or 111 or 112 or 113
115. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/ or pragmatic clinical trials as topic/
116. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial or pragmatic clinical trial).pt.
117. Random*.ti,ab.
118. control groups/ or double-blind method/ or single-blind method/
119. clinical trial*.ti,ab.
120. controlled trial*.ti,ab.
121. (meta analy* or metaanaly*).ti,ab.
122. cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/ or retrospective studies/
123. cohort.ti,ab.
124. longitudinal.ti,ab.
125. retrospectiv*.ti,ab.
126. prospectiv*.ti,ab.
127. case-control studies/
128. case control*.ti,ab.
129. 115 or 116 or 117 or 118 or 119 or 120 or 121 or 122 or 123 or 124 or 125 or 126 or 127 or 128
130. 64 and 114 and 129
131. limit 130 to yr="2002 -Current"
132. limit 131 to english language
133. animals/ not (humans/ and animals/)
134. 132 not 133
135. remove duplicates from 134

## CENTRAL Issue 9 of 12, September 2017

#1 (pancrea* or Acinar* or Acinus or hepatopancreat* or ampull*):ti,ab,kw near/3 (cancer* or carcinoma* or adenocarcinoma* or apudoma* or adenoma* or carcinoid* or sarcoma* or malignan* or tumor* or tumour* or neoplas* or lesion* or cyst or cysts):ti,ab,kw
#2 panin:ti,ab,kw
#3 ("intraductal papillary mucinous" next neoplas*):ti,ab,kw
#4 ipmn:ti,ab,kw
#5 (mucinous cystic next neoplas*):ti,ab,kw
#6 {or #1-#5}
#7 screen*:ti,ab,kw
#8 ultrasonogra*:ti,ab,kw
#9 ultrasound*:ti,ab,kw
#10 ("magnetic resonance" next imag*):ti,ab,kw
#11 mri:ti,ab,kw
#12 (cholangiography or cholangiopancreato*):ti,ab,kw
#13 tomograph*:ti,ab,kw
#14 (ct or pet or octreotide):ti,ab,kw near/2 scan:ti,ab,kw
#15 octreoscan:ti,ab,kw
#16 angiograph*:ti,ab,kw
#17 ercp:ti,ab,kw
#18 {or #7-#17}
#19 pancreatectom*:ti,ab,kw
#20 Pancreaticoduodenectom*:ti,ab,kw
#21 (surger* or surgical):ti,ab,kw
#22 resect*:ti,ab,kw
#23 radiotherapy:ti,ab,kw
#24 (radiation next therap*):ti,ab,kw
#25 (therap* next radiation):ti,ab,kw
#26 whipple:ti,ab,kw
#27 chemoradiotherap*:ti,ab,kw
#28 chemotherap*:ti,ab,kw
#29 photochemotherap*:ti,ab,kw
#30 folfirinox:ti,ab,kw
#31 Leucovorin:ti,ab,kw
#32 Fluorouracil:ti,ab,kw
#33 Capecitabine:ti,ab,kw
#34 gemcitabine:ti,ab,kw
#35 gemzar:ti,ab,kw
#36 5-fu:ti,ab,kw
#37 Paclitaxel:ti,ab,kw
#38 Camptothecin:ti,ab,kw
#39 {or #19-#38}
#40 #18 or #39
#41 #6 and #40 Publication Year from 2002 to 2017

### PubMed, Publisher Supplied Segment

Search | Query
#33 (https://www.ncbi.nlm.nih.gov/pubmed) | Search #32 AND publisher[sb] AND English[language] AND (“2002”[Date - Publication] : “3000”[Date - Publication])
#32 (https://www.ncbi.nlm.nih.gov/pubmed) | Search #9 OR #11 OR #20 OR #26 OR #31
#31 (https://www.ncbi.nlm.nih.gov/pubmed) | Search #3 AND #23 AND #30
#30 (https://www.ncbi.nlm.nih.gov/pubmed) | Search #27 OR #28 OR #29
#29 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (lung*[tiab] OR pulmonary[tiab] OR heart[tiab] OR cardiac[tiab] OR cardio*[tiab] OR kidney*[tiab] OR renal[tiab] OR nephro*[tiab] OR nerve*[tiab] OR neural*[tiab]) AND (damage*[tiab] OR injur*[tiab])
#28 (https://www.ncbi.nlm.nih.gov/pubmed) | Search cardiotoxic*[tiab] Or osteoradionecrosis[tiab] OR radiodermatitis[tiab] OR nausea[tiab] OR nauseous*[tiab] OR vomit*[tiab] OR diarrhea[tiab] OR diarrhoea[tiab] OR alopeci*[tiab] OR “hair loss”[tiab] OR “loss of appetite”[tiab] OR “appetite loss”[tiab] OR fatigu*[tiab] OR letharg*[tiab] OR fever*[tiab] OR mouth sore*[tiab] OR pain*[tiab] OR constipat*[tiab] OR contusion*[tiab] OR bruis*[tiab]
#27 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (radiation[tiab] AND (expos*[tiab] OR damag*[tiab] OR induce*[tiab] OR injur*[tiab]))
#26 (https://www.ncbi.nlm.nih.gov/pubmed) | Search #3 AND #23 AND #25
#25 (https://www.ncbi.nlm.nih.gov/pubmed) | Search #8 OR #24
#24 (https://www.ncbi.nlm.nih.gov/pubmed) | Search cohort*[tiab] OR longitudinal[tiab] OR “follow up”[tiab] OR followup[tiab] OR prospectiv*[tiab] OR retrospectiv*[tiab]
#23 (https://www.ncbi.nlm.nih.gov/pubmed) | Search #21 OR #22
#22 (https://www.ncbi.nlm.nih.gov/pubmed) | Search radiation[tiab] AND therap*[tiab]
#21 (https://www.ncbi.nlm.nih.gov/pubmed) | Search pancreatectom*[tiab] OR pancreaticoduodenectom*[tiab] OR surger*[tiab] OR surgical[tiab] OR resect*[tiab] OR radiotherapy[tiab] OR whipple[tiab] OR chemoradiotherap*[tiab] OR chemotherap*[tiab] OR photochemotherap*[tiab] OR folfirinox[tiab] OR Leucovorin[tiab] OR Fluorouracil[tiab] OR Capecitabine[tiab] OR gemcitabine[tiab] OR gemzar[tiab] OR 5-fu[tiab] OR Paclitaxel[tiab] OR Camptothecin[tiab]
#20 (https://www.ncbi.nlm.nih.gov/pubmed) | Search #3 AND #4 AND #19
#19 (https://www.ncbi.nlm.nih.gov/pubmed) | Search #12 OR #13 Or #14 OR #15 OR #16 OR #17 OR #18
#18 (https://www.ncbi.nlm.nih.gov/pubmed) | Search anxiet*[tiab] OR anxious*[tiab] OR depress*[tiab] OR “cancer worry”[tiab] OR “cancer worries”[tiab]
#17 (https://www.ncbi.nlm.nih.gov/pubmed) | Search malignan*[tiab] AND seed*[tiab]
#16 (https://www.ncbi.nlm.nih.gov/pubmed) | Search neoplas*[tiab] AND seed*[tiab]
#15 (https://www.ncbi.nlm.nih.gov/pubmed) | Search bile[tiab] AND peritonitis[tiab]
#14 (https://www.ncbi.nlm.nih.gov/pubmed) | Search perforat*[tiab] OR infect*[tiab] OR iatrogen*[tiab] OR hemorrhag*[tiab] OR haemorrhag*[tiab]
#13 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (adverse[tiab] AND (effect*[tiab] OR event[tiab] OR outcome[tiab] OR reaction[tiab]))
#12 (https://www.ncbi.nlm.nih.gov/pubmed) | Search harm[tiab] OR harms[tiab] OR harmful[tiab] OR harmed[tiab] OR mortal*[tiab] OR death*[tiab] OR complication*[tiab] OR “side effect”[tiab] OR “side effects”[tiab] OR safety[tiab]
#11 (https://www.ncbi.nlm.nih.gov/pubmed) | Search #3 AND #4 AND #10
#10 (https://www.ncbi.nlm.nih.gov/pubmed) | Search sensitivit*[tiab] OR specificit*[tiab] OR predictive value[tiab] OR predictive values[tiab] OR accuracy[tiab] OR false positive[tiab] OR false positives[tiab] OR false positivity[tiab] OR false positivities[tiab] OR false negative[tiab] OR false negatives[tiab] OR false negativity[tiab] OR false negativities[tiab] OR miss rate[tiab] OR miss rates[tiab] OR error rate[tiab] OR error rates[tiab] OR roc curve[tiab] OR roc curves[tiab] OR receiver operat*[tiab] OR reference value[tiab] OR reference values[tiab] OR reference standard[tiab] OR reference standards[tiab]
#9 (https://www.ncbi.nlm.nih.gov/pubmed) | Search #3 AND #4 AND #8
#8 (https://www.ncbi.nlm.nih.gov/pubmed) | Search #5 OR #6 OR #7
#7 (https://www.ncbi.nlm.nih.gov/pubmed) | Search metaanaly*[tiab] or “meta analysis”[tiab]
#6 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (control[tiab] OR controls[tiab] OR controlled[tiab]) AND (trial[tiab] OR trials[tiab])
#5 (https://www.ncbi.nlm.nih.gov/pubmed) | Search “clincial trials”[tiab] OR “clinical trial”[tiab] OR random*[tiab]
#4 (https://www.ncbi.nlm.nih.gov/pubmed) | Search screen*[tiab] OR ultrasonogra*[tiab] OR ultrasound*[tiab] OR tomograph*[tiab] OR magnetic resonance imag*[tiab] OR cholangiography[tiab] OR cholangiopancreato*[tiab] OR ct scan*[tiab] OR pet scan*[tiab] OR mri[tiab] OR octreoscan*[tiab] OR octreotide scan*[tiab] OR angiograph*[tiab] OR ercp[tiab]
#3 (https://www.ncbi.nlm.nih.gov/pubmed) | Search #1 OR #2
#2 (https://www.ncbi.nlm.nih.gov/pubmed) | Search pancreatic intraepithelial neoplas*[tiab] OR panin[tiab] OR intraductal papillary mucinous neoplas*[tiab] OR ipmn[tiab] OR mucinous cystic neoplas*[tiab]
#1 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (pancreas[tiab] OR pancreati*[tiab] OR pancreato*[tiab] OR Acinar*[tiab] OR Acinus[tiab] OR hepatopancreat*[tiab] OR ampull*[tiab]) AND (cancer*[tiab] OR carcinoma*[tiab] OR adenocarcinoma*[tiab] OR apudoma*[tiab] OR adenoma*[tiab] OR carcinoid*[tiab] OR sarcoma*[tiab] OR malignan*[tiab] OR tumor*[tiab] OR tumour*[tiab] OR neoplas*[tiab] OR lesion*[tiab] OR cyst[tiab] OR cysts[tiab])

Appendix A Figure 1 Literature Flow Diagram

Abbreviations: KQ = Key question

Appendix A Figure 1 is a flow chart that summarizes the search and selection of articles. There were 19,298 citations identified through literature databases. An additional 298 citations were identified from outside sources such as reference lists and suggestions from peer reviewers. After duplicates were removed, 19,596 unique citations were screened at the title/abstract stage. The full text of 824 citations were examined for inclusion for one or more of the five Key Questions. Ultimately, 13 unique studies reported in 24 articles were included in the review.

Appendix A Table 1 Inclusion and Exclusion Criteria

| Included | Excluded
Population | KQs 1 3: Adults age ≥18 years, with or without risk factors for pancreatic adenocarcinoma (e.g., family history of pancreatic cancer, personal history of new-onset diabetes, or other risk factors)^*^; KQs 4, 5: Adults with screen-detected or asymptomatic pancreatic adenocarcinoma | KQs 1 3:; - Children and adolescents; - Persons with history of pancreatic cancer; - Studies focusing only on persons with a known genetic syndrome associated with increased risk for pancreatic cancer (e.g., Peutz-Jeghers syndrome, Lynch syndrome, hereditary pancreatitis, known mutations in CDKN2A, BRCA1, BRCA2, CTFR, or ATM genes)^†^; KQs 4, 5: Symptomatic populations with pancreatic adenocarcinoma; populations with pancreatic endocrine or exocrine tumors other than adenocarcinoma
Setting | Studies conducted in countries categorized as “Very High” on the 2016 Human Development Index (as defined by the United Nations Development Programme)^1^
Screening test | Any imaging-based screening protocol, including but not limited to computed tomography scan, endoscopic ultrasonography, magnetic resonance imaging, and abdominal ultrasonography | Serum, stool, or saliva-based testing for biomarkers, such as cancer antigen 19-9, carcinoembryonic antigen, cell-surface proteins, micro-RNA, hypermethylation of specific genes in circulating DNA, circulating tumor cells, or multiple-biomarker panels
Treatment | KQs 4, 5: Surgical resection, with or without chemotherapy or radiation therapy | Chemotherapy or palliative care alone
Comparisons | KQ 1: No screening; KQ 2: Reference standard (e.g., clinical followup); KQ 4: No treatment or delayed treatment | Comparative effectiveness screening or treatment studies
Outcomes | KQs 1, 4: Reduced pancreatic adenocarcinoma morbidity or mortality, reduced all-cause mortality, and improved quality of life; KQ 2: Sensitivity, specificity, positive predictive value, and lesion detection rate; KQs 3, 5: Any harm from screening or treatment, including false-positive or false-negative results, serious psychological harms, or screening- or treatment-related adverse events | KQ 3: Incidentally identified lesions
Study design | All KQs: Fair- or good-quality studies (according to design-specific USPSTF criteria) published from 2002 to the present^‡^; KQ 1: Randomized, controlled trials; controlled clinical trials; KQ 2: Diagnostic accuracy studies with a reference standard; systematic evidence reviews; KQs 3, 5: Randomized, controlled trials; controlled clinical trials; cohort studies; case-control studies; KQ 4: Randomized, controlled trials; controlled clinical trials; cohort studies | Poor-quality studies with a fatal flaw; studies occurring outside of the specified publication dates; case reports and case series; narrative reviews, commentaries, editorials, theses, qualitative studies, ecologic studies, comparative effectiveness studies, and decision analyses; studies not available in the English language

Abbreviations: DNA=deoxyribonucleic acid; RNA=ribonucleic acid.

* Results were stratified by risk factors, such as age, sex, or clinical characteristics, where possible.

† Studies consisting entirely of populations with high-risk genetic syndromes were excluded, but studies that include persons with high-risk genetic syndromes in addition to persons with other risk factors were not excluded.

‡ Studies included in the previous USPSTF review (search dates through December 2001) that meet current inclusion criteria were evaluated, but none of them met our inclusion criteria.

Appendix A Table 2 Quality Assessment Criteria

Study Design | Quality criteria
Randomized controlled trials USPSTF methods^2^ | - Valid random assignment?; - Was allocation concealed?; - Was eligibility criteria specified?; - Were groups similar at baseline?; - Were measurements equal, valid, and reliable?; - Was there intervention fidelity?; - Was there adequate adherence to the intervention?; - Were outcome assessors blinded?; - Was there acceptable followup?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?; - Was there evidence of selective reporting of outcomes?; - Was the device calibration and/or maintenance reported?
Observational studies (e.g., prospective cohort studies), adapted from the Newcastle-Ottawa Scale (NOS)^3^ | - Was the cohort systematically selected to avoid bias?; - Was eligibility criteria specified?; - Were groups similar at baseline?; - Was the outcome of interest not present at baseline?; - Were measurements equal, valid, and reliable?; - Were outcome assessors blinded?; - Was there acceptable followup?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?
Diagnostic accuracy studies adapted from QUADAS I and II^4,^ ^5^ | - Screening test relevant, available for primary care, and adequately described; - Study uses a credible reference standard performed regardless of test results; - Reference standard interpreted independently of screening test; - Handles indeterminate results in a reasonable manner; - Spectrum of patients included in study; - Sample size reported; - Administration of reliable screening test

Abbreviations: USPSTF = U.S. Preventive Services Task Force

## References

1 United Nations Development Programme. Human Development Index: 2016 Rankings. United Nations Development Programme [2017 December 1]. http://hdr.undp.org/en/2016-report.
2 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2015.
3 Wells GA, Shea B, O’Connell D, . The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. Ottawa: University of Ottawa [2018 August 23]. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp.
4 Whiting P, Rutjes AW, Reitsma JB, . The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 2003;3:25. PMID: 14606960.14606960
5 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011;155(8):529–36. PMID: 22007046.22007046