# References

1 U.S. Preventive Services Task Force. Medications to decrease the risk for breast cancer in women: recommendations from the U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2013 Nov 19;159(10):698–708. doi: 10.7326/0003-4819-159-10-201311190-00717. PMID: 24061412.24061412
2 Nelson HD, Smith ME, Griffin JC, . Use of medications to reduce risk for primary breast cancer: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2013 Apr 16;158(8):604–14. doi: 10.7326/0003-4819-158-8-201304160-00005. PMID: 23588749.23588749
3 National Cancer Institute. NCI dictionary of cancer terms: breast cancer. National Institute of Health; 2016. https://www.cancer.gov/publications/dictionaries/cancer-terms?cdrid=444971. Accessed June 21 2019.
4 National Cancer Institute. NCI dictionary of cancer terms: lobular carcinoma. National Institute of Health; 2016. https://www.cancer.gov/publications/dictionaries/cancer-terms?search=lobular%20carcinoma. Accessed June 21 2019.
5 American Cancer Society. Cancer Facts & Figures 2018. Atlanta: American Cancer Society, Inc.; 2018. https://www.cancer.org/content/dam/cancer-org/research/cancer-facts-and-statistics/annual-cancer-facts-and-figures/2018/cancer-facts-and-figures-2018.pdf. Accessed June 21 2019.
6 National Cancer Institute. Cancer Stat Facts: Female Breast Cancer. National Institute of Health; 2018. https://seer.cancer.gov/statfacts/html/breast.html. Accessed June 21 2019.
7 American Cancer Society. Breast Cancer Facts & Figures 2017-2018. Atlanta: American Cancer Society, Inc.; 2018. https://www.cancer.org/content/dam/cancer-org/research/cancer-facts-and-statistics/breast-cancer-facts-and-figures/breast-cancer-facts-and-figures-2017-2018.pdf. Accessed June 21 2019.
8 Centers for Disease Control and Prevention. What are the Risk Factors for Breast Cancer? Atlanta, GA: U.S Department of Health and Human Services 2016. http://www.cdc.gov/cancer/breast/basic_info/risk_factors.htm. Accessed June 21 2019.
9 Nelson HD, Fu R, Griffin JC, . Systematic review: comparative effectiveness of medications to reduce risk for primary breast cancer. Ann Intern Med. 2009 Nov 17;151(10):703–15, w-226–35. doi: 10.7326/0003-4819-151-10-200911170-00147. PMID: 19920271.19920271
10 Eli Lilly and Company. EVISTA (raloxifene) Medication Guide. Indianapolis, IN; 2007. https://www.fda.gov/downloads/Drugs/DrugSafety/ucm088593.pdf. Accessed June 21 2019.
11 AstraZeneca Pharmaceuticals LP. NOLVADEX (tamoxifen) Medication Guide. Wilmington, DE; 2004. https://www.fda.gov/downloads/drugs/drugsafety/ucm088661.pdf. Accessed June 21 2019.
12 AstraZeneca Pharmaceuticals LP. ARIMIDEX (anastrozole) FDA Prescription Label. Wilmington, DE; 2010. https://www.accessdata.fda.gov/drugsatfda_docs/label/2011/020541s026lbl.pdf. Accessed June 21 2019.
13 Pfizer Inc. AROMASIN (exemestane) FDA Prescription Label. New York, NY; 2018. https://www.accessdata.fda.gov/drugsatfda_docs/label/2018/020753s020lbl.pdf. Accessed June 24 2019.
14 Novartis Pharmaceuticals Corporation. Femara (letrozole) FDA Prescription Label. East Hanover, NJ; 2018. https://www.accessdata.fda.gov/drugsatfda_docs/label/2018/020726s035lbl.pdf. Accessed June 24 2019.
15 Cuzick J, Sestak I, Bonanni B, . Selective oestrogen receptor modulators in prevention of breast cancer: an updated meta-analysis of individual participant data. Lancet. 2013 May 25;381(9880):1827–34. doi: 10.1016/s0140-6736(13)60140-3. PMID: 23639488.23639488
16 Richardson H, Johnston D, Pater J, . The National Cancer Institute of Canada Clinical Trials Group MAP.3 trial: an international breast cancer prevention trial. Curr Oncol. 2007 Jun;14(3):89–96. PMID: 17593981.17593981
17 Cuzick J, Sestak I, Forbes JF, . Anastrozole for prevention of breast cancer in high-risk postmenopausal women (IBIS-II): an international, double-blind, randomised placebo-controlled trial.[Erratum appears in Lancet. 2014 Mar 22;383(9922):1040]. Lancet. 2014 Mar 22;383(9922):1041–8. doi: 10.1016/S0140-6736(13)62292-8. PMID: 24333009.24333009
18 van de Velde CJ, Rea D, Seynaeve C, . Adjuvant tamoxifen and exemestane in early breast cancer (TEAM): a randomised phase 3 trial. Lancet. 2011 Jan 22;377(9762):321–31. doi: 10.1016/S0140-6736(10)62312-4. PMID: 21247627.21247627
19 Smith SG, Sestak I, Forster A, . Factors affecting uptake and adherence to breast cancer chemoprevention: A systematic review and meta-analysis. Cancer Res. 2016;76(4)doi: 10.1158/1538-7445.SABCS15-PD1-08. PMID: 26646754.26646754
20 Pinsky P, Miller E, Heckman-Stoddard B, . Use of raloxifene and tamoxifen by breast cancer risk level in a Medicare-eligible cohort. Am J Obstet. Gynecol. 2018. doi: 10.1016/j.ajog.2018.03.031. PMID: 29630889.29630889
21 Waters EA, Cronin KA, Graubard BI, . Prevalence of tamoxifen use for breast cancer chemoprevention among U.S. women. Cancer Epidemiol Biomarkers Prev. 2010 Feb;19(2):443–6. doi: 10.1158/1055-9965.epi-09-0930. PMID: 20142242.20142242
22 Smith SG, Foy R, McGowan JA, . Prescribing tamoxifen in primary care for the prevention of breast cancer: a national online survey of GPs’ attitudes. Br J Gen Pract. 2017 Jun;67(659):e414–e27. doi: 10.3399/bjgp17X689377. PMID: 28193617.28193617
23 National Comprehensive Cancer Network. NCCN Clinical Practices Guidelines in Onconlogy: Breast Cancer Risk Reduction. 2019. Available at https://www.nccn.org/professionals/physician_gls/pdf/breast_risk.pdf.
24 U.S. Preventive Services Task Force. Methods and Processes. 2018. https://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes. Accessed June 21 2019.
25 Homer D, Lemeshow S. Applied logistic regression. 2nd ed. New York, NY: John Wiley & Sons Inc.; 2000.
26 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002 Jun 15;21(11):1539–58. doi: 10.1002/sim.1186. PMID: 12111919.12111919
27 Hardy RJ, Thompson SG. A likelihood approach to meta-analysis with random effects. Stat Med. 1996 Mar 30;15(6):619–29. doi: 10.1002/(sici)1097-0258(19960330)15:6<619::aid-sim188>3.0.co;2-a. PMID: 8731004.8731004
28 Adams-Campbell LL, Makambi KH, Palmer JR, . Diagnostic accuracy of the Gail model in the Black Women’s Health Study. Breast J. 2007;13(4):332–6. PMID: 17593036.17593036
29 Amir E, Evans DG, Shenton A, . Evaluation of breast cancer risk assessment packages in the family history evaluation and screening programme. J Med Genet. 2003 Nov;40(11):807–14. PMID: 14627668.14627668
30 Barlow WE, White E, Ballard-Barbash R, . Prospective breast cancer risk prediction model for women undergoing screening mammography. J Natl Cancer Inst. 2006 Sep 6;98(17):1204–14. doi: 10.1093/jnci/djj331. PMID: 16954473.16954473
31 Boughey JC, Hartmann LC, Anderson SS, . Evaluation of the Tyrer-Cuzick (International Breast Cancer Intervention Study) model for breast cancer risk prediction in women with atypical hyperplasia. J Clin Oncol. 2010 Aug 1;28(22):3591–6. doi: 10.1200/jco.2010.28.0784. PMID: 20606088.20606088
32 Boyle P, Mezzetti M, La Vecchia C, . Contribution of three components to individual cancer risk predicting breast cancer risk in Italy. Eur J Cancer Prev. 2004;13:183–91. PMID: 15167217.15167217
33 Brentnall AR, Harkness EF, Astley SM, . Mammographic density adds accuracy to both the Tyrer-Cuzick and Gail breast cancer risk models in a prospective UK screening cohort. Breast Cancer Res. 2015;17(1)doi: 10.1186/s13058-015-0653-5. PMID: 26627479.26627479
34 Chen J, Pee D, Ayyagari R, . Projecting absolute invasive breast cancer risk in white women with a model that includes mammographic density. J Natl Cancer Inst. 2006 Sep 6;98(17):1215–26. doi: 10.1093/jnci/djj332. PMID: 16954474.16954474
35 Chlebowski RT, Anderson GL, Lane DS, . Predicting risk of breast cancer in postmenopausal women by hormone receptor status. J Natl Cancer Inst. 2007;99(22):1695–705. doi: 10.1093/jnci/djm224 PMID: 18000216.18000216
36 Colditz GA, Rosner B. Cumulative risk of breast cancer to age 70 years according to risk factor status: data from the Nurses’ Health Study. Am J Epidemiol. 2000 Nov 15;152(10):950–64. PMID: 11092437.11092437
37 Colditz GA, Rosner BA, Chen WY, . Risk factors for breast cancer according to estrogen and progesterone receptor status. J Natl Cancer Inst. 2004 Feb 4;96(3):218–28. PMID: 14759989.14759989
38 Costantino JP, Gail MH, Pee D, . Validation studies for models projecting the risk of invasive and total breast cancer incidence. J Natl Cancer Inst. 1999;91(18):1541–8. PMID: 10491430.10491430
39 Decarli A, Calza S, Masala G, . Gail model for prediction of absolute risk of invasive breast cancer: Independent evaluation in the florence–european prospective investigation into cancer and nutrition cohort. J Natl Cancer Inst. 2006 December 6, 2006;98(23):1686–93. doi: 10.1093/jnci/djj463. PMID: 17148770.17148770
40 Gail M, Anderson W, Garcia-Closas M, . Absolute risk models for subtypes of breast cancer [Editorial]. J Natl Cancer Inst. 2007;99:1657–9. PMID: 18000214.18000214
41 Gail MH, Brinton LA, Byar DP, . Projecting individualized probabilities of developing breast cancer for white females who are being examined annually. J Natl Cancer Inst. 1989;81(24):1879–86. PMID: 2593165.2593165
42 Li K, Anderson G, Viallon V, . Risk prediction for estrogen receptor-specific breast cancers in two large prospective cohorts 11 Medical and Health Sciences 1117 Public Health and Health Services. Breast Cancer Res. 2018;20(3):147. doi: 10.1186/s13058-018-1073-0. PMID: 30509329.30509329
43 Matsuno RK, Costantino JP, Ziegler RG, . Projecting individualized absolute invasive breast cancer risk in Asian and Pacific Islander American women. J Natl Cancer Inst. 2011 Jun 22;103(12):951–61. doi: 10.1093/jnci/djr154. PMID: 21562243.21562243
44 Petracci E, Decarli A, Schairer C, . Risk factor modification and projections of absolute breast cancer risk. J Natl Cancer Inst. 2011 June 24, 2011doi: 10.1093/jnci/djr172. PMID: 21705679.21705679
45 Rockhill B, Byrne C, Rosner B, . Breast cancer risk prediction with a log-incidence model: evaluation of accuracy. J Clin Epidemiol. 2003 9//;56(9):856–61. doi: 10.1016/S0895-4356(03)00124-0. PMID: 14505770.14505770
46 Rockhill B, Spiegelman D, Byrne C, . Validation of the Gail et al. model of breast cancer risk prediction and implications for chemoprevention. J Natl Cancer Inst. 2001 Mar 7;93(5):358–66. PMID: 11238697.11238697
47 Tamimi RM, Rosner B, Colditz GA. Evaluation of a breast cancer risk prediction model expanded to include category of prior benign breast disease lesion. Cancer. 2010;116(21):4944–53. doi: 10.1002/cncr.25386. PMID: 20645399.20645399
48 Tice JA, Cummings SR, Smith-Bindman R, . Using clinical factors and mammographic breast density to estimate breast cancer risk: Development and validation of a new predictive model. Ann Intern Med. 2008;148(5):337–47. PMID: 18316752.18316752
49 Tice JA, Miglioretti DL, Li CS, . Breast density and benign breast disease: Risk assessment to identify women at high risk of breast cancer. J Clin Oncol. 2015;33(28):3137–43. doi: 10.1200/JCO.2015.60.8869. PMID: 26282663.26282663
50 Tyrer J, Duffy SW, Cuzick J. A breast cancer prediction model incorporating familial and personal risk factors. Stat Med. 2004 Apr 15;23(7):1111–30. doi: 10.1002/sim.1668. PMID: 15057881.15057881
51 Vacek PM, Skelly JM, Geller BM. Breast cancer risk assessment in women aged 70 and older. Breast Cancer Res Treat. 2011 Nov;130(1):291–9. doi: 10.1007/s10549-011-1576-1. PMID: 21604157.21604157
52 Warwick J, Birke H, Stone J, . Mammographic breast density refines Tyrer-Cuzick estimates of breast cancer risk in high-risk women: findings from the placebo arm of the International Breast Cancer Intervention Study I. Breast Cancer Res. 2014 Oct 08;16(5):451. doi: 10.1186/s13058-014-0451-5. PMID: 25292294.25292294
53 DeCensi A, Bonanni B, Maisonneuve P, . A phase-III prevention trial of low-dose tamoxifen in postmenopausal hormone replacement therapy users: the HOT study. Ann Oncol. 2013 Nov;24(11):2753–60. doi: 10.1093/annonc/mdt244. PMID: 23864098.23864098
54 Cuzick J, Forbes J, Edwards R, . First results from the International Breast Cancer Intervention Study (IBIS-I): a randomised prevention trial. Lancet. 2002 Sep 14;360(9336):817–24. PMID: 12243915.12243915
55 Veronesi U, Maisonneuve P, Costa A, . Prevention of breast cancer with tamoxifen: preliminary findings from the Italian randomised trial among hysterectomised women. Italian Tamoxifen Prevention Study. Lancet. 1998 Jul 11;352(9122):93–7. PMID: 9672273.9672273
56 Goss PE, Ingle JN, Ales-Martinez JE, . Exemestane for breast-cancer prevention in postmenopausal women.[Erratum appears in N Engl J Med. 2011 Oct 6;365(14):1361]. N Engl J Med. 2011 Jun 23;364(25):2381–91. doi: 10.1056/NEJMoa1103507. PMID: 21639806.21639806
57 Martino S, Cauley JA, Barrett-Connor E, . Continuing outcomes relevant to Evista: breast cancer incidence in postmenopausal osteoporotic women in a randomized trial of raloxifene. J Natl Cancer Inst. 2004 Dec 1;96(23):1751–61. doi: 10.1093/jnci/djh319. PMID: 15572757.15572757
58 Fisher B, Costantino JP, Wickerham DL, . Tamoxifen for prevention of breast cancer: report of the National Surgical Adjuvant Breast and Bowel Project P-1 Study. J Natl Cancer Inst. 1998 Sep 16;90(18):1371–88. PMID: 9747868.9747868
59 Powles T, Eeles R, Ashley S, . Interim analysis of the incidence of breast cancer in the Royal Marsden Hospital tamoxifen randomised chemoprevention trial. Lancet. 1998;352(9122):98–101. doi: 10.1016/S0140-6736(98)85012-5. PMID: 9672274.9672274
60 Barrett-Connor E, Mosca L, Collins P, . Effects of raloxifene on cardiovascular events and breast cancer in postmenopausal women. N Engl J Med. 2006;355(2):125–37. doi: 10.1056/NEJMoa062462. PMID: 16837676.16837676
61 Vogel VG, Costantino JP, Wickerham DL, . Effects of tamoxifen vs raloxifene on the risk of developing invasive breast cancer and other disease outcomes: the NSABP Study of Tamoxifen and Raloxifene (STAR) P-2 trial. JAMA. 2006 Jun 21;295(23):2727–41. doi: 10.1001/jama.295.23.joc60074. PMID: 16754727.16754727
62 Christodoulakos GE, Botsis DS, Lambrinoudaki IV, . A 5-year study on the effect of hormone therapy, tibolone and raloxifene on vaginal bleeding and endometrial thickness. Maturitas. 2006 Mar 20;53(4):413–23. doi: 10.1016/j.maturitas.2005.07.003. PMID: 16140483.16140483
63 Cohen FJ, Watts S, Shah A, . Uterine effects of 3-year raloxifene therapy in postmenopausal women younger than age 60. Obstet Gynecol. 2000 Jan;95(1):104–10. PMID: 10636511.10636511
64 Delmas PD, Bjarnason NH, Mitlak BH, . Effects of raloxifene on bone mineral density, serum cholesterol concentrations, and uterine endometrium in postmenopausal women. N Engl J Med. 1997 Dec 4;337(23):1641–7. doi: 10.1056/nejm199712043372301. PMID: 9385122.9385122
65 Johnston CC, Jr., Bjarnason NH, Cohen FJ, . Long-term effects of raloxifene on bone mineral density, bone turnover, and serum lipid levels in early postmenopausal women: three-year data from 2 double-blind, randomized, placebo-controlled trials. Arch Intern Med. 2000 Dec 11–25;160(22):3444–50. PMID: 11112238.11112238
66 Jolly EE, Bjarnason NH, Neven P, . Prevention of osteoporosis and uterine effects in postmenopausal women taking raloxifene for 5 years. Menopause. 2003 Jul-Aug;10(4):337–44. doi: 10.1097/01.gme.0000058772.59606.2a. PMID: 12851517.12851517
67 Lufkin EG, Whitaker MD, Nickelsen T, . Treatment of established postmenopausal osteoporosis with raloxifene: a randomized trial. J Bone Miner Res. 1998 Nov;13(11):1747–54. doi: 10.1359/jbmr.1998.13.11.1747. PMID: 9797484.9797484
68 McClung MR, Siris E, Cummings S, . Prevention of bone loss in postmenopausal women treated with lasofoxifene compared with raloxifene. Menopause. 2006 May-Jun;13(3):377–86. doi: 10.1097/01.gme.0000188736.69617.4f. PMID: 16735934.16735934
69 Meunier PJ, Vignot E, Garnero P, . Treatment of postmenopausal women with osteoporosis or low bone density with raloxifene. Raloxifene Study Group. Osteoporos Int. 1999;10(4):330–6. PMID: 10692984.10692984
70 Morii H, Ohashi Y, Taketani Y, . Effect of raloxifene on bone mineral density and biochemical markers of bone turnover in Japanese postmenopausal women with osteoporosis: results from a randomized placebo-controlled trial. Osteoporos Int. 2003 Oct;14(10):793–800. doi: 10.1007/s00198-003-1424-1. PMID: 12955333.12955333
71 Nickelsen T, Lufkin EG, Riggs BL, . Raloxifene hydrochloride, a selective estrogen receptor modulator: safety assessment of effects on cognitive function and mood in postmenopausal women. Psychoneuroendocrinology. 1999 Jan;24(1):115–28. PMID: 10098223.10098223
72 Palacios S, Farias ML, Luebbert H, . Raloxifene is not associated with biologically relevant changes in hot flushes in postmenopausal women for whom therapy is appropriate. Am J Obstet Gynecol. 2004 Jul;191(1):121–31. doi: 10.1016/j.ajog.2003.10.701. PMID: 15295352.15295352
73 Abramson N, Costantino JP, Garber JE, . Effect of Factor V Leiden and prothrombin G20210A mutations on thromboembolic risk in the national surgical adjuvant breast and bowel project breast cancer prevention trial. J Natl Cancer Inst. 2006 Jul 05;98(13):904–10. doi: 10.1093/jnci/djj262. PMID: 16818854.16818854
74 Barrett-Connor E, Cauley JA, Kulkarni PM, . Risk-benefit profile for raloxifene: 4-year data From the Multiple Outcomes of Raloxifene Evaluation (MORE) randomized trial. J Bone Miner Res. 2004 Aug;19(8):1270–5. doi: 10.1359/jbmr.040406. PMID: 15231013.15231013
75 Barrett-Connor E, Grady D, Sashegyi A, . Raloxifene and cardiovascular events in osteoporotic postmenopausal women: four-year results from the MORE (Multiple Outcomes of Raloxifene Evaluation) randomized trial. JAMA. 2002 Feb 20;287(7):847–57. PMID: 11851576.11851576
76 Brisson J, Brisson B, Cote G, . Tamoxifen and mammographic breast densities. Cancer Epidemiol Biomarkers Prev. 2000 Sep;9(9):911–5. PMID: 11008908.11008908
77 Bruno S, Maisonneuve P, Castellana P, . Incidence and risk factors for non-alcoholic steatohepatitis: prospective study of 5408 women enrolled in Italian tamoxifen chemoprevention trial. BMJ. 2005 Apr 23;330(7497):932. doi: 10.1136/bmj.38391.663287.E0. PMID: 15746106.15746106
78 Cauley JA, Norton L, Lippman ME, . Continued breast cancer risk reduction in postmenopausal women treated with raloxifene: 4-Year results from the MORE trial. Breast Cancer Res Treat. 2001;65(2):125–34. doi: 10.1023/a:1006478317173. PMID: 11261828.11261828
79 Chalas E, Costantino JP, Wickerham DL, . Benign gynecologic conditions among participants in the Breast Cancer Prevention Trial. Am J Obstet Gynecol. 2005 Apr;192(4):1230–7; discussion 7-9. doi: 10.1016/j.ajog.2004.12.083. PMID: 15846210.15846210
80 Cummings SR, Eckert S, Krueger KA, . The effect of raloxifene on risk of breast cancer in postmenopausal women: results from the MORE randomized trial. Multiple Outcomes of Raloxifene Evaluation. JAMA. 1999 Jun 16;281(23):2189–97. PMID: 10376571.10376571
81 Cuzick J, Forbes JF, Sestak I, . Long-term results of tamoxifen prophylaxis for breast cancer-96-month follow-up of the randomized IBIS-I trial. J Natl Cancer Inst. 2007 Feb 21;99(4):272–82. doi: 10.1093/jnci/djk049. PMID: 17312304.17312304
82 Cuzick J, Sestak I, Cawthorn S, . Tamoxifen for prevention of breast cancer: extended long-term follow-up of the IBIS-I breast cancer prevention trial. Lancet Oncol. 2015 Jan;16(1):67–75. doi: 10.1016/S1470-2045(14)71171-4. PMID: 25497694.25497694
83 Day R, Ganz PA, Costantino JP. Tamoxifen and depression: More evidence from the National Surgical Adjuvant Breast and Bowel Project’s Breast Cancer Prevention (P-1) randomized study. J Natl Cancer Inst. 2001 November 7, 2001;93(21):1615–23. doi: 10.1093/jnci/93.21.1615. PMID: 11698565.11698565
84 Decensi A, Maisonneuve P, Rotmensz N, . Effect of tamoxifen on venous thromboembolic events in a breast cancer prevention trial. Circulation. 2005;111(5):650–6. doi: 10.1161/01.cir.0000154545.84124.ac. PMID: 15699284.15699284
85 Delmas PD, Ensrud KE, Adachi JD, . Efficacy of raloxifene on vertebral fracture risk reduction in postmenopausal women with osteoporosis: four-year results from a randomized clinical trial. J Clin Endocrinol Metab. 2002 Aug;87(8):3609–17. doi: 10.1210/jcem.87.8.8750. PMID: 12161484.12161484
86 Delmas PD, Genant HK, Crans GG, . Severity of prevalent vertebral fractures and the risk of subsequent vertebral and nonvertebral fractures: results from the MORE trial. Bone. 2003 Oct;33(4):522–32. PMID: 14555255.14555255
87 Duvernoy CS, Kulkarni PM, Dowsett SA, . Vascular events in the Multiple Outcomes of Raloxifene Evaluation (MORE) trial: incidence, patient characteristics, and effect of raloxifene. Menopause. 2005 Jul–Aug;12(4):444–52. doi: 10.1097/01.gme.0000151653.02620.89. PMID: 16037760.16037760
88 Ensrud KE, Stock JL, Barrett-Connor E, . Effects of raloxifene on fracture risk in postmenopausal women: the raloxifene use for the heart trial. J Bone Miner Res. 2008 Jan;23(1):112–20. doi: 10.1359/jbmr.070904. PMID: 17892376.17892376
89 Ettinger B, Black DM, Mitlak BH, . Reduction of vertebral fracture risk in postmenopausal women with osteoporosis treated with raloxifene: results from a 3-year randomized clinical trial. Multiple Outcomes of Raloxifene Evaluation (MORE) Investigators. JAMA. 1999 Aug 18;282(7):637–45. PMID: 10517716.10517716
90 Fisher B, Costantino JP, Wickerham DL, . Tamoxifen for the prevention of breast cancer: current status of the National Surgical Adjuvant Breast and Bowel Project P-1 study. J Natl Cancer Inst. 2005 Nov 16;97(22):1652–62. doi: 10.1093/jnci/dji372. PMID: 16288118.16288118
91 Grady D, Cauley JA, Geiger MJ, . Reduced incidence of invasive breast cancer with raloxifene among women at increased coronary risk. J Natl Cancer Inst. 2008 Jun 18;100(12):854–61. doi: 10.1093/jnci/djn153. PMID: 18544744.18544744
92 Grady D, Cauley JA, Stock JL, . Effect of raloxifene on all-cause mortality. Am J Med. 2010 May;123(5):469.e1–7. doi: 10.1016/j.amjmed.2009.12.018. PMID: 20399327.20399327
93 Grady D, Ettinger B, Moscarelli E, . Safety and adverse effects associated with raloxifene: multiple outcomes of raloxifene evaluation. Obstet Gynecol. 2004 Oct;104(4):837–44. doi: 10.1097/01.AOG.0000137349.79204.b8. PMID: 15458908.15458908
94 Johnell O, Cauley JA, Kulkarni PM, . Raloxifene reduces risk of vertebral fractures [corrected] in postmenopausal women regardless of prior hormone therapy. J Fam Pract. 2004 Oct;53(10):789–96. PMID: 15469774.15469774
95 Keech CA, Sashegyi A, Barrett-Connor E. Year-by-year analysis of cardiovascular events in the Multiple Outcomes of Raloxifene Evaluation (MORE) trial. Curr Med Res Opin. 2005 Jan;21(1):135–40. PMID: 15881485.15881485
96 Land SR, Wickerham DL, Costantino JP, . Patient-reported symptoms and quality of life during treatment with tamoxifen or raloxifene for breast cancer prevention: the NSABP Study of Tamoxifen and Raloxifene (STAR) P-2 trial. JAMA. 2006 Jun 21;295(23):2742–51. doi: 10.1001/jama.295.23.joc60075. PMID: 16754728.16754728
97 Lippman ME, Cummings SR, Disch DP, . Effect of raloxifene on the incidence of invasive breast cancer in postmenopausal women with osteoporosis categorized by breast cancer risk. Clin Cancer Res. 2006 Sep 1;12(17):5242–7. doi: 10.1158/1078-0432.ccr-06-0688. PMID: 16951244.16951244
98 Martino S, Disch D, Dowsett SA, . Safety assessment of raloxifene over eight years in a clinical trial setting. Curr Med Res Opin. 2005 Sep;21(9):1441–52. doi: 10.1185/030079905x61839. PMID: 16197663.16197663
99 Maunsell E, Goss PE, Chlebowski RT, . Quality of life in MAP.3 (Mammary Prevention 3): a randomized, placebo-controlled trial evaluating exemestane for prevention of breast cancer. J Clin Oncol. 2014 May 10;32(14):1427–36. doi: 10.1200/JCO.2013.51.2483. PMID: 24711552.24711552
100 Powles TJ, Ashley S, Tidy A, . Twenty-year follow-up of the Royal Marsden randomized, double-blinded tamoxifen breast cancer prevention trial. J Natl Cancer Inst. 2007 Feb 21;99(4):283–90. doi: 10.1093/jnci/djk050. PMID: 17312305.17312305
101 Runowicz CD, Costantino JP, Wickerham DL, . Gynecologic conditions in participants in the NSABP breast cancer prevention study of tamoxifen and raloxifene (STAR). Am J Obstet Gynecol. 2011 Dec;205(6):535.e1–5. doi: 10.1016/j.ajog.2011.06.067. PMID: 21872200.21872200
102 Sestak I, Singh S, Cuzick J, . Changes in bone mineral density at 3 years in postmenopausal women receiving anastrozole and risedronate in the IBIS-II bone substudy: an international, double-blind, randomised, placebo-controlled trial.[Erratum appears in Lancet Oncol. 2014 Dec;15(13):e587]. Lancet Oncol. 2014 Dec;15(13):1460–8. doi: 10.1016/S1470-2045(14)71035-6. PMID: 25456365.25456365
103 Silverman SL, Delmas PD, Kulkarni PM, . Comparison of fracture, cardiovascular event, and breast cancer rates at 3 years in postmenopausal women with osteoporosis. J Am Geriatr Soc. 2004 Sep;52(9):1543–8. doi: 10.1111/j.1532-5415.2004.52420.x. PMID: 15341559.15341559
104 Siris ES, Harris ST, Eastell R, . Skeletal effects of raloxifene after 8 years: results from the continuing outcomes relevant to Evista (CORE) study. J Bone Miner Res. 2005 Sep;20(9):1514–24. doi: 10.1359/jbmr.050509. PMID: 16059623.16059623
105 Spagnolo F, Sestak I, Howell A, . Anastrozole-induced carpal tunnel syndrome: Results from the international breast cancer intervention study II prevention trial. J Clin Oncol. 2016 Jan 10;34(2):139–43. doi: 10.1200/JCO.2015.63.4972. PMID: 26598748.26598748
106 Veronesi U, Maisonneuve P, Rotmensz N, . Tamoxifen for the prevention of breast cancer: late results of the Italian Randomized Tamoxifen Prevention Trial among women with hysterectomy. J Natl Cancer Inst. 2007 May 2;99(9):727–37. doi: 10.1093/jnci/djk154. PMID: 17470740.17470740
107 Veronesi U, Maisonneuve P, Rotmensz N, . Italian randomized trial among women with hysterectomy: tamoxifen and hormone-dependent breast cancer in high-risk women. J Natl Cancer Inst. 2003 Jan 15;95(2):160–5. PMID: 12529349.12529349
108 Armstrong K, Quistberg DA, Micco E, . Prescription of tamoxifen for breast cancer prevention by primary care physicians. Arch Intern Med. 2006 Nov 13;166(20):2260–5. doi: 10.1001/archinte.166.20.2260. PMID: 17101945.17101945
109 Corbelli J, Borrero S, Bonnema R, . Use of the Gail model and breast cancer preventive therapy among three primary care specialties. J Womens Health (Larchmt). 2014 Sep;23(9):746–52. doi: 10.1089/jwh.2014.4742. PMID: 25115368.25115368
110 Hackett J, Thorneloe R, Side L, . Uptake of breast cancer preventive therapy in the UK: results from a multicentre prospective survey and qualitative interviews. Breast Cancer Res Treat. 2018 Apr 24 doi: 10.1007/s10549-018-4775-1. PMID: 29687178.29687178
111 Holmberg C, Bandos H, Fagerlin A, . NRG oncology/national surgical adjuvant breast and bowel project decision-making project-1 results: Decision making in breast cancer risk reduction. Cancer Prev Res (Phila). 2017 Nov;10(11):625–34. doi: 10.1158/1940-6207.capr-17-0076. PMID: 28978566.28978566
112 Kaplan CP, Haas JS, Perez-Stable EJ, . Factors affecting breast cancer risk reduction practices among California physicians. Prev Med. 2005 Jul;41(1):7–15. doi: 10.1016/j.ypmed.2004.09.041. PMID: 15916987.15916987
113 Kaplan CP, Kim SE, Wong ST, . Willingness to use tamoxifen to prevent breast cancer among diverse women. Breast Cancer Res Treat. 2012 May;133(1):357–66. doi: 10.1007/s10549-012-1960-5. PMID: 22315131.22315131
114 Liede A, Mansfield CA, Metcalfe KA, . Preferences for breast cancer risk reduction among BRCA1/BRCA2 mutation carriers: a discrete-choice experiment. Breast Cancer Res Treat. 2017 Sep;165(2):433–44. doi: 10.1007/s10549-017-4332-3. PMID: 28624978.28624978
115 Martinez KA, Fagerlin A, Witteman HO, . What matters to women when making decisions about breast cancer chemoprevention? Patient. 2016 Apr;9(2):149–59. doi: 10.1007/s40271-015-0134-z. PMID: 26115846.26115846
116 Meiser B, Wong WKT, Peate M, . Motivators and barriers of tamoxifen use as risk-reducing medication amongst women at increased breast cancer risk: a systematic literature review. Hered Cancer Clin Pract. 2017;15:14. doi: 10.1186/s13053-017-0075-8. PMID: 28943990.28943990
117 Reimers LL, Sivasubramanian PS, Hershman D, . Breast cancer chemoprevention among high-risk women and those with ductal carcinoma in situ. Breast J. 2015 Jul-Aug;21(4):377–86. doi: 10.1111/tbj.12418. PMID: 25879521.25879521
118 Roetzheim RG, Lee JH, Fulp W, . Acceptance and adherence to chemoprevention among women at increased risk of breast cancer. Breast. 2015 Feb;24(1):51–6. doi: 10.1016/j.breast.2014.11.006. PMID: 25491191.25491191
119 Ropka ME, Keim J, Philbrick JT. Patient decisions about breast cancer chemoprevention: a systematic review and meta-analysis. J Clin Oncol. 2010 Jun 20;28(18):3090–5. doi: 10.1200/jco.2009.27.8077. PMID: 20458026.20458026
120 Skandarajah AR, Thomas S, Shackleton K, . Patient and medical barriers preclude uptake of tamoxifen preventative therapy in women with a strong family history. Breast. 2017 Apr;32:93–7. doi: 10.1016/j.breast.2017.01.002. PMID: 28107734.28107734
121 National Cancer Institute. Breast Cancer Risk Assessment Tool. National Institutes of Health 2011. https://www.cancer.gov/bcrisktool/. Accessed June 21 2019.
122 Gail MH, Costantino JP, Pee D, . Projecting individualized absolute invasive breast cancer risk in African American women. J Natl Cancer Inst. 2007;99(23):1782–92. doi: 10.1093/jnci/djm223 PMID: 18042936.18042936
123 Vogel VG, Costantino JP, Wickerham DL, . Update of the National Surgical Adjuvant Breast and Bowel Project Study of Tamoxifen and Raloxifene (STAR) P-2 Trial: Preventing breast cancer. Cancer Prev Res (Phila). 2010 Jun;3(6):696–706. PMID: 20404000.20404000
124 Veronesi U, Maisonneuve P, Sacchini V, . Tamoxifen for breast cancer among hysterectomised women. Lancet. 2002 Mar 30;359(9312):1122–4. doi: 10.1016/s0140-6736(02)08159-x. PMID: 11943263.11943263
125 Gail MH. The estimation and use of absolute risk for weighing the risks and benefits of selective estrogen receptor modulators for preventing breast cancer. Ann N Y Acad Sci. 2001 Dec;949:286–91. PMID: 11795364.11795364
126 Smith SG, Sestak I, Howell A, . Participant-reported symptoms and their effect on long-term adherence in the International Breast Cancer Intervention Study I (IBIS I). J Clin. Oncol. 2017 Aug 10;35(23):2666–73. doi: 10.1200/jco.2016.71.7439. PMID: 28661758.28661758
127 Goldstein SR, Johnson S, Watts NB, . Incidence of urinary incontinence in postmenopausal women treated with raloxifene or estrogen. Menopause. 2005 Mar;12(2):160–4. PMID: 15772563.15772563
128 Powles TJ, Jones AL, Ashley SE, . The Royal Marsden Hospital pilot tamoxifen chemoprevention trial. Breast Cancer Res Treat. 1994;31(1):73–82. PMID: 7981459.7981459
129 Day R, Ganz PA, Costantino JP, . Health-related quality of life and tamoxifen in breast cancer prevention: a report from the National Surgical Adjuvant Breast and Bowel Project P-1 Study. J. Clin Oncol. 1999 Sep;17(9):2659–69. PMID: 10561339.10561339
130 Fagerlin A, Zikmund-Fisher BJ, Nair V, . Women’s decisions regarding tamoxifen for breast cancer prevention: responses to a tailored decision aid. Breast Cancer Res Treat. 2010 Feb;119(3):613–20. doi: 10.1007/s10549-009-0618-4. PMID: 19908143.19908143
131 Melnikow J, Paterniti D, Azari R, . Preferences of Women Evaluating Risks of Tamoxifen (POWER) study of preferences for tamoxifen for breast cancer risk reduction. Cancer. 2005 May 15;103(10):1996–2005. doi: 10.1002/cncr.20981. PMID: 15825209.15825209
132 McKay A, Martin W, Latosinsky S. How should we inform women at higher risk of creast cancer about tamoxifen? An approach with a decision guide. Breast Cancer Res. Treat. 2005;94(2):153–9. doi: 10.1007/s10549-005-6932-6. PMID: 16261414.16261414
133 Paterniti DA, Melnikow J, Nuovo J, . “I’m going to die of something anyway”: women’s perceptions of tamoxifen for breast cancer risk reduction. Ethn Dis. 2005 Summer;15(3):365–72. PMID: 16108294.16108294
134 Metcalfe KA, Snyder C, Seidel J, . The use of preventive measures among healthy women who carry a BRCA1 or BRCA2 mutation. Fam Cancer. 2005;4(2):97–103. doi: 10.1007/s10689-005-4215-3. PMID: 15951959.15951959
135 Bober SL, Hoke LA, Duda RB, . Decision-making about tamoxifen in women at high risk for breast cancer: Clinical and psychological factors. J Clin Oncol. 2004;22(24):4951–7. doi: 10.1200/JCO.2004.05.192. PMID: 15598980.15598980
136 Freedman AN, Yu B, Gail MH, . Development of a benefit/risk assessment tool for breast cancer chemoprevention. Pharmacoepidemiol Drug Saf. 2011;20:S273–S4. doi: 10.1002/pds.2206.
137 Freedman AN, Yu B, Gail MH, . Benefit/risk assessment for breast cancer chemoprevention with raloxifene or tamoxifen for women age 50 years or older. J Clin Oncol. 2011 Jun 10;29(17):2327–33. doi: 10.1200/jco.2010.33.0258. PMID: 21537036.21537036
138 Sestak I, Smith SG, Howell A, . Early participant-reported symptoms as predictors of adherence to anastrozole in the International Breast Cancer Intervention Studies II. Ann Oncol. 2018;29(2):504–9. PMID: 29126161.29126161
139 Brentnall AR, Cuzick J, Buist DSM, . Long-term accuracy of breast cancer risk assessment combining classic risk factors and breast density. JAMA Oncology. 2018 Apr 5:e180174. doi: 10.1001/jamaoncol.2018.0174. PMID: 29621362.29621362
140 Forbes JF, Sestak I, Howell A, . Anastrozole versus tamoxifen for the prevention of locoregional and contralateral breast cancer in postmenopausal women with locally excised ductal carcinoma in situ (IBIS-II DCIS): a double-blind, randomised controlled trial. Lancet. 2016 Feb 27;387(10021):866–73. doi: 10.1016/S0140-6736(15)01129-0. PMID: 26686313.26686313
141 Aromatase inhibitors versus tamoxifen in early breast cancer: patient-level meta-analysis of the randomised trials. Lancet. 2015 Oct 3;386(10001):1341–52. doi: 10.1016/s0140-6736(15)61074-1. PMID: 26211827.26211827
142 Goldvaser H, Barnes TA, Seruga B, . Toxicity of extended adjuvant therapy with aromatase inhibitors in early breast cancer: a systematic review and meta-analysis. J Natl Cancer Inst. 2018 Jan 01;110(1)doi: 10.1093/jnci/djx141. PMID: 28922781.28922781
143 King MC, Wieand S, Hale K, . Tamoxifen and breast cancer incidence among women with inherited mutations in BRCA1 and BRCA2: National Surgical Adjuvant Breast and Bowel Project (NSABP-P1) Breast Cancer Prevention Trial. JAMA. 2001 Nov 14;286(18):2251–6. PMID: 11710890.11710890
144 Kurz-Milcke E, Gigerenzer G, Martignon L. Transparency in risk communication: graphical and analog tools. Ann N Y Acad Sci. 2008;18(28)doi: 10.1196/annals.1399.004. PMID: 84692118469211
145 Gierach G, Lacey JJ, Schatzkin A, . Nonsteroidal anti-inflammatory drugs and breast cancer risk in the National Institutes of Health-AARP Diet and Health Study. Breast Cancer Res. 2008;10(2)doi: 10.1186/bcr2089. PMID: 18447943.18447943
146 Shen Y, Costantino JP, Qin J. Tamoxifen chemoprevention treatment and time to first diagnosis of estrogen receptor-negative breast cancer. J Natl Cancer Inst. 2008;100(20):1448–53. PMID: 18840821.18840821