# Acknowledgments

The authors thank AHRQ Medical Officers Ernie Sullivent, MD, MPH, and Tina Fan, MD, MPH; U.S. Preventive Services Task Force leads Alex Krist, MD, MPH, Carol Mangione, MD, MSPH, and Michael Barry, MD; expert reviewers of the draft report; expert consultant Rachel Yung, MD; and research librarian Andrew Hamilton, MLS, MS.