# Chapter 4 Discussion

## Summary of Review Findings

Table 10 summarizes the evidence reviewed for this update. New studies include updated long-term results from the placebo-controlled IBIS-I trial of tamoxifen^82^ and two placebo-controlled trials of aromatase inhibitors, IBIS-II of anastrozole^17,102,105^ and the MAP.3 trial of exemestane.^56,99^ A new placebo-controlled tamoxifen trial, HOT, used a lower dose than the other trials (5 mg/day vs. 20 mg/day), and indicated no differences between tamoxifen and placebo.^53^ In addition, four new studies of risk prediction models include two studies that added breast density to the Gail and Tyrer-Cuzick models;^33,52^ a study modifying the Gail model for Asian Americans;^43^ a study that added benign breast disease to the BCSC model;^49^ and models to predict ER+ and ER− breast cancer specifically.^42^

Table 10 Summary of Evidence Table

Key Question | Interventions | Studies (k) Observations (n) Study Designs | Summary of Findings | Consistency and Precision | Other Limitations | Strength of Evidence | Applicability
KQ 1. Diagnostic accuracy of risk assessment methods | Breast cancer risk assessment | 24 discriminatory accuracy studies of 17 risk stratification models (n>5,000,000) | Most models have low discriminatory accuracy in predicting the probability of breast cancer in individuals (c-statistics 0.55 to 0.65) | Consistent; precise | While some studies used inappropriate reference groups, enrolled small numbers, or inadequately described methods, most studies met criteria for good quality | High | High
KQ 1a. Optimal age at which to begin risk assessment | Breast cancer risk assessment | No studies | Not applicable | Not applicable | Not applicable | Insufficient | Not applicable
KQ 1b. Optimal frequency of risk assessment | Breast cancer risk assessment | No studies | Not applicable | Not applicable | Not applicable | Insufficient | Not applicable
KQ 2. Benefits of risk reducing medications | Tamoxifen vs. raloxifene | 1 RCT (n=19,747) | Tamoxifen reduced invasive breast cancer compared with raloxifene (RR 1.24; 95% CI, 1.05 to 1.47; 5 fewer cases [95% CI, 1 to 9]^*^). No differences for ER+, ER-, or noninvasive breast cancer; all-cause or breast cancer-specific mortality; or fractures | Not applicable | None | High; 1 large definitive trial | High
KQ 2. Benefits of risk reducing medications, continued | Tamoxifen vs. placebo | 4 RCTs (n=28,193) | Tamoxifen reduced invasive breast cancer (RR 0.69; 95% CI, 0.59 to 0.84; 7 fewer cases; 95% CI, 4 to 12^*^); ER+ breast cancer (RR 0.58; 95% CI, 0.42 to 0.81; 8 fewer cases [95% CI, 4 to 1]^*^); and nonvertebral fractures (RR 0.66; 95% CI, 0.45 to 0.98; 3 fewer cases [95% CI, 0.2 to 5]^*^) compared with placebo. No differences for ER− or noninvasive breast cancer; all-cause or breast cancer-specific mortality; or vertebral fractures | Consistent; precise | Clinical heterogeneity across trials from varying eligibility criteria, adherence, and ascertainment of certain outcomes | High for all outcomes except fractures (based on one trial) | High
KQ 2. Benefits of risk reducing medications, continued | Raloxifene vs. placebo | 2 RCTs (n=17,806) | Raloxifene reduced invasive breast cancer (RR 0.44; 95% CI, 0.24 to 0.80; 9 fewer cases [95% CI, 3 to 15]^*^); ER+ breast cancer (RR 0.33; 95% CI, 0.15 to 0.70; 8 fewer cases [95% CI, 4 to 13]^*^); and vertebral fractures (RR 0.61; 95% CI, 0.53 to 0.73; 7 fewer cases [95% CI, 5 to 9]^*^) compared with placebo. No differences for ER− or noninvasive breast cancer; all-cause or breast cancer-specific mortality; or nonvertebral fractures | Consistent; precise | Trials were primarily designed for osteoporosis and cardiovascular outcomes; participants were not selected based on breast cancer risk | High for all outcomes | High
KQ 2. Benefits of risk reducing medications, continued | Aromatase inhibitors (anastrozole;exemestane) vs. placebo | 2 RCTs (n=8,424) | Aromatase inhibitors reduced invasive breast cancer (RR 0.45; 95% CI, 0.26 to 0.70; 16 fewer cases [95% CI, 8 to 24]^*^); and ER+ breast cancer (RR 0.37; 95% CI, 0.19 to 0.63; 15 fewer cases [95% CI, 8 to 20]^*^) compared with placebo. No differences for ER− or noninvasive breast cancer; all-cause or breast cancer-specific mortality; or fractures | Consistent; precise | Trials use different medications and exposure durations | High for all outcomes | High
KQ 2a. Benefits of risk reducing medications—timing and duration | Tamoxifen, raloxifene, aromatase inhibitors (anastrozole;exemestane) | 9 RCTs (n=74,170) | No significant differences in breast cancer outcomes by age. Despite variations in exposure time from 3 to 5 years, comparisons across similar medications indicated consistency in risk reduction for invasive breast cancer | Consistent; precise | No trials compared timing and duration directly. Age categories and durations varied across trials. | Moderate for tamoxifen; insufficient for other medications | High
KQ 2a. Benefits of risk reducing medications—persistence of effects | Tamoxifen, raloxifene, aromatase inhibitors (anastrozole;exemestane) | 2 RCTs of tamoxifen (n=9,610); no trials of other medications | Tamoxifen reduced invasive and ER+ breast cancer 8 years after discontinuation | Consistent; precise | Long term followup data are lacking from most trials | Moderate for tamoxifen; insufficient for other medications | High
KQ 3. Harms of risk reducing medications | Tamoxifen vs. raloxifene | 1 RCT (n=19,747) | Tamoxifen increased thromboembolic events (RR 0.75; 95% CI, 0.60 to 0.93; 4 more cases [95% CI, 1 to 7]^*^); DVT (RR 0.72; 95% CI, 0.54 to 0.95; 3 more cases [95% CI, 1 to 5]^*^); endometrial cancer (RR 0.55; 95% CI, 0.36 to 0.83; 5 more cases [95% CI, 2 to 9^*^); and cataracts (RR 0.80; 95% CI, 0.72 to 0.95; 15 more cases [95% CI, 8 to 22]^*^) compared with raloxifene. No differences for PE; CHD events; or stroke | Not applicable | None | High; 1 large definitive trial | High
KQ 3. Harms of risk reducing medications, continued | Tamoxifen vs. placebo | 4 RCTs (n=28,193) | Tamoxifen increased thromboembolic events (RR 1.93; 95% CI, 1.33 to 2.68; 5 more cases [95% CI, 2 to 9]^*^); endometrial cancer (RR 2.25; 95% CI, 1.17 to 4.41; 4 more cases [95% CI, 1 to 8]^*^); and cataracts (RR 1.22; 95% CI, 1.08 to 1.48; 26 more cases [95% CI, 5 to 50]^*^) compared with placebo. No differences for DVT; PE; CHD events; or stroke | Consistent; precise | Clinical heterogeneity across trials from varying eligibility criteria, adherence, and ascertainment of certain outcomes | High for all outcomes except DVT, PE (based on 2 trials) | High
KQ 3. Harms of risk reducing medications, continued | Raloxifene vs. placebo | 2 RCTs (n=17,806) | Raloxifene increased thromboembolic events (RR 1.56; 95% CI, 1.11 to 2.60; 7 more cases [95% CI, 0.3 to 17]^*^); endometrial cancer (RR 2.25; 95% CI, 1.17 to 4.41; 4 more cases [95% CI, 1 to 8]^*^); and cataracts (RR 1.22; 95% CI, 1.08 to 1.48; 26 more cases [95% CI, 5 to 50]^*^) compared with placebo. No differences for DVT; PE; CHD events; stroke; endometrial cancer; or cataracts | Consistent; precise | Trials were primarily designed for osteoporosis and cardiovascular outcomes; participants were not selected based on breast cancer risk | High for all outcomes | High
KQ 3. Harms of risk reducing medications, continued | Aromatase inhibitors (anastrozole;exemestane) vs. placebo | 2 RCTs (n=8,424) | No differences between aromatase inhibitors and placebo for thromboembolic events; DVT; PE; CHD events; stroke; endometrial cancer; or cataracts | Consistent; precise | Trials use different medications and exposure durations | Low to moderate; followup inadequate for several outcomes | High
KQ 3a. Harms of risk reducing medication—timing and duration | Tamoxifen, raloxifene, aromatase inhibitors (anastrozole;exemestane) | 2 RCTs of tamoxifen for thromboembolic events (n=18,583); 1 RCT of tamoxifen (n=13,175) for endometrial cancer; no trials of other medications | Risks for thromboembolic events and endometrial cancer with tamoxifen were higher for older compared with younger women | Consistent; precise | No trials compared timing and duration directly. Age categories and durations varied across trials. | Moderate for tamoxifen; insufficient for other medications | High
KQ 3a. Harms of risk reducing medication — persistence of effects | Tamoxifen, raloxifene, aromatase inhibitors (anastrozole;exemestane) | 2 RCTs of tamoxifen for thromboembolic events (n=9,610); 1 RCT of tamoxifen (n=7,139) for endometrial cancer; no trials of other medications | Risks for thromboembolic events and endometrial cancer with tamoxifen declined to normal after discontinuation | Consistent; precise | Long term followup data are lacking from most trials | Moderate for tamoxifen; insufficient for other medications | High
KQ 4. Variability by sub-populations | Tamoxifen, raloxifene, aromatase inhibitors (anastrozole;exemestane) | 2 RCTs for menopausal status (n=12,547); 5 RCTs for family history (n=56,136); 4 RCTs for BMI (n=26,230); 4 RCTs for breast lesions (n=41,346); 4 RCTs for risk categories (n=13,965); 1 RCT for reproductive factors (n=10,101) | Reduced risk for invasive cancer:; Tamoxifen in both pre and postmenopausal women.; Tamoxifen and raloxifene in women with or without family history of breast cancer, but inconsistent results, with sometimes more reduction in women without family histories.; Raloxifene, anastrozole, and exemestane in all BMI categories.; Tamoxifen and anastrozole had more effect when previous breast lesions (LCIS, ADH, ALH).; Tamoxifen, raloxifene, and anastrozole in all modified Gail model risk categories.; Raloxifene regardless of age at menarche, parity, or age at first live birth. | Inconsistent; imprecise | Trials were not designed for subgroup comparisons and analysis of differences between groups may be underpowered | Low and insufficient | High

* Per 1000 women over 5 years of use.

Abbreviations: ADH=atypical ductal hyperplasia; ALH=atypical lobular hyperplasia; CHD=coronary heart disease; CI=confidence interval; DVT=deep vein thrombosis; ER+=estrogen receptor positive; ER-=estrogen receptor negative; KQ=key question; LCIS=lobular carcinoma in situ; PE=pulmonary embolism; RCT=randomized control trial; RR=risk ratio.

Eighteen risk models have been evaluated in 25 studies including various modifications of the original Gail model, a model developed from the BCSC, the Tyrer-Cuzick model developed from the IBIS-I trial, models developed for specific populations (Italian, African American, Asian American), and others (Chlebowski, Rosner-Colditz, Model_ER+_). While most models share common risk factor variables, they differ by including additional variables and using different reference populations. Regardless of their complexity, models have low discriminatory accuracy in predicting the probability of breast cancer in an individual woman (AUC c-statistics 0.55 to 0.65). Isolated studies demonstrating higher accuracy were methodologically limited or inconsistent with other studies of the same model. Models that include breast density, postmenopausal hormone use, and a more extensive family history minimally improved predictive estimates. Most models performed only slightly better than age alone as a risk predictor. No studies evaluated optimal ages or frequencies for risk assessment.

A modified 5-year Gail score of 1.67 percent or higher has been used as a risk threshold in primary prevention trials and in FDA approval of tamoxifen and raloxifene for reducing risk for primary breast cancer. However, thresholds based on tools with low discriminatory accuracy may not be clinically useful in selecting candidates for therapy. Most women aged 60 years and older without other risk factors would meet this threshold by age alone.

Tamoxifen, raloxifene, and aromatase inhibitors (anastrozole, exemestane) reduced risk for invasive breast cancer in women without preexisting breast cancer after 3 to 5 years of use in clinical trials. Placebo-controlled trials indicated clinically significant reductions for tamoxifen (RR 0.69; 95% CI, 0.59 to 0.84; 7 fewer cases per 1000 women over 5 years of use [95% CI, 4 to 12]; 4 trials), raloxifene (RR 0.44; 95% CI, 0.24 to 0.80; 9 fewer cases [95% CI, 3 to 15]; 2 trials), and aromatase inhibitors (RR 0.45; 95% CI, 0.26 to 0.70; 16 fewer cases [95% CI, 8 to 24]; 2 trials). Risk for invasive breast cancer was higher for raloxifene than tamoxifen in the STAR head-to-head trial (RR, 1.24; 95% CI, 1.05 to 1.47) after long-term followup. Effects did not differ by age of initiation (before or after age 50 years) or duration of use (3 to 5 years), although this effect was not directly compared. Risk reduction persisted at least 8 years after discontinuation in the two tamoxifen trials providing long-term followup data. All medications reduced ER+, but not ER− invasive breast cancer; tamoxifen reduced noninvasive cancer in two trials. Breast-cancer specific and all-cause mortality were not reduced, although statistical power and followup of trials were insufficient for mortality outcomes.

In placebo-controlled trials, raloxifene (RR 0.61; 95% CI, 0.53 to 0.73; 2 trials) reduced vertebral fractures; tamoxifen reduced nonvertebral fractures in the NSABP P-1 trial (RR 0.66; 95% CI, 0.45 to 0.98); while the aromatase inhibitors had no effect on fractures. Tamoxifen and raloxifene had similar effects on fractures at multiple vertebral and nonvertebral sites in the STAR head-to-head trial.

In placebo-controlled trials, tamoxifen (RR 1.93; 95% CI, 1.33 to 2.68; 4 trials) and raloxifene (RR 1.56; 95% CI, 1.11 to 2.60; 2 trials) increased thromboembolic events while aromatase inhibitors did not. Raloxifene caused fewer thromboembolic events (RR 0.75; 95% CI, 0.60 to 0.93) than tamoxifen in the STAR head-to-head trial. Tamoxifen, raloxifene, and aromatase inhibitors did not increase risk for coronary heart disease events or strokes.

Tamoxifen increased endometrial cancer compared with placebo (RR 2.25; 95% CI, 1.17 to 4.41; 3 trials), while endometrial cancer was not increased with raloxifene and aromatase inhibitors. In the STAR head-to-head trial, raloxifene caused fewer cases of endometrial cancer (RR 0.55; 95% CI, 0.36 to 0.83) and endometrial hyperplasia (RR 0.19; 95% CI, 0.12 to 0.29), and fewer hysterectomies (RR 0.45; 95% CI, 0.37 to 0.54) than tamoxifen. Tamoxifen increased cataracts (RR 1.22; 95% CI, 1.08 to 1.48; 3 trials) and cataract surgery compared with placebo, while raloxifene and aromatase inhibitors did not. Risks for thromboembolic events and endometrial cancer with tamoxifen were higher for older compared with younger women (<50 or ≥50 years) and returned to normal after discontinuation. All medications caused effects that impact quality of life and could lead to discontinuation,^126,138^ such as vasomotor or musculoskeletal symptoms, that varied by medication. Symptoms such as arthralgia often occurred at high rates in both treatment and placebo groups.

Risks for invasive cancer were generally reduced in all population subgroups evaluated based on menopausal status (pre and postmenopausal); family history of breast cancer; BMI categories; modified Gail model risk categories; and age at menarche, parity, or age at first live birth although this varied across trials. Tamoxifen and anastrozole had more effects on women with previous breast lesions (LCIS, ADH, or ALH). Trials were not designed for subgroup comparisons and analysis of differences may be underpowered.

Regarding treatment choice, small descriptive studies indicate that women make decisions to use medications to reduce breast cancer risk based on their concern for adverse effects as well as their risks of breast cancer informed by an abnormal breast biopsy or risk assessment. They weigh their physicians’ recommendations highly in their decisions. Physicians are more likely to prescribe medications if they believe benefits outweigh risks, they consider determining eligibility for medication is easy, and their patients ask for more information.

## Limitations

While most discriminatory accuracy studies of risk assessment methods met criteria for good-quality, others inadequately met criteria or methods were not well-described. These studies varied in size, study populations, and methods and results may not be directly comparable. Studies primarily reported AUC c-statistics as accuracy measures, however, other approaches may be better suited for predicting relatively rare events, such as breast cancer. For example, a longitudinal cohort study of 132,139 women in a breast registry found that women with 10-year risk for breast cancer of 8 percent or higher determined by the Tyrer-Cuzick model with and without breast density had statistically significantly elevated hazards ratios for breast cancer.^139^ An approach targeting higher risk women would be relevant to identifying candidates for risk reducing medications in primary care practice.

Primary prevention trials are limited by clinical heterogeneity related to different medications, exposure durations, eligibility criteria, adherence, and ascertainment of outcomes. Trials were not designed for subgroup comparisons and analysis of differences may be underpowered. No trials compared timing and duration directly and long-term followup data were lacking from most trials.

The aromatase inhibitor prevention trials particularly lack followup data. However, these data are important to understanding whether harms demonstrated in trials of breast cancer treatment also occur when aromatase inhibitors are used for risk reduction. While treatment trials do not meet inclusion criteria for this evidence review, they provide additional insight on potential harms that have not yet been adequately studied in prevention trials (Appendix C4). A multicenter RCT of 2,980 women with locally excised ER+ DCIS compared 1 mg/day of oral anastrozole with 20 mg/day of oral tamoxifen for 5 years with median followup of 7.2 years.^140^ Results indicated increased fractures (9% anastrozole vs. 7% tamoxifen; OR 1.36, 95% CI, 1.03 to 1.80) and stroke (OR 3.36, 95% CI, 1.04 to 14.18) with anastrozole; increased venous thromboembolic events with tamoxifen; and no differences in coronary heart disease. A meta-analysis of individual-level data from 31,920 postmenopausal women with ER+ early breast cancer in treatment RCTs of aromatase inhibitors versus tamoxifen also indicated increased fractures for aromatase inhibitors, but showed no differences for coronary heart disease, venous thromboembolic events, or stroke outcomes.^141^ Also, seven RCTs that compared extended aromatase inhibitor treatment with treatment followed by placebo or no treatment also showed increased fractures and stroke for extended aromatase inhibitors.^142^ It is unclear how well the results of treatment trials of women with early breast cancer translate to women without cancer, particularly in the absence of true placebo comparison groups. For example, does the increase in fractures reflect the direct harm of aromatase inhibitors or the protective effect of tamoxifen?

Many issues outside the scope of this systematic review influence the decision to use medications to reduce risk of breast cancer. These issues need to be considered when applying the results of this review to health policy, insurance coverage, or patient decisions. Research is lacking in many areas including optimal doses, duration of use, persistence of effects after treatment, and outcomes in population subgroups. Data are lacking for nonwhite women, premenopausal women, and women with co-morbidities or taking additional medications for other indications.

## Emerging Issues/Next Steps

Studies of emerging medications and other types of interventions to reduce breast cancer risk are under investigation. Ongoing National Cancer Institute-funded studies of topical tamoxifen metabolites that maintain the preventive benefits of tamoxifen while decreasing systemic harms are in early phases. Research on mechanisms and intermediate markers would be useful. Well designed and powered head-to-head trials of different medications and regimens could contribute much needed information on outcomes, duration and timing of treatment, and identification of optimal candidates. Controlled trials of lifestyle modification interventions to reduce risk for breast cancer, such as weight loss and exercise, could also be explored. These interventions could be incorporated into comparative trials that could also include medications.

## Relevance for Priority Populations, Particularly Racial/Ethnic Minorities

While priority populations were not explicitly excluded from studies in this systematic review, results were not reported specifically by population.

## Future Research

The efficacy of tamoxifen, raloxifene, and aromatase inhibitors to reduce risk for invasive breast cancer has been demonstrated for women without preexisting cancer in RCTs, however, it is not clear which women in clinical practice would optimally benefit from risk reducing medications. Inclusion criteria for three of the placebo-controlled tamoxifen trials (NSABP P-1, IBIS, and Royal Marsden), STAR, and the aromatase inhibitors included assessments of risk for breast cancer and only women meeting criteria were enrolled. However, for the other trials, no breast cancer risk assessment was performed and women of all risk groups were included. Despite these differences, trials of all the medications demonstrated efficacy in reducing invasive breast cancer. Further analysis comparing various subgroups, such as by age and risk factors, also indicated no major differences, suggesting that most women could benefit. Future research to determine the optimal candidates for these medications and the effects of risk-reducing therapy on them would focus risk-reducing efforts. Applying these findings to clinical selection criteria would improve identification of candidates in practice settings.

No new studies and no studies in the 2013 review evaluated risk-reducing medications specifically in pathogenic BRCA1/2 mutation carriers. However, mutation testing was not a common practice when most of the trials were conducted and it is not known how many BRCA1/2 carriers were enrolled. The NSABP P-1 trial of tamoxifen described results for 288 mutation carriers who developed breast cancer during the trial.^143^ Of the eight women with breast cancer who had BRCA1 mutations, five received tamoxifen and three placebo (RR 1.67; 95% CI, 0.32 to 10.70). Of 11 women with breast cancer and BRCA2 mutations, three received tamoxifen and eight placebo (RR 0.38; 95% CI, 0.06 to 1.56). Also, 86 percent (6/7) of women with BRCA1 mutations had ER− breast cancer, and 67 percent (6/9) with BRCA2 mutations had ER+. Tamoxifen is only effective in reducing risk for ER+ breast cancer. Additional research on benefits and harms of risk-reducing medications for BRCA1/2 mutation carriers would guide their clinical decisions, particularly as mutation testing becomes more widespread.

In addition to improving our understanding of optimal candidates for therapy, research is needed to further evaluate clinical risk instruments to identify women who are most likely to benefit from risk-reducing interventions. Current research indicates that prediction models that include breast density offer marginal improvement in diagnostic accuracy. Addition of other factors such as diet, alcohol use, physical activity, smoking status, and height offer little improvement in diagnostic accuracy. New methods need to build on current research findings, and research needs to expand beyond diagnostic accuracy studies. Methods need to be evaluated in relevant clinical settings and populations to determine their effectiveness in identifying high-risk women for clinical decisionmaking. Effective methods should also be validated in various racial and ethnic populations, among non-English speakers, and across multiple age groups. This work should include research regarding optimal methods for communicating risks and benefits to women^144^ and lead to the development of effective patient decision aids.

The results of current trials indicate that adverse effects differ between medications and may drive decisions for risk-reducing medications as much or more than benefits. Further research to more clearly identify characteristics of individuals experiencing specific adverse effects would guide physicians and patients to regimens that cause the least harm. Strategies could be tested that optimize benefits and minimize harms. For example, the effects of adding aspirin in conjunction with tamoxifen or raloxifene might improve the benefit/harm balance for women by reducing risks of thromboembolic adverse events, stroke, and possibly breast cancer itself.^145^ Further analysis of data from the MORE and RUTH trials could address this question because a large proportion of subjects were using aspirin in these trials. Future trials could evaluate the benefits and harms of using tamoxifen or raloxifene with an anticoagulant such as warfarin, heparin, or low molecular weight heparin.

Primary prevention trials need to be continually evaluated for long-term and unanticipated outcomes. Many questions remain regarding the persistence of beneficial and harmful effects of medications. For example, tamoxifen users in the NSABP P-1 trial who developed ER− breast cancer had shorter times to diagnosis and were more likely to be detected by routine mammograms than placebo users who developed ER− breast cancer.^146^

Evaluating the timing of medication use may also lead to effective clinical strategies. Results of current trials suggest that breast cancer risk reduction persists after treatment while some harms diminish. It is important to understand these changes over time. Use of medication for risk reduction at younger ages (45 to 55 years) could provide better long-term benefit and short-term harm for individuals at lower risk of thromboembolism or stroke than use at older ages (over age 60 years). Placebo-controlled trials of raloxifene in younger postmenopausal women selected for breast cancer risk would be more comparable to trials of other risk reducing medications and could provide more accurate estimates of benefits and harms for raloxifene. Also, further analysis of data from currently available trials could compare risk/benefit profiles for women of various ages and risk groups. Additional analysis could also indicate optimal treatment durations. Shortening treatment duration would reduce harms, but also could compromise efficacy.

Despite prior recommendations to identify women at increased risk for breast cancer and offer medications to reduce their risks,^1^ and the availability of effective medications for this purpose, use is low in the United States.^20,21,108^ Understanding this experience requires additional research regarding the attitudes of physicians toward recommending 3 to 5 years of medication therapy to reduce risk as well as attitudes of patients regarding receptivity to this recommendation and adherence over time. Additional research on the physician and patient decisionmaking process could identify factors important for selecting use of medications to reduce breast cancer risk beyond empirical risk and lead to the development of effective clinical decision aids.

## Conclusions

Tamoxifen, raloxifene, and aromatase inhibitors reduce invasive breast cancer for women without preexisting breast cancer, but also cause adverse effects that vary by medication. Tamoxifen and raloxifene increase thromboembolic events and tamoxifen increases endometrial cancer and cataracts. Identifying candidates for therapy is complicated by risk stratification methods that demonstrate low accuracy.