# Chapter 3 Results

A total of 46 studies (in 82 articles)^17,28–107^ met inclusion criteria for key questions including 25 studies of discriminatory accuracy and 21 studies of the efficacy and harms of medications (20 RCTs; one observational study). In addition, 14 studies addressed the contextual question regarding clinician and patient attitudes and practices.^19,108–120^

## Key Question 1 In Adult Women Without Preexisting Breast Cancer, What Is the Accuracy of Risk Assessment Methods to Identify Women Who Could Benefit From Medications to Reduce Risk for Primary Breast Cancer?

### Summary

The goal of clinical assessment for breast cancer risk is to stratify women into average and above average risk groups to determine candidates for risk reduction therapy. Current U.S. clinical recommendations indicate a threshold of at least 1.67 percent or 3 percent 5-year risk of breast cancer as determined by the modified Gail model. Eighteen models incorporating risk factors for breast cancer to predict a woman’s risk have been evaluated for use in clinical settings. Risk models demonstrate good calibration, with the expected number of breast cancer cases in a study population closely matching the number of breast cancer cases observed. However, most models have low discriminatory accuracy in predicting the probability of breast cancer in an individual with c-statistics generally ranging from 0.55 to 0.65, performing only slightly better than age alone as a risk predictor.

### Evidence

A total of 25 studies reporting results of evaluations of 18 risk models met inclusion criteria (Table 1).^28–52^ Of these, 14 were rated good-quality because they met quality criteria, adequately described methods, used appropriate reference standards, and included large sample sizes (Appendix B1).^28,31,34–39,41,44–48^ Ten studies were rated fair-quality because they inadequately met some of the criteria or methods were not well-described.^29,30,32,33,40,42,43,49–51^ One study rated poor-quality^52^ was excluded from the results.

Table 1 Studies of Risk Stratification Models

Author, Year | Model | Population | Participants | Study Type | Comparison Group | Inclusion Criteria | Quality Rating
Adams-Campbell et al., 2007^28^ | Gail African American (invasive breast cancer) | BWHS; black women; age ≥ 35 years from 1995 to 2003 | 725 cases; 725 age-matched controls | Validation; nested case-control; 8 year followup | SEER | Incident invasive breast cancer; must have complete data available | Good
Amir et al., 2003^29^ | Tyrer-Cuzick (10-year risk of invasive breast cancer) | Family history clinic at University Hospital of South Manchester, high-risk population; total population age 21 to 73 years (median 44); screened population age 25 to 73 years (median age 46); from 1987 to 2001 | 64 cases among 3150 women; subanalysis on screening population; 52 cases among 1933 woman cohort | Women whose risk estimate could be derived by all the models were compared and only incident cases included | U.K. Northwest cancer registry | Complete risk data for all models being compared (Gail, Claus, Ford, Tyrer-Cuzick); excluded incomplete data | Fair
Barlow et al., 2006^30^ | BCSC Barlow (1-year risk of DCIS or invasive breast cancer) | BCSC; women without breast cancer age 35 to 84 years; from 1996 to 2001 | 11,638 cases from 2,392,998 woman cohort | Cases within cohort of women being screened with mammography; 1 year followup | BSCS (compared with SEER) | DCIS or invasive breast cancer in women age 35 to 84 years who had previous mammography within the last 5 years; no previous breast cancer, no breast augmentation, no previous mammography but detected breast cancer within 1 year of first mammography; if no data on menopause, excluded from subgroup analysis | Fair
Boughey et al., 2010^31^ | Tyrer-Cuzick (10-year risk of invasive breast cancer) | Mayo benign breast disease cohort including women with benign breast biopsy results; 1967 to 1991; mean age 58.1 years; 1967 to 2009; median followup, 14.6 years (86.7% >5 years) | 311 cases with atypical hyperplasia in 9376 woman cohort with benign breast disease | Validation; nested case-control | Not reported | Women aged 18 to 85 years with diagnosis of atypical hyperplasia at time of biopsy | Good
Boyle et al., 2004^32^ | Italian 1-Gail Model (all breast cancer) | Derivation: Italian multicenter case-control study of diet and breast cancer, 1991 to 1994; age of cases 23 to 74 years (mean age 55); controls 20 to 74 years (mean age 56).; Validation: Italian Tamoxifen Prevention Study, 1992 to 1997; age of cases 35 to 70 years (median age 51) | Derivation: 2569 cases with 2588 controls; Validation: 2700 tamoxifen, 2708 placebo | Derivation: case control; Validation: cases in cohort | Regional Cancer Registry Data | Women admitted with breast cancer diagnosed within 1 year of the study interview with no prior history of cancer; no admissions for gynecological, neoplastic, hormonal diseases or those related to increased risk for breast cancer in controls | Fair
Brentnall et al., 2015^33^ | Tyrer-Cuzick plus breast density vs. Gail plus breast density (invasive breast cancer) | Screening areas in Greater Manchester, U.K.; data collected 2009 to 2014 | 697 cases among 50,628 woman cohort | Cases within cohort of women screened | Not compared | Women invited for routine mammographic screening 2009 to 2013 | Fair
Chen et al., 2006^34^ | Gail plus breast density (invasive breast cancer) | BCDDP; primarily white women age > 40 years; invasive or noninvasive cancer vs. control; data collected 1973 to 1979 | 2852 cases (1235 with mammography density); 3146 age-matched controls (1656 with breast density) | Case-control; followup through 1998 | SEER | Cases with missing data excluded | Good
Chlebowski et al., 2007^35^ | Expanded and simplified models versus Gail 2; (ER+ versus ER− invasive breast cancer) | WHI; age 50 to 79 years (mean age 63) | 3236 cases, 363 excluded due to missing data; 2873 for subgroup analysis; 2412 ER+ cases; 461 ER− cases; 144,680 controls | Derivation and validation; case-control; 5 years followup | SEER | Unlikely to move or die within 3 years; no history of breast cancer or mastectomy | Good
Colditz and Rosner, 2000^36^ | Colditz-Rosner, Model 2 (invasive breast cancer) | NHS; age 35 to 70 years; 1980 to1994 | 1761 cases among 58,520 women | Derivation; cases within cohort of NHS; derivation; 14 years followup | Not compared | Incident invasive breast cancer; exclusions include pregnancy/offspring history discrepancies; inaccurate age of menarche; unknown age of menopause or death; missing height, weight, or hormone use data; hysterectomy with 1 or no ovaries removed; or missing menopause data | Good
Colditz et al., 2004^37^ | Rosner-Colditz, Model 2 (invasive breast cancer) | NHS; age 35 to 79 years; 1980 to 2000 | 2096 cases (1281 ER+/PR+, 417 ER-/PR-, 318 ER+/PR-, 80 ER-/PR+) among 66,145 women | Validation; cases within cohort of NHS | Not reported | Invasive breast cancer with reported estrogen receptor status | Good
Costantino et al., 1999^38^ | Gail (invasive breast cancer) | BCPT; white women between 1992 to 1998 | 5969 women in placebo group of BCPT; 204 incident cases | Validation study of Gail-1 and 2 comparing BCDDP, CASH, NHS, BCPT cohorts; followup 1 to 70 months (mean 48.4) | BCDDP rates for invasive or noninvasive cancer (Gail-1); SEER data for invasive cancer (Gail-2) | 10-year life expectancy, no history of breast cancer, negative mammogram within 180 days, negative clinical breast exam, no history of DCIS, LCIS | Good
DeCarli et al., 2006^39^ | Italian Gail Model; Italian 1-Gail Model^*^ (all breast cancer) | Derivation: Italian multicenter case-control study of diet and breast cancer; Florence European Prospective Investigation into Cancer and Nutrition; 1991 to 1994; age of cases 23 to 74 years (mean age 55); age of controls 20 to 74 years (mean age 56); Validation: age 35 to 64 years | Derivation: 2569 cases with 2588 controls Validation: 194 cases in 10,031 woman cohort | Derivation: case-control Validation: cases in cohort | Florence Cancer Registry | Women admitted with breast cancer diagnosed within 1 year of the study interview with no previous history of cancer. No admissions for gynecologic, neoplastic, hormonal diseases or those related to increased risk of breast cancer in controls | Good
Gail et al., 1989^41^ | Gail (invasive breast cancer and LCIS) | BCDDP; white women age 35 to 79 years with invasive or noninvasive cancer and women without cancer between 1973 to 1979 | 2582 cases, 3146 controls | Derivation; case-control; abstracted risk factor information from 80% of eligible cases and 83% of eligible controls; followup through 1998 | 243,221 white women in BCDDP registry | 10-year life expectancy, no history of breast cancer, negative mammography within 180 days, negative clinical breast exam, no history of DCIS | Fair
Gail et al., 2007^40^ | Gail African American (invasive breast cancer) | CARE; black women; age 35 to 64 years; 1994 to 1998 and 1993 to 1998 | 1607 cases; 1647 controls; women matched for 5-year age group, location, and race; 14,059 from WHI | Derivation: CARE Validation: WHI case-control; WHI Followup 7.57 years | SEER | First primary incident invasive breast cancer in black women age 35 to 64 years; must have complete data available | Fair
Li et al., 2018^42^ | Model_ER+_ | EPIC study; age 40 to 70 years; 1992 to 2000 | 6572 cases in 281,330 EPIC cohort of women; 2951 cases in 82,319 WHI cohort of women | Derivation: EPIC Validation: WHI | WHI | Women age 40 to 70 years not diagnosed with cancer before recruitment | Fair
Matsuno et al., 2011^43^ | NCI Breast Cancer Risk Assessment Tool and Gail (invasive breast cancer) | Asian American Breast Cancer Study Derivation: age 20 to 55 years; 1983 to 1987; Validation: age 50 to 79 years; 1993 to 1998 | 589 cases; 952 controls; same ethnicity, age, and residence | Derivation: case-control Validation: cohort | SEER | Histologically confirmed, first primary incident breast cancer diagnosed between the ages of 20 to 55 years in Asian Americans | Fair
Petracci et al., 2011^44^ | Italian-2^*^ (invasive breast cancer) | Florence registry of the EPIC study Derivation: age 23 to 74 years; 1991 to 1994 Validation: age 35 to 64 years; 1998 to 2004 | Derivation: 2569 cases and 2588 controls Validation: 10,083 participants | Derivation: case-control Validation: cohort | Florence EPIC cohort | Women age 23 to 74 years with invasive breast cancer served as cases; women age 20 to 74 years without breast cancer and admitted for acute conditions to hospitals in the same catchment areas as cases served as controls | Good
Rockhill et al., 2001^46^ | Gail 5-year risk (invasive breast cancer) | NHS; white women age 45 to 71 years in 1992; study duration from 1992 to 1997 | 1354 cases in 82,109 woman cohort | Validation; prospective cohort; followup 60 months | SEER | White women with complete risk factor data | Good
Rockhill et al., 2003^45^ | Rosner-Colditz, Model (invasive breast cancer) | NHS; age 45 to 73 years; 1992 to 1997 | 757 cases among 45,210 women | Validation; cases within cohort of NHS | Not reported | Invasive breast cancer; no previous cancer, natural menopause or hysterectomy without oophorectomy, complete data | Good
Tamimi et al., 2010^47^ | Rosner-Colditz, adapted to include category of benign breast disease (invasive breast cancer) | NHS; age 35 to 79 years; 1980 to 2000 | 240 cases; 1036 controls | Derivation; nested case-control within cohort of cohort of NHS | Not reported | Women with biopsy-proven benign breast disease; incident invasive breast cancer within this cohort with age and year of biopsy-matched control | Good
Tice et al., 2008^48^ | BCSC-Tice (invasive breast cancer) | BCSC; women without breast cancer age 35 to 84 years; 71% white | 1,095,484 in cohort; 14,766 cases of invasive breast cancer; 629,229 for clinical risk factor analysis | Cases within cohort of women screened with mammography; median followup 5.3 years | SEER (BCSC vs. SEER, state tumor registries, and path databases) | Women age 35 years or older with 1 previous mammography with BI-RAD measurement in BCSC; excluded women with diagnosis of breast cancer, women diagnosed within 6 months of index mammography, and women with breast implants | Good
Tice et al., 2015^49^ | BCSC-Tice + benign breast disease (invasive breast cancer) | BCSC; women without breast cancer age 35 to 74 years; 75% white | 1,135,977 in cohort; 17,908 cases of invasive breast cancer | Cases within cohort of women screened with mammography; mean followup 6.9 years | SEER (BCSC vs. SEER, state tumor registries, and path databases) | Women age 35 to 74 years with ≥1 mammography with BI-RAD measurement in BCSC between 1994 and 2010; excluded women with diagnosis of breast cancer before first eligible mammography, women diagnosed in the first 3 months of followup, women with breast implants or mastectomy | Fair
Tyrer et al., 2004^50^ | Tyrer-Cuzick (invasive breast cancer) | U.K. national statistics of breast cancer incidence rates in general population; BRCA risk tables from U.K. | Not reported | Derivation; data from other sources | U.K. rates of breast cancer and positive BRCA | Not reported | Fair
Vacek et al., 2011^51^ | Gail vs. Tice vs. Barlow vs. Vermont (invasive and noninvasive breast cancer) | VBCSS; women age 70 years or older, 97.7% white | 821 cases (668 invasive) among 19,779 women cohort | Cases within cohort of women screened | SEER | Women age ≥70 years with mammography in the VBCSS between 1996 and 2001; not previously diagnosed with breast cancer; and did not decline the use of their data for research. Excluded those diagnosed with cancer or lost to followup within a year of their entry mammography | Fair
Warwick et al., 2014^52^ | Tyrer-Cuzick plus breast density (invasive breast cancer) | IBIS-I; age 35 to 70 years (mean age 49) | 72 cases in 558 woman cohort | Cases within cohort; median followup to diagnosis 5.1 years for cases, 11.6 years followup for controls | Not reported | Women from the placebo arm of the IBIS-I trial; breast cancer free but with a risk at least twice the population average | Poor

* Italian-Gail Model: 1) calibration varies from Gail by only 1 ordinal value for 1 variable; 2) varies by using categorical rather than ordinal.

Abbreviations: BCDDP=Breast Cancer Detection and Demonstration Project; BCPT=Breast Cancer Prevention Trial; BCSC=Breast Cancer Surveillance Consortium; BRCA=breast cancer susceptibility genes; CARE=Women’s Contraceptive and Reproductive Experiences; DCIS=ductal carcinoma in situ; EPIC=European Prospective Investigation into Cancer and Nutrition; ER+=estrogen receptor positive; ER-=estrogen receptor negative; FHESP=Family History and Evaluation Screening Program- University Hospital of South Manchester; IBIS=International Breast Cancer Intervention Study; IMCCSDBC=Italian Multicenter Case-Control Study of Diet and Breast Cancer; LCIS=lobular carcinoma in situ; NHS=Nurses’ Health Study; SEER=Surveillance, Epidemiology, and End Results Program; VBCSS=Vermont Breast Cancer Surveillance System; WHI=Women’s Health Initiative.

Three new studies enhanced existing models by adding breast density to the Gail and Tyrer-Cuzick models;^33^ modifying the Gail model for Asian Americans;^43^ and adding benign breast disease to the Breast Cancer Surveillance Consortium (BCSC) model.^49^ A fourth new study developed models to predict ER+ and ER− breast cancer specifically.^42^

#### Risk Models

The Gail model was the first major breast cancer risk model to be used clinically.^41^ The current version is referred to as the Breast Cancer Risk Assessment Tool and is provided on a publicly accessible National Cancer Institute website.^121^ This model was derived from multivariate logistic regression analysis of identified risk factors for breast cancer.^41^ In the original version of the Gail model, breast cancer incidence rates and baseline hazard rates were determined for invasive cancer, DCIS, and LCIS from a cohort of women in the Breast Cancer Detection and Demonstration Project (BCDDP). The model was subsequently modified by using U.S. national data for invasive cancer from the Surveillance, Epidemiology, and End Results (SEER) program.^38^ From these data, the model was developed to allow the prediction of individualized absolute risk (probability) of developing breast cancer in women undergoing annual screening mammography. The Gail model has been tested in large populations of white women, data from the Women’s Health Initiative (WHI) for black women, and Asian and Pacific Islander women in the WHI and data from SEER, but needs further validation for Hispanic women and other subgroups. The Breast Cancer Risk Assessment Tool is updated periodically as new data or research becomes available, and the algorithm was last updated in 2011.^121^

Subsequent risk models use a similar approach as the Gail model, however, they vary in their use of reference standards. Age-specific breast cancer rates and attributable risk estimates to determine baseline age-specific hazard ratios should ideally be obtained from an applicable population reference standard, such as SEER data in the United States. Several studies of subsequent models do not provide information about their reference standards.^35–37,40,43,45,46^

Models also vary by the variables they include (Table 2). The original Gail model included age, age at menarche, age of first birth, family history of breast cancer in first degree relatives, number of previous breast biopsies, and history of atypical hyperplasia.^41^ Subsequent models include one or more of these variables in addition to other factors. These include race,^30,35,48,122^ BMI or height,^30,32,34–36,42,50^ estrogen and progestin use,^30,32,35,36,42^ parity,^35,36,42^ history or duration of breast feeding,^35,42^ menopause status or age,^30,36,42,50^ smoking,^35^ alcohol use,^32,35,36,42^ physical activity,^32,35^ breast density,^30,33,34,48^ benign breast disease,^49^ and diet.^32^ Some variations have been developed for specific populations, such a Asian American,^43^ African American,^28,40^ and Italian^32,39,44^ women.

Table 2 Risk Stratification Models Variables and Accuracy

Model | Age (years) | Menarche Age (years) | Age at Birth of First Child (years) | First Degree Relatives With Breast Cancer, n | Previous Breast Biopsy, n | Other Factors | Discriminatory Accuracy C-Statistic (95% CIs)^*^
Gail-2; (5-year risk) | <50; ≥50 | <12; 12–13; ≥14 | <20; 20-24; 25-29; ≥30; or none | 0; 1; ≥2 | 0; 1; ≥2; AH: 0; ≥1 | Not included | 0.55 (0.51 to 0.60);^28^ 0.60;^38^ 0.58 (0.56 to 0.60);^46^ 0.58;^32^ 0.59 (0.54 to 0.63);^39^ 0.60;^34^ 0.61 (0.60 to 0.62)^48^
Gail-2; (10-year risk) | <50; ≥50 | <12; 12–13; ≥14 | <20; 20-24; 25-29; ≥30; or none | 0; 1; ≥2 | 0; 1; ≥2; AH: 0; ≥1 | Not included | 0.74 (0.67 to 0.80);^29^ 0.54 (0.52 to 0.56)^33^
African American Gail; (5-year risk) | <50; ≥50 | ≤13; >13 | Not included | 0; 1; ≥2 | 0; 1; ≥2 | African American race | 0.56 (0.54 to 0.58);^40^ 0.56 (0.51 to 0.60)^28^
Asian American Gail; (5-year risk) | <50; ≥50 | ≤13; >13 | Not included | 0; 1; ≥2 | 0; 1; ≥2 | Asian American race | 0.61 (0.59 to 0.64)^47^
Gail + density; (10-year risk) | <50; ≥50 | <12; 12–13; ≥14 | <20; 20-24; 25-29; ≥30; or none | 0; 1; ≥2 | Yes; no | Breast density (%); BMI | 0.59 (0.57 to 0.61)^33^
Gail + density; (5-year risk) | <50; ≥50 | <12; 12–13; ≥14 | <20; 20-24; 25-29; ≥30; or none | 0; 1; ≥2 | 0; 1; ≥2 | Breast density (%); BMI | 0.64^34^
BCSC^†^; (premenopausal; 1-year risk) | 45-84 by 5-year groups | Not included | Not included | 0; 1; ≥2; unknown | Yes; no; unknown | Breast density (BIRADS)^§^ | 0.63 (0.60 to 0.66)^30^
BCSC^†^; (postmenopausal; 1-year risk) | 45-84 by 5-year groups | Not included | <30; ≥30; none; unknown | 0; 1; ≥2; unknown | 0; ≥1; unknown | Breast density (BIRADS), prior false-positive mammogram, BMI, menopause type, HT, race or ethnicity | 0.62 (0.62 to 0.63)^30^
BCSC; (5-year risk) | 45-84 by 5-year groups | Not included | Not included | Yes; no | Yes; no | Breast density (BIRADS), race or ethnicity | 0.66 (0.65 to 0.66);^48^ 0.664^49^
BCSC + BBD^†^; (5-year risk) | 45-84 by 5-year groups | Not included | Not included | Yes; no | Yes; no | Breast density (BIRADS), race or ethnicity, benign breast disease | 0.665^49^
Rosner-Colditz^‡^ | <50; ≥50 | <12; 12–13; ≥14 | <20; 20–24; 25-29; ≥30; or none | Yes; no | Not included | BMI, benign breast disease, menopause type, menopause age, HT use and duration, height, alcohol use, parity | 0.57 (0.55 to 0.59);^45^ 0.64 (0.63 to 0.66) (ER+/PR+);^37^ 0.61 (0.58 to 0.64) (ER-/PR-)^37^
Rosner-Colditz-2^‡^ | <50; ≥50 | <12; 12–13; ≥14 | <20; 20–24; 25-29; ≥30; or none | Yes; no | AH: 0; ≥1 | Benign breast disease presence or type | 0.63 (0.61 to 0.65);^45^ 0.64 (type)^45^
Tyrer-Cuzick; (10-year risk) | <50; ≥50 | ≤12; >12 | ≤30; >30; none | 1; 2; ≥3 | 0; 1; ≥2; LCIS: 0; ≥1 | BMI, height, menopause age, family history of ovarian or other cancer, age of cancer onset, bilateral or male breast cancer | 0.76 (0.70 to 0.82);^29^ 0.54 (0.42 to 0.65);^31^ 0.57 (0.55 to 0.59)^33^
Tyrer-Cuzick + density; (10-year risk) | <50; ≥50 | ≤12; >12 | ≤30; >30; none | 1; 2; ≥3 | Yes; no | BMI, height, menopause age, family history of ovarian or other cancer, age of cancer onset, bilateral or male breast cancer; breast density (%) | 0.61 (0.58 to 0.63)^33^
Italian-1; (5-year risk) | <50; ≥50 | <12; 12–13; ≥14 | <20; 20–24; 25-29; ≥30; or none | 0; 1; ≥2 | Not included | Age of relative at diagnosis, diet score, alcohol use, BMI, HT use, physical activity | 0.59 (vitamin);^32^ 0.60 (diet)^32^
Italian-2^ll^; (20-year risk) | <50; ≥50 | <12; 12–13; ≥14 | <20; 20–24; 25-29; ≥30; or none | 0; 1; ≥2 | 0; 1; ≥2 | Occupational and leisure physical activity, education, alcohol use, BMI | 0.62 (0.56 to 0.69) (age <50 years);^44^ 0.57 (0.52 to 0.61) (age ≥50 years)^44^
Chlebowski; (5-year risk) | 50-59; 60-69; 70-79 | <12; 12–13; ≥14 | <20; 20–24; 25-29; ≥30 or none | 0; ≥1 | 0; 1; ≥2 | BMI, menopause age, HT use and duration, race, alcohol use, parity, breast-feeding, smoking status, physical activity | 0.61 (0.59 to 0.63);^35^ 0.62 (0.60 to 0.64) (ER+);^35^ 0.53 (0.47 to 0.58) (ER-)^35^
Chlebowski-simplified; (5-year risk) | <50; ≥50 | Not included | Not included | 0; ≥1 | 0; 1; ≥2 | Not included | 0.58 (0.56 to 0.60) (ER+)^35^
Model_ER+_ | Not included | <12; 12; 13; 14; >14 | ≤20; 20.1-25; 25.1-30; 30.1-35; >35 | Not included | Not included | BMI, menopause status and age, alcohol use, HT use, breast-feeding duration, parity | 0.59 (0.58 to 0.60)^42^

* For invasive breast cancer, other outcomes are specifically indicated.

† Includes nonproliferative, proliferative without atypia, proliferative with atypia, and lobular carcinoma in situ.

‡ Invasive and noninvasive breast cancer.

§ BI-RADS categories include 0=unknown; 1=entirely fat; 2=scattered fibroglandular densities; 3=heterogeneously dense; 4=extremely dense.

ll Includes an Italian population and used incidence rates from the Italian Multicenter case-control study of Diet and Breast Cancer and from Italian cancer registries.

Abbreviations: AH=atypical hyperplasia; BBD=benign breast disease; BCSC=Breast Cancer Surveillance Consortium; BI-RADS=Breast Imaging Reporting and Data System; BMI=body mass index (mg/kg^2^); DCIS=ductal carcinoma in situ; ER-=estrogen receptor negative; ER+=estrogen receptor positive; HT=hormone therapy; LCIS=lobular carcinoma in situ.

Calibration is a measure of how well predicted probabilities agree with actual observed risk. The calibration of a model refers to its ability to predict the average risk in a subset of the population. When the predicted risk matches the proportion that actually develops disease, a model is considered to be well calibrated. In a perfect prediction model, the predicted risk in a population (percent expected) would equal the observed number of cases (percent observed) such that the percent expected/percent observed (E/O) equals 1.0. For most models, the expected numbers of cases of breast cancer closely matched the observed numbers.^1,30,32,34–36,38,39,42,48,50,122^

#### Studies of Discriminatory Accuracy

In prognostic modeling, discriminatory accuracy is the ability to correctly classify individuals at higher risk from those at lower risk, and is measured by the model’s c-statistic (AUC). Studies indicate that discriminatory accuracy for most of the models ranges from 0.55 to 0.65 (Table 2).^28–51^ Only one study reported levels above 0.70 for both the Gail-2 and the Tyrer-Cuzick models, with a c-statistic of 0.74 (95% CI, 0.67 to 0.80) and 0.76 (95% CI, 0.70 to 0.82), respectively.^29^ However, this study was small (<100 cases) and did not include a primary care population, limiting its clinical applicability. The BCSC-Tice model, drawing from large U.S. national populations, provided the next highest discriminatory accuracy, with a c-statistic of 0.66 (95% CI, 0.65 to 0.66).^48^ The model with the lowest level of discrimination was the African American Gail model, with a c-statistic of 0.56 in two studies.^28,122^ The discriminatory accuracies of age^30,45^ or breast density alone^30^ as a predictor of breast cancer risk ranged from 0.55 to 0.57 and 0.55 to 0.56, respectfully.

In most of the primary prevention trials, women were assessed for their individual risks for developing breast cancer, and only those meeting established risk thresholds were eligible to participate. One study evaluated this approach to risk stratification by determining discriminatory accuracy based on a low (<1.67%) versus high (≥1.67%) risk threshold.^48^ This threshold was used as inclusion criteria in the National Surgical Adjuvant Breast and Bowel Project (NSABP P-1) and the Study of Tamoxifen And Raloxifene (STAR) trials, and is included in the FDA’s approval of the use of SERMS for risk reduction. In this study, the BCSC-Tice model demonstrated high calibration (E/O 0.99 to 1.03), and consistent, although low, discriminatory accuracy across quintiles (c-statistic 0.61 to 0.64).^48^

## Key Question 1a What Is the Optimal Age at Which to Begin Risk Assessment to Identify Women Who Could Benefit From Medications to Reduce Risk for Primary Breast Cancer?

No studies were identified that addressed this question.

## Key Question 1b What Is the Optimal Frequency of Risk Assessment to Identify Women Who Could Benefit From Medications to Reduce Risk for Primary Breast Cancer?

No studies were identified that addressed this question.

## Key Question 2 In Adult Women Without Preexisting Breast Cancer, What Is the Effectiveness and Comparative Effectiveness of Medications to Reduce Risk for Primary Breast Cancer on Improvement in Short- and Long-Term Health Outcomes?

### Overview of the Primary Prevention Trials

Ten large RCTs of tamoxifen, raloxifene, and the aromatase inhibitors anastrozole and exemestane enrolled women without breast cancer and reported breast cancer outcomes. These trials provide the main results for Key Questions 2, 3, and 4 in this systematic review. The primary prevention trials include one head-to-head trial of tamoxifen and raloxifene, STAR;^61,96,123^ five placebo-controlled trials of tamoxifen, including the International Breast Cancer Intervention Study (IBIS-I),^54,81,82^ NSABP P-1,^58,83,90^ Royal Marsden Hospital Trial,^59,100^ Italian Tamoxifen Prevention Study,^55,84,106,107,124^ and the Hormone Replacement Therapy Opposed by Low-dose Tamoxifen (HOT) study;^53^ two placebo-controlled trials of raloxifene, the Multiple Outcomes of Raloxifene Evaluation (MORE) with long-term followup in the Continuing Outcomes Relevant to Evista (CORE) study,^74,75,78,80,85–87,89,93–95,97,98,103,104^ and the Raloxifene Use for the Heart (RUTH) trial;^60,91^ and two placebo-controlled trials of aromatase inhibitors, the International Breast Cancer Intervention Study II (IBIS-II) of anastrozole,^17,102,105^ and the Mammary Prevention.3 trial (MAP.3) of exemestane.^56,99^ The newest placebo-controlled tamoxifen trial, HOT, uses a lower dose than the other trials (5 mg/day vs. 20 mg/day) and was considered separately. Details of individual trials are provided in Table 3. The trials met criteria for fair- or good-quality (Appendix B2).

Table 3 Randomized, Controlled Trials of Medications to Reduce Risk for Breast Cancer

Trial | Treatment (n); Comparison (n) | Breast Cancer Risk Criteria | Participants, Setting | Age, Median (years) | White (%) | Post Hyster-ectomy (%) | Used Estrogen During Trial (%) | Primary Outcomes | Follow-up, Median (years) | Exposure, Median (years) | Quality Rating
STAR^61,96,123^ | Tamoxifen 20 mg/day (9872); raloxifene 60 mg/day (9875) | 5-year predicted breast cancer risk ≥1.66% based on the modified Gail model^*^ | Postmeno-pausal, age ≥35 years, U.S.-based with sites in North America | 58.5^†^ | 18204 (93.5) | 10027 (51.5) | 0 (0) | Invasive breast cancer | 3.9^†^ initial; 6.8^†^ long-term | 3.6-3.9^†^ | Good
IBIS-I^54,81–82^ | Tamoxifen 20 mg/day (3573); placebo (3566) | 2-fold relative risk for breast cancer for ages 45-70 years, 4-fold for ages 40-44 years, 10-fold for ages 35-39 years based on family history criteria.^‡^ | 35-70 years, U.K., Australia, New Zealand, Europe | 50.8^†^ | Not reported | 2515 (35) | 2844 (40) | Invasive and noninvasive breast cancer | 4.2 initial; 8.0 long-term; 16 longer term | 5 | Good
NSABP-P1^58,83,90^ | Tamoxifen 20 mg/day (6576); placebo (6599) | Age ≥60 years or 35-59 years with a 5-year predicted breast cancer risk ≥1.66% based on the modified Gail model,^*^ or history of LCIS | ≥35 years, U.S.-based with sites in North America | Median not reported; 5177 (39.3%) <50 | 12706 (96.4) | 4884 (37) | 0 (0) | Invasive and noninvasive breast cancer | 4.6 initial; 7.0 long-term | 4.0 when unblinded | Good
Royal Marsden Hospital Trial^59,100^ | Tamoxifen 20 mg/day (1238); placebo (1233) | Family history of breast cancer^§^ | 30-70 years, U.K. | 47 | Not reported | Not reported | 389 (15.6) | Invasive breast cancer | 5.8 initial; 13.2 long-term | Not reported | Good
Italian Tamoxifen Prevention Study^55,84,106–107^ | Tamoxifen 20 mg/day (2700); placebo (2708) | None | 35-70 years, Italy-based with in Europe and South America | 51 | Not reported | 100 (100) | 751 (14) | Breast cancer incidence and mortality | 3.8 initial; 11.2 long-term | 4 | Fair; dropout rate 26.3%
HOT^53^ | Tamoxifen 5 mg/day (938); placebo (946) | None | Post-menopausal, Italy-based | 53^†^ | Not reported | Not reported | 100 (100) | Invasive breast cancer | 6.2^†^ | 5^†^ | Good
MORE and CORE^57,74–75,78,80,85–87,89,93–95,103–104^ | MORE: raloxifene 60 or 120 mg/day (5129); placebo (2576); CORE: raloxifene 60 mg/day (2725); placebo (1286) | None | Post-menopausal, age 31-80 years, with osteo-porosis,^∥^ U.S.-based with sites in 25 countries; CORE includes a subset of MORE participants | 66.9 | Not reported (96) | Not reported (23) | 0 (0) | MORE: Incident radiographic vertebral fractures and clinical nonvertebral fractures CORE: Breast cancer | MORE: 3, 4; CORE: 4, 8 (combines data) | Not reported | Good
RUTH^60,88,91^ | Raloxifene 60 mg/day (5044); placebo (5057) | None | Post-menopausal, age ≥55 years, CHD or risk factors,^¶^ U.S.-based with sites in 26 countries | 67.5 | 8481 (84) | 2319 (23) | 0 (0) | Coronary events, invasive breast cancer | 5.6 | 5.1 | Good
IBIS-II^17,102,105^ | Anastrozole 1 mg/day (1920); placebo (1944) | Increased risk for breast cancer: age 45-60 years ≥2 times higher than the general population; age 60-70 years 1.5 times higher; age 40-44 years 4 times higher | Post-menopausal, age 40-70 years, U.K.-based with sites in 18 countries | 59.5 | Not reported | 1287 (33.3) | 0 (0) | Invasive and noninvasive breast cancer | 5 | 5 | Good
MAP.3^56,99^ | Exemestane 25 mg/day (2285); placebo (2275) | Risk factors for breast cancer: age ≥60 years; Gail risk score >1.66%^*^; prior ADH, ALH, LCIS or DCIS | Post-menopausal, ≥35 years, U.S.-based with sites in 4 countries | 62.5 | 4261 (93.4) | Not reported | 0 (0) | Invasive breast cancer | 2.9 | 3 | Good

* STAR, NSABP-1, MAP.3: The Gail model includes age, number of first-degree relatives with breast cancer, nulliparity or age at first live birth, number of benign breast biopsies, pathologic diagnosis of atypical hyperplasia, and age at menarche. The original model was further modified to predict expected rates of invasive breast cancer only (not invasive and noninvasive as originally designed) and to allow for race-specific determinations of risk.

† Values are means.

‡ IBIS: All criteria permit entry to trial at age 45 years: first-degree relative with breast cancer age ≤50 years; first-degree relative with bilateral breast cancer (permits entry from age 40 years; if relative age ≤40 years, permits entry at age 35 years); ≥2 first-degree or second-degree relatives with breast cancer (permits entry from age 40 years if both developed breast cancer before age 50 years; permits entry at age 35 years if both relatives are first-degree and both developed breast cancer before age 50 years); benign breast biopsy and first-degree relative with breast cancer; lobular carcinoma in situ (permits entry from age 35); atypical hyperplasia (permits entry from age 40); nulliparous and a first-degree relative who developed breast cancer; risk equivalent (strong family history, not fitting specific categories, but judged to be at higher risk than eligibility category by the study chairman).

§ Family history criteria for Royal Marsden Hospital Trial: one first-degree relative age <50 y with breast cancer, or one first-degree relative with bilateral breast cancer, or one affected first-degree of any age plus another affected first-degree or second-degree relative; benign breast biopsy and a first-degree relative with breast cancer.

∥ MORE: Study Group 1, femoral neck or lumbar spine bone mineral density (BMD) T-score < −2.5; Study Group 2, low BMD and one or more moderate or severe vertebral fractures or ≥2 milder vertebral fractures (20-25% reduction in height); or ≥2 moderate fractures (25-40% reduction from expected vertebral height), regardless of BMD.

¶ Cardiovascular risk score ≥4: established coronary heart disease (4 points), arterial disease of the leg (4 points), age ≥70 y (2 points), diabetes mellitus (3 points), cigarette smoking (1 point), hypertension (1 point), and hyperlipidemia (1 point).

Abbreviations: ADH=atypical ductal hyperplasia; ALH=atypical lobular hyperplasia; CHD=coronary heart disease; CORE=Continuing Outcomes Relevant to Evista; DCIS=ductal carcinoma in situ; HOT=Hormone replacement therapy Opposed by low-dose Tamoxifen; IBIS-I=International Breast Cancer Intervention Study; IBIS-II=International Breast cancer Intervention Study II; LCIS=lobular carcinoma in situ; MAP.3=Mammary Prevention.3 trial; mg=milligram; MORE=Multiple Outcomes of Raloxifene Evaluation; NSABP-P1=National Surgical Adjuvant Breast and Bowel Project P-1 Study; RUTH=Raloxifene Use for the Heart; STAR=Study of Tamoxifen and Raloxifene; UK=United Kingdom; US=United States.

The trials included large numbers of women, ranging from the HOT study^53^ enrolling 1,884 women to the STAR trial enrolling 19,747.^61^ Participants were recruited from clinics and communities located in several countries, with North America, Europe, and the United Kingdom most represented. The majority of participants were white and none of the trials provided outcomes specific to racial or ethnic groups. Participants ranged in age from 30s to 80s at baseline.

Inclusion criteria for trials are described in Table 3 and Appendixes C1 and C2. All trials included women who could be considered candidates for risk reduction medications in the intended target population, although participant characteristics varied across trials. The tamoxifen trials enrolled both pre and postmenopausal women, while the raloxifene and aromatase inhibitor trials enrolled only postmenopausal women. The Italian trial of tamoxifen exclusively enrolled women who had undergone prior hysterectomy including some with oophorectomy,^55^ representing only a subgroup of the target population. Several trials enrolled women using exogenous estrogen including the Italian (14% of women), Royal Marsden (15 to 27%), IBIS-I (40%), and HOT (100%) tamoxifen trials. Estrogen use could modify or confound breast cancer risk, as well as other outcomes, such as thromboembolic events.

The tamoxifen trials, including STAR, were designed to determine invasive breast cancer incidence as the primary outcome.^53–55,58,59,61,81,84,90,100,106,107^ As such, inclusion criteria considered breast cancer risk in all tamoxifen trials except the Italian^55^ and HOT^53^ trials. Two trials, STAR and NSABP P-1, used the modified Gail model^41,125^ to identify participants at increased risk. In STAR, women were eligible for the trial if they were postmenopausal and had a Gail model 5-year predicted breast cancer risk of 1.67 percent or greater.^61^ The NSABP P-1 trial used this same threshold as well as additional criteria, such as age 60 years and older, or a history of LCIS.^58^ The IBIS-I and Royal Marsden trials defined risk based on numbers of relatives with breast cancer as well as personal history of prior benign breast biopsies.^54,59^

For the raloxifene trials, breast cancer incidence was one of two primary outcomes in RUTH and was a secondary outcome in MORE. The MORE trial enrolled women with osteoporosis in order to determine the efficacy of raloxifene in preventing fractures.^80,89^ Eligibility criteria included bone mineral density (BMD) T-score of −2.5 or less at the femoral neck or lumbar spine, or low BMD with pre-existing vertebral fractures at baseline. The RUTH trial was designed to determine the efficacy of raloxifene in preventing coronary events and enrolled women with coronary heart disease or multiple risk factors for heart disease.^60^ Participants were required to have a cardiovascular risk score of 4 or greater according to a point system that assigned values for specific conditions.

The aromatase inhibitor trials enrolled postmenopausal women with risk factors for breast cancer. The IBIS-II trial of anastrozole based inclusion criteria on age and estimated breast cancer risk from a list of risk factors (age 40 to 44 years with risk 4 times higher than the general population; age 45 to 60 years with risk ≥2 times higher; age 60 to 70 years with risk 1.5 times higher).^17^ The MAP.3 trial of exemestane used risk criteria based on age 60 years and older, Gail risk score of 1.67 percent or greater, and prior DCIS or high-risk breast lesion on biopsy.^56^

Differences in inclusion criteria across the trials led to the enrollment of dissimilar groups of women (Appendix C3). The mean age of participants at entry ranged from 47^59^ to 53^53^ years in the tamoxifen trials, 67^80^ to 68^60,80^ years in the raloxifene trials, 58.5 years in STAR,^61^ and 60^17^ to 63^56^ years in the aromatase inhibitor trials. Risks for most outcomes measured in the trials increase with age including risks for breast cancer and adverse events, such as thromboembolic events and strokes. The 15- to 20-year age difference between participants in the different trials would be expected to influence results and limit comparisons across trials. Although the head-to-head design of the STAR trial allows direct comparisons between tamoxifen and raloxifene, there are no head-to-head comparison trials that include the aromatase inhibitors or alternative dosing regimens.

Trials also varied by treatment durations and followup times. These variations could influence results because participants with short exposures may not attain the optimal benefits or experience the adverse effects that would accrue for those with longer exposures. Also, short followup times may not allow conditions with slower progression, such as breast cancer, to be detected during the course of the trial. The STAR trial reported a mean treatment duration of 3.6 to 3.9 years and mean followup of 3.9 years for initial results, and 6.8 years for long-term results.^61,96,123^ Median treatment duration in the placebo-controlled trials of tamoxifen were approximately 4 to 5 years,^58,106^ while median followup times ranged from 6 years in the HOT^53^ trial to 16 years in IBIS-I.^82^ The Royal Marsden^100^ and IBIS-I^81^ trials provided some results by active versus posttreatment periods, while other trials did not. Absolute risk reduction depends on followup time and trials with longer followup provide better estimates, such as the IBIS-I trial with 16 years and Royal Marsden with 13 years.

In the raloxifene trials, results of the MORE trial were reported after 3 and 4 years of treatment.^74,75,78,80,85–87,89,93,95,103^ The CORE study is a continuation of MORE that follows a subset of MORE participants in order to further examine raloxifene’s effect on breast cancer incidence. Although participants continued their randomized assignment to raloxifene or placebo in CORE, all had a gap in use. Median time between participation in MORE and CORE was 10.6 months (2.6 to 62 months).^57^ Results of CORE were reported for 4-year and combined 8-year outcomes (MORE + CORE).^97,98,104^ For RUTH, the median treatment duration was 5.1 years and followup 5.6 years.^60^ The aromatase inhibitor trials are the most recent and have the shortest followup times. The median treatment duration and followup was 5 years for IBIS-II^17^ and 3 years for MAP.3.^56^

Adherence and completion rates varied across trials and treatment groups. In the STAR trial, the mean duration of treatment was similar for raloxifene and tamoxifen (3.2 vs. 3.1 years, respectively).^61^ In IBIS-I, adherence after 4.5 years was 65.2 percent for tamoxifen versus 74.0 percent for placebo (p<0.001).^126^ In the Italian trial, designed for 60 months of treatment, women using tamoxifen had lower completion rates than placebo (59.8 vs. 61.8%, respectively).^106^ In the Royal Marsden trial, adherence was 8 percent lower with tamoxifen compared with placebo (p=0.002).^100^ In RUTH, 70 percent of raloxifene versus 71 percent of placebo groups took at least 70 percent of the study medication.^60^ Also, women using raloxifene had slightly higher completion rates than placebo (80 vs. 79%; p=0.02), although the median duration of treatment was 5.05 years for both groups.^60^ Adherence was not reported by group in MORE; 92 percent of the entire study population took at least 80 percent of the assigned study medication.^80^ In IBIS-II, 5-year adherence was 68 percent for anastrozole and 72 percent for placebo (p=0.0047),^17^ while for MAP.3, 3-year adherence was 67 percent for exemestane and 71 percent for placebo.^56^

Protocol specified and non-protocol specified events affecting adherence were reported by some of the trials. Protocol specified events are outcomes explicitly stated in the protocol requiring that a participant discontinue the study medication. In the NSABP P-1 trial, discontinuation related to non-protocol specified events was 23.7 percent of tamoxifen versus 19.7 percent of placebo groups.^58^ In the Italian trial, 7.6 percent of tamoxifen versus 6.9 percent of placebo groups experienced protocol specified events and withdrew from treatment; 26.7 percent of tamoxifen versus 25.3 percent of placebo groups experienced non-protocol specified events and withdrew from treatment.^106^ In RUTH, 22 percent of raloxifene and 20 percent of placebo groups experienced adverse events and discontinued study medications (p=0.01); specific adverse events were not described.^60^ In the MORE trial, significantly more women receiving raloxifene than placebo reported hot flashes and withdrew from treatment.^80^ Early discontinuation in IBIS-II was related to toxic effects (20% anastrozole vs. 15% placebo) and patient refusal (5% in each group).^17^ In MAP.3, early discontinuation was also related to toxic effects (15.4% exemestane vs. 10.8% placebo; p<0.001) and patient refusal (6.9% exemestane vs. 6.0% placebo; p=0.22).^56^

Although most trials reported similar outcomes (Table 4), the ascertainment of outcomes varied by trial. While diagnostic criteria for primary outcomes were generally well-defined and diagnoses were determined by blinded adjudication committees, ascertainment of additional outcomes was not well described. For these outcomes, it is likely that differences in results between trials may be due, at least in part, to how the outcomes were determined. All of the primary prevention trials reported incidence of invasive, ER+, ER-, and noninvasive breast cancer. All-cause mortality was provided in all of the trials, and breast cancer specific mortality in all but RUTH, while combined mortality results of MORE, CORE, and RUTH were reported in a review.^92^ Fracture outcomes were more comprehensively evaluated in the MORE trial^80,85,89,104^ that evaluated fractures at multiple anatomic sites, such as the hip and wrist specifically, and detected rigorously defined radiographic vertebral fractures. The NSABP P-1, RUTH, STAR, HOT, MAP.3, and IBIS-II trials included clinical vertebral fractures^17,53,56,60,61,90^ identified by physical findings or symptoms. Most trials reported various categories of nonvertebral fractures including all types or those specific to osteoporosis (hip, vertebral, wrist).

Table 4 Outcomes Reported in Trials

Outcomes | Placebo-Controlled Trials Reporting Outcomes | Included in Meta-Analysis | Reported in STAR Trial
Benefits
All breast cancer | NSABP-1, Marsden, IBIS-I, Italian, MORE, RUTH, MAP.3, HOT, IBIS-II | X | NR
Invasive breast cancer | NSABP-1, Marsden, IBIS-I, Italian, MORE, RUTH, MAP.3, IBIS-II | X | X
ER+ breast cancer | NSABP-1, Marsden, IBIS-I, Italian, MORE, RUTH, MAP.3, IBIS-II | X | NR
ER− breast cancer | NSABP-1, Marsden, IBIS-I, Italian, MORE, RUTH, MAP.3, IBIS-II | X | NR
Noninvasive breast cancer | NSABP-1, Marsden, IBIS-I, Italian, MORE, RUTH, MAP.3, IBIS-II | X | X
DCIS | Marsden, IBIS-I, MORE, MAP.3, IBIS-II | | X
Breast cancer mortality | NSABP-1, Marsden, IBIS-I, Italian, MORE, MAP.3, IBIS-II | X | NR
All-cause mortality | NSABP-1, Marsden, IBIS-I, Italian, MORE, RUTH, MAP.3, IBIS-II | X | X
All fractures | Marsden, IBIS-I, MAP.3, HOT, IBIS-II | X | NR
Hip, wrist, spine fractures | NSABP-1, IBIS-I, MAP.3 | X | X
Vertebral fractures | NSABP-1, MORE, RUTH, MAP.3, IBIS-II | X | X
Nonvertebral fractures | NSABP-1, MORE, RUTH, MAP.3, IBIS-II | X | NR
Hip fractures | NSABP-1, MORE, MAP.3 | | X
Wrist fractures | NSABP-1, MORE, MAP.3 | | X
Harms
Thromboembolic events | NSABP-1, Marsden, IBIS, Italian, MORE, RUTH, MAP.3, HOT, IBIS-II | X | X
Deep vein thrombosis | NSABP-1, Italian, MORE, RUTH | X | X
Pulmonary embolus | NSABP-1, Italian, MORE, RUTH | X | X
Superficial phlebitis | Italian, IBIS-I, IBIS-II | X | NR
Coronary heart events | NSABP-1, Marsden, IBIS-I, Italian, MORE, RUTH, MAP.3, HOT, IBIS-II | X | X
Myocardial infarction | NSABP-1, IBIS-I, Italian, MAP.3, IBIS-II | X | X
Stroke | NSABP-1, Marsden, IBIS-I, Italian, RUTH, MORE, MAP.3, HOT, IBIS-II | X | X
Transient ischemic attack | NSABP-1, IBIS, Italian, MAP.3 | X | X
Endometrial cancer | NSABP-1, Marsden, IBIS-I, MORE, RUTH, MAP.3, HOT, IBIS-II | X | X
Cataracts | NSABP-1, Marsden, IBIS-I, MORE, RUTH, IBIS-II | X | X
Quality of life
Depression | NSABP-1, IBIS-II, MAP.3 | | X
Anxiety | IBIS-II | | NR
Sleep disturbances | Marsden, MAP.3 | | NR
Sexual functioning | NSABP-1, Marsden, MAP.3 | | X
Vasomotor symptoms | IBIS, Marsden, IBIS-II, MAP.3 | | X
Vaginal dryness | Italian, IBIS, IBIS-II, MAP.3, HOT | | X
Vaginal discharge | NSABP-1, IBIS, Marsden, Italian, HOT | | X
Hot flashes or flushes | NSABP-1, Italian, Marsden, MORE, RUTH, IBIS-II, MAP.3, HOT | | X
Night sweats | NSABP-1, MAP.3, HOT | | NR
Gynecological conditions | IBIS-II | | X
Leiomyomas | NSABP-1 | | X
Ovarian cysts | NSABP-1, IBIS | | X
Uterine fibroids | IBIS | | NR
Endometrial polyps | IBIS, HOT | | NR
Cervical polyps | IBIS | | NR
Uterine polyps | MORE | | NR
Polyps, unspecified | NSABP-1 | | X
Endometriosis | NSABP-1, IBIS | | X
Endometritis | NSABP-1 | | NR
Gynecological procedures
Currettage | NSABP-1 | | X
Hysterectomy | NSABP-1, Marsden, IBIS | | X
Oophorectomy | NSABP-1, IBIS | | X
Laparoscopy | NSABP-1 | | X
Hysteroscopy | NSABP-1, IBIS | | X

Abbreviations: DCIS=ductal carcinoma in situ; ER+=estrogen receptor positive; ER-=estrogen receptor negative; HOT=Hormone replacement therapy Opposed by low dose Tamoxifen; IBIS=International Breast Cancer Intervention Study; MAP.3=Mammary Prevention.3 Trial; MORE=Multiple Outcomes of Raloxifene Evaluation; NR=not reported; NSABP-1=National Surgical Adjuvant Brest and Bowel Project P-1 Study; RUTH=Raloxifene Use for the Heart; STAR=Study of Tamoxifen and Raloxifene.

All trials reported thromboembolic events, and some provided specific results for deep vein thrombosis (DVT),^58,60,84,93^ pulmonary embolus (PE),^58,60,84,93^ and superficial phlebitis.^17,81,84^ Coronary heart events were described in all trials and generally included myocardial infarction, angina, acute ischemic syndrome, and other cardiac events. However, specific outcomes included in this broad category varied and were often not well specified. The RUTH trial, designed primarily to measure coronary outcomes, provided the most comprehensive measures.^60^ Stroke was measured in all trials and transient ischemic attack in six.^17,53,56,58,61,80,81,106^ Endometrial cancer, hysterectomy, endometrial hyperplasia, uterine fluid, and vaginal bleeding were determined in various ways in most trials. While seven trials reported cataracts,^17,58,60,61,81,93,100^ most of these were self-reported. Descriptions of other outcomes, such as vasomotor symptoms, edema, pain, for example, varied by trial.

### Summary

Ten large RCTs provide data on breast cancer risk reduction in women without preexisting breast cancer. These include one good-quality head-to-head trial of tamoxifen and raloxifene and nine fair- and good-quality placebo-controlled trials (five tamoxifen, two raloxifene, and two aromatase inhibitors). The HOT trial of low-dose tamoxifen indicated no statistically significant differences in outcomes compared with placebo and was not included in the meta-analyses of tamoxifen trials. Results of placebo-controlled trials cannot be directly compared between types of medications because of important differences between study participants, especially differences in age.

Tamoxifen 20 mg/day (RR 0.69; 95% CI, 0.59 to 0.84; 4 trials), raloxifene (RR 0.44; 95% CI, 0.24 to 0.80; 2 trials), and aromatase inhibitors (RR 0.45; 95% CI, 0.26 to 0.70; 2 trials) reduced the incidence of invasive breast cancer in midlife and older women by approximately 31 to 56 percent in placebo-controlled trials. These estimates are comparable to 7 (4 to 12) fewer events per 1000 women over 5 years of use for tamoxifen, 9 (3 to 15) for raloxifene, and 16 (8 to 24) for aromatase inhibitors. Tamoxifen reduced invasive breast cancer more than raloxifene in the STAR head-to-head trial (RR 1.24; 95% CI, 1.05 to 1.47) after long-term followup comparable to 5 (1 to 9) fewer events with tamoxifen per 1000 women over 5 years of use. Tamoxifen (RR 0.58; 95% CI, 0.42 to 0.81; 4 trials), raloxifene (RR 0.33; 95% CI, 0.15 to 0.70; 2 trials), and aromatase inhibitors (RR 0.37; 95% CI, 0.19 to 0.63; 2 trials) reduced ER+ invasive breast cancer, but not ER− invasive breast cancer, in placebo-controlled trials. Raloxifene and tamoxifen had similar effects on ER+ and ER− invasive breast cancer in the STAR head-to-head trial while on active treatment.

For noninvasive cancer, risks were reduced only in the NSABP P-1^90^ (RR 0.63; 95% CI, 0.45 to 0.89) and IBIS-I^82^ (RR 0.65; 95% CI, 0.43 to 1.00) tamoxifen trials. Meta-analyses of trials of tamoxifen, raloxifene, and aromatase inhibitors indicated no reduction in noninvasive cancer. The STAR head-to-head trial indicated no differences between raloxifene and tamoxifen in reducing noninvasive breast cancer (RR 1.22; 95% CI, 0.95 to 1.59).

All-cause mortality was similar for women using raloxifene compared with tamoxifen; or tamoxifen, raloxifene, or aromatase inhibitors compared with placebo, although followup times in trials varied. Tamoxifen did not reduce breast cancer mortality compared with raloxifene or placebo, while few cases of breast cancer mortality were reported in placebo-controlled trials of raloxifene and aromatase inhibitors.

Tamoxifen and raloxifene had similar effects on fractures at multiple vertebral and nonvertebral sites in the STAR head-to-head trial. In placebo-controlled trials, raloxifene (RR 0.61; 95% CI, 0.53 to 0.73; 2 trials) reduced vertebral fractures, tamoxifen reduced nonvertebral fractures in the NSABP P-1 trial (RR 0.66; 95% CI, 0.45 to 0.98), while the aromatase inhibitors had no effect on fractures.

### Evidence

The ten RCTs described above and in Tables 3, 4, and Appendix B3 provide data for Key Question 2. Trials are reported in 32 publications, of which seven are new and 25 were cited in the 2013 review. The new studies include updated long-term results of the IBIS-I trial of tamoxifen,^82^ a placebo-controlled trial of low-dose tamoxifen,^53^ and placebo-controlled trials of anastrozole^17,102,105^ and exemestane.^56,99^ Results are summarized in Tables 5 and 6. The HOT trial of low-dose tamoxifen indicated no statistically significant differences in outcomes compared with placebo and was not included in the meta-analyses of tamoxifen trials discussed in this section.^53^

Table 5 Results of the STAR Trial—Relative and Absolute Effects

Outcome | RR for Raloxifene vs. Tamoxifen (95% CI) | Events Reduced or Increased (95% CI), n^*^
Benefits
Invasive breast cancer | 1.24 (1.05 to 1.47)^†^ | 5 (1 to 9) fewer with tamoxifen
ER+ breast cancer | 0.93 (0.72 to 1.24)^‡^ | –
ER− breast cancer | 1.15 (0.75 to 1.77)^‡^ | –
Noninvasive breast cancer | 1.22 (0.95 to 1.59)^†^ | –
Breast cancer mortality | 0.36 (0.08 to 1.21)^†^ | –
All-cause mortality | 0.84 (0.70 to 1.02)^†^ | –
Vertebral fracture | 0.98 (0.65 to 1.46)^‡^ | –
Nonvertebral fracture | Not reported | –
Harms
Thromboembolic events^§^ | 0.75 (0.60 to 0.93)^†^ | 4 (1 to 7) more with tamoxifen
DVT | 0.72 (0.54 to 0.95)^†^ | 3 (1 to 5) more with tamoxifen
PE | 0.80 (0.57 to 1.11)^†^ | –
CHD events | 1.10 (0.85 to 1.43)^‡^ | –
Stroke | 0.96 (0.64 to 1.43)^‡^ | –
Endometrial cancer | 0.55 (0.36 to 0.83)^†^ | 5 (2 to 9) more with tamoxifen
Cataracts | 0.80 (0.72 to 0.95)^†^ | 15 (8 to 22) more with tamoxifen

* Numbers of events reduced for benefits or increased for harms compared with raloxifene per 1000 women, assuming 5 years of use.

† Updated results from STAR, 2010.^123^

‡ Initial results from STAR, 2006.^61^

§ Includes DVT and PE.

Abbreviations: CHD=coronary heart disease; CI=confidence interval; DVT=deep vein thrombosis; ER−=estrogen receptor negative; ER+=estrogen receptor positive; n=number; PE=pulmonary embolism; RR=risk ratio; STAR=Study of Tamoxifen and Raloxifene.

Table 6 Meta-Analysis of Results of Placebo-Controlled Trials—Relative and Absolute Effects for Beneficial Outcomes

Outcome | RR for Tamoxifen vs. Placebo; (95% CI) | Trials, n^*^ | Placebo Rate (±SE)^†^ | Events Reduced or Increased With Tamoxifen (95% CI), n^‡^ | RR for Taloxifene vs. Placebo; (95% CI) | Trials, n^*^ | Placebo Rate (±SE)^†^ | Events Reduced or Increased With Raloxifene (95% CI), n^‡^ | RR for AIs vs. Placebo; (95% CI) | Trials, n^*^ | Placebo Rate (±SE)^†^ | Events Reduced or Increased With AIs (95% CI), n^‡^
Breast cancer
Invasive | 0.69; (0.59 to 0.84) | 4 | 4.58 ± 0.96 | 7 (4 to 12) fewer | 0.44; (0.24 to 0.80) | 2 | 3.19 ± 0.59 | 9 (3 to 15) fewer | 0.45; (0.26 to 0.70) | 2 | 5.90 ± 0.64 | 16 (8 to 24) fewer
ER+ | 0.58; (0.42 to 0.81) | 4 | 3.62 ± 0.76 | 8 (4 to 13) fewer | 0.33; (0.15 to 0.70) | 2 | 2.45 ± 0.42 | 8 (4 to 13) fewer | 0.37; (0.19 to 0.63) | 2 | 4.55 ± 0.53 | 15 (8 to 20) fewer
ER− | 1.18; (0.93 to 1.53) | 4 | – | – | 1.25; (0.60 to 2.58) | 2 | – | – | 0.79; (0.35 to 1.79) | 2 | – | –
Non-invasive | 0.72; (0.56 to 1.41)^§^ | 4 | – | – | 1.47; (0.61 to 3.85) | 2 | – | – | 0.46; (0.16 to 1.42) | 2 | – | –
Mortality
Breast cancer | 1.20; (0.79 to 1.79) | 4 | – | – | NR^∥^ | – | – | – | NR | – | – | –
All-cause | 1.07; (0.91 to 1.23) | 4 | – | – | 0.90; (0.63 to 1.05) | 2 | – | – | 1.02; (0.58 to 1.82) | 2 | – | –
Fracture
Vertebral | 0.75; (0.48 to 1.15)^¶^ | 1 | – | – | 0.61; (0.53 to 0.73) | 2 | 3.45 ± 0.35^**^ | 7 (5 to 9) fewer | 1.28; (0.59 to 2.75) | 2 | – | –
Non-vertebral | 0.66; (0.45 to 0.98)^¶^ | 1 | 1.55 ± 0.20 | 3 (0.2 to 5) fewer | 0.97; (0.86 to 1.12) | 2 | – | – | 1.05; (0.87 to 1.28) | 2 | – | –

* Number of trials included in meta-analysis.

† Per 1000 women, estimated from a meta-analysis of rates from the placebo groups from the same trials included in the RRs.

‡ Numbers of events reduced for benefits or increased for harms compared with placebo per 1000 women assuming 5 y of use.

§ The RR was significantly reduced in NSABP P-1, 2005 (60 vs. 93 events; RR, 0.63 [95% CI, 0.45–0.89]).^90^

∥ 2 breast cancer deaths in 7601 women for raloxifene vs. 0 in 7633 women for placebo.^91,93^

¶ NSABP P-1, 2007.^90^

** Estimated from the placebo group of the RUTH trial, 2006.^60^

Abbreviations: AIs=aromatase inhibitors; CI=confidence interval; ER−=estrogen receptor–negative; ER+=estrogen receptor–positive; n=number; NR=not reported; NSABP=National Surgical Adjuvant Breast and Bowel Project; PE=pulmonary embolism; RR=risk ratio; RUTH=Raloxifene Use for the Heart; SE=standard error.

#### Invasive Breast Cancer

Tamoxifen versus raloxifene. Risk for invasive breast cancer was higher for raloxifene than tamoxifen in the STAR head-to-head trial (RR, 1.24; 95% CI, 1.05 to 1.47) after long-term followup, comparable to 5 (1 to 9) fewer events with tamoxifen per 1000 women over 5 years of use.^123^ Differences for ER+ and ER− subtypes were not statistically significant.^61^

Tamoxifen versus placebo. Tamoxifen (20 mg/day) reduced invasive breast cancer in all four prevention trials compared with placebo based on long-term followup data (7 to 16 years).^82,90,100,106^ Reductions ranged from 20 to 43 percent with the biggest effect from the largest trial, the NSABP P-1 trial (RR 0.57; 95% CI, 0.46 to 0.70).^90^ Combined results indicate a summary RR of 0.69 (95% CI, 0.59 to 0.84; 4 trials; Figure 2), comparable to 7 (4 to 12) fewer cases per 1000 women over 5 years of use. Tamoxifen reduced risks for ER+ (RR 0.58; 95% CI, 0.42 to 0.81; 4 trials; Figure 3), but not ER− breast cancer (RR 1.18; 95% CI, 0.93 to 1.53; 4 trials; Figure 4).^81,90,100,106^

Figure 2 Meta-Analysis of Trials: Invasive Breast Cancer

* Per 1,000 women-years.

^†^ Veronesi, 2007 and Barrett-Connor, 2006 reported mean or median duration of the actual treatment period.

^‡^ The analysis included data from both MORE and CORE. Participants from MORE had 4-year treatment and those who continued in CORE had 4 additional years of treatment. The total followup time is averaged over both MORE and CORE for 7705 participants.

^§^ The intended treatment duration is 5 years or until a breast, neoplastic, cardiovascular or toxicity event.

Abbreviations: CI=confidence interval; CORE=Continuing Outcomes Relevant to Evista; HOT=Hormone replaced therapy Opposed by low-dose Tamoxifen study; IBIS-I=International Breast Cancer Intervention Study; MAP.3=Mammary Prevention.3 trial; MORE=Multiple Outcomes of Raloxifene; N=number; NSABP-1=National Surgical Adjuvant Breast and Bowel Project P-1 study; RUTH=Raloxifene Use for the Heart.

Figure 2 is a forest plot of studies reporting the risk ratio of invasive breast cancer stratified by type of medication. Data for Figure 2 are presented in Appendix B3. In one tamoxifen trial, the risk ratio was 0.83 (95% CI, 0.42 to 1.62). In four tamoxifen trials the combined risk ratio was 0.69 (95% CI, 0.59 to 0.84). In two raloxifene trials the combined risk ratio was 0.44 (95% CI, 0.24 to 0.80). In two aromatase inhibitor trials the combined risk ratio was 0.45 (95% CI, 0.26 to 0.70).

Figure 3 Meta-Analysis of Trials: Estrogen Receptor Positive Breast Cancer

* Per 1,000 women-years.

^†^ Veronesi, 2007 and Barrett-Connor, 2006 reported mean or median duration of the actual treatment period.

^‡^ The analysis included data from both MORE and CORE. Participants from MORE had 4-year treatment and those who continued in CORE had 4 additional years of treatment. The total followup time is averaged over both MORE and CORE for 7705 participants.

^§^ The intended treatment duration is 5 years or until a breast, neoplastic, cardiovascular or toxicity event.

Abbreviations: CI=confidence interval; CORE=Continuing Outcomes Relevant to Evista; ER+=estrogen receptor positive; HOT=Hormone replaced therapy Opposed by low-dose Tamoxifen study; IBIS-I=International Breast Cancer Intervention Study; IBIS-II=International Breast Cancer Intervention Study II; MAP.3=Mammary Prevention.3 trial; MORE=Multiple Outcomes of Raloxifene; N=number; NSABP-1=National Surgical Adjuvant Breast and Bowel Project P-1 study; RUTH=Raloxifene Use for the Heart.

Figure 3 is a forest plot of studies reporting the risk ratio of estrogen receptor positive breast cancer stratified by type of medication. Data for Figure 3 are presented in Appendix B3. In one tamoxifen trial, the risk ratio was 0.61 (95% CI, 0.27 to 1.30). In four tamoxifen trials the combined risk ratio was 0.58 (95% CI, 0.42 to 0.81). In two raloxifene trials the combined risk ratio was 0.33 (95% CI, 0.15 to 0.70). In two aromatase inhibitor trials the combined risk ratio was 0.37 (95% CI, 0.19 to 0.63).

Figure 4 Meta-Analysis of Trials: Estrogen Receptor Negative Breast Cancer

* Per 1,000 women-years.

^†^ Veronesi, 2007 and Barrett-Connor, 2006 reported mean or median duration of the actual treatment period.

^‡^ The analysis included data from both MORE and CORE. Participants from MORE had 4-year treatment and those who continued in CORE had 4 additional years of treatment. The total followup time is averaged over both MORE and CORE for 7705 participants.

^§^ The intended treatment duration is 5 years or until a breast, neoplastic, cardiovascular or toxicity event.

Abbreviations: CI=confidence interval; CORE=Continuing Outcomes Relevant to Evista; ER-=estrogen receptor negative; HOT=Hormone replaced therapy Opposed by low-dose Tamoxifen study; IBIS-I=International Breast Cancer Intervention Study; IBIS-II=International Breast Cancer Intervention Study II; MAP.3=Mammary Prevention.3 trial; MORE=Multiple Outcomes of Raloxifene; N=number; NSABP-1=National Surgical Adjuvant Breast and Bowel Project P-1 study; RUTH=Raloxifene Use for the Heart.

Figure 4 is a forest plot of studies reporting the risk ratio of estrogen receptor negative breast cancer stratified by type of medication. Data for Figure 4 are presented in Appendix B3. In one tamoxifen trial, the risk ratio was 2.02 (95% CI, 0.29 to 22.4). In four tamoxifen trials the combined risk ratio was 1.18 (95% CI, 0.93 to 1.53). In two raloxifene trials the combined risk ratio was 1.25 (95% CI, 0.60 to 2.58). In two aromatase inhibitor trials the combined risk ratio was 0.79 (95% CI, 0.35 to 1.79).

Raloxifene versus placebo. Raloxifene reduced invasive breast cancer by 44 and 66 percent in the MORE^57^ and RUTH^60^ trials, respectively. Combined results indicate a RR of 0.44 (95% CI, 0.24 to 0.80; 2 trials; Figure 2), comparable to 9 (3 to 15) fewer cases per 1000 women over 5 years of use. Raloxifene also reduced risk for ER+ (RR 0.33; 95% CI, 0.15 to 0.70; 2 trials; Figure 3), but not ER− breast cancer (RR 1.25; 95% CI, 0.60 to 2.58; 2 trials; Figure 4).

Aromatase inhibitors versus placebo. Anastrozole^17^ and exemestane^56^ reduced invasive breast cancer compared with placebo (RR 0.45; 95% CI, 0.26 to 0.70; 2 trials; Figure 2), comparable to 16 (8 to 24) fewer cases per 1000 women over 5 years of use. The aromatase inhibitors reduced risk for ER+ (RR 0.37; 95% CI, 0.19 to 0.63; 2 trials; Figure 3), but not ER− breast cancer (RR 0.79; 95% CI, 0.35 to 1.79; 2 trials; Figure 4) similar to tamoxifen and raloxifene.

#### Noninvasive Breast Cancer Including Ductal Carcinoma In Situ

Tamoxifen versus raloxifene. STAR reported no statistically significant difference between tamoxifen and raloxifene for noninvasive breast cancer (RR 1.22; 95% CI, 0.95 to 1.59), although the point estimate is favorable for tamoxifen.^123^

Tamoxifen versus placebo. All four tamoxifen trials reported noninvasive cancer outcomes, although specific definitions of noninvasive cancer varied between trials. Risks were reduced in the NSABP P-1^90^ (RR 0.63; 95% CI, 0.45 to 0.89) and IBIS-I^82^ (RR 0.65; 95% CI, 0.43 to 1.00) trials, but not in the Royal Marsden^100^ and Italian^106^ trials. When trials were combined, the risk of noninvasive breast cancer was not significantly reduced (RR 0.72; 95% CI, 0.56 to 1.41; 4 trials (Figure 5).

Figure 5 Meta-Analysis of Trials: Noninvasive Breast Cancer

* Per 1,000 women-years.

^†^ Veronesi, 2007 and Barrett-Connor, 2006 reported mean or median duration of the actual treatment period.

^‡^ The analysis included data from both MORE and CORE. Participants from MORE had 4-year treatment and those who continued in CORE had 4 additional years of treatment.

^|^ The total followup time is averaged over both MORE and CORE for 7705 participants.

^§^ The intended treatment duration is 5 years or until a breast, neoplastic, cardiovascular or toxicity event.

Abbreviations: CI=confidence interval; CORE=Continuing Outcomes Relevant to Evista; HOT=Hormone replaced therapy Opposed by low-dose Tamoxifen study; IBIS-I=International Breast Cancer Intervention Study; IBIS-II=International Breast Cancer Intervention Study II; MAP.3=Mammary Prevention.3 trial; MORE=Multiple Outcomes of Raloxifene; N=number; NSABP-1=National Surgical Adjuvant Breast and Bowel Project P-1 study; RUTH=Raloxifene Use for the Heart.

Figure 5 is a forest plot of studies reporting the risk ratio of noninvasive breast cancer stratified by type of medication. Data for Figure 5 are presented in Appendix B3. In one tamoxifen trial, the risk ratio was 0.51 (95% CI, 0.05 to 5.33). In four tamoxifen trials the combined risk ratio was 0.72 (95% CI, 0.56 to 1.41). In two raloxifene trials the combined risk ratio was 1.47 (95% CI, 0.61 to 3.85). In two aromatase inhibitor trials the combined risk ratio was 0.46 (95% CI, 0.16 to 1.42).

Raloxifene versus placebo. Both the MORE^57^ and RUTH^60^ trials indicated increased point estimates for noninvasive breast cancer, although results were not statistically significant (RR 1.47; 95% CI, 0.61 to 3.85; 2 trials; Figure 5).

Aromatase inhibitors versus placebo. Risk for noninvasive breast cancer was reduced in the IBIS-II^17^ trial (RR 0.30; 95% CI, 0.12 to 0.74), but not in the MAP.3 trial.^56^ When trials were combined, the risk of noninvasive breast cancer was not significantly reduced (RR 0.46; 95% CI, 0.16 to 1.42; 2 trials; Figure 5).

#### Breast Cancer Mortality

Tamoxifen versus raloxifene. STAR reported no statistically significant difference between tamoxifen and raloxifene for breast cancer mortality (RR 0.36; 95% CI, 0.08 to 1.21).^123^

Tamoxifen versus placebo. All four tamoxifen trials reported breast cancer specific mortality using long-term followup data (7 to 16 years).^81,90,100,106^ None of these results were significantly different for tamoxifen versus placebo (RR 1.20; 95% CI, 0.79 to 1.79; 4 trials Figure 6).

Figure 6 Meta-Analysis of Trials: Breast Cancer Mortality

* Per 1,000 women-years.

^†^ Veronesi, 2007 reported mean or median duration of the actual treatment period.

Abbreviations: CI=confidence interval; HOT=Hormone replaced therapy Opposed by low-dose Tamoxifen study; IBIS-I=International Breast Cancer Intervention Study; N=number; NSABP-1=National Surgical Adjuvant Breast and Bowel Project P-1 study.

Figure 6 is a forest plot of studies reporting the risk ratio of breast cancer mortality stratified by type of medication. Data for Figure 6 are presented in Appendix B3. In four tamoxifen trials the combined risk ratio was 1.20 (95% CI, 0.79 to 1.79).

Raloxifene versus placebo. In a review that reported results of MORE, CORE, and RUTH combined, there were two breast cancer deaths in the raloxifene group and none reported in the placebo group.^92^

Aromatase inhibitors versus placebo. Very few breast cancer deaths occurred in the IBIS-II^17^ and MAP.3^56^ trials and no relative risks were reported.^56^

#### All-Cause Mortality

Tamoxifen versus raloxifene. All-cause mortality in the STAR trial was similar for women treated with tamoxifen or raloxifene (RR 0.84; 95% CI, 0.70 to 1.02).^123^

Tamoxifen versus placebo. All four tamoxifen trials reported all-cause mortality using long-term followup data (7 to 16 years), and none were significantly different for tamoxifen compared with placebo (RR 1.07; 95% CI, 0.91 to 1.23; 4 trials; Figure 7).^82,90,100,106^

Figure 7 Meta-Analysis of Trials: All-Cause Mortality

* Per 1,000 women-years.

^†^ Veronesi, 2007 and Barrett-Connor, 2006 reported mean or median duration of the actual treatment period.

^‡^ The analysis included a subset of data from both MORE and CORE. Participants from MORE had 4-year treatment and those who continued in CORE had 4 additional years of treatment. The total followup time is averaged over both MORE and CORE for 7705 participants.

^§^ The intended treatment duration is 5 years or until a breast, neoplastic, cardiovascular or toxicity event.

Abbreviations: CI=confidence interval; CORE=Continuing Outcomes Relevant to Evista; HOT=Hormone replaced therapy Opposed by low-dose Tamoxifen study; IBIS-I=International Breast Cancer Intervention Study; IBIS-II=International Breast Cancer Intervention Study II; MAP.3=Mammary Prevention.3 trial; MORE=Multiple Outcomes of Raloxifene; N=number; NR=not reported; NSABP-1=National Surgical Adjuvant Breast and Bowel Project P-1 study; RUTH=Raloxifene Use for the Heart.

Figure 7 is a forest plot of studies reporting the risk ratio of all-cause mortality stratified by type of medication. Data for Figure 7 are presented in Appendix B3. In one tamoxifen trial, the risk ratio was 3.03 (95% CI, 0.54 to 30.7). In four tamoxifen trials the combined risk ratio was 1.07 (95% CI, 0.91 to 1.23). In two raloxifene trials the combined risk ratio was 0.90 (95% CI, 0.63 to 1.05). In two aromatase inhibitor trials the combined risk ratio was 1.02 (95% CI, 0.58 to 1.82).

Raloxifene versus placebo. All-cause mortality was similar between raloxifene and placebo in the RUTH and MORE trials (RR 0.90; 95% CI, 0.63 to 1.05; 2 trials; Figure 7).^57,60^

Aromatase inhibitors versus placebo. All-cause mortality was similar between aromatase inhibitors and placebo in the IBIS II^17^ and MAP.3^56^ trials (RR 1.02; 95% CI, 0.58 to 1.82; 2 trials; Figure 7).

#### Osteoporotic Fractures

Tamoxifen versus raloxifene. Results of the STAR trial indicate no differences between tamoxifen and raloxifene for clinical vertebral (RR 0.98; 95% CI, 0.65 to 1.46), hip, wrist, or total fractures, although all rates were slightly less for raloxifene.^61^

Tamoxifen versus placebo. The NSABP P-1,^90^ IBIS-I,^81^ and Royal Marsden^100^ trials reported fractures as secondary outcomes. In the NSABP P-1 trial, tamoxifen did not significantly reduce clinical vertebral fractures compared with placebo (RR 0.75; 95% CI, 0.48 to 1.15; Figure 8). Combined outcomes of hip and wrist fractures were significantly reduced with tamoxifen compared with placebo (RR 0.66; 95% CI, 0.45 to 0.98; Figure 9),^90^ comparable to 3 (0.2 to 5) fewer cases per 1000 women over 5 years of use. Point estimates of RRs were also reduced for these fractures in the IBIS-I^81^ and Royal Marsden trials,^100^ however, results were not statistically significant.

Figure 8 Meta-Analysis of Trials: Vertebral Fractures

* Per 1,000 women-years.

^†^ Barrett-Connor, 2006 reported median duration of the actual treatment period.

^‡^ Included fractures from rib, spine, or collarbone.

Abbreviations: CI=confidence interval; CORE=Continuing Outcomes Relevant to Evista; HOT=Hormone replaced therapy Opposed by low-dose Tamoxifen study; IBIS-II=International Breast Cancer Intervention Study II; MAP.3=Mammary Prevention.3 trial; MORE=Multiple Outcomes of Raloxifene; N=number; NR=not reported; NSABP-1=National Surgical Adjuvant Breast and Bowel Project P-1 study; RUTH=Raloxifene Use for the Heart.

Figure 8 is a forest plot of studies reporting the risk ratio of vertebral fractures stratified by type of medication. Data for Figure 8 are presented in Appendix B3. In one tamoxifen trial, the risk ratio was 0.75 (95% CI, 0.48 to 1.15). In two raloxifene trials the combined risk ratio was 0.61 (95% CI, 0.53 to 0.73). In two aromatase inhibitor trials the combined risk ratio was 1.28 (95% CI, 0.59 to 2.75).

Figure 9 Meta-Analysis of Trials: Nonvertebral Fractures

* Per 1,000 women-years.

^†^ Only hip and radius fractures were included.

^‡^ Barrett-Connor, 2006 reported median duration of the actual treatment period.

Abbreviations: CI=confidence interval; CORE=Continuing Outcomes Relevant to Evista; HOT=Hormone replaced therapy Opposed by low-dose Tamoxifen study; IBIS-II=International Breast Cancer Intervention Study II; MAP.3=Mammary Prevention.3 trial; MORE=Multiple Outcomes of Raloxifene; N=number; NR=not reported; NSABP-1=National Surgical Adjuvant Breast and Bowel Project P-1 study; RUTH=Raloxifene Use for the Heart.

Figure 9 is a forest plot of studies reporting the risk ratio of nonvertebral fractures stratified by type of medication. Data for Figure 9 are presented in Appendix B3. In one tamoxifen trial, the risk ratio was 0.66 (95% CI, 0.45 to 0.98). In two raloxifene trials the combined risk ratio was 0.97 (95% CI, 0.86 to 1.12). In two aromatase inhibitor trials the combined risk ratio was 1.05 (95% CI, 0.87 to 1.28).

Raloxifene versus placebo. The MORE trial recruited women with low BMD (T-score ≤ −2.5) and/or prior vertebral fractures.^85,104^ At baseline, 37 percent of women had prior radiographically defined vertebral fractures. In MORE, raloxifene reduced radiographically defined vertebral fractures (RR 0.60; 95% CI, 0.53 to 0.69),^85^ but not nonvertebral or hip fractures compared with placebo.^104^ Results were similar for women with and without prior vertebral fractures and for women using two different doses of raloxifene (60 or 120 mg/day).

The RUTH trial measured fractures as secondary outcomes.^60,88^ RUTH reported reduced clinical vertebral fractures (RR 0.65; 95% CI, 0.47 to 0.89), but not nonvertebral fractures (RR 0.96; 95% CI, 0.84 to 1.10) among raloxifene users compared with placebo, consistent with results of MORE.^60^ Combining results of MORE and RUTH indicates a vertebral fracture RR of 0.61 (95% CI, 0.53 to 0.73; 2 trials; Figure 8) comparable to 7 (4 to 12) fewer cases per 1000 women over 5 years of use, and a nonvertebral fracture RR of 0.97 (0.86 to 1.12; 2 trials; Figure 9).

Aromatase inhibitors versus placebo. The IBIS-II^17^ and MAP.3^56^ trials reported fractures as secondary outcomes. Clinical vertebral (RR 1.28; 95% CI, 0.59 to 2.75; 2 trials; Figure 8) and nonvertebral fractures (RR 1.05; 95% CI, 0.87 to 1.28; 2 trials; Figure 9) were not significantly reduced in either trial or when combined in meta-analysis.

## Key Question 2a Does the Effectiveness of Risk-Reducing Medications Vary by Timing of Initiation or Duration of Use?

### Summary

Eight trials reported no significant differences in breast cancer outcomes by age, although age categories varied by trial. No studies specifically compared shorter versus longer regimens of medication use or initiation based on time since menopause. While most trials intended 5 years of use, mean exposure times varied across the trials from 3 to 5 years. Despite these variations, comparisons across similar medications indicate general consistency in risk reduction for invasive breast cancer.

### Evidence

#### Timing of Initiation

The STAR,^61^ IBIS-I,^81^ Italian,^106^ NSABP P-1,^90^ RUTH,^91^ MORE,^97^ IBIS-II,^17^ and MAP.3^56^ trials reported no significant differences in breast cancer outcomes by age, although age categories varied by trial. The HOT trial of low-dose tamoxifen indicated reduced risk for women initiating therapy under 55 years, but not women aged 55 years and older, based on few cases.^53^ Initiation based on time since menopause was not reported in any trial. In STAR, invasive breast cancer outcomes did not differ for women using raloxifene compared with tamoxifen in the three age categories evaluated (≤49; 50 to 59; ≥60 years), and results were similar across categories.^61^ In the three standard dose tamoxifen placebo-controlled trials, combined risk estimates for invasive or all breast cancer outcomes were significantly reduced and similar for women age 50 years and younger (RR 0.65; 95% CI, 0.54 to 0.85; 3 trials) and women over 50 years (RR 0.68; 95% CI, 0.50 to 0.94; 3 trials; Figure 10).^17,81,90,106^ The raloxifene placebo-controlled trials showed similar results for invasive breast cancer across different age categories (MORE <65 years; RUTH <60 years) that were not combined in a meta-analysis (Figure 10).^91,97^ Risk reduction was similar regardless of age (<60; >60 years) in the aromatase inhibitor trials as well (Figure 10).^17,56^

Figure 10 Meta-Analysis of Trials: Timing of Initiation

* Per 1,000 women-years.

^†^ For Grady 2008, total n=1670 for age < 60 years and 8431 for age ≥60 years.

Abbreviations: CI=confidence interval; CORE=Continuing Outcomes Relevant to Evista; HOT=Hormone replaced therapy Opposed by low-dose Tamoxifen study; IBIS-I=International Breast Cancer Intervention Study; IBIS-II=International Breast Cancer Intervention Study II; MAP.3=Mammary Prevention.3 trial; MORE=Multiple Outcomes of Raloxifene; N=number; NR=not reported; NSABP-1=National Surgical Adjuvant Breast and Bowel Project P-1 study; RUTH=Raloxifene Use for the Heart.

Figure 10 is a forest plot of studies reporting the risk ratio of breast cancer stratified by type of medication and timing of initiation. Data for Figure 10 are presented in Appendix B3. In one tamoxifen low dose trial the risk ratio was 0.34 (95% CI, 0.10 to 0.99) for women under 55 years and 1.54 (95% CI, 0.67 to 3.57) for women 55 years or older. In three tamoxifene trials the combined risk ratio was 0.65 (95% CI, 0.54 to 0.85) for women under 50 years and 0.68 (95% CI, 0.50 to 0.94) for women over 50 years. In one raloxifene trial the risk ratio was 0.42 (95% CI, 0.21 to 0.85) for women under 65 years and 0.49 (95% CI, 0.15 to 1.64) for women under 60 years. In one raloxifene trial the risk ratio was 0.30 (95% CI, 0.18 to 0.49) for women 65 years and over and 0.57 (95% CI, 0.38 to 0.86) for women 60 years and over. In two aromatase inhibitor trials the combined risk ratio was 0.46 (95% CI, 0.25 to 0.83) for women under 60 years and 0.41 (95% CI, 0.20 to 0.71) for women over 60 years.

#### Duration of Use

Although most trials intended 5 years of medication use, mean exposure times varied across the trials from 3 years in MAP.3^56^ to 5 years in IBIS-I,^81^ Royal Mardsen,^100^ RUTH,^91^ and IBIS-II.^17^ No studies specifically compared shorter versus longer regimens. Despite these variations, comparisons across similar medications indicate general consistency in risk reduction for invasive breast cancer. Among the four tamoxifen placebo-controlled trials, risk reduction was similar regardless of exposures of 4 (NSABP P-1,^90^ Italian^106^) or 5 years (IBIS-I,^81^ Royal Marsden^100^). Notably, the tamoxifen trial with the shortest mean exposure time resulted in the largest risk reduction (NSABP P-1 RR 0.57; 95% CI, 0.46 to 0.70).^90^ Slight differences between risk reduction estimates across the trials may relate to additional factors leading to heterogeneity in addition to duration of use, especially variations in participant eligibility criteria.

## Key Question 2b Does the Effectiveness of Risk-Reducing Medications Persist Beyond Discontinuation of Use?

The IBIS-I^81^ and Royal Marsden^100^ trials provided results for invasive and ER+ breast cancer for both active treatment (mean duration 5 years) and posttreatment periods (median followup 13 and 16 years, respectively). These results indicate continued risk reduction after discontinuation of tamoxifen, providing point estimates of even larger reductions in invasive and ER+ breast cancer during the posttreatment period. For IBIS-I, risk reduction for invasive breast cancer was 0.74 (95% CI, 0.60 to 0.93) for the 0 to 10 year followup period, and 0.70 (95% CI, 0.52 to 0.95) for the greater than 10 year followup period,^17^ although the difference between periods was not statistically significant.

## Key Question 3 What Are the Harms of Using Medications to Reduce Risk for Primary Breast Cancer?

### Summary

Raloxifene caused fewer thromboembolic events (RR 0.75; 95% CI, 0.60 to 0.93) than tamoxifen in the STAR head-to-head trial, comparable to 4 (1 to 7) fewer events per 1000 women over 5 years of use. Tamoxifen (RR 1.93; 95% CI, 1.33 to 2.68; 4 trials) and raloxifene (RR 1.56; 95% CI, 1.11 to 2.60; 2 trials) increased thromboembolic events compared with placebo, while aromatase inhibitors did not. These estimates are comparable to 5 (2 to 9) more events per 1000 women over 5 years of use for tamoxifen and 7 (0.3 to 17) for raloxifene. Tamoxifen, raloxifene, and aromatase inhibitors did not increase coronary heart disease events or strokes.

In the STAR head-to-head trial, raloxifene caused fewer cases of endometrial cancer (RR 0.55; 95% CI, 0.36 to 0.83) and endometrial hyperplasia (RR 0.19; 95% CI, 0.12 to 0.29), and fewer hysterectomies (RR 0.45; 95% CI, 0.37 to 0.54) than tamoxifen. Tamoxifen increased endometrial cancer compared with placebo (RR 2.25; 95% CI, 1.17 to 4.41; 3 trials); while risks for endometrial cancer were not increased with raloxifene and aromatase inhibitors.

Raloxifene caused fewer cataracts (RR 0.80; 95% CI, 0.72 to 0.95) and cataract surgeries (RR 0.79; 95% CI, 0.70 to 0.90) than tamoxifen in the STAR head-to-head trial. Tamoxifen increased cataracts compared with placebo (RR 1.22; 95% CI, 1.08 to 1.48; 3 trials). Raloxifene and aromatase inhibitors did not increase risks for cataracts or cataract surgery in trials.

In head-to-head comparisons, women using raloxifene reported more musculoskeletal problems, dyspareunia, and weight gain, while those using tamoxifen had more gynecological problems, vasomotor symptoms, leg cramps, and bladder control symptoms. Compared with placebo, the most commonly reported side effects for tamoxifen were hot flashes and other vasomotor symptoms, vaginal discharge, and other vaginal symptoms such as itching or dryness; for raloxifene, vasomotor symptoms and leg cramps; and for aromatase inhibitors, arthralgia, carpal tunnel syndrome, joint stiffness, vasomotor symptoms, dry eyes, and hypertension.

### Evidence

A total of 22 studies (in 54 publications) met inclusion criteria for Key Question 3 including eight new publications and 46 cited in the prior review. The new publications include updated long-term results of the IBIS-I trial of tamoxifen,^82^ a placebo-controlled trial of low-dose tamoxifen,^53^ and placebo-controlled trials of anastrozole^17,102,105^ and exemestane.^56,99^ Details of studies are provided in Tables 3, 7, and Appendix B3.

Table 7 Methods of Followup for Adverse Events in Trials

Trial | References | Methods
Tamoxifen (20 mg/day) vs. raloxifene (60 mg/day)
Study of Tamoxifen and Raloxifene (STAR) | Vogel, 2006; Land, 2006; Vogel, 2010 | Participants were followed every 6 months for 5 years and annually thereafter. Gynecologic examinations, complete blood counts, and routine serum chemistry tests were obtained annually. Information about the occurrence of all protocol-defined endpoints (endometrial cancer, cardiovascular disease, stroke, pulmonary embolism, deep vein thrombosis, transient ischemic attack, osteoporotic fracture, cataracts, death, quality of life, other cancers) was ascertained at each followup visit and verified by reviewing medical records. Self-reported symptoms were also collected at each visit.
Tamoxifen (20 mg/day) vs. placebo
International Breast Cancer Intervention Study (IBIS-I) | IBIS, 2002; Cuzick, 2007; 2015 | Adverse effects were assessed using a checklist of predefined outcomes with a free text field. These included myocardial infarction, cardiovascular disease events, thromboembolic events, osteoporotic fractures, any non-breast cancer, nausea, vomiting, hot flushes, headaches, vaginal discharge, vaginal dryness, and vaginal bleeding. During the active treatment phase, these questions were asked directly to participants, while during the followup phase, a less detailed version of the checklist was mailed to participants. For postal replies, adverse outcomes were confirmed by medical record review. Approximately 85% of women returned at least one questionnaire during followup.
National Surgical Adjuvant Breast and Bowel Project P-1 Study (NSABP-1) | Fisher, 1998; 2005; Day, 2001; Brisson, 2000; Chalas, 2005; Abramson, 2006 | Adverse effects were documented by using a global index modeled after the Women’s Health Initiative. Followup visits occurred at 3 and 6 months, and then every 6 months thereafter. Endometrial cancer and thromboembolic events were considered secondary end points. Gynecologic symptoms of hot flashes, vaginal discharge, vaginal dryness, and abnormal vaginal bleeding were monitored, and clinical sites reported additional uterine and ovarian disorders and gynecologic procedures. Medical records for participants with suspected cardiovascular disease events were collected by the clinical sites and adjudicated by investigators blinded to treatment assignment.
Royal Marsden Hospital Trial | Powles, 1998; 2007 | Followup visits occurred every 6 months during the course of the trial and acute toxicity and other conditions were assessed at each visit. Further details of the followup procedures for adverse effects were not reported.
Italian Tamoxifen Prevention Study | Veronesi, 1998; 2003; 2007; Decensi, 2005; Bruno, 2005 | Adverse effects were evaluated at visits and physical examinations every 6 months. After completion of treatment, or in the case of dropouts, women were followed on an annual basis, although only adverse events that occurred during study treatment were reported. Information about major endpoints, such as death, serious adverse events, or cancer, was collected and submitted to the data center. Secondary endpoints included cardiovascular disease, psychological measures, and cognitive function. Surveillance for onset of acute or chronic liver injury based on blood levels of transaminases was also included.
Tamoxifen (5 mg/day) vs. placebo
Hormone replacement therapy Opposed by low-dose Tamoxifen (HOT) study | DeCensi, 2013 | Clinical examinations were repeated every 6 months during treatment. Transvaginal ultrasounds were obtained at baseline and repeated if atypical bleeding was reported, followed by hysteroscopy if clinically indicated. Clinical visits were repeated annually up to 10 years during the followup period, although he details of the visits were not specified.
Raloxifene (60 or 120 mg/day) vs. placebo
Multiple Outcomes of Raloxifene Evaluation (MORE) and Continuing Outcomes Relevant to Evista (CORE) | Ettinger, 1999; Cummings, 1999; Cauley, 2001; Barrett-Connor, 2002; Delmas, 2002; 2003; Grady, 2004; Grady, 2010; Barrett-Connor, 2004; Silverman, 2004; Johnell, 2004; Martino, 2005; Duvernoy, 2005; Keech, 2005; Siris, 2005; Lippman, 2006 | Participants were followed every 6 months in the MORE trial and were queried about potential adverse effects at every visit. Fasting plasma glucose levels were evaluated annually. Endometrial changes were monitored with transvaginal ultrasound, however some of the 17 centers only performed transvaginal ultrasound on a subset of women. Three physicians who were blinded to treatment assignment (the outcome adjudication panel) reviewed medical records of any patient with a reported case of endometrial cancer to confirm the diagnosis.
Raloxifene Use for the Heart (RUTH) | Barrett-Connor, 2006; Grady, 2008; Ensrud, 2008 | Participants reported adverse events every 6 months at either a visit or by a telephone call. Electrocardiograms were performed at baseline, years 2 and 4, and the final visit. Serum lipids were measured at baseline, years 1 and 5, and the final visit. Committees of experts blinded to treatment assignment adjudicated coronary events, breast cancer, stroke, thromboembolism, and death outcomes.
Anastrozole (1 mg/day) vs. placebo
International Breast cancer Intervention Study II (IBIS-II) | Cuzick, 2014; Sestak, 2014; Spagnolo, 2016 | Secondary end points included other cancer, cardiovascular disease, fractures, adverse events, and deaths. Participants had clinical visits at baseline, 6 months, 12 months, and annually until the 5-year visit. Followup after 5 years varied and included clinic visits, annual questionnaires, and record linkage systems in the United Kingdom.
Exemestane (25 mg/day) vs. placebo
Mammary Prevention.3 trial (MAP.3) | Goss, 2011; Maunsell, 2014 | Secondary end points included adverse cardiovascular events, incidence of other cancer, side effect profile and safety, and health-related and menopause-specific qualities of life. Clinical assessments occurred at 6 and 12 months after randomization and then yearly during the trial. These included physical examinations, symptoms, adverse events, and quality of life assessments. Safety data across study sites were reviewed every 6 months by an independent data and safety monitoring committee.

For tamoxifen, information on adverse effects was confined to the five large placebo controlled primary prevention trials,^53–55,58,59,76,77,79,81–84,90,100,106,107^ and the STAR head-to-head trial.^61,96,101,123^ No other randomized controlled trials or observational studies evaluated adverse effects of tamoxifen in women without breast cancer. Trials ascertained and reported adverse effects in different ways, although most evaluated them at clinic visits using either self or staff administered questionnaires and checklists. The HOT trial of low-dose tamoxifen indicated no statistically significant differences in outcomes compared with placebo and was not included in the meta-analyses of tamoxifen trials discussed in this section.^53^

For raloxifene, adverse effects were reported from the two large placebo-controlled trials, MORE/CORE and RUTH,^60,74,75,78,80,85–89,91,93–95,97,98,103,104^ the STAR head-to-head trial,^61,96,123^ eight smaller trials (in 11 publications) evaluating either bone density, biochemical profiles, or fractures (Appendix B3),^63–72,127^ and one observational study.^62^ Of the smaller raloxifene trials, six reported thromboembolic events;^65–67,69,70,72^ four uterine outcomes;^63,64,67,68^ one urinary outcomes;^127^ one cognitive function;^71^ and none reported cardiovascular events. The most commonly reported adverse events were hot flashes and vasomotor symptoms reported in eight trials.^64–66,68–72^ The one observational study evaluated the effect of raloxifene on vaginal bleeding and endometrial thickness.^62^ These studies contribute little to the evaluation of harms because they involve so few women relative to the large primary prevention trials, although they are generally consistent with the results of the larger trials. Consequently, they were not included in the meta-analyses of raloxifene trials discussed in this section.

For anastrozole and exemestane, information on adverse effects was confined to the two large placebo-controlled primary prevention trials.^17,56^ Similar to tamoxifen, no other RCT or observational studies evaluated adverse effects of aromatase inhibitors in women without breast cancer.

#### Thromboembolic Events

Tamoxifen versus raloxifene. In the STAR trial, raloxifene caused fewer thromboembolic events (DVT + PE) than tamoxifen (RR 0.75; 95% CI, 0.60 to 0.93), comparable to 4 (1 to 7) fewer events per 1000 women over 5 years of use (Table 5).^123^ Separate estimates for DVT (RR 0.72; 95% CI, 0.54 to 0.95), and PE (RR 0.80; 95% CI, 0.57 to 1.11) indicated reduced events with raloxifene.^123^

Tamoxifen versus placebo. The four tamoxifen prevention trials identified thromboembolic complications as an adverse effect of active treatment, although the definition of this outcome varied by trial.^58,81,84,100^ All trials included DVT and PE outcomes, the IBIS-I trial also included superficial thrombophlebitis and retinal vein thrombosis,^81^ and the Italian trial included visceral, retinal, and superficial thrombophlebitis.^84^ All of these trials excluded women with either a history of prior thromboembolic events or one within 10 years prior to study enrollment.

Active treatment with tamoxifen increased composite measures of thromboembolic events in all four prevention trials resulting in a RR of 1.93 (95% CI, 1.33 to 2.68; 4 trials; Figure 11),^58,81,84,100^ comparable to 5 (2 to 9) more events with tamoxifen per 1000 women over 5 years of use. The IBIS-I^82^ and Royal Marsden^100^ trials provided results for both active and posttreatment periods indicating no increased risk after discontinuation of active treatment (RR 0.98; 95% CI, 0.48 to 1.80; 2 trials; Figure 11).

Figure 11 Meta-Analysis of Trials: Venous Thromboembolism

* Per 1,000 women-years.

^†^ For tamoxifen and IBIS-II trials, venous thromboembolic events include deep-vein thrombosis (DVT) and pulmonary embolism (PE) only. For other trials, other events such as retinal vein thrombosis may be included, depending on the reported overall category.

^‡^ Events were reported from at least 3 months after treatment was stopped until the end of followup.

Abbreviations: CI=confidence interval; DVT=deep vein thrombosis; HOT=Hormone replaced therapy Opposed by low-dose Tamoxifen study; IBIS-I=International Breast Cancer Intervention Study; IBIS-II=International Breast Cancer Intervention Study II; MAP.3=Mammary Prevention.3 trial; MORE=Multiple Outcomes of Raloxifene; N=number; NR=not reported; NSABP-1=National Surgical Adjuvant Breast and Bowel Project P-1 study; PE=pulmonary embolism; RUTH=Raloxifene Use for the Heart.

Figure 11 is a forest plot of studies reporting the risk ratio of venous thromboembolism stratified by type of medication. Data for Figure 11 are presented in Appendix B3. In one tamoxifen trial, the risk ratio was 2.02 (95% CI, 0.29 to 22.4). In four tamoxifen active treatment trials the combined risk ratio was 1.93 (95% CI, 1.33 to 2.68). In two tamoxifen posttreatment trials the combined risk ratio was 0.98 (95% CI, 0.48 to 1.80). In two raloxifene trials the combined risk ratio was 1.56 (95% CI, 1.11 to 2.60). In two aromatase inhibitor trials the combined risk ratio was 1.24 (95% CI, 0.65 to 2.61).

Only the NSABP P-1^58^ and Italian trials^84^ evaluated DVT and PE separately. In the NSABP P-1 trial, tamoxifen increased risks for PE (RR 3.01; 95% CI, 1.15 to 9.27); but risk was not statistically significantly increased for DVT (RR 1.60; 95% CI, 0. 91 to 2.86).^58^ In the Italian trial, risks were not elevated.^84^ Combining results, RRs are 2.69 (95% CI, 0.54 to 8.13; 2 trials) for PE and 1.45 (95% CI, 0.73 to 2.59; 2 trials) for DVT (Figure 12).

Figure 12 Meta-Analysis of Trials: Deep Vein Thrombosis, Pulmonary Embolism, and Superficial Phlebitis

* Per 1,000 women-years.

Abbreviations: CI=confidence interval; DVT=deep vein thrombosis; IBIS-I=International Breast Cancer Intervention Study; IBIS-II=International Breast Cancer Intervention Study II; MORE=Multiple Outcomes of Raloxifene; N=number; NR=not reported; NSABP-1=National Surgical Adjuvant Breast and Bowel Project P-1 study; PE=pulmonary embolism; RUTH=Raloxifene Use for the Heart.

Figure 12 is a forest plot of studies reporting the risk ratio of deep vein thrombosis, pulmonary embolism, and superficial phlebitis stratified by type of medication. Data for Figure 12 are presented in Appendix B3. In two tamoxifen active treatment trials, the combined risk ratio of deep vein thrombosis was 1.45 (95% CI, 0.73 to 2.59). In two raloxifene trials the combined risk ratio of deep vein thrombosis was 1.66 (95% CI, 0.79 to 5.14). In two tamoxifen active treatment trials, the combined risk ratio of pulmonary embolism was 2.69 (95% CI, 0.54 to 8.13). In two raloxifene trials, the combined risk ratio of pulmonary embolism was 2.11 (95% CI, 0.82 to 6.12). In two tamoxifen active treatment trials, the combined risk ratio of superficial phlebitis was 2.14 (95% CI, 1.17 to 4.42). In one tamoxifen posttreatment trial, the risk ratio of superficial phlebitis was 1.43 (95% CI, 0.39 to 5.71). In one aromatase inhibitor trial, the combined risk ratio of superficial phlebitis was 1.13 (95% CI, 0.59 to 2.17).

Tamoxifen increased superficial thrombophlebitis in the Italian (RR 1.96; 1.10 to 3.51)^84^ and IBIS-I trials (RR 2.84; 95% CI, 1.07 to 8.78),^81^ with a combined RR of 2.14 (95% CI, 1.17 to 4.42; 2 trials; Figure 12). The Italian trial also reported one retinal vein thrombosis in each arm of the trial and one visceral thrombosis in the placebo group.^84^

Raloxifene versus placebo. Raloxifene increased thromboembolic events in both the MORE (RR 2.10; 95% CI, 1.20 to 3.80)^93^ and RUTH (RR 1.44; 95% CI, 1.06 to 1.95)^60^ trials. Further analysis of the MORE trial by year of treatment indicated the highest risks during the first 2 years of therapy (RR ≥6 in years 1 and 2 vs. 0.9 in year 4).^93^ Combining results of both trials in a meta-analysis results in a RR of 1.56 (95% CI, 1.11 to 2.60; 2 trials; Table 8 and Figure 11), comparable to 7 (0.3 to 17) more events with raloxifene per 1000 women over 5 years of use.^123^ Both trials also reported elevated risks for PE (combined RR 2.11; 95% CI, 0.82 to 6.12; 2 trials) and DVT separately (combined RR 1.66; 95% CI, 0.79 to 5.14; 2 trials; Figure 12) that did not reach statistical significance.

Table 8 Meta-Analysis of Results of Placebo-Controlled Trials—Relative and Absolute Effects for Harmful Outcomes

| RR for Tamoxifen vs. Placebo; (95% CI) | Trials, n^*^ | Placebo Rate (±SE)^†^ | Events Reduced or Increased With Tamoxifen (95% CI), n^‡^ | RR for Raloxifene vs. Placebo; (95% CI) | Trials, n^*^ | Placebo Rate (±SE)^†^ | Events Reduced or Increased With Raloxifene (95% CI), n^‡^ | RR for AIs vs. Placebo; (95% CI) | Trials, n^*^ | Placebo Rate (±SE)^†^ | Events Reduced or Increased With AIs (95% CI), n^‡^
Vascular
VTE^∥^ | 1.93; (1.33 to 2.68) | 4 | 0.91 ± 0.19 | 5 (2 to 9) more | 1.56; (1.11 to 2.60) | 2 | 2.34 ± 0.25 | 7 (0.3 to 17) more | 1.24; (0.65 to 2.16) | 2 | – | –
DVT | 1.45; (0.73 to 2.59) | 2 | – | – | 1.66; (0.79 to 5.14) | 2 | – | – | NR | – | – | –
PE | 2.69; (0.54 to 8.13) | 2 | – | – | 2.11; (0.82 to 6.12) | 2 | – | – | NR | – | – | –
CHD events | 1.00; (0.75 to 1.30) | 4 | – | – | 0.95; (0.80 to 1.10) | 2 | – | – | 0.76; (0.41 to 1.49) | 2 | – | –
Stroke | 1.36; (0.78 to 2.20) | 4 | – | – | 1.04; (0.64 to 1.36) | 2 | – | – | 0.98; (0.27 to 2.56) | 2 | – | –
Other
Endometrial cancer | 2.25; (1.17 to 4.41) | 3 | 0.62 ± 0.10 | 4 (1 to 8) more | 1.14; (0.54 to 2.17) | 2 | – | – | 0.60; (0.09 to 3.07) | 1 | – | –
Cataracts | 1.22; (1.08 to 1.48) | 3 | 22.85 ± 0.75^¶^ | 26 (5 to 50) more | 0.93; (0.82 to 1.06) | 2 | – | – | 0.94; (0.70 to 1.27) | 1 | – | –

* Number of trials included in meta-analysis.

† Per 1000 women, estimated from a meta-analysis of rates from the placebo groups from the same trials included in the RRs.

‡ Number of events reduced for benefits or increased for harms compared with placebo per 1000 women assuming 5 years of use.

∥ Includes DVT and PE.

¶ The placebo rate was from NSABP P-1, 2005.^90^

Abbreviations: AI=aromatase inhibitors; CHD=coronary heart disease; CI=confidence interval; DVT=deep vein thrombosis; n=number; NR=not reported; NSABP=National Surgical Adjuvant Breast and Bowel Project; PE=pulmonary embolism; RR=risk ratio; SE=standard error; VTE=venous thromboembolism.

Aromatase inhibitors versus placebo. In contrast to tamoxifen and raloxifene, anastrozole^17^ and exemestane^56^ did not increase thromboembolic events compared with placebo (RR 1.24; 0.65 to 2.61; 2 trials; Table 8 and Figure 11). The aromatase inhibitor trials did not report DVT or PE separately; risk for superficial thrombophlebitis was not increased in IBIS-II.^17^

#### Cardiovascular Events

Tamoxifen versus raloxifene. The STAR trial reported no differences between raloxifene and tamoxifen for a composite measure of ischemic coronary heart disease events (RR 1.10; 95% CI, 0.85 to 1.43; Table 5).^61^ Specific events, such as myocardial infarction, severe angina, and acute ischemic syndrome, were also not significantly different between medications.^61^ Stroke and transient ischemic attacks were also similar for raloxifene and tamoxifen in STAR (RR 0.96; 95% CI, 0.64 to 1.43 and 1.21; 95% CI, 0.79 to 1.88, respectively; Table 5).^61^

Tamoxifen versus placebo. Although the four prevention trials evaluated cardiovascular events,^58,81,84,100^ definitions of outcomes, and the quality and detail of reporting varied across trials. Only the Italian trial indicated that they excluded women with a history of cardiovascular disease other than stable angina.^84^

The NSABP P-1 trial provided the most detailed information on cardiovascular outcomes, although it did not explicitly describe how these events were defined or adjudicated.^58^ In this trial, rates of a composite measure of coronary heart disease, myocardial infarction, acute coronary syndrome, and severe angina were similar for tamoxifen and placebo.^58^ The IBIS-I trial reported no increase in a composite measure of “all cardiac problems,” including myocardial infarction, angina and other cardiac problems, as well as myocardial infarction specifically for both active treatment and posttreatment periods.^81^ Definitions for these outcomes were not provided. The Italian trial indicated no increase in myocardial infarction but identified an elevated rate of atrial fibrillation (RR 1.73; 95% CI, 1.02 to 2.98) among women randomized to tamoxifen,^106^ however, this is the only trial reporting atrial fibrillation specifically. The Royal Marsden trial reported no differences in “cardiovascular problems.”^100^

Since tamoxifen showed no differential effects on multiple specific coronary heart disease outcomes, results of composite measures of coronary heart disease were combined in meta-analysis, resulting in a summary RR of 1.00 (95% CI, 0.75 to 1.30; 4 trials; Table 8 and Figure 13).^58,81,100,106^ The combined RR for myocardial infarction specifically is 1.01 (95% CI, 0.45 to 1.70; 3 trials; Figure 14).^58,81,106^

Figure 13 Meta-Analysis of Trials: Coronary Heart Disease

* Per 1,000 women-years.

^†^ CHD events includes any reported coronary heart disease, such as myocardial infarction, angina, acute ischemic syndrome and other CHD events.

Abbreviations: CHD=coronary heart disease; CI=confidence interval; HOT=Hormone replaced therapy Opposed by low-dose Tamoxifen study; IBIS-I=International Breast Cancer Intervention Study; IBIS-II=International Breast Cancer Intervention Study II; MAP.3=Mammary Prevention.3 trial; MORE=Multiple Outcomes of Raloxifene; N=number; NR=not reported; NSABP-1=National Surgical Adjuvant Breast and Bowel Project P-1 study; RUTH=Raloxifene Use for the Heart.

Figure 13 is a forest plot of studies reporting the risk ratio of coronary heart disease stratified by type of medication. Data for Figure 13 are presented in Appendix B3. In one tamoxifen trial, the risk ratio was 0.67 (95% CI, 0.14 to 2.84). In four tamoxifen active treatment trials, the combined risk ratio was 1.00 (95% CI, 0.75 to 1.30). In two tamoxifen posttreatment trials, the combined risk ratio was 0.93 (95% CI, 0.58 to 1.34). In two raloxifene trials, the combined risk ratio was 0.95 (95% CI, 0.80 to 1.10). In two aromatase inhibitor trials, the combined risk ratio was 0.76 (95% CI, 0.41 to 1.49).

Figure 14 Meta-Analysis of Trials: Myocardial Infarction

* Per 1,000 women-years.

Abbreviations: CI=confidence interval; HOT=Hormone replaced therapy Opposed by low-dose Tamoxifen study; IBIS-I=International Breast Cancer Intervention Study; MAP.3=Mammary Prevention.3 trial; N=number; NSABP-1=National Surgical Adjuvant Breast and Bowel Project P-1 study; RUTH=Raloxifene Use for the Heart.

Figure 14 is a forest plot of studies reporting the risk ratio of myocardial infarction stratified by type of medication. Data for Figure 14 are presented in Appendix B3. In one tamoxifen trial, the risk ratio was 3.04 (95% CI, 0.24 to 159.3). In three tamoxifen active treatment trials, the combined risk ratio was 1.01 (95% CI, 0.45 to 1.70). In one tamoxifen posttreatment trial, the risk ratio was 1.12 (95% CI, 0.43 to 2.95). In one raloxifene trial, the risk ratio was 0.87 (95% CI, 0.71 to 1.06). In one aromatase inhibitor trial, the risk ratio was 1.00 (95% CI, 0.19 to 5.39).

All four prevention trials evaluated stroke outcomes, and stroke was a predefined outcome in the IBIS-I trial. None of the trials indicated how stroke was defined or whether it was adjudicated. Tamoxifen did not increase stroke in either the active or posttreatment periods of the Royal Marsden^100^ and IBIS-I^82^ trials. The Italian^106^ and NSABP P-1^58^ trials reported elevated RRs for stroke during active treatment that did not reach statistical significance. In meta-analysis, the combined RR for stroke is 1.36 (95% CI, 0.78 to 2.20; 4 trials; Table 8 and Figure 15). After discontinuation of treatment in the IBIS-I^81^ and Royal Marsden^100^ trials, tamoxifen had no effect on stroke (RR 0.92; 95% CI, 0.25 to 2.09; 2 trials; Figure 15).

Figure 15 Meta-Analysis of Trials: Stroke

* Per 1,000 women-years.

^†^ Events were reported from at least 3 months after treatment was stopped until the end of followup.

^‡^ MAP3. trial reported cerebrovascular events including both stroke and transient ischemic attack.

Abbreviations: CI=confidence interval; HOT=Hormone replaced therapy Opposed by low-dose Tamoxifen study; IBIS-I=International Breast Cancer Intervention Study; IBIS-II=International Breast Cancer Intervention Study II; MAP.3=Mammary Prevention.3 trial; MORE=Multiple Outcomes of Raloxifene; N=number; NR=not reported; NSABP-1=National Surgical Adjuvant Breast and Bowel Project P-1 study; RUTH=Raloxifene Use for the Heart.

Figure 15 is a forest plot of studies reporting the risk ratio of stroke stratified by type of medication. Data for Figure 15 are presented in Appendix B3. In one tamoxifen trial, the risk ratio was 0.51 (95% CI, 0.01 to 9.72). In four tamoxifen active treatment trials, the combined risk ratio was 1.36 (95% CI, 0.78 to 2.20). In two tamoxifen posttreatment trials, the combined risk ratio was 0.92 (95% CI, 0.25 to 2.09). In two raloxifene trials, the combined risk ratio was 1.04 (95% CI, 0.64 to 1.36). In two aromatase inhibitor trials, the combined risk ratio was 0.98 (95% CI, 0.27 to 2.56).

Tamoxifen did not increase risk for transient ischemic attack in the trials evaluating this outcome (RR 0.77; 95% CI, 0.42 to 1.42; 3 trials; Figure 16).^58,81,106^

Figure 16 Meta-Analysis of Trials: Transient Ischemic Attack

* Per 1,000 women-years.

Abbreviations: CI=confidence interval; HOT=Hormone replaced therapy Opposed by low-dose Tamoxifen study; IBIS-I=International Breast Cancer Intervention Study; N=number; NSABP-1=National Surgical Adjuvant Breast and Bowel Project P-1 study.

Figure 16 is a forest plot of studies reporting the risk ratio of transient ischemic attack stratified by type of medication. Data for Figure 16 are presented in Appendix B3. In three tamoxifen active treatment trials, the combined risk ratio was 0.77 (95% CI, 0.42 to 1.42). In one tamoxifen posttreatment trial, the risk ratio was 0.76 (95% CI, 0.42 to 1.34).

Raloxifene versus placebo. Cardiovascular outcomes were extensively evaluated in the MORE and RUTH trials.^60,75^ In the MORE trial, raloxifene did not increase risk for a composite measure of coronary heart disease, including myocardial infarction, coronary death, silent myocardial infarction, sudden death, unstable angina, coronary ischemia, and acute coronary syndrome (RR 0.92; 95% CI, 0.66 to 1.27).^75^ Results using a more narrow definition of coronary heart disease events, including coronary death, myocardial infarction, and unstable angina, were similar between raloxifene and placebo. Followup in the CORE trial also showed no relationship between the use of raloxifene for 8 years and major cardiovascular events (HR 1.16; 95% CI, 0.86 to 1.56) or coronary events (RR 1.22; 95% CI, 0.82 to 1.83).^88^ The RUTH trial was designed to determine whether raloxifene prevented coronary heart disease among women at high-risk for heart disease or with existing heart disease. In RUTH, raloxifene showed no benefit in reducing composite coronary heart disease outcomes including coronary heart disease death, non-fatal myocardial infarction, and acute coronary syndrome (RR 0.95; 95% CI, 0.84 to 1.07) or myocardial infarction specifically.^60^ Combining coronary heart disease composite measures from MORE and RUTH provides a RR of 0.95 (95% CI, 0.80 to 1.10; 2 trials; Figure 13).

Raloxifene did not increase risk of stroke in the MORE^75^ or RUTH^60^ trials (RR 1.04; 95% CI, 0.64 to 1.36; 2 trials; Figure 15). In CORE, raloxifene did not increase risk of stroke after 8 years of followup.^88^ None of the raloxifene trials evaluated transient ischemic attacks.

Aromatase inhibitors versus placebo. Anastrozole^17^ and exemestane^56^ showed no differences compared with placebo for coronary heart disease events (combined RR 0.76; 95% CI, 0.41 to 1.49; 2 trials; Figure 13) or stroke (combined RR 0.98; 95% CI, 0.27 to 2.56; 2 trials; Figure 15).

#### Genitourinary Outcomes

Tamoxifen versus raloxifene. Raloxifene caused fewer cases of endometrial cancer (RR 0.55; 95% CI, 0.36 to 0.83) than tamoxifen, comparable to 5 (2 to 9) more cases with tamoxifen per 1000 women over 5 years of use^123^ (Table 5). Raloxifene was also associated with less endometrial hyperplasia (RR 0.16; 95% CI, 0.09 to 0.29) and fewer hysterectomies (RR 0.44; 95% CI, 0.35 to 0.56) than tamoxifen.

Tamoxifen versus placebo. Three prevention trials reported data on endometrial cancer;^58,81,100^ the Italian trial included only women with prior hysterectomies.^55^ Trials evaluated endometrial changes in different ways. The Royal Marsden trial evaluated endometrial thickness with ultrasound, although the protocol was not reported.^128^ The IBIS-I trial included endometrial cancer as a predefined outcome. The NSABP P-1 trial included endometrial sampling prior to randomization for women enrolled later in the trial,^58^ and monitored gynecologic conditions and procedures during the course of the trial.^79^

All three trials reported increased risks for endometrial cancer with tamoxifen, although only results from the NSABP P-1 trial reached statistical significance (RR 3.28; 95% CI, 1.87 to 6.03).^58,90^ Combining results from the three trials provides a RR of 2.25 (95% CI, 1.17 to 4.41; 3 trials; Table 8 and Figure 17), comparable to 4 (1 to 8) more events with tamoxifen per 1000 women over 5 years of use.^90,100,123^

Figure 17 Meta-Analysis of Trials: Endometrial Cancer

* Per 1,000 women-years, based on number of women with an intact uterus.

^†^ The number of women at risk (non-hysterectomized) was not reported and risk ratio is calculated based on the number of randomized subjects at baseline.

Abbreviations: CI=confidence interval; CORE=Continuing Outcomes Relevant to Evista; HOT=Hormone replaced therapy Opposed by low-dose Tamoxifen study; IBIS-I=International Breast Cancer Intervention Study; IBIS-II=International Breast Cancer Intervention Study II; MORE=Multiple Outcomes of Raloxifene; N=number; NR=not reported; NSABP-1=National Surgical Adjuvant Breast and Bowel Project P-1 study; RUTH=Raloxifene Use for the Heart.

Figure 17 is a forest plot of studies reporting the risk ratio of endometrial cancer stratified by type of medication. Data for Figure 17 are presented in Appendix B3. In one tamoxifen trial, the risk ratio was 0.34 (95% CI, 0.01 to 4.20). In three tamoxifen trials, the combined risk ratio was 2.25 (95% CI, 1.17 to 4.41). In two raloxifene trials, the combined risk ratio was 1.14 (95% CI, 0.54 to 2.17). In one aromatase inhibitor trial, the risk ratio was 0.60 (95% CI, 0.09 to 3.07).

In the NSABP P-1 trial, tamoxifen increased rates of endometrial hyperplasia without atypia (RR 2.06; 95% CI, 1.64 to 2.60)^79^ and other benign gynecologic conditions for both pre and postmenopausal women. For premenopausal women, these included endometrial polyps (RR 1.9; 95% CI, 1.55 to 2.41), leiomyomas (RR 1.3; 95% CI, 1.14 to 1.55), endometriosis (RR 1.9; 95% CI, 1.35 to 2.70), and ovarian cysts (RR 1.5; 95% CI, 1.2 to 1.78), as well as gynecologic surgical procedures including hysterectomy (RR 1.6; 95% CI, 1.88 to 11.29).^79^ For postmenopausal women, these included endometrial polyps (RR 2.4; 95% CI, 1.65 to 3.24), leiomyomas (RR 1.4; 95% CI, 1.04 to 1.80), endometriosis (RR 1.9; 95% CI, 1.29 to 5.58), and gynecologic procedures (RR 2.2; 95% CI, 1.6 to 3.13).^79^ Tamoxifen had similar effects in the IBIS-I trial increasing rates of gynecologic procedures including hysterectomy, abnormal bleeding, endometrial polyps, and ovarian cysts.^54^ Tamoxifen was associated with higher rates of hysterectomy than placebo in the Royal Marsden trial (177 vs. 96 per 1000 women years, respectively; p<0.001).^100^ None of the tamoxifen trials reported rates of ovarian cancer.

Tamoxifen increased vaginal symptoms, including dryness, discharge, and other types, in all of the prevention trials.^58,81,100,106^ Over twice as many women using tamoxifen versus placebo reported vaginal discharge (p<0.001) or vaginal symptoms (p=0.008) in the Royal Marsden trial.^100^ In the NSABP P-1 trial, 13 percent of women taking placebo and 29 percent taking tamoxifen reported vaginal discharge that was at least moderately bothersome.^58^ Tamoxifen increased risks for vaginal dryness (RR 1.14; 95% CI, 0.97 to 1.34) and discharge (RR 3.44; 95% CI, 2.9 to 4.09) in the Italian trial.^106^ Tamoxifen increased symptoms of cystitis and incontinence in the Italian trial (RR 1.52; 95% CI, 1.23 to 1.89),^106^ but not similar symptoms during and after active treatment in the Royal Marsden trial.^100^

Raloxifene versus placebo. The raloxifene trials differed in their methods of ascertaining endometrial cancer outcomes. In the MORE trial, 17 clinical centers performed annual transvaginal ultrasonography in all participants with a uterus, carefully monitoring uterine pathology.^93^ In the RUTH trial, endometrial cancer was determined on the basis of unsolicited reporting by the participant.^60^ In neither trial were the risks of endometrial cancer elevated (combined RR 1.14; 95% CI, 0.54 to 2.17; 2 trials; Figure 17).^60,93^

Raloxifene increased rates of endometrial cavity fluid, as determined by periodic transvaginal ultrasound in the MORE trial (p<0.009).^78^ Raloxifene did not increase rates of ovarian cancer in RUTH, the only trial reporting this outcome.^60^ Raloxifene increased urinary symptoms in the CORE trial (2.1% raloxifene vs. 1.2% placebo; p=0.041).^57^

Aromatase inhibitors versus placebo. Anastrozole did not increase endometrial cancer compared with placebo (RR 0.60; 95% CI, 0.09 to 3.07) in IBIS-II.^17^ This outcome was not reported in MAP.3.^56^

#### Ophthalmologic Disorders

Tamoxifen versus raloxifene. In the STAR trial, women on raloxifene had fewer cataracts (RR 0.80; 95% CI, 0.72 to 0.95) and cataract surgeries than women on tamoxifen, comparable to 15 (8 to 22) more cases with tamoxifen (Table 5).^123^

Tamoxifen versus placebo. All four prevention trials evaluated ocular outcomes,^58,81,100,106^ although the Italian trial reported data on the composite category of “ophthalmologic diseases.”^106^ None of the trials described how women were evaluated for ophthalmologic outcomes. The NSABP P-1,^58^ Royal Marsden,^100^ and IBIS-I^81^ trials reported increased cataracts with tamoxifen, although results for the IBIS-I trial did not reach statistical significance. The combined RR for cataracts is 1.22 (95% CI, 1.08 to 1.48; 3 trials), comparable to 26 (5 to 50) more events with tamoxifen per 1000 women over 5 years of use (Table 8 and Figure 18).^81,90,100^ Cataract surgery was also more common with tamoxifen in the NSABP-1 trial during the initial (RR 1.57; 95% CI, 1.16 to 2.14)^58^ and followup (RR 1.21; 95% CI, 1.10 to 1.34)^90^ phases.

Figure 18 Meta-Analysis of Trials: Cataracts

* Per 1,000 women-years, based on number of women with an intact uterus.

^†^ The numbers of cataract events are calculated based on the report follow-up women years and the rates of cataract.

Abbreviations: CI=confidence interval; CORE=Continuing Outcomes Relevant to Evista; IBIS-I=International Breast Cancer Intervention Study; IBIS-II=International Breast Cancer Intervention Study II; MORE=Multiple Outcomes of Raloxifene; N=number; NR=not reported; NSABP-1=National Surgical Adjuvant Breast and Bowel Project P-1 study; RUTH=Raloxifene Use for the Heart.

Figure 18 is a forest plot of studies reporting the risk ratio of cataracts stratified by type of medication. Data for Figure 18 are presented in Appendix B3. In three tamoxifen trials, the combined risk ratio was 1.22 (95% CI, 1.08 to 1.48). In two raloxifene trials, the combined risk ratio was 0.93 (95% CI, 0.82 to 1.06). In one aromatase inhibitor trial, the risk ratio was 0.94 (95% CI, 0.70 to 1.27).

Raloxifene versus placebo. Raloxifene did not cause more cataracts than placebo in the MORE and RUTH trials (combined RR 0.93; 95% CI, 0.82 to 1.06; 2 trials; Figure 18).^60,93^

Aromatase inhibitors versus placebo. Anastrozole did not increase cataracts compared with placebo (RR 0.94; 95% CI, 0.70 to 1.27) in IBIS-II.^17^ This outcome was not reported in MAP.3.^56^

#### Other Adverse Effects

Tamoxifen versus raloxifene. In STAR, mean scores on quality of life instruments (health survey, depression scale, sexual questionnaire) did not differ between women using tamoxifen versus raloxifene, except sexual function was slightly better for tamoxifen (odds ratio [OR] 1.22%; 95% CI, 1.01 to 1.46).^96^ Women using raloxifene reported more musculoskeletal problems, dyspareunia, and weight gain, while those using tamoxifen reported more gynecological problems, vasomotor symptoms, leg cramps, and bladder control symptoms.^96^

Tamoxifen versus placebo. Tamoxifen increased vasomotor symptoms in the four prevention trials.^58,81,100,106^ In the Royal Marsden trial, 32 percent of women taking placebo reported hot flashes versus 48 percent of women taking tamoxifen (p<0.001).^100^ In the NSABP P-1 trial, 29 percent of placebo and 46 percent of tamoxifen users reported hot flashes.^58^ Hot flashes were also increased with tamoxifen in the Italian trial (RR 1.78; 95% CI, 1.57 to 2.0).^106^

Two studies from the NSABP P-1 trial evaluated depression and other symptoms and identified no increased depression with tamoxifen.^83,129^ Women randomized to tamoxifen reported 4 percent more sexual side effects than women randomized to placebo, although women on tamoxifen were slightly more sexually active (p=0.031).^129^ Tamoxifen caused weight gain in the Royal Marsden trial,^100^ but not in the Italian trial.^106^ Tamoxifen did not increase headaches in the IBIS-I or Royal Marsden trials.^81,100^

Raloxifene versus placebo. Raloxifene increased vasomotor symptoms in both the MORE and RUTH trials.^60,78^ In MORE, 7 percent of women using placebo, 11 percent using raloxifene 60 mg/day, and 12 percent using raloxifene 120 mg/day reported vasomotor symptoms (p<0.05).^78^ In the RUTH trial, comprised of older women, the rates of vasomotor symptoms were lower in general than in MORE, but higher for women taking raloxifene compared with placebo (8.0 vs. 4.8%, respectively; p<0.001).^60^

Raloxifene caused leg cramps^60,78^ and peripheral edema in the MORE (6.1% placebo vs. 7.1% raloxifene 60 mg vs. 7.9% raloxifene 120 mg; p=0.026)^78^ and RUTH trials (12.1% placebo vs. 14.4% raloxifene; p<0.001).^60^ Influenza syndrome symptoms occurred at a higher rate among women taking raloxifene in MORE (16.2% raloxifene 60 mg vs. 16.7% raloxifene 120 mg vs. 14% placebo),^78^ but not in RUTH.^60^ In RUTH, raloxifene caused joint pain, but had no effect on mood, depression, and anxiety symptoms.^60^

Aromatase inhibitors versus placebo. Anastrozole is associated with increased moderate arthralgia, carpal tunnel syndrome, joint stiffness, vasomotor symptoms, dry eyes, and hypertension.^17^ Exemestane is associated with fatigue, sweating, insomnia, and arthralgia.^56^ Increased menopause-related vasomotor symptoms, sexual symptoms, and pain were more common with exemestane compared with placebo mainly during the first 6 months to 2 years of the study.^99^

## Key Question 3a Do Harms of Risk-Reducing Medications Vary by Timing of Initiation and/or Duration of Use?

The NSABP P-1 tamoxifen placebo-controlled trial suggested higher risks for DVT, PE, and stroke for women aged 50 years and older compared with women younger than 50 years, although results were not statistically significant.^58^ Results of the NSABP P-1 trial also indicated that the risk of thromboembolic events was elevated only during the first 3 years of tamoxifen use.^73^ Age over 60 years was also an important risk factor for venous thrombosis in the Italian trial.^84^ The NSABP P-1 trial found that endometrial cancer was more common among women aged 50 years and older compared with women younger than 50 years (RR 4.01; 95% CI, 1.70 to 10.90 vs. RR 1.21; 95% CI, 0.41 to 3.60; respectively).^58^ Initiation based on time since menopause was not reported.

## Key Question 3b Do Harms of Risk-Reducing Medications Persist Beyond Discontinuation of Use?

### Summary

While tamoxifen increased thromboembolic events compared with placebo in trials, risk returned to normal after discontinuation of tamoxifen in the two trials providing posttreatment data. Risk for endometrial cancer also diminished after discontinuation of tamoxifen.

### Evidence

Long-term followup of the IBIS-I^81^ and Royal Marsden^100^ trials provides results for thromboembolic outcomes for both active treatment (mean duration 5 and 8 years, respectively) and posttreatment periods (median followup 16 and 13 years, respectively). Similar followup results are not available for raloxifene or the aromatase inhibitors. During active treatment, tamoxifen significantly increased venous thromboembolic events compared with placebo (RR 1.93; 95% CI, 1.33 to 2.68; 4 trials).^58,81,84,100^ After discontinuation of tamoxifen, risk returned to normal (RR 0.98; 95% CI, 0.48 to 1.80; 2 trials; Figure 11).^82^

The IBIS-I trial also provided long-term data on risk of endometrial cancer. During the 0 to 5 year followup period, risk increased for tamoxifen compared with placebo (RR 3.76; 95% CI, 1.20 to 15.56), while risk declined after discontinuation (5 to 10 year followup RR 0.64; 95% CI, 0.21 to 1.80; ≥10 year followup RR 1.40; 95% CI, 0.38 to 5.61).^82^

## Key Question 4 How Do Outcomes Vary by Population Subgroups?

### Summary

Trials of risk-reducing medications provide data for specific population subgroups, although outcomes are predominantly confined to breast cancer and most estimates are not statistically significant because of smaller numbers of participants in the comparison groups. Subgroups are based on menopausal status, hysterectomy status, estrogen use, family history of breast cancer, BMI, history of breast abnormalities, predicted breast cancer risk,^61,90,91^ and reproductive factors. No trials reported outcomes by race or ethnic groups.

Tamoxifen and raloxifene had similar effects on breast cancer outcomes regardless of family history of breast cancer in the head-to-head STAR trial. Tamoxifen reduced breast cancer outcomes in subgroups evaluated in placebo-controlled trials based on menopausal status, estrogen use, family history of breast cancer, and history of LCIS or atypical hyperplasia. In the NSABP P-1 trial, cancer rates were highest and risk reduction greatest among women in the highest modified Gail model risk category and among women with prior atypical hyperplasia. Raloxifene reduced breast cancer outcomes in subgroups evaluated in placebo-controlled trials based on age at menarche, parity, age at first live birth, and BMI. Aromatase inhibitors had similar effects regardless of BMI or Gail risk score, but risk reduction was greatest for women with LCIS, ADH, or ALH compared with women without these breast lesions for anastrozole. Estimates from subgroups based on prior estrogen use, family history of breast cancer, and prior hysterectomy or oophorectomy were limited by smaller numbers of participants.

### Evidence

Some trials of risk-reducing medications provide data for population subgroups, although outcomes are predominantly confined to breast cancer (all breast cancer, invasive, and ER+). Data are available for subgroups based on menopausal status,^81,97,100,106^ hysterectomy status,^91^ estrogen use,^81,90,91,97,106^ family history of breast cancer,^61,90,91,97,106^ BMI,^73,91,97^ history of breast abnormalities,^61,90^ predicted breast cancer risk,^61,90,91^ and reproductive factors.^91^ No trials reported outcomes by race or ethnic groups.

#### Menopausal Status

The IBIS-I^81^ and Italian^106^ tamoxifen trials evaluated breast cancer outcomes by menopausal status (pre vs. postmenopausal). Point estimates indicated similar risk reduction with tamoxifen for both pre and postmenopausal women, although results were of borderline statistical significance for postmenopausal women in both trials (Figure 19). In the MORE/CORE studies, raloxifene had less effect on invasive cancer outcomes among women with estradiol levels less than 5 pmol/L (RR 0.52; 95% CI, 0.26 to 1.06) than women with higher levels (5 to 10 pmol/L, RR 0.33; 95% CI, 0.13 to 0.84; >10 pmol/L, RR 0.25; 95% CI, 0.14 to 0.47).^97^

Figure 19 Meta-Analysis of Trials: Menopausal Status

* Per 1,000 women-years.

Abbreviations: CI=confidence interval; ER+=estrogen receptor positive; IBIS-I=International Breast Cancer Intervention Study; N=number.

Figure 19 is a forest plot of studies reporting the risk ratio of breast cancer stratified by type of medication and menopausal status. Data for Figure 19 are presented in Appendix B3. In two tamoxifen trials the combined risk ratio was 0.63 (95% CI, 0.39 to 0.91) for premenopausal women and 0.72 (95% CI, 0.38 to 1.04) for postmenopausal women.

#### Hysterectomy Status

In RUTH, raloxifene did not significantly reduce risk for invasive cancer for women with prior hysterectomies or oophorectomies, while risk reduction was significant in women without these prior surgeries.^91^ However, these differences could reflect the smaller numbers of women in the surgical subgroups.

#### Use of Exogenous Estrogen

The IBIS-I,^81^ Royal Marsden,^100^ Italian,^106^ RUTH,^91^ MORE,^97^ IBIS-II,^17^ and MAP.3^56^ trials evaluated breast cancer outcomes by use of menopausal hormone therapy (estrogen with or without progestin). In the IBIS-I, Royal Marsden, and Italian tamoxifen trials, women were allowed to use hormones during the trial, and use rates varied from 14 percent in the Italian trial^106^ to 40 percent in IBIS-I.^54^ Women in the raloxifene and aromatase inhibitor trials were not allowed to use hormones during the trial and hormone use status represented prior use. For all medications, risk reduction was generally similar for hormone users and nonusers (Figure 20). Differences in point estimates and CIs may reflect the smaller numbers of hormone users in the trials.

Figure 20 Meta-Analysis of Trials: Estrogen Use

* Per 1,000 women-years.

^†^ For tamoxifen trials, hormone replacement therapy (HRT) use refers to HRT use during the trial period only.

For raloxifene and aromatase inhibitor trials, HRT use refers to prior HRT use.

^‡^ The total followup time is averaged over both MORE and CORE for the 7705 participants.

Abbreviations: CI=confidence interval; CORE=Continuing Outcomes Relevant to Evista; ER+=estrogen receptor positive; HOT=Hormone replaced therapy Opposed by low-dose Tamoxifen study; HRT=hormone replacement therapy; IBIS-I=International Breast Cancer Intervention Study; IBIS-II=International Breast Cancer Intervention Study II; MAP.3=Mammary Prevention.3 trial; MORE=Multiple Outcomes of Raloxifene; N=number; NR=not reported; RUTH=Raloxifene Use for the Heart.

Figure 20 is a forest plot of studies reporting the risk ratio of breast cancer stratified by type of medication and use of menopausal hormone replacement therapy (HRT). Data for Figure 20 are presented in Appendix B3. In three tamoxifen trials the combined risk ratio was 0.82 (95% CI, 0.46 to 1.14) for women who used HRT and 0.66 (95% CI, 0.51 to 0.87) for women who did not use HRT. In two raloxifene trials the combined risk ratio was 0.46 (95% CI, 0.16 to 1.30) for women who used HRT and 0.44 (95% CI, 0.27 to 0.73) for women who did not use HRT. In two aromatase inhibitor trials the combined risk ratio was 0.53 (95% CI, 0.21 to 0.97) for women who used HRT and 0.38 (95% CI, 0.21 to 0.68) for women who did not use HRT.

#### Family History of Breast Cancer

The STAR,^61^ Italian,^106^ NSABP P-1,^90^ RUTH,^91^ and MORE^97^ trials evaluated breast cancer outcomes by family history of breast cancer, most commonly referring to the number of first-degree relatives with breast cancer. In STAR, risk estimates for invasive breast cancer did not differ significantly for women using raloxifene compared with tamoxifen in the three family history categories evaluated (0, 1, ≥2), and results were similar across categories.^61^ In the NSABP P-1 tamoxifen trial, risk was reduced for subgroups of women with and without family histories of breast cancer.^90^ In the Italian trial,^106^ risk estimates did not reach statistical significance for subgroups based on family history (Figure 21). The raloxifene trials indicated similar significantly reduced risk estimates for women without family history, while risks for women with family histories were reduced in MORE, but not in RUTH (Figure 21).^91,97^ These results may reflect the smaller numbers of women with positive family history for breast cancer in these trials rather than true medication effects.

Figure 21 Meta-Analysis of Trials: Family History

* Per 1,000 women-years.

^†^ With family history (FH) is defined as having at least one first-degree relative with breast cancer, and otherwise it is without FH.

^‡^ The total followup time is averaged over both MORE and CORE for the 7705 participants.

Abbreviations: CI=confidence interval; CORE=Continuing Outcomes Relevant to Evista; FH=family history; MORE=Multiple Outcomes of Raloxifene; N=number; RUTH=Raloxifene Use for the Heart.

Figure 21 is a forest plot of studies reporting the risk ratio of breast cancer stratified by type of medication and family history of breast cancer. Data for Figure 21 are presented in Appendix B3. For women who did not have a family history of breast cancer, the combined risk ratio was 0.64 (95% CI, 0.42 to 0.94) in two tamoxifen trials and 0.47 (95% CI, 0.32 to 0.70) in two raloxifene trials . For women who had a family history of breast cancer, the risk ratio was 0.58 (95% CI, 0.46 to 0.73) in one tamoxifen trial, 1.43 (95% CI, 0.65 to 3.15) in another tamoxifen trial, 0.11 (95% CI, 0.03 to 0.38) in one raloxifene trial, and 0.89 (95% CI, 0.34 to 2.31) in another raloxifene trial.

#### Body Mass Index

The RUTH and MORE trials evaluated invasive breast cancer by BMI (≤25 vs. >25 kg/m^2^).^91,97^ While MORE indicated similar significantly reduced risk estimates for women with low and high BMI, RUTH reported lower risk estimates for women with high BMI (Figure 22), although estimates were not significantly different. The aromatase inhibitors reduced invasive breast cancer in all BMI groups evaluated in the IBIS-II^17^ and MAP.3^56^ trials (BMI <25, 25 to 30, <30 kg/m^2^; Figure 22).

Figure 22 Meta-Analysis of Trials: Body Mass Index

* Per 1,000 women-years.

^†^ For Grady 2008, total n=2416 for BMI ≤25, and 7655 for BMI > 25.

^‡^ The total followup time is averaged over both MORE and CORE for the 7705 participants.

Abbreviations: BMI=body mass index; CI=confidence interval; CORE=Continuing Outcomes Relevant to Evista; IBIS-II=International Breast Cancer Intervention Study II; MAP.3=Mammary Prevention.3 trial; MORE=Multiple Outcomes of Raloxifene; N=number; NR=not reported; RUTH=Raloxifene Use for the Heart.

Figure 22 is a forest plot of studies reporting the risk ratio of breast cancer stratified by type of medication and body mass index (BMI). In two raloxifene trials the combined risk ratio was 0.47 (95% CI, 0.14 to 1.43) for women with a BMI of 25 or under and 0.43 (95% CI, 0.27 to 0.72) for women with a BMI greater than 25. In two aromatase inhibitor trials the combined risk ratio was 0.41 (95% CI, 0.18 to 0.89) for women with a BMI less than 25, 0.44 (95% CI, 0.20 to 0.85) for women with a BMI between 25 and 30, and 0.46 (95% CI, 0.23 to 0.86) for women with a BMI greater than 30.

A nested case-control analysis of data from the NSABP P-1 trial indicated that increased BMI is associated with higher risk of thromboembolic events among women in both the placebo and control groups (RR 3.69; 95% CI, 2.09 to 6.65).^73^

#### History of Breast Abnormalities

Breast cancer risk reduction was similar regardless of history of LCIS or atypical hyperplasia for tamoxifen and raloxifene in STAR,^61^ tamoxifen in IBIS-I,^81^ and exemestane in MAP.3.^56^ In NSABP P-1, tamoxifen reduced invasive cancer compared with placebo regardless of history of LCIS or atypical hyperplasia, although reduction was greatest among women with prior atypical hyperplasia (RR 0.25; 95% CI, 0.10 to 0.52).^90^ Risk reduction was also greatest for women with LCIS, ADH, or ALH for anastrozole in IBIS-II (HR 0.32; 95% CI, 0.13 to 0.79).^17^

#### Predicted Breast Cancer Risk

In STAR, tamoxifen and raloxifene had similar effects on invasive breast cancer for women in all risk categories determined by the modified Gail model (5-year predicted risk ≤3.00; 3.01 to 5.00; ≥5.01).^61^ In NSABP P-1, tamoxifen reduced risk for invasive cancer compared with placebo for women in all modified Gail model risk categories (5-year predicted risk ≤2.00; 2.01 to 3.00; 3.01 to 5.00, ≥5.01).^90^ Cancer rates were highest and risk reduction greatest among women in the highest risk group in this trial. In RUTH, raloxifene reduced risk for invasive cancer compared with placebo for women in all modified Gail model risk categories (5-year predicted risk ≤2.00; 2.01 to 3.00; 3.01 to 5.00), although results were statistically significant only for the large number of women in the lowest risk group.^91^ Exemestane had similar effects in reducing invasive breast cancer for women with high and low Gail risk scores (≤2.0%; >2.0%).^56^

#### Reproductive Factors

Raloxifene reduced risk for invasive cancer regardless of age at menarche (<11, ≥11 years), parity (0, 1 to 2, ≤3), or age at first live birth (<20, ≥20 years) in the RUTH trial.^91^

## Contextual Question 1 What Are Current Clinician and Patient Attitudes and Practices Regarding Use of Medications to Reduce Risk for Primary Breast Cancer? Do They Vary by Population Subgroups?

### Patient Perspectives

Three systematic reviews examined factors related to patient uptake of risk-reducing medications for breast cancer.^19,116,119^ Although reviews included several of the same studies, each had a different focus. Two reviews used criteria to critically appraise included studies,^19,119^ while the other did not.^116^ Most studies were conducted in the United States or similar countries and are applicable to primary care practice.

Use of risk-reducing medications was 16.3 percent (95% CI, 13.6 to 19.0, I^2^ = 98.9%, p <0.001) in a meta-analysis of 26 studies of women at increased risk for breast cancer and without previous breast cancer diagnosis.^19^ Uptake ranged from 0 to 54.9 percent, with significantly higher uptake in trials (25.2%; 95% CI, 18.3 to 32.2; 13 trials) compared with non-trials (8.7%; 95% CI, 6.6 to 10.9; 13 studies). Uptake was not affected by study location or type of medication (tamoxifen, raloxifene, aromatase inhibitors). Predictors of uptake include having an abnormal breast biopsy, receiving a physician recommendation for medication, and higher clinically assessed or perceived risk for breast cancer, although no factor was consistently associated with uptake across studies. Lower uptake was associated with concerns about adverse effects and contraindications with estrogen. No patient or demographic factors were associated with uptake across studies in this review.

Motivators and barriers to both hypothetical and actual uptake rates in women at increased risk for breast cancer were examined in a systematic review of 31 observational and qualitative studies (Table 9),^116^ including 13 studies not included in the previous review.^19^ Uptake was increased among women who had higher perceived risk of breast cancer, were more worried about breast cancer, had received a recommendation for use from their health care providers, and had a positive perception of drug effectiveness. Barriers to uptake included concerns about side effects, not wanting to take a medication regularly or as a preventive measure, and not wanting a daily reminder of their risk. Four studies demonstrated that women who were better informed of the benefits and risks of tamoxifen were less likely to use it.^130–133^ A study of BRCA1/2 mutation carriers found that women preferred mastectomy or bilateral oophorectomy rather than tamoxifen to reduce their risks for breast cancer.^134^

Table 9 Facilitators and Barriers to Uptake of Risk-Reducing Medications for Breast Cancer

Facilitators | Barriers
Patients
Higher objective or perceived risk of breast cancer | Concern for side effects of medication
Healthcare provider recommendation | Concern for contraindications with estrogen
Knowing others with a good experience with medications | Knowing others with a poor experience with medications
Positive attitude and perception of medication effectiveness | Perception that medication is for treatment and not risk reduction
Higher level of anxiety or worry | Perception that medication is a daily reminder of illness
Abnormal breast biopsy^*^ | Preference for other preventive management such as mastectomy
Enrollment in a trial of risk-reducing medications | Being better informed about benefits and harms of medications
Physicians
More breast cancer diagnoses in clinical practice | Lack of training, experience, or comfort with medications
Perception that benefits of medications outweigh harms | Negative perception of benefit of medications in relation to harms
Patients asking about medications | Perception that patients lack interest in medications
Personal experience with breast cancer in self or a relative | Perception that prescribing medications should be initiated by specialists
Perception that eligibility for medications is easy to determine | Lack of comfort or certainty with identifying women eligible for medications
| Time constraints at visits for discussion of medications

* Including atypical hyperplasia and lobular carcinoma in situ.

A review of similar studies reported findings by hypothetical versus real decisionmaking about the use of risk-reducing medications.^119^ In regression analysis controlling for intervention and breast cancer risk, studies of women making hypothetical decisions reported significantly higher mean uptake (24.7%, 9 studies) compared with studies of real decisions (14.8%, 5 studies), as defined by participants taking tamoxifen and raloxifene or being enrolled in the STAR trial (OR 1.65; 95% CI, 1.26 to 2.16). Uptake varied widely in both settings (real, 0.5 to 51.2%; hypothetical, 5.7 to 60.0%). Notably, mean uptake for real decisions was skewed by one study with high uptake;^135^ the mean rate of uptake among the remaining four studies was 5.8 percent. One study that reported both hypothetical and real uptake rates in the same cohort described rates of 5.7 percent compared with 0.5 percent, respectively.^130^ Studies that included an educational or decision-support intervention had lower mean uptake rates than those that did not in both real (4.1 vs. 31.0%) and hypothetical situations (11.7 vs. 31.2%). Studies of high-risk women making hypothetical decisions demonstrated lower uptake than studies that were not limited to high-risk women (22.3 vs. 29.6%, respectively).

Six recent observational studies not included in systematic reviews reported use of SERMS for breast cancer risk reduction among high-risk women ranging from 5.5 to 54.4 percent.^110,111,114,117,118,120^ Similar to findings from systematic reviews, recurrent themes among individual studies included interest in risk reduction, but concerns about side effects. Notably, a study of high-risk women in Australia (median age 39 years) reported that 87 percent of eligible women (n=168; 95% premenopausal) declined therapy, and of these, 28 percent were not able to provide a specific reason for declining even when probed.^120^

The importance of risk in clinical decisionmaking is supported by several studies. In a study of high-risk women attending a breast center in the United States (n=189; 51.5% postmenopausal; 57.7% white), for every 1 percent increase in 5-year Gail risk score, use of risk-reducing medications (tamoxifen, raloxifene, aromatase inhibitors) increased by 17 percent (RR 1.17; 95% CI, 1.03 to1.33).^117^ Similarly, in a multivariable analysis of high-risk women attending a clinic in the United States (69.1% postmenopausal; 88.5% white), the odds of accepting risk-reducing medications increased 4 percent for every 1 percent increase in lifetime risk.^118^ In addition, odds increased with diagnoses of LCIS (OR 7.65; 95% CI, 1.48 to 39.5) and atypical hyperplasia (OR 2.76; 95% CI, 1.37 to 5.54) in this cohort.^118^ Risk reduction was also the most important factor in hypothetical decisions about medication use in a discrete-choice experiment among 622 women with pathogenic BRCA1/2 mutations in Australia.^114^ However, few women who said they would take a risk-reducing medication in theory (28%) followed through with this decision in practice (5.5%). Reasons for declining medications in this study included the lack of a physician recommendation (52%) and concerns for side effects (39%).

Provider recommendation was the most influential independent factor for risk-reducing medication uptake among predominantly postmenopausal women surveyed in one large U.S. study (n=795; 88% white).^111^ Other factors that increased the likelihood of use included a positive attitude toward taking risk-reducing SERMs compared with a negative attitude; higher levels of worry about breast cancer in the next 5 years; knowing others who had a good experience with a SERM; having considered taking a SERM in the past; having a positive perception of SERM users as being brave, smart, or healthy; having atypical hyperplasia on prior biopsy; and having a discussion of test results with a health care provider. Factors that decreased the likelihood of use included knowing someone with a bad experience with SERMs, and family members with thromboembolic conditions or endometrial cancer.

Familial considerations were also important in a survey of 258 high-risk women in England (mean age 45.4 years; 96.5% white). In this study, women with children were significantly more likely to initiate tamoxifen for risk-reduction compared with women without children (17.6 vs. 3.8%, respectively; OR 5.26; 95% CI, 1.13 to 24.49).^110^ Qualitative themes in this study suggested that women were also influenced by their family’s views and experiences taking medications more generally.

Few studies focused on decisionmaking about risk-reducing medications for breast cancer in the context of race/ethnicity. A study of racially diverse women (n=417; mean age 59 years; 28.5% white; 14.6% black; 20.6% Latina; 36.2% Asian) recruited from primary care community clinics found that willingness to take risk-reducing medications varied considerably, and was not based only on risk perception or understanding the risks and benefits of the medications.^113^ After receiving brief information about tamoxifen, 40 percent of women reported they would be willing to take tamoxifen if considered high-risk. In this sample, characteristics of women more likely to take tamoxifen included being Asian, uninsured, having less than a high school education, higher numeracy, and greater breast cancer knowledge. However, women with higher knowledge about tamoxifen were less willing to use it for breast cancer risk reduction. In another study of 1,094 racially diverse women surveyed from the general population (mean age 54 years; 79.1% white; 15.6% Hispanic; 15.3% black), interest in risk-reducing medications was low, even when presented in a scenario of maximum benefit with fewest risks.^115^ Time needed to take the medication for effect and 5-year risk of breast cancer were the most important drivers of tradeoff preferences between different scenarios in this study.

### Provider Perspectives

Prescribing risk-reducing medications is an uncommon practice among primary care physicians surveyed in three U.S. studies.^108,109,112^ In a cross-sectional survey of 316 primary care physicians (34% with >20 years attending experience) at an academic health center, only 13 percent of physicians had ever prescribed a risk-reducing medication for breast cancer risk reduction in a high-risk patient.^109^ In adjusted analysis, there were no significant differences in prescribing practices across specialties including internal medicine (8.5%), family medicine (8.0%) and gynecology (30%). Among prescribers, 65 percent had prescribed risk-reducing medications only one to five times.

Among 822 physicians (mean age 47 years; 92% board-certified) surveyed in California, only 10.6 percent had prescribed tamoxifen and 30.7 percent had prescribed raloxifene for breast cancer risk reduction in the past year.^112^ In this sample, obstetrician/gynecologists were significantly more likely than their internal medicine and family medicine counterparts to prescribe tamoxifen or raloxifene to reduce breast cancer risk (tamoxifen: 15 vs. 9.0 and 7.5%, p=0.01; raloxifene: 43.2 vs. 23.3 and 21.9%, p<0.001, respectively). Factors significantly associated with low prescribing included practice in Health Management Organizations or academic settings, and physicians who were foreign-born. Raloxifene prescribing was more common among physicians who were female and had more breast cancer diagnoses per year in their practices; while tamoxifen prescribing was more common among physicians who had more breast cancer diagnoses per year in their practices and those with personal experience of breast cancer themselves or among relatives.

In an additional survey of U.S. primary care physicians (n=350; mean age 46 years), 27.4 percent had prescribed tamoxifen for breast cancer prevention in the past year.^108^ However, the vast majority (85.4%) of prescribers had prescribed tamoxifen for breast cancer risk reduction only one to six times. Prescribers tended to be older, were less likely to be female, and more likely to have a family member with breast cancer.

Responses from physicians in U.S. studies described several key considerations when prescribing risk-reducing medications for breast cancer. These include comfort with medications, perceived evidence of benefit and harm, patient interest, and perceived role in prescribing risk-reducing medications. Among primary care physicians at an academic health center, the main reasons for not prescribing risk-reducing medications included discomfort with medications (79.8%), not identifying candidates for risk-reducing medications (60.7%), not enough time to discuss medications with patients (32.1%), and not believing that these medications were of benefit for most eligible women (10.7%).^109^ Additionally, California-based physicians reported that factors relating to training and role (i.e. not my role to prescribe, not sufficiently trained/informed to prescribe) were barriers to prescribing tamoxifen and raloxifene for breast cancer risk reduction.^112^ Patient factors (i.e. lack of patient interest, patient would not understand) were additional barriers.

In a cohort of U.S. primary care physicians, factors related to prescribing included having a family member with breast cancer, physician belief that benefits outweigh risks, considering it easy to determine eligibility, and patients asking for more information.^108^ Employing hypothetical vignettes of a 55-year old woman with varied family history and hysterectomy status, physicians were more likely to recommend tamoxifen to a woman who had a mother with breast cancer than to a woman with no family history of breast cancer; and also more likely to recommend tamoxifen if a women had a mother and a sister with breast cancer compared with only a mother with breast.^108^

## Contextual Question 2 How Well Do Statistical Models Inform the Practice of Identifying and Treating Women With Medications to Reduce Risk for Breast Cancer?

One statistical model estimated the benefits and harms of tamoxifen and raloxifene for breast cancer risk reduction to identify candidates for therapy.^136^ This model was used by the USPSTF in its previous recommendation that set a 5-year breast cancer risk threshold of 3 percent to select candidates for medications to reduce breast cancer risk.^1^ The model uses risk/benefit indices developed from weighting various health outcomes; estimating baseline incidence of health outcomes from breast cancer risk-reducing medication trials, the SEER, and the WHI; and calculating relative risk estimates for health outcomes in the presence of tamoxifen or raloxifene from the NSABP P-1 and STAR trials. The model is limited by not including aromatase inhibitors and updated estimates in its assumptions.

In the model, life-threatening events (invasive breast cancer, hip fracture, endometrial cancer, stroke, and PE) were weighted as 1.0; severe events (in situ breast cancer and DVT) were weighted as 0.5; while other events (wrist and spine fractures and cataracts) were weighted as 0.0. The net benefit index was estimated using the expected number of life-threatening equivalent events in 5 years without risk-reducing medication in 10,000 women minus the expected number of life-threatening equivalent events if risk-reducing medication is used.

Results of the model suggested that the benefits and harms of tamoxifen and raloxifene for breast cancer risk reduction in postmenopausal women varied by age, race, risk for invasive breast cancer, and history of hysterectomy. These estimates were described in tables that could be used to guide decisionmaking^137^ For women aged 50 to 59 years with 5-year Gail model risks of 4.5 to 6.5 percent or higher, tamoxifen had moderate to strong net positive benefit in the model. However, for older women, harms outweighed benefits regardless of risk level. Raloxifene had strong net benefit for women aged 50 to 59 years with 5-year risks of 3.5 percent or higher, and for older women with 5-year risks of 6.5 percent or higher. For postmenopausal black and Hispanic women with a uterus, raloxifene demonstrated a better risk/benefit profile compared with tamoxifen, similar to that seen in white women. Net benefit indices were typically larger in Hispanic compared with white women, and smaller in black compared with white women. Also, over a 5-year period, postmenopausal women with a uterus had a better risk/benefit ratio for raloxifene than for tamoxifen, whereas for women without a uterus the risk/benefit ratio of raloxifene and tamoxifen was similar.