# Chapter 2 Methods

## Key Questions and Analytic Framework

Using the methods developed by the USPSTF,^24^ the USPSTF and the Agency for Healthcare Research and Quality (AHRQ) determined the scope and key questions for this review. Investigators created an analytic framework with the key questions and the patient populations, interventions, and outcomes reviewed (Figure 1).

Figure 1 Analytic Framework

Figure 1 is a flow diagram of the selection of candidates for medications to reduce the risk for primary breast cancer. Women without preexisting breast cancer are screened and sorted into either appropriate or inappropriate candidates for medication. Women who are appropriate candidates for medication receive medications to reduce the risk for primary breast cancer. Women may experience adverse effects due to these medications. Women who are treated with these medications may have reduced incidence of invasive breast cancer and reduced incidence of noninvasive breast cancer, which may lead to improved breast cancer related mortality and all-cause mortality.

### Key Questions

1. In adult women without preexisting breast cancer, what is the accuracy of risk assessment methods to identify women who could benefit from medications to reduce risk for primary breast cancer (e.g., clinical risk assessment models)?
  a. What is the optimal age at which to begin risk assessment to identify women who could benefit from medications to reduce risk for primary breast cancer?
  b. What is the optimal frequency of risk assessment to identify women who could benefit from medications to reduce risk for primary breast cancer?
2. In adult women without preexisting breast cancer, what is the effectiveness and comparative effectiveness of medications to reduce risk for primary breast cancer on improvement in short- and long-term health outcomes, including invasive breast cancer, noninvasive breast cancer (including DCIS), breast cancer mortality, all-cause mortality, and other beneficial outcomes (such as reduced fractures caused by certain medications and improved quality of life)?
  a. Does the effectiveness of risk-reducing medications vary by timing of initiation or duration of use?
  b. Does the effectiveness of risk-reducing medications persist beyond discontinuation of use?
3. What are the harms of using medications to reduce risk for primary breast cancer?
  a. Do the harms of risk-reducing medications vary by timing of initiation or duration of use?
  b. Do the harms of risk-reducing medications persist beyond discontinuation of use?
4. Do the outcomes of using medications to reduce risk for primary breast cancer vary by population subgroups?

### Contextual Questions

Contextual questions provide additional information for the USPSTF, but are not systematically reviewed or represented in the Analytic Framework.

1. What are current clinician and patient attitudes and practices regarding use of medications to reduce risk for primary breast cancer? Do they vary by population subgroups, including nonwhite women; premenopausal women; women with comorbid conditions; and women with lower educational levels, socioeconomic status, and access to care?
2. How well do statistical models inform the practice of identifying and treating women with medications to reduce risk for breast cancer?

## Search Strategies

A research librarian searched the Cochrane Central Register of Controlled Trials and Cochrane Database of Systematic Reviews and Ovid EMBASE and MEDLINE (January 1, 2013 to February 1, 2019) for relevant English-language studies, systematic reviews, and meta-analyses. Search strategies are available in Appendix A1. Studies published before 2013 were identified from prior systematic reviews for the USPSTF.^2,9^ Investigators manually reviewed reference lists of relevant articles.

## Study Selection

Selection criteria for studies based on the patient populations, interventions, outcome measures, and types of evidence were developed for each key question (Appendix A2). After an initial review of citations and abstracts, investigators retrieved full-text articles of potentially relevant material and conducted a second review to determine inclusion. A second reviewer confirmed results of the initial reviewer, and discrepancies were resolved by team consensus. For Key Question 1, studies of clinical risk assessment models that could be used in primary care settings to identify women at higher than average risk for breast cancer were included. Only studies reporting discriminatory accuracy of the models were included. Discriminatory accuracy is a measure of how well the model can correctly classify persons at higher risk from those at lower risk and is measured by the model’s concordance statistic or c-statistic. The c-statistic is determined by the area under the receiver operating characteristic curve (AUC), a plot of sensitivity (true-positive rate) versus 1 – specificity (false-positive rate). Perfect discrimination is a c-statistic of 1.0, whereas a c-statistic of 0.5 would result from chance alone. An acceptable level of discrimination is between 0.70 and 0.79, excellent is between 0.80 and 0.89, and outstanding is 0.90 or greater,^25^ although these thresholds vary depending on the clinical condition and purpose of the test. Studies of individual risk factors or laboratory tests as well as models designed primarily to evaluate risk for pathogenic mutations in breast cancer susceptibility genes (e.g. BRCA1/2) were excluded.

For Key Question 2, only double-blind, placebo-controlled or head-to-head randomized controlled trials (RCT) of tamoxifen, raloxifene, or aromatase inhibitors for primary prevention of breast cancer that enrolled women without preexisting breast cancer were included. These trials reported breast cancer incidence as a primary or secondary outcome of the study. For Key Question 3, RCTs and observational studies of tamoxifen, raloxifene, or aromatase inhibitors in women without preexisting breast cancer that had a nonuser comparison group or direct comparisons between the medications were included. All adverse outcomes at all reported followup times were considered to capture potential short- and long-term adverse effects. Studies reporting only intermediate outcomes rather than health outcomes, such as cholesterol levels rather than cardiovascular disease events, were not included.

The selection of literature is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists excluded studies with reasons for exclusion.

## Data Abstraction and Quality Rating

For the included RCTs and observational studies, investigators abstracted the following data: study design; setting; population characteristics (including age, ethnicity, diagnosis); eligibility criteria; interventions (dose and duration); numbers enrolled and lost to followup; method of outcome ascertainment; and results for each outcome. For studies of risk models, investigators abstracted: study design; population characteristics; eligibility criteria; reference standards; risk factors included in the models; and performance measures of the models.

Two investigators independently applied criteria developed by the USPSTF^24^ to rate the quality of each study as good, fair, or poor (Appendix A5). Discrepancies were resolved through a consensus process.

## Data Synthesis

For all key questions, the overall quality of evidence was determined using the approach described in the USPSTF Procedure Manual.^24^ Evidence was rated good, fair, or poor, based on study quality, consistency of results between studies, precision of estimates, study limitations, risk of reporting bias, and applicability, and summarized in a table.^24^

### Statistical Analysis

#### Meta-Analysis

Results of the placebo-controlled primary prevention trials were combined using meta-analyses to obtain more precise estimates of clinical outcomes for the target population (Key Questions 2, 3, and 4). To determine the appropriateness of meta-analysis, investigators considered clinical and methodological differences and assessed statistical heterogeneity.

Estimates of risk ratios (RR) (rate ratio, hazard ratio [HR], or relative risk) and their standard errors were abstracted or estimated from each study and used as the effect measure. For each outcome, the following steps were adopted to obtain the RR and to account for the varying followup periods of the trials:

1. If a study reported a rate ratio based on a Poisson model, where women-years of followup was incorporated in the estimates, or a HR from a Cox regression model, the reported estimate was used.
2. If not, but the study reported the number of events and women-years of followup, or women-years of followup could be estimated from the reported data, the biostatistician estimated the rate ratio based on a Poisson distribution using the number of events and women-years of followup.
3. If both 1. and 2. were not possible, the reported or estimated relative risk was used, which does not account for the women-years of followup. However, the estimate of relative risk would be expected to be very close to the estimate of rate ratio since the mean or median followup time was similar between the treatment and control arms in the trials.

The presence of statistical heterogeneity among the studies was assessed using Cochran’s χ^2^ tests, and the magnitude of heterogeneity using the I^2^ statistic.^26^ The RRs were combined by using a profile likelihood random effects model to account for variation among studies.^27^ When there is no variation among studies, the random effects model yields the same results as a fixed effects model.

To explore whether the combined estimate differed among subpopulations, subgroup analysis was performed by age (£50; > 50 years), family history of breast cancer (yes; no), use of menopausal hormone therapy (yes; no), menopausal status (pre; post), and body mass index (BMI; ≤25; >25), when at least two studies reported results. For outcomes of major adverse events, the analyses were stratified by active versus posttreatment periods, although the tamoxifen trials were the only trials to report data by treatment periods.

For all above analyses, results were combined separately for tamoxifen, raloxifene, and the aromatase inhibitors. All analyses were performed by using STATA® 13.1 (StataCorp, College Station, TX), and all results were provided with 95 percent confidence intervals (CIs).

#### Event Rates

To facilitate the evaluation of benefits and harms across trials, event rates for both treatment and placebo groups, along with combined estimates of RRs, were provided in the forest plots for each meta-analysis. Using steps similar to those for RRs, event rates per 1000 women-years were presented if the study reported such data. Otherwise, if the study reported the number of events and women-years of followup, or women-years of followup could be estimated from the reported data, the event rates per 1000 women-years were estimated by the biostatistician. When the event rates were not reported or estimated, they were shown as NR (not reported) in the plots.

#### Estimation of the Number of Events Reduced or Increased

To interpret the clinical impact of the risk-reducing medications, the biostatistician estimated the number of events reduced for benefits or increased for harms compared with placebo per 1000 women assuming 5 years of medication use, when the meta-analysis indicated a significant difference between the treatment and the placebo groups. These numbers and the corresponding 95 percent CIs were estimated using the combined RRs from the meta-analyses and the combined event rates from the placebo groups of included trials. The combined event rates were estimated from a meta-analysis of the placebo event rates from each trial by using a random effects Poisson model and raw data of the number of events and women-years of followup. This analysis was performed using PROC NLMIXED, SAS 9.4. (SAS Institute Inc., Cary, NC). The 95 percent confidence intervals (CIs) for the number of events reduced or increased were obtained using a simulation method that assumed that both the logs of the RRs and event rates have normal distributions, and then drew 10,000 random samples from these normal distributions. The numbers of events reduced or increased were then estimated from each sample, and the 95 percent CIs were obtained by computing the 2.5 percent and 97.5 percent quantiles of the full sample.

## External Review

The draft report was reviewed by content experts (Appendix A6), USPSTF members, AHRQ Project Officers, and collaborative partners and was posted for public comment. The report was revised based on reviewer comments.