# Chapter 1 Introduction and Background

## Purpose

This report will be used by the U.S. Preventive Services Task Force (USPSTF) to update the 2013 recommendation on the use of medications to reduce risk for primary breast cancer in women.^1,2^

## Condition Background

### Condition Definition

Breast cancer is a malignancy that develops in breast tissue beginning in the lining of the lactation ducts or lobules of the breast.^3^ Invasive breast cancer has the potential to spread into surrounding tissue, while noninvasive or in situ breast cancer is confined to the ducts or lobules.^3^ Estrogen receptor positive (ER+) breast cancer, approximately 75 percent of cases, describes cells that have a receptor protein that binds estrogen. ER+ cells may need estrogen to grow, and may stop growing when treated with substances that block the binding and actions of estrogen. Estrogen receptor negative (ER-) cells do not respond to estrogen. Ductal carcinoma in situ (DCIS) may be a precursor form of breast cancer, while lobular carcinoma in situ (LCIS) serves as a marker for increased risk of developing invasive cancer.^4^

### Prevalence and Burden of Disease/Illness

Breast cancer is the second most commonly diagnosed cancer among women in the United States after nonmelanoma skin cancer, and is the second leading cause of cancer death after lung cancer. In 2018, an estimated 266,120 women developed breast cancer in the United States and 40,920 women died from the disease.^5^ Based on data from 2011 to 2015, 70 percent of female breast cancer cases occurred in women aged 45 to 74 years (median age of diagnosis was 62 years).^6^ White and black women have similar rates of breast cancer incidence (128.6 and 126.9 per 100,000 persons, respectively) and are more likely to be diagnosed with breast cancer compared with other races. In 2018, breast cancer accounted for 15.3 percent of all new cancer diagnoses in the United States. In 2015, approximately 3,418,124 women were living with breast cancer in the United States.^6^

### Etiology and Natural History

Based on data from 2013 to 2015, 12.4 percent of women will be diagnosed with breast cancer at some point in their lives.^6^ The 5-year relative survival rate in the United States for any breast cancer diagnosis is 91 percent, which improves to 99 percent with localized disease. Five-year relative survival rates for women with regional and distant disease are 85 percent and 27 percent, respectively.^7^ Older women are more likely to die of the disease compared with younger women, and 81 percent of female breast cancer deaths occurred in women over the age of 54 years between 2011 and 2015 (median age of death was 68 years).^6^ Black women are more likely to die of breast cancer (28.7 deaths per 100,000 persons) compared with other races.

### Risk Factors

Several factors are associated with increased risk for breast cancer. The strongest predictors are female sex and increasing age. Other important risk factors include previous diagnosis of high-risk breast lesions (DCIS, LCIS, atypical ductal or lobular hyperplasia [ADH, ALH], and others), first degree relatives with breast cancer, presence of breast cancer susceptibility mutations, previous breast biopsy, increased breast density, and previous radiation therapy to the chest (e.g., treatment for Hodgkin lymphoma).^8^ While many other risk factors have been associated with breast cancer in epidemiologic studies, their effects are lower or inconsistent.^2,9^

### Rationale for Screening/Screening Strategies

Periodic mammography screening is the current approach to early detection. Prevention strategies include use of risk-reducing medications and surgeries (i.e., mastectomy, oophorectomy) for women identified at increased risk. This review focuses on risk-reducing medications.

Candidates for risk-reducing medications need to be accurately identified to optimize potential benefits and minimize harms. The goal of clinical assessment for breast cancer risk is to stratify women into average and above average risk groups. Some of the clinical trials established inclusion criteria based on individual risk factors, while others set risk thresholds of at least 1.67 percent 5-year risk of breast cancer as determined by the modified Gail model, a clinical model to predict individualized probability of developing breast cancer. The previous USPSTF recommendation indicated 3 percent 5-year risk of breast cancer.^1^ Clinical tools to assess individual risks for breast cancer in primary care settings, such as the Gail model, incorporate information about specific risk factors to estimate the likelihood of future breast cancer.^2,9^ However, risk assessment tools were developed from population-level data and have only a low degree of discriminatory accuracy when used to determine risk for individual women. In the previous systematic review, c-statistic scores ranged from 0.55 to 0.65 among 13 models tested.^2,9^

### Interventions/Treatment

Medications used in the United States to reduce the risk of breast cancer in women at increased risk include raloxifene,^10^ tamoxifen,^11^ and aromatase inhibitors.^12–14^ Only raloxifene and tamoxifen are approved by the U.S. Food and Drug Administration (FDA) for this indication, and raloxifene is only approved for use in postmenopausal women.^10,11^ Raloxifene and tamoxifen are selective estrogen receptor modulators (SERMs) that act by blocking the response of estrogen receptors in breast tissue, limiting breast tissue proliferation and subsequent cancer. The previous review reported that the degree of risk reduction from use of these medications ranged from 30 percent to 68 percent compared with placebo, predominantly reducing incidence of ER+ invasive breast cancer.^2^ A subsequent meta-analysis of individual participant data from nine trials of SERMs, including tamoxifen and raloxifene, reported a 38 percent risk reduction in breast cancer incidence over 10 years of followup.^15^ Both SERMs increase risk of thromboembolism and tamoxifen increases risk of endometrial cancer.^2^

Aromatase inhibitors, including exemestane^16–18^ and anastrozole,^17^ have been evaluated for breast cancer risk reduction in postmenopausal women in clinical trials, although they are primarily used to treat breast cancer. These medications act by blocking aromatase, the enzyme responsible for converting androgen to estrogen, thereby decreasing the production of estrogen in tissue.

### Current Clinical Practice/Recommendations of Other Groups

Use of medications for breast cancer risk reduction has been limited in clinical practice. The uptake of risk-reducing medications among 21,423 women in 26 studies was 16.3 percent in a recent meta-analysis.^19^ However, use among clinical populations is much lower, with estimates ranging from approximately 4 percent of women at increased risk to less than 1 percent of eligible women overall.^20,21^ Women’s concerns about adverse effects and their beliefs that benefits are not worth the harms are important factors in their decisions to decline use of these medications.^2^ In addition, many primary care physicians are unfamiliar with tamoxifen and aromatase inhibitors because they are primarily used for breast cancer treatment.^22^

The National Comprehensive Cancer Network (NCCN) Breast Cancer Risk Reduction Panel recommends tamoxifen (20 mg/day) as an option to reduce breast cancer risk in healthy pre and postmenopausal women 35 years of age or older, whose life expectancy is 10 years or more, and who have at least 1.7 percent 5-year risk of breast cancer as determined by the modified Gail Model, or who have had LCIS.^23^ The NCCN recommends tamoxifen over raloxifene for most postmenopausal women desiring non-surgical risk reduction therapy because it is more effective. However, consideration of toxicity may still lead to the choice of raloxifene in some women. If raloxifene is chosen, the NCCN Breast Cancer Risk Reduction Panel recommends use of 60 mg/day.^23^ The NCCN has also added exemestane and anastrozole as choices of risk-reduction agents.^23^ All four medications may be used in postmenopausal women, while tamoxifen is the only medication indicated for premenopausal women.