# Appendix C Supplemental Tables

## Appendix C1 Detailed Inclusion Criteria for Primary Prevention Trials

### Tamoxifen vs. Raloxifene

#### Study of Tamoxifen and Raloxifene (STAR)

- At least a 5-year predicted breast cancer risk of 1.66% based on the Gail model.
- At least 35 years old and postmenopausal.
- Not taking tamoxifen, raloxifene, hormone therapy, oral contraceptives, or androgens for a least the previous 3 months.
- Not currently taking either warfarin or cholestyramine.
- No history of stroke, pulmonary embolism, or deep vein thrombosis and no history of any malignancy diagnosed less than 5 years before randomization except basal or squamous cell carcinoma of the skin or carcinoma in situ of the cervix.
- No uncontrolled atrial fibrillation, uncontrolled diabetes, or uncontrolled hypertension.
- No psychiatric condition that would interfere with adherence or a performance status that would restrict normal activity for a significant portion of each day.

### Tamoxifen vs. Placebo

#### National Surgical Adjuvant Breast and Bowel Project P-1 (NSABP-1)

- 60 years of age or older or between the ages of 35 and 59 with a 5-year predicted risk for breast cancer of at least 1.66% or had a history of lobular carcinoma in situ.
- Life expectancy of at least 10 years.
- Breast exam demonstrated no clinical evidence of cancer.
- Mammogram within 180 days before randomization had no evidence of breast cancer.
- Normal white blood cell and platelet counts and normal hepatic and renal function tests.
- Not pregnant upon entry into the study or planned not to become pregnant while on protocol therapy.
- Accessible for follow up.
- Underwent endometrial sampling before randomization if they had a uterus and were randomly assigned after July 8, 1994.
- No estrogen or progesterone replacement therapy, oral contraceptives, or androgens for at least 3 months before randomization.
- No history of deep vein thrombosis or pulmonary embolism.

#### International Breast Cancer Intervention Study (IBIS-I)

Increased risk for breast cancer based on family history criteria:

- 35 to 39 years with 10-fold relative risk
- 40 to 44 years with 4-fold relative risk
- 45 to 70 years with 2-fold relative risk

All criteria permit entry to trial at age 45 years:

- First-degree relative who developed breast cancer at or before age 50.
- First-degree relative with bilateral breast cancer (permits entry from age 40; if relative diagnosed before age 40, permits entry at age 35).
- Two or more first-degree or second-degree relatives with breast cancer (permits entry from age 40 if both developed breast cancer before age 50, permits entry at age 35 if both relatives are first-degree and both developed breast cancer before age 50).
- Benign breast biopsy and first-degree relative with breast cancer.
- Lobular carcinoma in situ (permits entry from age 35).
- Atypical hyperplasia (permits entry from age 40).
- Nulliparous and a first-degree relative who developed breast cancer.
- Risk equivalent (strong family history, not fitting specific categories, but judged to be at higher risk than eligibility category by the study chairman).

#### Royal Marsden

Between the ages of 30 to 70 with no clinical or screening evidence of breast cancer and with an increased risk of breast cancer because of family history:

- At least 1 first degree relative under 50 with breast cancer, or
- One first degree relative with bilateral breast cancer, or
- One affected first degree relative of any age plus another affected first degree or second degree relative, or
- History of a benign breast biopsy and had a first-degree relative with breast cancer

#### Italian Trial

Healthy women aged 35 to 70 years at average risk for breast cancer who had had a total hysterectomy to avoid the risk of endometrial cancer associated with tamoxifen use.

### Raloxifene vs. Placebo

#### Multiple Outcomes of Raloxifene (MORE/CORE)

- At least 2 years postmenopausal and no older than 80 years.
- Osteoporosis defined as bone density at least 2.5 SDs below mean for normal young women at either the lumbar spine or femoral neck, or had at least 1 moderate or 2 mild vertebral fractures that were detected by lateral spine radiography.
- Women with a history of breast cancer, invasive endometrial cancer, or history of stroke or venous thromboembolism during the past 10 years were excluded.

#### Raloxifene Use for the Heart (RUTH)

- 1 year or more postmenopausal and age 55 years and older.
- Have established CHD or at increased risk for CHD based on a cardiovascular risk score of 4 or more according to a point system that takes into account the presence of:
  ○ Established CHD (4 points)
  ○ Arterial disease of the leg (4 points)
  ○ Age of at least 70 years (2 points)
  ○ Diabetes mellitus (3 points)
  ○ Cigarette smoking (1 point)
  ○ Hypertension (1 point)
  ○ Hyperlipidemia (1 point)

### Exemestane vs. Placebo

#### Mammary Prevention.3 (MAP.3)

Women who were 35 years and older, postmenopausal, and at least 1 of the following risk factors:

- 60 years or older
- Gail risk score greater than 1.66%
- Prior atypical ductal or lobular hyperplasia or lobular carcinoma in situ on breast biopsy or prior ductal carcinoma in situ treated with mastectomy.

Prior menopausal hormone therapies, luteinizing hormone-releasing hormone analogues, prolactin inhibitors, antiandrogens, or selective estrogen receptor modulators were allowable but not within 3 months of randomization.

### Anastrozole vs. Placebo

#### International Breast Cancer Intervention Study (IBIS-II)

Postmenopausal with increased risk for breast cancer:

- 40 to 44 years with risk 4 times higher than in the general population
- 45 to 60 years with risk 2 times higher
- 60 to 70 with risk 1.5 times higher

40-44, meeting at least one of the criteria:

- Two or more first or second degree relatives who developed breast cancer or ovarian cancer at age 50 or less
- First degree relative with bilateral breast cancer who developed first breast cancer at age 50 or less
- Nulliparous or age 30 or above at first birth, and first degree relative who developed breast cancer at age 40 or less
- Benign biopsy with proliferative disease and first degree relative who developed breast cancer at 40 or less

45-70 years, meeting at least one of the criteria:

- First degree relative who developed breast cancer at age 50 or less
- First degree relative who developed bilateral cancer
- Two or more first degree relatives who developed breast or ovarian cancer
- Nulliparous or age 30 or above at first birth, and first degree relative who developed breast cancer
- Benign biopsy with proliferative disease and first degree relative who developed breast cancer
- Mammographic opacity covering at least 50% of the breast
- First degree relative with breast cancer at any age
- Age at menopause 55 years or more
- Nulliparous or age 30 or above at first birth

Women in all age groups

- Lobular carcinoma in situ (LCIS)
- Atypical ductal or lobular hyperplasia in a benign lesion
- DCIS (ER-positive) diagnosed within last 6 months with completed adequate local treatment
- Women with a clearly apparent family history indicating appropriate increased risk

## Appendix C2 Summary of Inclusion Criteria for Primary Prevention Trials

Comparators | Primary Prevention Trial | Age | Post-menopausal | >1.66% 5-Year Gail | Family History | Breast Pathology | Other BC Risk Factors
Tamoxifen vs. Raloxifene | Study of Tamoxifen & Raloxifene (STAR) | X | X | X
Tamoxifen vs. Placebo | National Surgical Adjuvant Breast and Bowel Project P-1 (NSABP-1) | X | | X | | LCIS
Tamoxifen vs. Placebo | International Breast Cancer Intervention Study (IBIS-I) | X | | | X | X | X
Tamoxifen vs. Placebo | Royal Marsden Hospital Trial | X | | | X | X
Tamoxifen vs. Placebo | Italian Trial | X
Raloxifene vs. Placebo | Multiple Outcomes of Raloxifene (MORE/CORE) | | X | Osteoporosis
Raloxifene vs. Placebo | Raloxifene Use for the Heart (RUTH) | X | X | CHD or risk factors
Exemestane vs. Placebo | Mammary Prevention.3 (MAP.3) | X | X | X | | X
Anastrozole vs. Placebo | International Breast Cancer Intervention Study (IBIS-II) | X | X | | X | X | X

Abbreviation: CHD=coronary heart disease.

Comparators | Primary Prevention Trial | N (drug vs. comparator) | Mean Age (SD) or Range (years) | Age, n (%) ≤ 50 Years | Age, n (%) 50-59 Years | Age, n (%) 60-69 Years | Age, n (%) ≥60 Years | Age, n (%) ≥70 Years
Tamoxifen vs. Raloxifene | STAR | 9872 | 58.5 | 884 (9.1) | 4850 (49.9) | 3133 (32.2) | | 859 (8.8)
Tamoxifen vs. Raloxifene | STAR | 9875 | 58.5 | 877 (9.0) | 4848 (49.7) | 3173 (32.6) | | 847 (8.7)
Tamoxifen vs. Placebo | NSABP-1 | 6681 | 53 | 2581 (39.2) | 2031 (30.9) | 1571 (23.9) | | 393 (6.0)
Tamoxifen vs. Placebo | NSABP-1 | 6707 | 53 | 2596 (39.3) | 2017 (30.6) | 1590 (24.1) | | 396 (6.0)
Tamoxifen vs. Placebo | IBIS-I | 3579 | 50.7 (7.0)
Tamoxifen vs. Placebo | IBIS-I | 3575 | 50.8 (6.7)
Tamoxifen vs. Placebo | Royal Marsden | 1238 | 47 (30-70) | 774 (61.9)
Tamoxifen vs. Placebo | Royal Marsden | 1233 | 47 (31-70) | 749 (60.2)
Tamoxifen vs. Placebo | Italian | 2700 | 51 | 1062 (39.3) | 1317 (48.8) | | 321 (11.9)
Tamoxifen vs. Placebo | Italian | 2708 | 51 | 1011 (37.3) | 1395 (51.5) | | 302 (11.2)
Raloxifene vs. Placebo | MORE/CORE | 2725 | 65.7 (6.8)
Raloxifene vs. Placebo | MORE/CORE | 1286 | 65.9 (6.7)
Raloxifene vs. Placebo | RUTH | 5044 | 67.5 (6.6) | | | | | 1952 (38.7)
Raloxifene vs. Placebo | RUTH | 5057 | 67.5 (6.7) | | | | | 1982 (39.2)
Exemestane vs. Placebo | MAP.3 | 2285 | 62.5 (38.5-88.2) | | | | 1545 (67.6)
Exemestane vs. Placebo | MAP.3 | 2275 | 62.4 (37.1-89.9) | | | | 1572 (69.1)
Anastrozole vs. Placebo | IBIS-II | 1920 | 59.5 (55.0-63.5)^*^
Anastrozole vs. Placebo | IBIS-II | 1944 | 59.4 (55.1-63.3)^*^

* Data presented as median IQR.

Comparators | Primary Prevention Trial | N (drug vs. comparator) | No 1^0^ Relatives With Breast Cancer, n (%) | One 1^0^ Relative With Breast Cancer, n (%) | Two 1^0^ Relatives With Breast Cancer, n (%) | Three 1^0^ Relatives With Breast Cancer, n (%) | ≥1 1^0^ Relatives With Breast Cancer, n (%) | ≥2 1^0^ Relatives With Breast Cancer, n (%) | ≥3 1^0^ Relatives With Breast Cancer, n (%)
Tamoxifen vs. Raloxifene | STAR | 9726 | 2835 (29.1) | 5041 (51.8) | 1532 (15.8) | 318 (3.3)
Tamoxifen vs. Raloxifene | STAR | 9745 | 2789 (28.6) | 5130 (52.6) | 1559 (16.0) | 267 (2.7)
Tamoxifen vs. Placebo | NSABP-1 | 6576 | 1540 (23.4) | 3754 (57.1) | 1069 (16.3) | | | | 213 (3.2)
Tamoxifen vs. Placebo | NSABP-1 | 6599 | 1595 (24.2) | 3731 (56.5) | 1092 (16.5) | | | | 181 (2.7)
Tamoxifen vs. Placebo | IBIS-I | 3573 | | | | | | 2204 (61.7)
Tamoxifen vs. Placebo | IBIS-I | 3566 | | | | | | 2206 (61.9)
Tamoxifen vs. Placebo | Royal Marsden | 1250 | 2359 (87.4) | | | | 341 (12.6) | 225 (18)
Tamoxifen vs. Placebo | Royal Marsden | 1244 | 2407 (88.9) | | | | 301 (11.1) | 205 (16.5)^†^
Tamoxifen vs. Placebo | Italian | 2700
Tamoxifen vs. Placebo | Italian | 2708
Raloxifene vs. Placebo | MORE/CORE | 2725
Raloxifene vs. Placebo | MORE/CORE | 1286
Raloxifene vs. Placebo | RUTH | 5044
Raloxifene vs. Placebo | RUTH | 5057
Exemestane vs. Placebo | MAP.3 | 2285
Exemestane vs. Placebo | MAP.3 | 2275
Anastrozole vs. Placebo | IBIS-II | 1920
Anastrozole vs. Placebo | IBIS-II | 1944

† Each participant had at least one first-degree relative aged under 50 with breast cancer, or one first-degree relative with bilateral breast cancer, or one affected first-degree relative of any age plus another affected first-degree or second-degree relative but data not shown for all.

Comparators | Primary Prevention Trial | N (drug vs. comparator) | 1^0^ Relative With Breast Cancer at Any Age | 1^0^ Relative With Breast Cancer at ≤50 | 1^0^ Relative With Bilateral Breast Cancer | ≥2 1^0^ or 2^0^ Relatives With Breast or Ovarian Cancer | Family History of Breast Cancer (not defined)
Tamoxifen vs. Raloxifene | STAR | 9726
Tamoxifen vs. Raloxifene | STAR | 9745
Tamoxifen vs. Placebo | NSABP-1 | 6576
Tamoxifen vs. Placebo | NSABP-1 | 6599
Tamoxifen vs. Placebo | IBIS-I | 3573 | | 1689 (47.3) | 579 (16.2) | 2204 (61.7)
Tamoxifen vs. Placebo | IBIS-I | 3566 | | 1744 (48.9) | 601 (16.9) | 2206 (61.9)
Tamoxifen vs. Placebo | Royal Marsden | 1250 | | 698 (55.8)
Tamoxifen vs. Placebo | Royal Marsden | 1244 | | 668 (53.7)^†^
Tamoxifen vs. Placebo | Italian | 2700
Tamoxifen vs. Placebo | Italian | 2708
Raloxifene vs. Placebo | MORE/CORE | 2725 | | | | | 636 (12.4)^‡^
Raloxifene vs. Placebo | MORE/CORE | 1286 | | | | | 312 (12.1)^‡^
Raloxifene vs. Placebo | RUTH | 5044 | | | | | 494 (9.8)
Raloxifene vs. Placebo | RUTH | 5057 | | | | | 491 (9.7)
Exemestane vs. Placebo | MAP.3 | 2285
Exemestane vs. Placebo | MAP.3 | 2275
Anastrozole vs. Placebo | IBIS-II | 1920 | 488 (25.4%) | 675 (35%) | 164 (9%) | 956 (50%)
Anastrozole vs. Placebo | IBIS-II | 1944 | 499 (25.7%) | 653 (34%) | 141 (7%) | 938 (48%)

† Each participant had at least one first-degree relative aged under 50 with breast cancer, or one first-degree relative with bilateral breast cancer, or one affected first-degree relative of any age plus another affected first-degree or second-degree relative but data not shown for all.

‡ Data from MORE study, MORE-CORE is a subset of MORE, n=4011 of 7705.

Comparators | Primary Prevention Trial | N (drug vs. comparator) | 5-Year Predicted Risk Score (Gail model), Mean (SD) | 5-Year Predicted Risk ≥1.66 (Gail model), n (%) | 5-Year Predicted Risk ≤ 2.00 (Gail model), n (%) | 5-Year Predicted Risk 2.01-3.00 (Gail model), n (%) | 5-Year Predicted Risk 3.01-5.00 (Gail model), n (%) | 5-Year Predicted Risk ≥5.01 (Gail model), n (%) | 10-Year Risk, % (Tyrer-Cuzick model)
Tamoxifen vs. Raloxifene | STAR | 9726 | | | 1055 (10.8) | 2988 (30.7) | 3039 (31.2) | 2644 (27.2)
Tamoxifen vs. Raloxifene | STAR | 9745 | | | 1097 (11.3) | 2893 (29.7) | 3082 (31.6) | 2673 (27.4)
Tamoxifen vs. Placebo | NSABP-1 | 6576 | | | 1636 (24.9) | 2057 (31.3) | 1714 (26.1) | 1169 (17.8)
Tamoxifen vs. Placebo | NSABP-1 | 6599 | | | 1660 (25.2) | 2031 (30.8) | 1791 (27.1) | 1117 (16.9)
Tamoxifen vs. Placebo | IBIS-I | 3573
Tamoxifen vs. Placebo | IBIS-I | 3566
Tamoxifen vs. Placebo | Royal Marsden | 1250
Tamoxifen vs. Placebo | Royal Marsden | 1244
Tamoxifen vs. Placebo | Italian | 2700
Tamoxifen vs. Placebo | Italian | 2708
Raloxifene vs. Placebo | MORE/CORE | 2725
Raloxifene vs. Placebo | MORE/CORE | 1286
Raloxifene vs. Placebo | RUTH | 5044 | 1.73 (0.76) | 2103 (41.7)
Raloxifene vs. Placebo | RUTH | 5057 | 1.73 (0.77) | 2083 (41.2)
Exemestane vs. Placebo | MAP.3 | 2285 | | 929 (40.7)
Exemestane vs. Placebo | MAP.3 | 2275 | | 905 (39.8)
Anastrozole vs. Placebo | IBIS-II | 1920 | | | | | | | 7.6 (5.8-9.9)
Anastrozole vs. Placebo | IBIS-II | 1944 | | | | | | | 7.8 (5.1-10.2)

Comparators | Primary Prevention Trial | N (drug vs. comparator) | Prior ADH, ALH, LCIS on Biopsy, n (%) | Prior LCIS, n (%) | Prior Atypical Hyperplasia, n (%) | Benign Biopsy and 1^0^ Relative, n (%) | Prior DCIS Treated With Mastectomy, n (%) | DCIS (ER-positive), n (%)
Tamoxifen vs. Raloxifene | STAR | 9726
Tamoxifen vs. Raloxifene | STAR | 9745
Tamoxifen vs. Placebo | NSABP-1 | 6576 | | 415 (6.3) | 579 (8.8)
Tamoxifen vs. Placebo | NSABP-1 | 6599 | | 411 (6.2) | 614 (9.3)
Tamoxifen vs. Placebo | IBIS-I | 3573 | | 44 (1.2) | 97 (2.7) | 123 (3.4)
Tamoxifen vs. Placebo | IBIS-I | 3566 | | 44 (1.2) | 104 (2.9) | 132 (3.7)
Tamoxifen vs. Placebo | Royal Marsden | 1250
Tamoxifen vs. Placebo | Royal Marsden | 1244
Tamoxifen vs. Placebo | Italian | 2700
Tamoxifen vs. Placebo | Italian | 2708
Raloxifene vs. Placebo | MORE/CORE | 2725
Raloxifene vs. Placebo | MORE/CORE | 1286
Raloxifene vs. Placebo | RUTH | 5044
Raloxifene vs. Placebo | RUTH | 5057
Exemestane vs. Placebo | MAP.3 | 2285 | 185 (8.1) | 56 (2.5)
Exemestane vs. Placebo | MAP.3 | 2275 | 188 (8.3) | 56 (2.5)
Anastrozole vs. Placebo | IBIS-II | 1920 | | 50 (2.6) | 55 (2.8) | | | 160 (8.3)
Anastrozole vs. Placebo | IBIS-II | 1944 | | 55 (2.8) | 135 (6.9) | | | 166 (8.5)

Abbreviation: LCIS=lobular carcinoma in situ.

Comparators | Primary Prevention Trial | N (drug vs. comparator) | Nulliparous or ≥30 at First Birth and a 1^0^ Relative With Breast Cancer, n (%) | Hysterectomy, n (%) | No Hysterectomy, n (%)
Tamoxifen vs. Raloxifene | STAR | 9726 | | 4994 (51.3) | 4732 (48.7)
Tamoxifen vs. Raloxifene | STAR | 9745 | | 5033 (51.6) | 4712 (48.4)
Tamoxifen vs. Placebo | NSABP-1 | 6576 | | 2479 (37.7) | 4097 (62.3)
Tamoxifen vs. Placebo | NSABP-1 | 6599 | | 2554 (71.6) | 4194 (63.6)
Tamoxifen vs. Placebo | IBIS-I | 3573 | 314 (8.8) | 2453 (68.7) | 1120 (31.3)^§^
Tamoxifen vs. Placebo | IBIS-I | 3566 | 325 (9.1) | 2554 (71.6) | 1012 (28.4)^§^
Tamoxifen vs. Placebo | Royal Marsden | 1250
Tamoxifen vs. Placebo | Royal Marsden | 1244
Tamoxifen vs. Placebo | Italian | 2700 | | 2700 (100) | 0
Tamoxifen vs. Placebo | Italian | 2708 | | 2708 (100) | 0
Raloxifene vs. Placebo | MORE/CORE | 2725 | | 559 (20.5) | 2166 (79.5)^§^
Raloxifene vs. Placebo | MORE/CORE | 1286 | | 260 (20.2) | 1026 (79.8)^§^
Raloxifene vs. Placebo | RUTH | 5044 | | 1178 (23.3) | 3879 (76.7)^§^
Raloxifene vs. Placebo | RUTH | 5057 | | 1145 (22.7) | 3899 (77.3)^§^
Exemestane vs. Placebo | MAP.3 | 2285
Exemestane vs. Placebo | MAP.3 | 2275
Anastrozole vs. Placebo | IBIS-II | 1920 | 207 (10.6) | 631 (33) | 1289 (67)
Anastrozole vs. Placebo | IBIS-II | 1944 | 211 (11.0) | 656 (34) | 1288 (66)^§^

§ Calculated from available data.

## Appendix C3 Distribution of Risk Factors in Primary Prevention Trials

Comparators | Primary Prevention Trial | N (drug vs. comparator) | Mean Age (years) | Menopause | Increased Breast Cancer Risk | Active Duration (years) | Followup Duration (years)
Tamoxifen vs. Raloxifene | Study of Tamoxifen & Raloxifene (STAR) | 9872 vs. 9875 | 58.5 | post | X | 3.6 to 3.9 | 6.8
Tamoxifen vs. Placebo | National Surgical Adjuvant Breast and Bowel Project P-1 (NSABP-1) | 6681 vs.6707 | 53 | pre/post | X | 4 | 7
Tamoxifen vs. Placebo | International Breast Cancer Intervention Study (IBIS-I) | 3579 vs. 3575 | 51 | pre/post | X | 5 | 16
Tamoxifen vs. Placebo | Royal Marsden Hospital Trial | 1238 vs. 1233 | 47 | pre/post | X | 5 | 13
Tamoxifen vs. Placebo | Italian Trial | 2700 vs. 2708 | 51 | pre/post | | 4 | 11
Raloxifene vs. Placebo | Multiple Outcomes of Raloxifene (MORE/CORE) | 5129 vs. 2576 | 67 | post | | 4 to 8 | 5 to 8
Raloxifene vs. Placebo | Raloxifene Use for the Heart (RUTH) | 5044 vs. 5057 | 67.5 | post | | 5 | 5.6
Exemestane vs. Placebo | Mammary Prevention.3 (MAP.3) | 2285 vs. 2275 | 62.5 | post | X | 3 | 3
Anastrozole vs. Placebo | International Breast Cancer Intervention Study (IBIS-II) | 1920 vs. 1044 | 59.5 | post | X | 5 | 5

## Appendix C4 Summary of Treatment Trials of Aromatase Inhibitors With Fracture and Cardiovascular Disease Outcomes

Study | Comparison | N | Method | Analysis | Major Adverse Outcomes
EBCTCG, 2015 | AI vs. tamoxifen for early breast cancer (meta-analysis) | 31,920 | Individual-level data on postmenopausal women with ER+ early breast cancer in treatment RCTs:; - AI (5 year) vs. tamoxifen (5 year); - AI (5 year) vs. tamoxifen (2-3 year), then AI to year 5; - Tamoxifen (2-3 year), then AI to year 5 vs. tamoxifen (5 year) | Intention-to-treat; log-rank analyses, stratified by age, nodal status, and trial, yielded aromatase inhibitor versus tamoxifen first-event rate ratios (RRs). | - Fractures: 5-year risk for AI 8.2% vs. 5.5% (RR 1.42; 95% CI, 1.28 to1.57 years 0-4; RR 1.29; 95% CI, 1.09 to 1.53 years 5-9); - CVD: no differences for VTE, CVA, CAD deaths
Forbes, 2016 | Anastrozole vs tamoxifen for DCIS (RCT) | 2980 | Multicenter RCT of women with locally excised ER+ DCIS given 1 mg oral anastrozole or 20 mg oral tamoxifen every day for 5 years. Median followup 7·2 years (IQR 5·6 to 8·9). | Modified intention-to-treat; proportional hazard models. | - Fractures: 9% AI vs. 7% tamoxifen (OR 1.36; 95% CI, 1.03 to 1.80); - CVD: increased VTE with tamoxifen; no CHD differences; - TIA: AI OR 2.69 (95% CI, 0.90 to 9.65); - CVA: AI OR 3.36 (95% CI, 1.04 to 14.18)
Goldvaser, 2018 | Extended AIs vs. placebo or no treatment for early ER+ breast cancer (meta-analysis) | 16,349 | 7 RCTs that compared extended AIs with placebo or no treatment published between 2013 and 2016. | Odds ratios (ORs), absolute risks, and the number needed to harm were computed for prespecified safety and tolerability outcomes. | - Fractures: 6.3% AI vs. 4.8% (OR 1.34; 95% CI, 1.16 to 1.55); - CVD events: 7% AI vs. 6% (OR 1.18; 95% CI, 1.00 to 1.40); - Treatment discontinuation for adverse events: (OR 1.45, 95% CI, 1.25 to 1.68)

## References

1 Early Breast Cancer Trialists’ Collaborative Group (EBCTCG). Aromatase inhibitors versus tamoxifen in early breast cancer: patient-level meta-analysis of the randomised trials. Lancet 2015; 386: 1341–52.26211827
2 Forbes JF, Sestak I, Howell A, Bonanni B, , on behalf of the IBIS-II investigators. Anastrozole versus tamoxifen for the prevention of locoregional and contralateral breast cancer in postmenopausal women with locally excised ductal carcinoma in situ (IBIS-II DCIS): a double-blind, randomized controlled trial. Lancet 2016; 387: 866–73.26686313
3 Goldvaser H, Barnes TA, Seruga B, Cescon DW, Ocana A, Ribnikar D, Amir E. Toxicity of extended adjuvant therapy with aromatase inhibitors in early breast cancer: A systematic review and meta-analysis. J Natl Cancer Inst 2018; 110(1): djx141.