# Appendix B Evidence Tables and Quality Tables

## Appendix B1 Quality Assessment of Diagnostic Accuracy Studies

Author, Year | Was a Consecutive or Random Sample of Patients Enrolled? | Was a Case-Control Design Avoided? | Did the Study Avoid Inappropriate Exclusions? | Were the Index Test Results Interpreted Without Knowledge of the Results of the Reference Standard? | If a Threshold Was Used, Was It Pre-specified? | Is the Reference Standard Likely To Correctly Classify the Target Condition? | Were the Reference Standard Results Interpreted Without Knowledge of the Results of the Index Test? | Was There an Appropriate Interval Between Index Test(s) and Reference Standard? | Did All Patients Receive a Reference Standard? | Did Patients Receive the Same Reference Standard? | Were All Patients Included in the Analysis? | Quality Rating
Prior review
Adams-Campbell, 2007 | Yes | No | Yes | NR | NA, evaluated cutoff values | Yes | Yes | Yes | Yes | Unclear | Yes | Good
Amir, 2003 | Yes | Yes | Yes | NR | No | Yes | Unclear | Yes | Yes | Unclear | Yes | Fair
Barlow, 2006 | Yes | Yes | Yes | NR | NA, evaluated cutoff values | Yes | Yes | Yes | Unclear | Unclear | Yes | Fair
Boughey, 2010 | Yes | Yes | Yes | NR | NA, evaluated cutoff values | Yes | NR | Yes | Yes | Yes | Yes | Good
Boyle, 2004 | Unclear | No | Yes | NR | NA, evaluated cutoff values | Yes | NR | Unclear | Yes | Yes | Yes | Fair
Chen, 2006 | Yes | No | Yes | NR | NA, evaluated cutoff values | Yes | NR | Yes | Yes | Yes | Yes | Good
Chlebowski, 2007 | Yes | Yes | Yes | NR | NA, evaluated cutoff values | Unclear | NR | Yes | Yes | Yes | Yes | Good
Colditz, 2000 | Yes | No | Yes | NR | NA, evaluated cutoff values | Unclear | NR | Yes | Yes | Yes | Yes | Good
Colditz, 2004 | Yes | Yes | Yes | NR | NA, evaluated cutoff values | Unclear | NR | Yes | Yes | Yes | Yes | Good
Costantino, 1999 | Yes | Yes | Yes | NR | NA, evaluated cutoff values | Yes | NR | Yes | Yes | Yes | Yes | Good
DeCarli, 2006 | Yes | No | Yes | NR | NA, evaluated cutoff values | Yes | NR | Yes | Yes | Yes | Yes | Good
Gail, 1989 | Yes | No | Yes | NR | NA, evaluated cutoff values | Yes | NR | Yes | Yes | Yes | Yes | Good
Gail, 2007 | Unclear | No | Unclear | NR | Unclear | Unclear | NR | Unclear | Unclear | Unclear | NR | Fair
Petracci, 2011 | Yes | No | Yes | NR | NA, evaluated cutoff values | Yes | NR | Yes | Yes | Yes | Yes | Good
Rockhill, 2001 | Yes | Yes | Yes | NR | NA, evaluated cutoff values | Unclear | NR | Yes | Yes | Yes | Yes | Good
Rockhill, 2003 | Yes | Yes | Yes | NR | NA, evaluated cutoff values | Unclear | NR | Yes | Yes | Yes | Yes | Good
Tamimi, 2010 | Yes | No | Yes | NR | NA, evaluated cutoff values | Yes | NR | Yes | Yes | Yes | Yes | Good
Tice, 2008 | Yes | Yes | Yes | NR | NA, evaluated cutoff values | Yes | NR | Yes | Yes | Yes | Yes | Good
Tyrer, 2004 | Yes | Unclear | Unclear | NR | NA, evaluated cutoff values | Yes | NR | NR | Yes | Yes | Yes | Fair
Current review
Brentnall, 2015 | Yes | Yes | Yes | Yes | Unclear | Yes | Unclear | Yes | No, only those suspected of cancer | Yes | Yes | Fair
Li, 2018 | Yes | Yes | Yes | Unclear | Yes | Yes | Unclear | Yes | No, only those suspected of cancer | Yes | Yes | Fair
Matsuno, 2011 | Yes | No | Yes | Unclear | Yes | Unclear | Unclear | Unclear | Unclear | Unclear | Yes | Fair
Tice, 2015 | Unclear | Yes | Yes | Unclear | Unclear | Yes | Unclear | Yes | Yes | Yes | Yes | Fair
Vacek, 2011 | Yes | Yes | Yes | Unclear | Unclear | Yes | Unclear | Unclear | Yes | Yes | Yes | Fair
Warwick, 2014 | No | No | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Yes | Poor

## Appendix B2 Quality Assessment of Randomized, Controlled Trials

Author, Year | Randomization Adequate? | Allocation Concealment Adequate? | Groups Similar at Baseline? | Eligibility Criteria Specified? | Outcome Assessors Masked? | Care Provider Masked? | Patient Masked? | Attrition and Withdrawals Reported? | Loss to Followup: Differential (>10%)/High (>20%)? | Analyze Patients in the Groups in Which They Were Randomized? | Quality Rating
Primary prevention trials
STAR Vogel, 2006 | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | No/No | Yes | Good
IBIS-I Cuzick, 2002 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Unclear | Yes | Good
NSABP-1 Fisher, 1998 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No/No | Yes | Good
Royal Marsden Powles, 1998 | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No/No | Yes | Good
Italian Veronesi, 1998 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No/No | Yes | Good
RUTH Barrett-Connor, 2006 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No/No | Yes | Good
MORE Cummings, 1999 | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No/Yes (23% overall) | Yes | Good
CORE Martino, 2004 | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No/No | Yes | Good
MAP.3 Goss, 2011 | Yes | Unclear | Yes | Yes | Unclear | Yes | Yes | Yes | No/No | Yes | Good
HOT DeCensi, 2013 | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | No/No | Yes | Good
IBIS-II Cuzick, 2014 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No/No | Yes | Good
Raloxifene trials
Cohen, 2000^*^ | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Fair
Delmas, 1997^*^ | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Not reported/Yes (25% overall) | Yes | Fair
Goldstein, 2005 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No/No | Yes | Good
Johnston, 2000^*^ | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Not reported/Yes (37% overall) | Yes | Fair
Jolly, 2003^*^ | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | No | Unclear | Yes | Fair
Lufkin, 1998 | Yes | Unclear | Mostly, differences in age and alcohol use | Yes | Yes | Yes | Yes | No | Unclear | Yes | Fair
McClung, 2006 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Yes | Yes | 33% discontinued overall, no other information | Yes | Fair
Meunier, 1999 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Yes | Yes | No/No | Yes | Fair
Morii, 2003 | Yes | Yes | Mostly, differences in lumbar spine bone mineral density, and serum parathyroid hormone | Yes | Unclear | Yes | Yes | Yes | No/No | Yes | Fair
Palacios, 2004 | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | No/No | Yes | Good

* Same study participants (Cohen, 2000; Delmas, 1997; Johnston, 2000; and Jolly, 2003)

## Appendix B3 Evidence Table of Trials of Risk-Reducing Medications for Breast Cancer